# Evidence Tables

Table 1 Risk of Bias

Evidence Table 2 Study characteristics for KQ1

Evidence Table 3 Participant characteristics for KQ1

Evidence Table 4 Intervention characteristics for KQ1 – Part A

Evidence Table 5 Patient-oriented Outcomes for KQ 1

Evidence Table 6 Other Patient-oriented Outcomes for KQ 1

Evidence Table 7 Adverse Events for KQ 1

Evidence Table 8 Study characteristics for KQ2a

Evidence Table 9 Participant characteristics for KQ2a

Evidence Table 10 Intervention characteristics for KQ2a

Evidence Table 11 Patient-oriented Outcomes for KQ2a

Evidence Table 12 Other Patient-oriented Outcomes for KQ2a

Evidence Table 13 Adverse Events for KQ2a

Evidence Table 14 Study characteristics for KQ2b

Evidence Table 15 Participant characteristics for KQ2b

Evidence Table 16 Intervention characteristics for KQ2b

Evidence Table 17 Patient-oriented Outcomes for KQ2b

Evidence Table 18 Other Patient-oriented Outcomes for KQ2b

Evidence Table 19 Adverse Events for KQ2b

Evidence Table 20 Study characteristics for KQ3

Evidence Table 21 Participant characteristics for KQ3

Evidence Table 22 Intervention characteristics for KQ3

Evidence Table 23 Other Outcomes for KQ3

Evidence Table 24 Adverse Events for KQ3

Evidence Table 25 Study characteristics for KQ5

Evidence Table 26 Participant characteristics for KQ5

Evidence Table 27 Intervention characteristics for KQ5

Evidence Table 28 Patient-oriented Outcomes (any bleeding events + major and non-major clinically relevant bleeding) over three time windows in the at-risk period for KQ5

Evidence Table 29 Patient-oriented Outcomes (Any Bleeding Events) over the total at risk period for KQ5

Evidence Table 30 Patient-oriented Outcomes (Major and non-major clinically relevant bleeding events) over the total at risk period for KQ5

Evidence Table 31 Adverse Events for KQ5

Evidence Table 32 Study characteristics KQ6

Evidence Table 33 Participant characteristics for KQ6

Evidence Table 34 Filter Interventions for KQ 6

Evidence Table 35 Drug Interventions for KQ 6

Evidence Table 36 Patient-oriented Outcomes for KQ 6

Evidence Table 37 Other Patient-oriented Outcomes for KQ6

Evidence Table 38 Adverse Events for KQ6

Evidence Table 39 Study characteristics for KQ7

Evidence Table 40 Participant characteristics for KQ7

Evidence Table 41 Interventions for KQ7

Evidence Table 42 Patient-oriented Outcomes for KQ7

Evidence Table 43 Other Patient-oriented Outcomes for KQ7

Evidence Table 44 Adverse Events for KQ7

Evidence Table 45 Study characteristics for KQ8

Evidence Table 46 Participant characteristics for KQ8

Evidence Table 47 Interventions for KQ8

Evidence Table 48 Patient-oriented Outcomes for KQ8

Evidence Table 49 Other Patient-oriented Outcomes

Evidence Table 50 Adverse Events for KQ8

Evidence Table 51 Between Group Comparisons for KQ8