# Excluded Studies

Appendix D lists studies that were excluded from this review, categorized by reason for exclusion and alphabetized

## Case Reports

Famularo G, Gasbarrone L, Minisola G, De Simone C. Systemic bleeding in a patient with enoxaparin-induced thrombocytopenia. Am J Emerg Med. 2009;27(6):756.e1-2. [pmid: 19751647].
Fargen KM, Bhasin RR, Murad GJ. Abdominal craniectomy implantation and thromboembolism prophylaxis resulting in wound hematoma. Neurosurgery. 2010;67(2):495-7. [pmid: 20644438].
Fryburg K, Nguyen HS, Cohen-Gadol AA. Spontaneous acute subdural hematoma due to fondaparinux: Report of two cases. Surg Neurol Int. 2011;2:44. [pmid: 21660271].
Han IS, Chung EY, Hahn YJ. Spinal epidural hematoma after epidural anesthesia in a patient receiving enoxaparin. A case report. Korean J Anesthesiol. 2010;59(2):119-22. [pmid: 20740218].
LaBan MM, Whitmore CE, Taylor RS. Bilateral adrenal hemorrhage after anticoagulation prophylaxis for bilateral knee arthroplasty. Am J Phys Med Rehabil. 2003;82(5):418-20. [pmid: 12704285].
McLaughlin JA, Paulson MM, Rosenthal RE. Delayed onset of anterior tibial compartment syndrome in a patient receiving low-molecular-weight heparin. A case report. J Bone Joint Surg Am. 1998;80(12):1789-90. [pmid: 9875937].
Plath J, Schulze R, Barz D, et al. Necrotizing skin lesions induced by low-molecular-weight heparin after total knee arthroplasty. Arch Orthop Trauma Surg. 1997;116(6-7):443-5. [pmid: 9266063].
Rowland CH, Woodford PA, De Lisle-Hammond J, Nair B. Heparin-induced thrombocytopenia-thrombosis syndrome and bilateral adrenal haemorrhage after prophylactic heparin use. Aust N Z J Med. 1999;29(5):741-2. [pmid: 10630659].
Salem M, Elrefai S, Shrit MA, Warkentin TE. Fondaparinux thromboprophylaxis-associated heparin-induced thrombocytopenia syndrome complicated by arterial thrombotic stroke. Thromb Haemost. 2010;104(5):1071-2. [pmid: 20806120].
Tsapatsaris NP. Low-dose heparin. A cause of hematoma of rectus abdominis. Arch Intern Med. 1991;151(3):597-9. [pmid: 1845603].
Wessler S, Avioli LV. Anticoagulants in treatment of patients with hip fracture. JAMA. 1968;204(2):140-4. [pmid: 5694537].

## Data Not Abstractable

A Prospective Comparison of Warfarin to Aspirin for Thromboprophylaxis in Total Hip and Total Knee Arthroplasty. J Arthroplasty. 2011.
Abernethy EA, Hartsuck JM. Postoperative pulmonary embolism. A prospective study utilizing low dose heparin. Am J Surg. 1974;128(6):739-42. [pmid: 4432994].
AbuRahma AF, Robinson PA, Boland JP, et al. Therapeutic and prophylactic vena caval interruption for pulmonary embolism: caval and venous insertion site patency. Ann Vasc Surg. 1993;7(6):561-8. [pmid: 8123459].
Ageno W. Rivaroxaban for the prevention of venous thromboembolism following major orthopedic surgery: the RECORD trials. Expert Rev Cardiovasc Ther. 2009;7(6):569-76. [pmid: 19505271].
Agnelli G, Bergqvist D, Cohen AT, Gallus AS, Gent M. Randomized clinical trial of postoperative fondaparinux versus perioperative dalteparin for prevention of venous thromboembolism in high-risk abdominal surgery. Br J Surg. 2005;92(10):1212-20. [pmid: 16175516].
Agnelli G, Cosmi B, Di Filippo P, et al. A randomised, double-blind, placebo-controlled trial of dermatan sulphate for prevention of deep vein thrombosis in hip fracture. Thromb Haemost. 1992;67(2):203-8. [pmid: 1621239].
Agnelli G, Haas S, Ginsberg JS, Krueger KA, Dmitrienko A, Brandt JT. A phase II study of the oral factor Xa inhibitor LY517717 for the prevention of venous thromboembolism after hip or knee replacement. J Thromb Haemost. 2007;5(4):746-53. [pmid: 17408408].
Ahmad I, Yeddula K, Wicky S, Kalva SP. Clinical sequelae of thrombus in an inferior vena cava filter. Cardiovasc Intervent Radiol. 2010;33(2):285-9. [pmid: 19688372].
Akanmu AS, Nnodu OE, Giwa SO, et al. Efficacy and safety of enoxaparin, a low molecular weight heparin in the prevention of deep vein thrombosis in Nigerian patients after orthopaedic surgery. Afr J Med Med Sci. 2004;33(4):335-40. [pmid: 15977441].
Alexander JJ, Yuhas JP, Piotrowski JJ. Is the increasing use of prophylactic percutaneous IVC filters justified?. Am J Surg. 1994;168(2):102-6. [pmid: 8053504].
Alfaro MJ, Paramo JA, Rocha E. Prophylaxis of thromboembolic disease and platelet-related changes following total hip replacement: a comparative study of aspirin and heparin-dihydroergotamine. Thromb Haemost. 1986;56(1):53-6. [pmid: 3535158].
Alho A, Stangeland L, Rottingen J, Wiig JN. Prophylaxis of venous thromboembolism by aspirin, warfarin and heparin in patients with hip fracture. A prospective clinical study with cost-benefit analysis. Ann Chir Gynaecol. 1984;73(4):225-8. [pmid: 6439100].
Alikhan R, Cohen AT, Combe S, et al. Prevention of venous thromboembolism in medical patients with enoxaparin. A subgroup analysis of the MEDENOX study. 2003;14:341-6.
Amin AN, Lin J, Lenhart G, Schulman KL. Clinical and economic outcomes in patients at risk of venous thromboembolism receiving appropriate enoxaparin or unfractionated heparin prophylaxis. Thromb Haemost. 2009;102(2):321-6. [pmid: 19652883].
Anderson JA, Hirsh J, Yusuf S, et al. Comparison of the anticoagulant intensities of fondaparinux and enoxaparin in the Organization to Assess Strategies in Acute Ischemic Syndromes (OASIS)-5 trial. J Thromb Haemost. 2010;8(2):243-9. [pmid: 19943881].
Antevil JL, Sise MJ, Sack DI, et al. Retrievable vena cava filters for preventing pulmonary embolism in trauma patients: a cautionary tale. J Trauma. 2006;60(1):35-40. [pmid: 16456434].
Arcelus JI, Caprini JA, Monreal M, Suarez C, Gonzalez-Fajardo J. The management and outcome of acute venous thromboembolism: a prospective registry including 4011 patients. J Vasc Surg. 2003;38(5):916-22. [pmid: 14603194].
Arcelus JI, Monreal M, Caprini JA, et al. Clinical presentation and time-course of postoperative venous thromboembolism: Results from the RIETE Registry. Thromb Haemost. 2008;99(3):546-51. [pmid: 18327403].
Asano H, Matsubara M, Suzuki K, Morita S, Shinomiya K. Prevention of pulmonary embolism by a foot sole pump. Journal of Bone & Joint Surgery, British Volume. 2001;83B(8):1130-2.
Atichartakarn V, Pathepchotiwong K, Keorochana S, Eurvilaichit C. Deep vein thrombosis after hip surgery among Thai. Arch Intern Med. 1988;148(6):1349-53. [pmid: 3377618].
Aujesky D, Guignard E, Pannatier A, Cornuz J. Pharmacological thromboembolic prophylaxis in a medical ward: room for improvement. J Gen Intern Med. 2002;17(10):788-91. [pmid: 12390555].
Austin MS, Parvizi J, Grossman S, Restrepo C, Klein GR, Rothman RH. The inferior vena cava filter is effective in preventing fatal pulmonary embolus after hip and knee arthroplasties. J Arthroplasty. 2007;22(3):343-8. [pmid: 17400088].
Avikainen V, Von Bonsdorff H, Partio E, et al. Low molecular weight heparin (enoxaparin) compared with unfractionated heparin in prophylaxis of deep venous thrombosis and pulmonary embolism in patients undergoing hip replacement. ANN. CHIR. GYNAECOL. 1995;84(1):85-90. [pmid: 7645915].
Aziz F, Spate K, Wong J, Aruny J, Sumpio B. Changing patterns in the use of inferior vena cava filters: review of a single center experience. J Am Coll Surg. 2007;205(4):564-9. [pmid: 17903730].
Bachmann F, McKenna R, Meredith P, Carta S. Intermittent pneumatic compression of leg and thigh: a new successful method for the prevention of postoperative thrombosis. Schweiz Med Wochenschr. 1976;106(50):1819-21. [pmid: 1013707].
Bailey JP, Kruger MP, Solano FX, Zajko AB, Rubash HE. Prospective randomized trial of sequential compression devices vs low-dose warfarin for deep venous thrombosis prophylaxis in total hip arthroplasty. J Arthroplasty. 1991;6(Suppl):S29-35. [pmid: 1774568].
Bara L, Planes A, Samama MM. Occurrence of thrombosis and haemorrhage, relationship with anti-Xa, anti-IIa activities, and D-dimer plasma levels in patients receiving a low molecular weight heparin, enoxaparin or tinzaparin, to prevent deep vein thrombosis after hip surgery. Br J Haematol. 1999;104(2):230-40. [pmid: 10050702].
Barber HM, Feil EJ, Galasko CS, et al. A comparative study of dextran-70, warfarin and low-dose heparin for the prophylaxis of thrombo-embolism following total hip replacement. Postgrad Med J. 1977;53(617):130-3. [pmid: 859784].
Barber HM, Feil EJ, Galasko CS, et al. A comparative study of dextran-70, warfarin and low-dose heparin for the prophylaxis of thrombo-embolism following total hip replacement. Postgrad Med J. 1977;53(617):130-3. [pmid: 859784].
Barnes RW, Brand RA, Clarke W. Efficacy of graded-compression antiembolism stockings in patients undergoing total hip arthroplasty. CLIN. ORTHOP. RELAT. RES. 1978;NO.132:61-7. [pmid: 679555].
Barsotti J, Gruel Y, Rosset P, et al. Comparative double-blind study of two dosage regimens of low-molecular weight heparin in elderly patients with a fracture of the neck of the femur. J Orthop Trauma. 1990;4(4):371-5. [pmid: 2176235].
Bauer KA, Eriksson BI, Lassen MR, Turpie AG. Fondaparinux compared with enoxaparin for the prevention of venous thromboembolism after elective major knee surgery. N Engl J Med. 2001;345(18):1305-10. [pmid: 11794149].
Bauersachs RM, Berger K, Hankowitz J, et al. Prophylaxis, diagnosis and therapy of surgery-related complications in orthopedic and trauma surgery: An observational survey (CHANGE). Eur. J. Trauma. 2005;31(2):158-67.
Beisaw NE, Comerota AJ, Groth HE, et al. Dihydroergotamine/heparin in the prevention of deep-vein thrombosis after total hip replacement. A controlled, prospective, randomized multicenter trial. J Bone Joint Surg Am. 1988;70(1):2-10. [pmid: 3275673].
Beksac B, Gonzalez Della Valle A, Anderson J, Sharrock NE, Sculco TP, Salvato EA. Symptomatic thromboembolism after one-stage bilateral THA with a multimodal prophylaxis protocol. Clin Orthop Relat Res. 2007;463:114-9. [pmid: 17960674].
Belding HH. Use of Anticoagulants in the Prevention of Venous Thromboembolic Disease in Postoperative Patients. Arch Surg. 1965;90:566-73. [pmid: 14267658].
Berges A, Laporte S, Epinat M, et al. Anti-factor Xa activity of enoxaparin administered at prophylactic dosage to patients over 75 years old. Br J Clin Pharmacol. 2007;64(4):428-38. [pmid: 17509040].
Bergqvist D, Benoni G, Bjorgell O, et al. Low-molecular-weight heparin (enoxaparin) as prophylaxis against venous thromboembolism after total hip replacement. NEW ENGL. J. MED. 1996;335(10):696-700. [pmid: 8703168].
Bergqvist D, Benoni G, Bjorgell O, et al. Low-molecular-weight heparin (enoxaparin) as prophylaxis against venous thromboembolism after total hip replacement. N Engl J Med. 1996;335(10):696-700. [pmid: 8703168].
Bergqvist D, Breddin K, Ten Cate JW, et al. Thromboprophylaxis in hip fracture surgery: A pilot study comparing danaparoid, enoxaparin and dalteparin. Haemostasis. 1999;29(6):310-7. [pmid: 10844404].
Bergqvist D, Burmark US, Flordal PA, et al. Low molecular weight heparin started before surgery as prophylaxis against deep vein thrombosis: 2500 versus 5000 XaI units in 2070 patients. Br J Surg. 1995;82(4):496-501. [pmid: 7613894].
Bergqvist D, Burmark US, Frisell J, et al. Low molecular weight heparin once daily compared with conventional low-dose heparin twice daily. A prospective double-blind multicentre trial on prevention of postoperative thrombosis. Br J Surg. 1986;73(3):204-8. [pmid: 3512031].
Bergqvist D, Burmark US, Frisell J, et al. Prospective double-blind comparison between Fragmin and conventional low-dose heparin: thromboprophylactic effect and bleeding complications. Haemostasis. Suppl 2. 1986;16:11-8. [pmid: 3744131].
Bergqvist D, Dahlgren S. Leg vein thrombosis diagnosed by 125 I-fibrinogen test in patients with fracture of the hip: a study of the effect of early prophylaxis with dicoumarol or dextran 70. Vasa. 1973;2(2):121-6. [pmid: 4121997].
Bergqvist D, Hallbook T. Prophylaxis of postoperative venous thrombosis in a controlled trial comparing dextran 70 and low-dose heparin. World J Surg. 1980;4(2):239-43. [pmid: 6157256].
Bergqvist D. Thromboprophylaxis in hip fracture surgery: A pilot study comparing danaparoid, enoxaparin and dalteparin. Haemostasis. 1999;29(6):310-7. [pmid: 10844404].
Bern M, Deshmukh RV, Nelson R, et al. Low-dose warfarin coupled with lower leg compression is effective prophylaxis against thromboembolic disease after hip arthroplasty. J Arthroplasty. 2007;22(5):644-50. [pmid: 17689770].
Bern MM, Bierbaum B, Wetzner S, Brennan W, McAlister S. Very low dose warfarin as prophylaxis against ultrasound detected deep vein thrombosis following primary hip replacement. American Journal of Hematology. 2002;71(2):69-74. [pmid: 12353302].
Bi C, Wen J, Jiang K, et al. Chinese drugs for supplementing Qi and activating blood circulation in preventing deep venous thrombosis after big operations in orthopaedics and traumatology. Zhongguo Zhong Yao Za Zhi. 2009;34(5):625-7. [pmid: 19526798].
Binkert CA, Drooz AT, Caridi JG, et al. Technical success and safety of retrieval of the G2 filter in a prospective, multicenter study. J Vasc Interv Radiol. 2009;20(11):1449-53. [pmid: 19875062].
Blanchard J, Meuwly JY, Leyvraz PF, et al. Prevention of deep-vein thrombosis after total knee replacement. Randomised comparison between a low-molecular-weight heparin (nadroparin) and mechanical prophylaxis with a foot-pump system. J Bone Joint Surg Br. 1999;81(4):654-9. [pmid: 10463739].
Blebea J, Wilson R, Waybill P, et al. Deep venous thrombosis after percutaneous insertion of vena caval filters. J Vasc Surg. 1999;30(5):821-8. [pmid: 10550179].
Borgen PO, Dahl OE, Reikeras O. Preoperative versus postoperative initiation of dalteparin thromboprophylaxis in THA. Hip Int. 2010;20(3):301-7. [pmid: 20640994].
Borghi B, Casati A. Thromboembolic complications after total hip replacement. Int Orthop. 2002;26(1):44-7. [pmid: 11954849].
Borris LC, Hauch O, Jorgensen LN, et al. Low-molecular-weight heparin (enoxaparin) vs dextran 70: The prevention of postoperative deep vein thrombosis after total hip replacement. ARCH. INTERN. MED. 1991;151(8):1621-4. [pmid: 1714709].
Borris LC, Lassen MR, Andersen BS, Poulsen A, Hansen BR. Low molecular weight heparin (enoxaparin) versus standard heparin in the prevention of venous thromboembolism in operatively treated hip fracture patients. Thrombosis and Haemostasis. 1993;69(6):1118. Abstract no:. 2058.
Bosson JL, Labarere J, Sevestre MA, et al. Deep vein thrombosis in elderly patients hospitalized in subacute care facilities: a multicenter cross-sectional study of risk factors, prophylaxis, and prevalence. Arch Intern Med. 2003;163(21):2613-8. [pmid: 14638561].
Bovyn G, Ricco JB, Reynaud P, Le Blanche AF. Long-duration temporary vena cava filter: a prospective 104-case multicenter study. J Vasc Surg. 2006;43(6):1222-9. [pmid: 16765244].
Brady LP. A multifaceted approach to prevention of thromboembolism: a report of 529 cases. South Med J. 1977;70(5):546-8. [pmid: 870979].
Brakenridge SC, Toomay SM, Sheng JL, Gentilello LM, Shafi S. Predictors of early versus late timing of pulmonary embolus after traumatic injury. Am J Surg. 2011;201(2):209-15. [pmid: 20385370].
Brantigan OC. Low-dose heparin preoperatively for prophylaxis against postoperative thromboembolism. Md State Med J. 1979;28(2):61-4. [pmid: 423621].
Braverman SJ, Battey PM, Smith RB 3rd. Vena caval interruption. Am Surg. 1992;58(3):188-92. [pmid: 1558337].
Brockmiller H, Nelson D, Finley J, Lynx D. Dalteparin use for the prevention of venous thromboembolism in patients undergoing total knee replacement (TKR) surgery.: Dalteparin use for the prevention of venous thromboembolism in patients undergoing total knee replacement (TKR) surgery. ASHP Midyear Clinical Meeting. 2002;37. P-D.
Brooks PJ, Keramati M, Wickline A. Thromboembolism in patients undergoing total knee arthroplasty with epidural analgesia. J Arthroplasty. 2007;22(5):641-3. [pmid: 17689769].
Brotman DJ, Jaffer AK, Hurbanek JG, Morra N. Warfarin prophylaxis and venous thromboembolism in the first 5 days following hip and knee arthroplasty. Thromb Haemost. 2004;92(5):1012-7. [pmid: 15543328].
Brown AP, Miller MJ, Smith TP. Caval Penetration with Retroperitoneal Hemorrhage Following Placement of an Inferior Vena Cava (IVC) Filter. Semin Intervent Radiol. 2007;24(3):312-5. [pmid: 21326475].
Bruchi O, Marconi F, Pozza V, et al. Prophylaxis of deep venous thrombosis with low-doses of warfarin in total hip replacement: la profilassi della trombosi venosa profonda con basse dosi di warfarin nella chirurgia protesica dell'anca. 1994;45(5):185-90.
Buller H, van Gogh Investigators, Cohen A, Davidson B, Raskob G, et al. Extended prophylaxis of venous thromboembolism with idraparinux: Extended prophylaxis of venous thromboembolism with idraparinux. New England Journal of Medicine (USA). 2007;357:1105-12.
Burnett RS, Clohisy JC, Wright RW, et al. Failure of the American College of Chest Physicians-1A protocol for lovenox in clinical outcomes for thromboembolic prophylaxis. J Arthroplasty. 2007;22(3):317-24. [pmid: 17400085].
Burns SP, Nelson AL, Bosshart HT, et al. Implementation of clinical practice guidelines for prevention of thromboembolism in spinal cord injury. J Spinal Cord Med. 2005;28(1):33-42. [pmid: 15832902].
Callaghan JJ, Warth LC, Hoballah JJ, Liu SS, Wells CW. Evaluation of deep venous thrombosis prophylaxis in low-risk patients undergoing total knee arthroplasty. J Arthroplasty. 2008;23(6 Suppl 1):20-4. [pmid: 18722299].
Camporese G, Bernardi E, Prandoni P, et al. Low-molecular-weight heparin versus compression stockings for thromboprophylaxis after knee arthroscopy: a randomized trial. Ann Intern Med. 2008;149(2):73-82. [pmid: 18626046].
Camporese G, Bernardi E, Prandoni P, et al. Low-molecular-weight heparin versus compression stockings for thrmoboprophylaxis after knee arthroscopy: a randomized trial. Annals of Internal Medicine. 2008;149(2):73-82. [pmid: 18626046].
Caprini JA, Chucker JL, Zuckerman L, Vagher JP, Franck CA, Cullen JE. Thrombosis prophylaxis using external compression. Surg Gynecol Obstet. 1983;156(5):599-604. [pmid: 6845123].
Cavezzi A, Sabatini D, Lonardi R, Hussein H, Sfrappini M, Infriccioli P. Preventing pulmonary embolism using venous caval filter in elderly patients. Arch Gerontol Geriatr. Suppl 1. 1996;22:447-9. [pmid: 18653075].
Celebi F, Balik AA, Yildirgan MI, Basoglu M, Adiguzel H, Oren D. Thromboembolic prophylaxis after major abdominal surgery. Ulus Travma Derg. 2001;7(1):44-8. [pmid: 11705173].
Cestac P, Bagheri H, Lapeyre-Mestre M, et al. Utilisation and safety of low molecular weight heparins: prospective observational study in medical inpatients. Drug Saf. 2003;26(3):197-207. [pmid: 12580648].
Charles HW, Black M, Kovacs S, et al. G2 inferior vena cava filter: retrievability and safety. J Vasc Interv Radiol. 2009;20(8):1046-51. [pmid: 19560938].
Chiapuzzo E, Orengo GB, Ottria G, Chiapuzzo A, Palazzini E, Fusillo M. The use of low molecular weight heparins for postsurgical deep vein thrombosis prevention in orthopaedic patients. J Int Med Res. 1988;16(5):359-66. [pmid: 3197913].
Chin PL, Amin MS, Yang KY, Yeo SJ, Lo NN. Thromboembolic prophylaxis for total knee arthroplasty in Asian patients: a randomised controlled trial. J Orthop Surg (Hong Kong). 2009;17(1):1-5. [pmid: 19398783].
Chotanaphuti T, Jareonarpornwatana A, Laoruengthana A. The mortality rate after thromboembolism prophylaxis in the hip fracture surgery. J Med Assoc Thai. Suppl 6. 2009;92:S115-9. [pmid: 20120672].
Christensen SW, Wille-Jorgensen P, Bjerg-Nielsen A, Holmich P, Duus B. Bleeding after hip arthroplasty not increased by heparin plus dihydroergotamine. Acta Orthop Scand. 1987;58(2):104-5. [pmid: 3604619].
Clark WB, MacGregor AB, Prescott RJ, Ruckley CV. Pneumatic compression of the calf and postoperative deep-vein thrombosis. Lancet. 1974;2(7871):5-7. [pmid: 4134404].
Clark WB, MacGregor AB, Prescott RJ, Ruckley CV. Prevention of early post-operative deep vein thrombosis by compression of the leg during and after operation. Vasa. 1974;3(2):148-52. [pmid: 4831538].
Clayton ML, Thompson TR. Activity, air boots, and aspirin as thromboembolism prophylaxis in knee arthroplasty. A multiple regimen approach. Orthopedics. 1987;10(11):1525-7. [pmid: 3684797].
Cohen A, Davidson B, Gallus A, Lassen M, ARTEMIS Investigators, et al. Efficacy and safety of fondaparinux for the prevention of venous thromboembolism in older acute medical patients: randomised placebo controlled trial: Efficacy and safety of fondaparinux for the prevention of venous thromboembolism in older acute medical patients: randomised placebo controlled trial. British Medical Journal (England). 2006;332:325-7.
Cohen AT, Bailey CS, Alikhan R, Cooper DJ. Extended thromboprophylaxis with low molecular weight heparin reduces symptomatic venous thromboembolism following lower limb arthroplasty--a meta-analysis. Thromb Haemost. 2001;85(5):940-1. [pmid: 11372694].
Cohen AT, Davidson BL, Gallus AS, et al. Efficacy and safety of fondaparinux for the prevention of venous thromboembolism in older acute medical patients: randomised placebo controlled trial. BMJ. 2006;332(7537):325-9. [pmid: 16439370].
Cohen AT, Davidson BL, Gallus AS, et al. Fondaparinux for the prevention of VTE (venous thromboembolism) in acutely ill medical patients. Blood. 2003;102(11 (Pt 1)):15a.
Cohen AT, Spiro TE, Buller HR, et al. Extended-duration rivaroxaban thromboprophylaxis in acutely ill medical patients: MAGELLAN study protocol. J Thromb Thrombolysis. 2011;31(4):407-16. [pmid: 21359646].
Cohen AT, Tapson VF, Bergmann JF, et al. Venous thromboembolism risk and prophylaxis in the acute hospital care setting (ENDORSE study): a multinational cross-sectional study. 2008;371:387-94.
Cohen AT, Turpie AGG, Leizorovicz A, Olsson C-G, Vaitkus PT, Goldhaber SZ. Thromboprophylaxis with dalteparin in medical patients: Which patients benefit?. Vasc. Med. 2007;12(2):123-8. [pmid: 17615800].
Cohen T, Spiro T, Buller H, et al. The magellan study methodology: Rivaroxaban compared with enoxaparin for the prevention of venous thromboembolism in hospitalized medically ill patients. Haematologica. 2010;95:66-7.
Colwell CW Jr, Berkowitz SD, Davidson BL, et al. Comparison of ximelagatran, an oral direct thrombin inhibitor, with enoxaparin for the prevention of venous thromboembolism following total hip replacement. A randomized, double-blind study. J Thromb Haemost. 2003;1(10):2119-30. [pmid: 14521593].
Colwell CW Jr, Berkowitz SD, Lieberman JR, et al. Oral direct thrombin inhibitor ximelagatran compared with warfarin for the prevention of venous thromboembolism after total knee arthroplasty. J Bone Joint Surg Am. 2005;87(10):2169-77. [pmid: 16203879].
Colwell CW Jr, Collis DK, Paulson R, et al. Comparison of enoxaparin and warfarin for the prevention of venous thromboembolic disease after total hip arthroplasty. Evaluation during hospitalization and three months after discharge. J Bone Joint Surg Am. 1999;81(7):932-40. [pmid: 10428124].
Colwell CW Jr, Collis DK, Paulson R, et al. Comparison of enoxaparin and warfarin for the prevention of venous thromboembolic disease after total hip arthroplasty. Evaluation during hospitalization and three months after discharge. J Bone Joint Surg Am. 1999;81(7):932-40. [pmid: 10428124].
Colwell CW Jr, Froimson MI, Mont MA, et al. Thrombosis prevention after total hip arthroplasty: a prospective, randomized trial comparing a mobile compression device with low-molecular-weight heparin. J Bone Joint Surg Am. 2010;92(3):527-35. [pmid: 20194309].
Colwell CW Jr, Froimson MI, Mont MA, et al. Thrombosis prevention after total hip arthroplasty: a prospective, randomized trial comparing a mobile compression device with low-molecular-weight heparin. J Bone Joint Surg Am. 2010;92(3):527-35. [pmid: 20194309].
Colwell CW Jr, Kwong LM, Turpie AG, Davidson BL. Flexibility in administration of fondaparinux for prevention of symptomatic venous thromboembolism in orthopaedic surgery. J Arthroplasty. 2006;21(1):36-45. [pmid: 16446183].
Colwell CW Jr, Spiro TE, Trowbridge AA, Stephens JW, Gardiner GA Jr, Ritter MA. Efficacy and safety of enoxaparin versus unfractionated heparin for prevention of deep venous thrombosis after elective knee arthroplasty. Enoxaparin Clinical Trial Group. Clin Orthop Relat Res. 1995;(321):19-27. [pmid: 7497668].
Colwell CW, Berkowitz SD, Comp PC, et al. Randomized, double-blind comparison of ximelagatran, an oral direct thrombin inhibitor, and warfarin to prevent venous thromboembolism (VTE) after total knee replacement (TKR): EXULT B [abstract]. Blood. 2003;102(11 Part 1):14a.
Colwell CW, Spiro TE, Trowbridge AA, et al. Use of enoxaparin, a low-molecular-weight heparin, and unfractionated heparin for the prevention of deep venous thrombosis after elective hip replacement. A clinical trial comparing efficacy and safety. Enoxaparin Clinical Trial Group. The Journal of Bone and Joint Surgery. American Volume. 1994;76(1):3-14. [pmid: 8288662].
Colwell CW Jr, Collis DK, Paulson R, et al. Comparison of enoxaparin and warfarin for the prevention of venous thromboembolic disease after total hip arthroplasty. Evaluation during hospitalization three months after discharge. J. Bone Jt. Surg. Ser. 1999;81(7):932-40.
Colwell CW Jr, Spiro TE, Trowbridge AA, et al. Use of enoxaparin, a low-molecular-weight heparin, and unfractionated heparin for the prevention of deep venous thrombosis after elective hip replacement. A clinical trial comparing efficacy and safety. J. BONE JT. SURG. SER. A. 1994;76(1):3-14.
Colwell CW Jr, Spiro TE, Trowbridge AA, Stephens JWG, Gardiner GA Jr, Ritter MA. Efficacy and safety of enoxaparin versus unfractionated heparin for prevention of deep venous thrombosis after elective knee arthroplasty. CLIN. ORTHOP. RELAT. RES. 1995;(321):19-27. [pmid: 7497668].
Comp P, Happe LE, Sarnes M, Farrelly E. Venous thromboembolism clinically detected after hip fracture surgery with prophylaxis in a clinical practice setting. Am J Orthop (Belle Mead NJ). 2008;37(9):470-5. [pmid: 18982184].
Comp PC, Spiro TE, Friedman RJ, et al. Prolonged enoxaparin therapy to prevent venous thromboembolism after primary hip or knee replacement. Enoxaparin Clinical Trial Group. J Bone Joint Surg Am. 2001;83-A(3):336-45. [pmid: 11263636].
Cook D, Attia J, Weaver B, McDonald E, Meade M, Crowther M. Venous thromboembolic disease: an observational study in medical-surgical intensive care unit patients. J Crit Care. 2000;15(4):127-32. [pmid: 11138871].
Cook D, Meade M, Guyatt G, et al. Dalteparin versus unfractionated heparin in critically ill patients. N Engl J Med. 2011;364(14):1305-14. [pmid: 21417952].
Corriere MA, Sauve KJ, Ayerdi J, et al. Vena cava filters and inferior vena cava thrombosis. J Vasc Surg. 2007;45(4):789-94. [pmid: 17398389].
Cospite M, Milio G, Ferrara F, Raimondi F. Low-dose heparin in the prevention of venous thromboses. Clin Ter. 1987;122(3):177-81. [pmid: 2973910].
Couinaud C, Cerceau F, Goddio A. Preventive treatment of thrombo-embolism in general surgery. A report of 5 242 observations (author's transl). Sem Hop. 1980;56(15-16):732-7. [pmid: 6246607].
Covey TH, Sherman L, Baue AE. Low-dose heparin in postoperative patients: a prospective, coded study. Arch Surg. 1975;110(8):1021-6. [pmid: 1100014].
Crandon AJ, Peel KR, Anderson JA, Thompson V, McNicol GP. Prophylaxis of postoperative deep vein thrombosis: selective use of low-dose heparin in high-risk patients. Br Med J. 1980;281(6236):345-7. [pmid: 7427272].
Crochet DP, Brunel P, Trogrlic S, Grossetete R, Auget JL, Dary C. Long-term follow-up of Vena TechLGM filter: Predictors and frequency of caval occlusion. 1999;10:137-42.
Cull DL, Wheeler JR, Gregory RT, Synder SO Jr, Gayle RG, Parent FN 3rd. The Vena Tech filter: evaluation of a new inferior vena cava interruption device. J Cardiovasc Surg (Torino). 1991;32(5):691-6.
Cumbo-Nacheli G, Samavati L, Guzman JA. Bioavailability of fondaparinux to critically ill patients. J Crit Care. 2011;26(4):342-6. [pmid: 20889286].
Cusick LA, Beverland DE. The incidence of fatal pulmonary embolism after primary hip and knee replacement in a consecutive series of 4253 patients. J Bone Joint Surg Br. 2009;91(5):645-8. [pmid: 19407300].
Dahan R, Houlbert D, Caulin C, et al. Prevention of deep vein thrombosis in elderly medical in-patients by a low molecular weight heparin: a randomized double-blind trial. Haemostasis. 1986;16(2):159-64. [pmid: 3710294].
Dahl OE, Aspelin T, Arnesen H, et al. Increased activation of coagulation and formation of late deep venous thrombosis following discontinuation of thromboprophylaxis after hip replacement surgery. Thromb Res. 1995;80(4):299-306. [pmid: 8585042].
Dahl OE, Gudmundsen TE, Bjornara BT, Solheim DM. Risk of clinical pulmonary embolism after joint surgery in patients receiving low-molecular-weight heparin prophylaxis in hospital: a 10-year prospective register of 3,954 patients. Acta Orthop Scand. 2003;74(3):299-304. [pmid: 12899550].
Dale C, Gallus A, Wycherley A, Langlois S, Howie D. Prevention of venous thrombosis with minidose warfarin after joint replacement: Prevention of venous thrombosis with minidose warfarin after joint replacement. British Medical Journal (England). 1991;303:224.
Dalldorf PG, Perkins FM, Totterman S, Pellegrini VD Jr. Deep venous thrombosis following total hip arthroplasty: Effects of prolonged postoperative epidural anesthesia. 1994;9(6):611-6.
Darcy MD, Cardella JF, Hunter DW, et al. Experience with the Amplatz retrievable vena caval filter. Work in progress. Radiology. 1986;161(3):611-4. [pmid: 3786707].
David W, Gross WS, Colaiuta E, Gonda R, Osher D, Lanuti S. Pulmonary embolus after vena cava filter placement. Am Surg. 1999;65(4):341-6. [pmid: 10190360].
Dazley JM, Wain R, Vellinga RM, Cohen B, Agulnick MA. Prophylactic Inferior Vena Cava Filters Prevent Pulmonary Embolisms in High-Risk Patients Undergoing Major Spinal Surgery. J Spinal Disord Tech. 2011.
de la Caffiniere JY, Mignot M, Bruch JM. The dangerous blood clot in orthopaedic surgery (author's transl). Rev Chir Orthop Reparatrice Appar Mot. 1981;67(1):47-58. [pmid: 6453395].
Deale FW, Cilliers PH. Greenfield filters in pulmonary embolism. S Afr J Surg. 1986;24(2):73-7. [pmid: 3726678].
Dechavanne M, Ville D, Berruyer M, et al. Randomized trial of a low-molecular-weight heparin (Kabi 2165) versus adjusted-dose subcutaneous standard heparin in the prophylaxis of deep-vein thrombosis after elective hip surgery. Haemostasis. 1989;19(1):5-12. [pmid: 2537787].
Demers C, Ginsberg JS, Brill-Edwards P, Panju A, McGinnis J. Heparin and graduated compression stockings in patients undergoing fractured hip surgery. J Orthop Trauma. 1991;5(4):387-91. [pmid: 1761997].
Denny DF Jr, Dorfman GS, Cronan JJ, Greenwood LH, Morse SS, Yoselevitz M. Greenfield filter: percutaneous placement in 50 patients. AJR Am J Roentgenol. 1988;150(2):427-9. [pmid: 3257335].
Desjardins L, Bara L, Boutitie F, et al. Correlation of plasma coagulation parameters with thromboprophylaxis, patient characteristics, and outcome in the MEDENOX study. Arch Pathol Lab Med. 2004;128(5):519-26. [pmid: 15086284].
Dh te R, Pellicer-Coeuret M, Belouet-Moreau C, Christoforov B, Vidal-Trecan G. Venous thromboembolism in medical inpatients: prophylaxis with low-weight heparin in a university hospital and prevalence of thromboembolic events. Clin Appl Thromb Hemost. 2001;7(1):16-20. [pmid: 11190898].
Dieter RA Jr, Asselmeier GH, McCray RM. Surgery and anticoagulation therapy. IMJ Ill Med J. 1973;144(3):205-7 passim. [pmid: 4147261].
DiGiovanni CW, Restrepo A, Gonzalez Della, Valle AG, et al. The safety and efficacy of intraoperative heparin in total hip arthroplasty. Clin Orthop Relat Res. 2000;(379):178-85. [pmid: 11039805].
Dorr LD, Gendelman V, Maheshwari AV, Boutary M, Wan Z, Long WT. Multimodal thromboprophylaxis for total hip and knee arthroplasty based on risk assessment. J Bone Joint Surg Am. 2007;89(12):2648-57. [pmid: 18056497].
Dovrish Z, Hadary R, Blickstein D, Shilo L, Ellis MH. Retrospective analysis of the use of inferior vena cava filters in routine hospital practice. Postgrad Med J. 2006;82(964):150-3. [pmid: 16461480].
Drouet JC, Bernard JM, Bourreli B, Gunst JP. Low-molecular-weight heparin (fraxiparine) to prevent deep vein thrombosis in patients undergoing orthopedic surgery: a clinical report of two regimens. Haemostasis. 1988;18(2):135-6. [pmid: 2842239].
Dulíček P, Pavlata J, Karpaš K, Urban K, Malý J. Prophylaxis of tromboembolic disease after total hip replacement: Profylaxe tromboembolické nemoci po náhradě kyčelního kloubu. 2000;67(4):243-5.
Edwards JZ, Pulido PA, Ezzet KA, Copp SN, Walker RH, Colwell CW Jr. Portable compression device and low-molecular-weight heparin compared with low-molecular-weight heparin for thromboprophylaxis after total joint arthroplasty. J Arthroplasty. 2008;23(8):1122-7. [pmid: 18534421].
Einav S, Dezigibker I, Naamad M, et al. Anti-activated factor X response to enoxaparin in critically ill patients. Crit. Care. 2009;13:S177.
Elalamy I, Potevin F, Lecrubier C, Bara L, Marie JP, Samama MM. A fatal low-molecular-weight heparin-associated thrombocytopenia after hip surgery: possible usefulness of PF4-heparin ELISA test. Blood Coagul Fibrinolysis. 1996;7(7):665-71. [pmid: 8958387].
Emerson RH Jr, Cross R, Head WC. Prophylactic and early therapeutic use of the Greenfield filter in hip and knee joint arthroplasty. J Arthroplasty. 1991;6(2):129-35. [pmid: 1875203].
Ennis RS. Postoperative deep vein thrombosis prophylaxis: a retrospective analysis in 1000 consecutive hip fracture patients treated in a community hospital setting. J South Orthop Assoc. 2003;12(1):10-7. [pmid: 12735619].
Enyart JJ, Jones RJ. Low-dose warfarin for prevention of symptomatic thromboembolism after orthopedic surgery. Ann Pharmacother. 2005;39(6):1002-7. [pmid: 15886295].
Epstein NE. Intermittent pneumatic compression stocking prophylaxis against deep venous thrombosis in anterior cervical spinal surgery: a prospective efficacy study in 200 patients and literature review. Spine (Phila Pa 1976). 2005;30(22):2538-43. [pmid: 16284592].
Eriksson B, Borris L, Dahl O, Haas S, ODIXa-HIP Study Invest, et al. A once-daily, oral, direct Factor Xa inhibitor, rivaroxaban (BAY 59- 7939), for thromboprophylaxis after total hip replacement: A once-daily, oral, direct Factor Xa inhibitor, rivaroxaban (BAY 59- 7939), for thromboprophylaxis after total hip replacement. Circulation. 2006;114:2374-81. [pmid: 17116766].
Eriksson B, Borris L, Friedman R, Haas S, RECORD1 Study Grp, et al. Rivaroxaban versus enoxaparin for thromboprophylaxis after hip arthroplasty: Rivaroxaban versus enoxaparin for thromboprophylaxis after hip arthroplasty. New England Journal of Medicine (USA). 2008;358:2765-75.
Eriksson B, Dahl O, Rosencher N, Kurth A, RE-NOVATE Study Grp, et al. Dabigatran etexilate versus enoxaparin for prevention of venous thromboembolism after total hip replacement: a randomised, double-blind, non-inferiority trial: Dabigatran etexilate versus enoxaparin for prevention of venous thromboembolism after total hip replacement: a randomised, double-blind, non-inferiority trial. Lancet, The (USA). 2007;370:949-56.
Eriksson B, PENTHIFRA Plus Inv, Lassen M. Duration of prophylaxis against venous thromboembolism with fondaparinux after hip fracture surgery - A multicenter, randomized, placebo-controlled, double-blind study: Duration of prophylaxis against venous thromboembolism with fondaparinux after hip fracture surgery - A multicenter, randomized, placebo-controlled, double-blind study. Archives of Internal Medicine (USA). 2003;163:1337-42.
Eriksson B, Zachrisson B, Teger-Nilsson AC, Risberg B, Lundmark S. Thrombosis prophylaxis with low molecular weight heparin in total hip replacement, fragmin versus dextran. Thrombosis Research. Suppl VII. 1987:22. Abstract no: 18.
Eriksson BI, Agnelli G, Cohen AT, et al. Direct thrombin inhibitor melagatran followed by oral ximelagatran in comparison with enoxaparin for prevention of venous thromboembolism after total hip or knee replacement. Thromb Haemost. 2003;89(2):288-96. [pmid: 12574809].
Eriksson BI, Agnelli G, Cohen AT, et al. The direct thrombin inhibitor melagatran followed by oral ximelagatran compared with enoxaparin for the prevention of venous thromboembolism after total hip or knee replacement: the EXPRESS study. J Thromb Haemost. 2003;1(12):2490-6. [pmid: 14675083].
Eriksson BI, Arfwidsson AC, Frison L, et al. A dose-ranging study of the oral direct thrombin inhibitor, ximelagatran, and its subcutaneous form, melagatran, compared with dalteparin in the prophylaxis of thromboembolism after hip or knee replacement: METHRO I. MElagatran for THRombin inhibition in Orthopaedic surgery. Thromb Haemost. 2002;87(2):231-7. [pmid: 11858482].
Eriksson BI, Bauer KA, Lassen MR, Turpie AG, et al. Fondaparinux compared with enoxaparin for the prevention of venous thromboembolism after hip-fracture surgery: Fondaparinux compared with enoxaparin for the prevention of venous thromboembolism after hip-fracture surgery. N. Engl. J. Med. 2001;345:1298-304. [pmid: 11794148].
Eriksson BI, Bauer KA, Lassen MR, Turpie AG. Fondaparinux compared with enoxaparin for the prevention of venous thromboembolism after hip-fracture surgery. N Engl J Med. 2001;345(18):1298-304. [pmid: 11794148].
Eriksson BI, Bauer KA, Lassen MR, Turpie AG. Influence of the duration of fondaparinux (Arixtra) prophylaxis in preventing venous thromboembolism following major orthopedic surgery. J Thromb Haemost. 2003;1(2):383-4. [pmid: 12871516].
Eriksson BI, Bergqvist D, Kalebo P, et al. Ximelagatran and melagatran compared with dalteparin for prevention of venous thromboembolism after total hip or knee replacement: the METHRO II randomised trial. Lancet. 2002;360(9344):1441-7. [pmid: 12433510].
Eriksson BI, Borris LC, Dahl OE, et al. A once-daily, oral, direct Factor Xa inhibitor, rivaroxaban (BAY 59-7939), for thromboprophylaxis after total hip replacement. Circulation. 2006;114(22):2374-81. [pmid: 17116766].
Eriksson BI, Borris LC, Dahl OE, et al. A once-daily, oral, direct Factor Xa inhibitor, rivaroxaban (BAY 59-7939), for thromboprophylaxis after total hip replacement. Circulation. 2006;114(22):2374-81. [pmid: 17116766].
Eriksson BI, Borris LC, Dahl OE, et al. Dose-escalation study of rivaroxaban (BAY 59-7939)--an oral, direct Factor Xa inhibitor--for the prevention of venous thromboembolism in patients undergoing total hip replacement. Thromb Res. 2007;120(5):685-93. [pmid: 17292948].
Eriksson BI, Borris LC, Friedman RJ, et al. Rivaroxaban versus enoxaparin for thromboprophylaxis after hip arthroplasty. N Engl J Med. 2008;358(26):2765-75. [pmid: 18579811].
Eriksson BI, Dahl OE, Ahnfelt L, et al. Dose escalating safety study of a new oral direct thrombin inhibitor, dabigatran etexilate, in patients undergoing total hip replacement: BISTRO I. J Thromb Haemost. 2004;2(9):1573-80. [pmid: 15333033].
Eriksson BI, Dahl OE, Buller HR, et al. A new oral direct thrombin inhibitor, dabigatran etexilate, compared with enoxaparin for prevention of thromboembolic events following total hip or knee replacement: the BISTRO II randomized trial. J Thromb Haemost. 2005;3(1):103-11. [pmid: 15634273].
Eriksson BI, Dahl OE, Huo MH, et al. Oral dabigatran versus enoxaparin for thromboprophylaxis after primary total hip arthroplasty (RE-NOVATE II*). A randomised, double-blind, non-inferiority trial. Thromb Haemost. 2011;105(4):721-9. [pmid: 21225098].
Eriksson BI, Dahl OE, Lassen MR, et al. Partial factor IXa inhibition with TTP889 for prevention of venous thromboembolism: an exploratory study. J Thromb Haemost. 2008;6(3):457-63. [pmid: 18088349].
Eriksson BI, Dahl OE, Rosencher N, et al. Dabigatran etexilate versus enoxaparin for prevention of venous thromboembolism after total hip replacement: a randomised, double-blind, non-inferiority trial. Lancet. 2007;370(9591):949-56. [pmid: 17869635].
Eriksson BI, Dahl OE, Rosencher N, et al. Oral dabigatran etexilate vs. subcutaneous enoxaparin for the prevention of venous thromboembolism after total knee replacement: the RE-MODEL randomized trial. J Thromb Haemost. 2007;5(11):2178-85. [pmid: 17764540].
Eriksson BI, Ekman S, Kalebo P, Zachrisson B, Bach D, Close P. Prevention of deep-vein thrombosis after total hip replacement: direct thrombin inhibition with recombinant hirudin, CGP 39393. Lancet. 1996;347(9002):635-9. [pmid: 8596376].
Eriksson BI, Kakkar AK, Turpie AG, et al. Oral rivaroxaban for the prevention of symptomatic venous thromboembolism after elective hip and knee replacement. J Bone Joint Surg Br. 2009;91(5):636-44. [pmid: 19407299].
Eriksson BI, Kalebo P, Anthymyr BA, Wadenvik H, Tengborn L, Risberg B. Prevention of deep-vein thrombosis and pulmonary embolism after total hip replacement. Comparison of low-molecular-weight heparin and unfractionated heparin. J Bone Joint Surg Am. 1991;73(4):484-93. [pmid: 2013587].
Eriksson BI, Lassen MR, Colwell CW Jr. Efficacy of fondaparinux for thromboprophylaxis in hip fracture patients. J Arthroplasty. 2004;19(7 Suppl 2):78-81. [pmid: 15457423].
Eriksson BI, Lassen MR. Duration of prophylaxis against venous thromboembolism with fondaparinux after hip fracture surgery: a multicenter, randomized, placebo-controlled, double-blind study. Arch Intern Med. 2003;163(11):1337-42. [pmid: 12796070].
Eriksson BI, Wille-Jorgensen P, Kalebo P, et al. A comparison of recombinant hirudin with a low-molecular-weight heparin to prevent thromboembolic complications after total hip replacement. N Engl J Med. 1997;337(19):1329-35. [pmid: 9358126].
Eriksson BI, Zachrisson BE, Teger-Nilsson AC, Risberg B. Thrombosis prophylaxis with low molecular weight heparin in total hip replacement. Br J Surg. 1988;75(11):1053-7. [pmid: 2463035].
Eskander MB, Limb D, Stone MH, et al. Sequential mechanical and pharmacological thromboprophylaxis in the surgery of hip fractures. A pilot study. Int Orthop. 1997;21(4):259-61. [pmid: 9349964].
Faroug R, Konnuru S, Min SS, Hussain F, Ampat G. Venous thromboembolism prevention post neck of femur fractures - does it make a difference?. Thromb J. 2008;6:8. [pmid: 18582377].
Fauno P, Suomalainen O, Rehnberg V, et al. Prophylaxis for the prevention of venous thromboembolism after total knee arthroplasty. A comparison between unfractionated and low-molecular-weight heparin. J Bone Joint Surg Am. 1994;76(12):1814-8. [pmid: 7989386].
Feller JA, Parkin JD, Phillips GW, Hannon PJ, Hennessy O, Huggins RM. Prophylaxis against venous thrombosis after total hip arthroplasty. Aust N Z J Surg. 1992;62(8):606-10. [pmid: 1642580].
Ferree BA, Stern PJ, Jolson RS, Roberts JM 5th, Kahn A 3rd. Deep venous thrombosis after spinal surgery. Spine (Phila Pa 1976). 1993;18(3):315-9. [pmid: 8475429].
Fink JA, Jones BT. The Greenfield filter as the primary means of therapy in venous thromboembolic disease. Surg Gynecol Obstet. 1991;172(4):253-6. [pmid: 2006447].
Fisher CG, Blachut PA, Salvian AJ, Meek RN, O'Brien PJ. Effectiveness of pneumatic leg compression devices for the prevention of thromboembolic disease in orthopaedic trauma patients: a prospective, randomized study of compression alone versus no prophylaxis. J Orthop Trauma. 1995;9(1):1-7. [pmid: 7714648].
Fishmann AJ, Greeno RA, Brooks LR, Matta JM. Prevention of deep vein thrombosis and pulmonary embolism in acetabular and pelvic fracture surgery. Clin Orthop Relat Res. 1994;(305):133-7. [pmid: 8050222].
Fitzgerald RH Jr, Spiro TE, Trowbridge AA, et al. Prevention of venous thromboembolic disease following primary total knee arthroplasty. A randomized, multicenter, open-label, parallel-group comparison of enoxaparin and warfarin. J Bone Joint Surg Am. 2001;83-A(6):900-6. [pmid: 11407799].
Fitzgerald RH Jr, Spiro TE, Trowbridge AA, et al. Prevention of venous thromboembolic disease following primary total knee arthroplasty. A randomized, multicenter, open-label, parallel-group comparison of enoxaparin and warfarin. J Bone Joint Surg Am. 2001;83-A(6):900-6. [pmid: 11407799].
Fitzgerald RH, Spiro TE, Trowbridge AA, et al. Prevention of venous thromboembolic disease following primary total knee arthroplasty. A randomized, multicenter, open-label, parallel-group comparison of enoxaparin and warfarin. The Journal of Bone and Joint Surgery. American Volume. 2001;83-A(6):900-6. [pmid: 11407799].
Fordyce MJ, Ling RS. A venous foot pump reduces thrombosis after total hip replacement. J Bone Joint Surg Br. 1992;74(1):45-9. [pmid: 1732264].
Francis C, Berkowitz S, Comp P, Lieberman J, EXULT A Study Grp, et al. Comparison of ximelagatran with warfarin for the prevention of venous thromboembolism after total knee replacement: Comparison of ximelagatran with warfarin for the prevention of venous thromboembolism after total knee replacement. New England Journal of Medicine (USA). 2003;349:1703-12.
Francis C, Davidson B, Berkowitz S, Lotke P, Colwell C, et al. Ximelagatran versus warfarin for the prevention of venous thromboembolism after total knee arthroplasty - A randomized, double-blind trial: Ximelagatran versus warfarin for the prevention of venous thromboembolism after total knee arthroplasty - A randomized, double-blind trial. Annals of Internal Medicine (USA). 2002;137:648-55.
Francis CW, Berkowitz SD, Comp PC, et al. Comparison of ximelagatran with warfarin for the prevention of venous thromboembolism after total knee replacement. N Engl J Med. 2003;349(18):1703-12. [pmid: 14585938].
Francis CW, Davidson BL, Berkowitz SD, et al. Ximelagatran versus warfarin for the prevention of venous thromboembolism after total knee arthroplasty. A randomized, double-blind trial. Ann Intern Med. 2002;137(8):648-55. [pmid: 12379064].
Francis CW, Marder VJ, Evarts CM, Yaukoolbodi S. Two-step warfarin therapy. Prevention of postoperative venous thrombosis without excessive bleeding. JAMA. 1983;249(3):374-8. [pmid: 6184493].
Francis CW, Pellegrini VD Jr, Harris CM, Marder VJ. Antithrombin III prophylaxis of venous thromboembolic disease after total hip or total knee replacement. Am J Med. 1989;87(3B):61S-6S. [pmid: 2478015].
Francis CW, Pellegrini VD Jr, Marder VJ, et al. Comparison of warfarin and external pneumatic compression in prevention of venous thrombosis after total hip replacement. JAMA. 1992;267(21):2911-5. [pmid: 1583760].
Francis CW, Pellegrini VD Jr, Marder VJ, et al. Prevention of venous thrombosis after total hip arthroplasty. Antithrombin III and low-dose heparin compared with dextran 40. J Bone Joint Surg Am. 1989;71(3):327-35. [pmid: 2466846].
Francis CW, Pellegrini VD Jr, Stulberg BN, Miller ML, Totterman S, Marder VJ. Prevention of venous thrombosis after total knee arthroplasty. Comparison of antithrombin III and low-dose heparin with dextran. J Bone Joint Surg Am. 1990;72(7):976-82. [pmid: 1696577].
Francis CW, Pellegrini VD Jr, Totterman S, et al. Prevention of deep-vein thrombosis after total hip arthroplasty. Comparison of warfarin and dalteparin. J Bone Joint Surg Am. 1997;79(9):1365-72. [pmid: 9314399].
Francis CW, Pellegrini VD Jr, Totterman S, et al. Prevention of deep-vein thrombosis after total hip arthroplasty. Comparison of warfarin and dalteparin. J Bone Joint Surg Am. 1997;79(9):1365-72. [pmid: 9314399].
Francis CW, Pellegrini VD, Marder VJ, Totterman S, Leibert KM, et al. Comparison of warfarin and external pneumatic compression in prevention of venous thrombosis after total hip replacement: Comparison of warfarin and external pneumatic compression in prevention of venous thrombosis after total hip replacement. Journal of the American Medical Association(USA). 1992;267:2911-5.
Fredin H, Bergqvist D, Cederholm C, Lindblad B, Nyman U. Thromboprophylaxis in hip arthroplasty. Dextran with graded compression or preoperative dextran compared in 150 patients. Acta Orthop Scand. 1989;60(6):678-81. [pmid: 2483018].
Fredin H, Lindblad B, Jaroszewski H, Bergqvist D. Prevention of thrombosis after hip fracture surgery. Comparison of dextran 70 with and without dihydroergotamine. Acta Chirurgica Scandinavica. 1985;151(8):681-4. [pmid: 2420105].
Fredin H, Nilsson B, Rosberg B, Tengborn L. Pre- and postoperative levels of antithrombin III with special reference to thromboembolism after total hip replacement. Thromb Haemost. 1983;49(3):158-61. [pmid: 6192514].
Fredin HO, Rosberg B, Arborelius M Jr, Nylander G. On thrombo-embolism after total hip replacement in epidural analgesia: a controlled study of dextran 70 and low-dose heparin combined with dihydroergotamine. Br J Surg. 1984;71(1):58-60. [pmid: 6689974].
Freick H, Haas S. Prevention of deep vein thrombosis by low-molecular-weight heparin and dihydroergotamine in patients undergoing total hip replacement. Thromb Res. 1991;63(1):133-43. [pmid: 1658962].
Friedman RJ, Caprini JA, Comp PC, et al. Dabigatran etexilate versus enoxaparin in preventing venous thromboembolism following total knee arthroplasty [abstract no:O-W-051]. Journal of Thrombosis & Haemostasis. 2007;5(Suppl 1).
Froimson MI, Murray TG, Fazekas AF. Venous thromboembolic disease reduction with a portable pneumatic compression device. J Arthroplasty. 2009;24(2):310-6. [pmid: 18534456].
Fuji T, Fuijita S, Ujihira T, Sato T. Dabigatran etexilate prevents venous thromboembolism after total knee arthroplasty in Japanese patients with a safety profile comparable to placebo. J Arthroplasty. 2010;25(8):1267-74. [pmid: 19854610].
Fuji T, Fujita S, Ochi T. Fondaparinux prevents venous thromboembolism after joint replacement surgery in Japanese patients. Int Orthop. 2008;32(4):443-51. [pmid: 17468868].
Fuji T, Fujita S, Tachibana S, et al. Efficacy and safety of edoxaban versus enoxaparin for the prevention of venous thromboembolism following total hip arthroplasty: Stars J-V trial [Abstract No. 3320]. Blood. 2010;116(21).
Fuji T, Fujita S, Tachibana S, Kawai Y. Randomized, double-blind, multi-dose efficacy, safety and biomarker study of the oral factor xa inhibitor DU-176b compared with placebo for prevention of venous thromboembolism in patients after total knee arthroplasty. Blood. 2008;112(11). Abstract no:34.
Fuji T, Ochi T, Niwa S, Fujita S. Prevention of postoperative venous thromboembolism in Japanese patients undergoing total hip or knee arthroplasty: two randomized, double-blind, placebo-controlled studies with three dosage regimens of enoxaparin. J Orthop Sci. 2008;13(5):442-51. [pmid: 18843459].
Fujisawa M, Naito M, Asayama I, Kambe T, Koga K. Effect of calf-thigh intermittent pneumatic compression device after total hip arthroplasty: comparative analysis with plantar compression on the effectiveness of reducing thrombogenesis and leg swelling. J Orthop Sci. 2003;8(6):807-11. [pmid: 14648269].
Fujita S, Hirota S, Oda T, Kato Y, Tsukamoto Y, Fuji T. Deep venous thrombosis after total hip or total knee arthroplasty in patients in Japan. Clin Orthop Relat Res. 2000;(375):168-74. [pmid: 10853166].
Funk L, Cohen A, Woodcock N, Roy B, Bradley JG. Comparison of the efficacy and safety of the A-V impulse system with that of enoxaparin in the prophylaxis of deep venous thrombosis in total knee arthroplasty. Journal of Bone and Joint Surgery - British Volume. 2000;82(Suppl 1):62.
Gabriel Botella F, Labios Gomez M, Balaguer Martinez JV, Bort Marti J, Bataller Sifre R, Campos Cervera JM. Adverse effects of 2 forms of therapy with heparin in patients with non-surgical risk factors of venous thromboembolism. An Med Interna. 1993;10(1):16-20. [pmid: 8383549].
Galanter WL, Thambi M, Rosencranz H, et al. Effects of clinical decision support on venous thromboembolism risk assessment, prophylaxis, and prevention at a university teaching hospital. Am J Health Syst Pharm. 2010;67(15):1265-73. [pmid: 20651317].
Galasko CS, Edwards DH, Fearn CB, Barber HM. The value of low dosage heparin for the prophylaxis of thromboembolism in patients with transcervical and intertrochanteric femoral fractures. Acta Orthop Scand. 1976;47(3):276-82. [pmid: 782146].
Gallay S, Waddell JP, Cardella P, Morton J. A short course of low-molecular-weight heparin to prevent deep venous thrombosis after elective total hip replacement. Can J Surg. 1997;40(2):119-23. [pmid: 9126125].
Gallus A, Raman K, Darby T. Venous thrombosis after elective hip replacement - the influence of preventive intermittent calf compression and of surgical technique. BR. J. SURG. 1983;70(1):17-9. [pmid: 6337668].
Gallus AS, Cade JF, Mills KW, Murphy W. Apparent lack of synergism between heparin and dihydroergotamine in prevention of deep vein thrombosis after elective hip replacement: a randomised double-blind trial reported in conjunction with an overview of previous results. Thromb Haemost. 1992;68(3):238-44. [pmid: 1440484].
Gallus AS, Hirsh J, Tutle RJ, et al. Small subcutaneous doses of heparin in prevention of venous thrombosis. N Engl J Med. 1973;288(11):545-51. [pmid: 4568221].
Gelfer Y, Tavor H, Oron A, Peer A, Halperin N, Robinson D. Deep vein thrombosis prevention in joint arthroplasties: continuous enhanced circulation therapy vs low molecular weight heparin. J Arthroplasty. 2006;21(2):206-14. [pmid: 16520208].
Genton E, Gent M, Hirsh J, Harker LA. Platelet-inhibiting drugs in the prevention of clinical thrombotic disease (third of three parts). N Engl J Med. 1975;293(25):1296-300. [pmid: 1102986].
Gerhart TN, Yett HS, Robertson LK, Lee MA, Smith M, Salzman EW. Low-molecular-weight heparinoid compared with warfarin for prophylaxis of deep-vein thrombosis in patients who are operated on for fracture of the hip. A prospective, randomized trial. J Bone Joint Surg Am. 1991;73(4):494-502. [pmid: 1707413].
Gerkens S, Beguin C, Crott R, Closon MC, Horsmans Y. Assessing the quality of pharmacological treatments from administrative databases: the case of low-molecular-weight heparin after major orthopaedic surgery. J Eval Clin Pract. 2008;14(4):585-94. [pmid: 18462276].
Gerlach R, Raabe A, Beck J, Woszczyk A, Seifert V. Postoperative nadroparin administration for prophylaxis of thromboembolic events is not associated with an increased risk of hemorrhage after spinal surgery. Eur Spine J. 2004;13(1):9-13. [pmid: 14615928].
Gerosa C, Calvani AB, Cornelli U, et al. A multicenter study of defibrotide in the prevention of deep venous thrombosis. Final results. Minerva Chir. 1989;44(10):1507-16. [pmid: 2671797].
Giannoni MF, Ciatti R, Capoccia L, Ruggiero M, Dauri M, Mariani PP. Total knee replacement: prevention of deep-vein thrombosis using pharmacological (low-molecular-weight heparin) and mechanical (intermittent foot sole pump system) combined prophylaxis. Preliminary results. Int Angiol. 2006;25(3):316-21. [pmid: 16878083].
Ginsberg JS, Davidson BL, Comp PC, et al. Oral thrombin inhibitor dabigatran etexilate vs North American enoxaparin regimen for prevention of venous thromboembolism after knee arthroplasty surgery. J Arthroplasty. 2009;24(1):1-9. [pmid: 18534438].
Girolami B, Prandoni P, Stefani PM, et al. The incidence of heparin-induced thrombocytopenia in hospitalized medical patients treated with subcutaneous unfractionated heparin: a prospective cohort study. Blood. 2003;101(8):2955-9. [pmid: 12480713].
Given MF, McDonald BC, Brookfield P, et al. Retrievable Gunther Tulip inferior vena cava filter: experience in 317 patients. J Med Imaging Radiat Oncol. 2008;52(5):452-7. [pmid: 19032390].
Glynn O. The express study: preliminary results. Int J Clin Pract. 2003;57(1):57-9. [pmid: 12587945].
Gnudi S, Picci P, Figus E. Thrombo-embolism as a complication of prosthetic replacement operations of the hip: prophylaxis with heparin at low doses. Ital J Orthop Traumatol. 1980;6(1):147-51. [pmid: 7203996].
Goel DP, Buckley R, deVries G, Abelseth G, Ni A, Gray R. Prophylaxis of deep-vein thrombosis in fractures below the knee: a prospective randomised controlled trial. J Bone Joint Surg Br. 2009;91(3):388-94. [pmid: 19258618].
Goldstein WM, Jimenez ML, Bailie DS, Wall R, Branson J. Safety of a clinical surveillance protocol with 3- and 6-week warfarin prophylaxis after total joint arthroplasty. Orthopedics. 2001;24(7):651-4. [pmid: 11478551].
Golob JF Jr, Sando MJ, Kan JC, Yowler CJ, Malangoni MA, Claridge JA. Therapeutic anticoagulation in the trauma patient: is it safe?. Surgery. 2008;144(4):591-6. discussion 596-7. [pmid: 18847643].
Golueke PJ, Garrett WV, Thompson JE, Smith BL, Talkington CM. Interruption of the vena cava by means of the Greenfield filter: expanding the indications. Surgery. 1988;103(1):111-7. [pmid: 3336860].
Gonzalez Della Valle A, Serota A, Go G, et al. Venous thromboembolism is rare with a multimodal prophylaxis protocol after total hip arthroplasty. Clin Orthop Relat Res. 2006;444:146-53. [pmid: 16446593].
Grande WJ, Trerotola SO, Reilly PM, et al. Experience with the recovery filter as a retrievable inferior vena cava filter. J Vasc Interv Radiol. 2005;16(9):1189-93. [pmid: 16151059].
Green L, Lawrie AS, Patel S, et al. The impact of elective knee/hip replacement surgery and thromboprophylaxis with rivaroxaban or dalteparin on thrombin generation. Br J Haematol. 2010;151(5):469-76. [pmid: 20950405].
Greenfield LJ, Cho KJ, Proctor M, et al. Results of a multicenter study of the modified hook-titanium Greenfield filter. J Vasc Surg. 1991;14(3):253-7. [pmid: 1880833].
Greenfield LJ, Cho KJ, Proctor MC, Sobel M, Shah S, Wingo J. Late results of suprarenal Greenfield vena cava filter placement. Arch Surg. 1992;127(8):969-73. [pmid: 1642540].
Greenfield LJ, Cho KJ, Tauscher JR. Limitations of percutaneous insertion of Greenfield filters. J Cardiovasc Surg (Torino). 1990;31(3):344-50.
Greenfield LJ, Michna BA. Twelve-year clinical experience with the Greenfield vena caval filter. Surgery. 1988;104(4):706-12. [pmid: 3175867].
Grion AM, Gallo U, Bano F, et al. Difference in mortality after hip fracture is associated with postdischarge prescription of antithrombotic prophylaxis: a case-control study. Clin Appl Thromb Hemost. 2002;8(2):143-6. [pmid: 12121055].
Guyer RD, Booth RE Jr, Rothman RH. The detection and prevention of pulmonary embolism in total hip replacement. A study comparing aspirin and low-dose warfarin. J Bone Joint Surg Am. 1982;64(7):1040-4. [pmid: 7118968].
Haas S, Breyer HG, Bacher HP, et al. Prevention of major venous thromboembolism following total hip or knee replacement: a randomized comparison of low-molecular-weight heparin with unfractionated heparin (ECHOS Trial). Int Angiol. 2006;25(4):335-42. [pmid: 17164738].
Haas S, Stemberger A, Fritsche HM, et al. Prophylaxis of deep vein thrombosis in high risk patients undergoing total hip replacement with low molecular weight heparin plus dihydroergotamine. Arzneimittelforschung. 1987;37(7):839-43. [pmid: 2823840].
Haas S, Wolf H, Kakkar AK, Fareed J, Encke A. Prevention of fatal pulmonary embolism and mortality in surgical patients: a randomized double-blind comparison of LMWH with unfractionated heparin. Thromb Haemost. 2005;94(4):814-9. [pmid: 16270636].
Haas SB, Insall JN, Scuderi GR, Windsor RE, Ghelman B. Pneumatic sequential-compression boots compared with aspirin prophylaxis of deep-vein thrombosis after total knee arthroplasty. J Bone Joint Surg Am. 1990;72(1):27-31. [pmid: 2404020].
Hainaut J, Monteil R, Migne J. Anticoagulants in burn patients. Therapie. 1971;26(2):317-28. [pmid: 5574555].
Hakki SI, Fareed J, Hoppensteadt DA, et al. Plasma tissue factor pathway inhibitor levels as a marker for postoperative bleeding after enoxaparin use in deep vein thrombosis prophylaxis in orthopedics and general surgery. Clin Appl Thromb Hemost. 2000;6(4):206-12. [pmid: 11030526].
Hameed MF, Browse DJ, Immelman EJ, Goldberg PA. Should knee-length replace thigh-length graduated compression stockings in the prevention of deep-vein thrombosis?. S Afr J Surg. 2002;40(1):15-6. [pmid: 12082962].
Hampson WG, Harris FC, Lucas HK, et al. Failure of low-dose heparin to prevent deep-vein thrombosis after hip-replacement arthroplasty. Lancet. 1974;2(7884):795-7. [pmid: 4138905].
Happe LE, Farrelly EM, Stanford RH, Sarnes MW. Cost and occurrence of thrombocytopenia in patients receiving venous thromboembolism prophylaxis following major orthopaedic surgeries. J Thromb Thrombolysis. 2008;26(2):125-31. [pmid: 18034323].
Hardwick ME, Pulido PA, Colwell CW Jr. A mobile compression device compared with low-molecular-weight heparin for prevention of venous thromboembolism in total hip arthroplasty. Orthop Nurs. 2011;30(5):312-6. [pmid: 21934585].
Harenberg J, Kallenbach B, Martin U, et al. Randomized controlled study of heparin and low molecular weight heparin for prevention of deep-vein thrombosis in medical patients. Thromb Res. 1990;59(3):639-50. [pmid: 2173168].
Harenberg J, Roebruck P, Stehle G, Habscheid W, Biegholdt M, Heene DL. Heparin Study in Internal Medicine (HESIM): design and preliminary results. Thromb Res. 1992;68(1):33-43. [pmid: 1333105].
Harrington DT, Mozingo DW, Cancio L, Bird P, Jordan B, Goodwin CW. Thermally injured patients are at significant risk for thromboembolic complications. 2001;50:495-9.
Harris WH, Athanasoulis CA, Waltman AC, Salzman EW. High and low-dose aspirin prophylaxis against venous thromboembolic disease in total hip replacement. J Bone Joint Surg Am. 1982;64(1):63-6. [pmid: 7054205].
Harris WH, Athanasoulis CA, Waltman AC, Salzman EW. Prophylaxis of deep-vein thrombosis after total hip replacement. Dextran and external pneumatic compression compared with 1.2 or 0.3 gram of aspirin daily. J Bone Joint Surg Am. 1985;67(1):57-62. [pmid: 2578469].
Harris WH, Salzman EW, Athanasoulis CA, Waltman AC, DeSanctis RW. Aspirin prophylaxis of venous thromboembolism after total hip replacement: Aspirin prophylaxis of venous thromboembolism after total hip replacement. New England Journal of Medicine (USA). 1977;297:1246-9.
Harris WH, Salzman EW, DeSanctis RW, Coutts RD. Prevention of venous thromboembolism following total hip replacement. Warfarin vs dextran 40. JAMA: the Journal of the American Medical Association. 1972;220(10):1319-22. [pmid: 5067322].
Harris WH, Salzman EW, DeSanctis RW, Coutts RD. Prevention of venous thromboembolism following total hip replacement. Warfarin vs dextran 40. JAMA. 1972;220(10):1319-22. [pmid: 5067322].
Hartman JT, Pugh JL, Smith RD, Robertson WW Jr, Yost RP, Janssen HF. Cyclic sequential compression of the lower limb in prevention of deep venous thrombosis. J Bone Joint Surg Am. 1982;64(7):1059-62. [pmid: 7118972].
Heit JA, Colwell CW, Francis CW, et al. Comparison of the oral direct thrombin inhibitor ximelagatran with enoxaparin as prophylaxis against venous thromboembolism after total knee replacement: a phase 2 dose-finding study. Arch Intern Med. 2001;161(18):2215-21. [pmid: 11575978].
Heit JA, Elliott CG, Trowbridge AA, Morrey BF, Gent M, Hirsh J. Ardeparin sodium for extended out-of-hospital prophylaxis against venous thromboembolism after total hip or knee replacement. A randomized, double-blind, placebo-controlled trial. Ann Intern Med. 2000;132(11):853-61. [pmid: 10836911].
Heiz-Valle C, de Maistre E, Commun N, Heck M, Lecompte T, Hoffman M. Desirudin (Revasc) to prevent thromboembolic complications after hip or knee replacement surgery. Therapie. 2002;57(1):34-8. [pmid: 12090145].
Herner SJ, Paulson DC, Delate T, Witt DM, Vondracek TG. Evaluation of venous thromboembolism risk following hospitalization. J Thromb Thrombolysis. 2011;32(1):32-9. [pmid: 21193946].
Hernigou P, Charpentier P. Routine use of adjusted low-dose oral anticoagulants during the first three postoperative months after hip fracture in patients without comorbidity factors. J Orthop Trauma. 2001;15(8):535-41. [pmid: 11733668].
Hernigou P, Fevrier MJ, Kergrohen F. Prevention of thromboembolic complications with adapted low-dose of antivitamins K after total hip prosthesis. Rev Chir Orthop Reparatrice Appar Mot. 1993;79(7):577-85. [pmid: 8085039].
Hiromatsu S, Nata S, Ohno T, et al. Non-permanent inferior vena cava filters for prophylaxis and treatment of lower limb venous thromboembolism. Vasc Endovascular Surg. 2010;44(8):668-73. [pmid: 20724287].
Hitos K, Fletcher JP. Venous thromboembolism and fractured neck of femur. Thromb Haemost. 2005;94(5):991-6. [pmid: 16363242].
Hodge WA. Prevention of deep vein thrombosis after total knee arthroplasty. Coumadin versus pneumatic calf compression. Clin Orthop Relat Res. 1991;(271):101-5. [pmid: 1914282].
Hoek JA, Nurmohamed MT, Hamelynck KJ, et al. Prevention of deep vein thrombosis following total hip replacement by low molecular weight heparinoid. Thromb Haemost. 1992;67(1):28-32. [pmid: 1615479].
Hoffmann JN, Wiedermann CJ, Juers M, et al. Benefit/risk profile of high-dose antithrombin in patients with severe sepsis treated with and without concomitant heparin. Thromb Haemost. 2006;95(5):850-6. [pmid: 16676077].
Hoppe H, Kaufman JA, Barton RE, et al. Safety of inferior vena cava filter retrieval in anticoagulated patients. Chest. 2007;132(1):31-6. [pmid: 17505040].
Hoppe H, Nutting CW, Smouse HR, et al. Gunther Tulip filter retrievability multicenter study including CT follow-up: final report. J Vasc Interv Radiol. 2006;17(6):1017-23. [pmid: 16778236].
Hu R. Prophylaxis of deep-vein thrombosis in total hip surgery. Can J Surg. 1989;32(3):207-9. [pmid: 2469531].
Hull R, Carter C, Turpie AG, et al. A randomized trial of sequential pneumatic limb compression in the prevention of venous thromboembolism following elective hip surgery [abstract no:0190]. Thrombosis and Haemostasis. 1983;50(1):66.
Hull R, Raskob G, Pineo G, et al. A comparison of subcutaneous low-molecular-weight heparin with warfarin sodium for prophylaxis against deep-vein thrombosis after hip or knee implantation. N Engl J Med. 1993;329(19):1370-6. [pmid: 8413432].
Hull RD, Pineo GF, Francis C, et al. Low-molecular-weight heparin prophylaxis using dalteparin extended out-of-hospital vs in-hospital warfarin/out-of-hospital placebo in hip arthroplasty patients: a double-blind, randomized comparison. North American Fragmin Trial Investigators. Arch Intern Med. 2000;160(14):2208-15. [pmid: 10904465].
Hull RD, Pineo GF, Francis C, et al. Low-molecular-weight heparin prophylaxis using dalteparin in close proximity to surgery vs warfarin in hip arthroplasty patients: a double-blind, randomized comparison. The North American Fragmin Trial Investigators. Arch Intern Med. 2000;160(14):2199-207. [pmid: 10904464].
Hull RD, Pineo GF, Francis C, et al. Low-molecular-weight heparin prophylaxis using dalteparin in close proximity to surgery vs warfarin in hip arthroplasty patients: a double-blind, randomized comparison. The North American Fragmin Trial Investigators. Arch Intern Med. 2000;160(14):2199-207. [pmid: 10904464].
Hull RD, Raskob GE, Gent M, et al. Effectiveness of intermittent pneumatic leg compression for preventing deep vein thrombosis after total hip replacement. JAMA. 1990;263(17):2313-7. [pmid: 2182917].
Hull RD, Schellong SM, Tapson VF, et al. Extended-duration thromboprophylaxis in acutely ill medical patients with recent reduced mobility: methodology for the EXCLAIM study. J Thromb Thrombolysis. 2006;22(1):31-8. [pmid: 16786230].
Hull RD, Schellong SM, Tapson VF, et al. Extended-duration venous thromboembolism prophylaxis in acutely ill medical patients with recently reduced mobility: a randomized trial. Ann Intern Med. 2010;153(1):8-18. [pmid: 20621900].
Hume M, Bierbaum B, Kuriakose TX, Surprenant J. Prevention of postoperative thrombosis by aspirin. Am J Surg. 1977;133(4):420-2. [pmid: 322520].
Huo M, Eriksson B, Dahl O, et al. Oral dabigatran versus enoxaparin for thromboprophylaxis after primary total hip arthroplasty: The re-novate II randomised trial. Haematologica. 2010;95:233.
Huo MH, Salvati EA, Sharrock NE, et al. Intraoperative heparin thromboembolic prophylaxis in primary total hip arthroplasty. A prospective, randomized, controlled, clinical trial. Clin Orthop Relat Res. 1992;(274):35-46. [pmid: 1729021].
Huo MH, Salvati EA, Sharrock NE, et al. Intraoperative heparin thromboembolic prophylaxis in primary total hip arthroplasty. A prospective, randomized, controlled, clinical trial. Clin Orthop Relat Res. 1992;(274):35-46. [pmid: 1729021].
Hurson B, Ennis JT, Corrigan TP, MacAuley P. Dextran prophylaxis in total hip replacement: a scintigraphic evaluation of the incidence of deep vein thrombosis and pulmonary embolus. Irish Journal of Medical Science. 1979;148(4):140-4. [pmid: 528170].
Husted H, Otte KS, Kristensen BB, Orsnes T, Wong C, Kehlet H. Low risk of thromboembolic complications after fast-track hip and knee arthroplasty. Acta Orthop. 2010;81(5):599-605. [pmid: 20919815].
Hye RJ, Mitchell AT, Dory CE, Freischlag JA, Roberts AC. Analysis of the transition to percutaneous placement of Greenfield filters. Arch Surg. 1990;125(12):1550-3. [pmid: 2123085].
Ibarra-Perez C, Lau-Cortes E, Colmenero-Zubiate S, et al. Prevalence and prevention of deep venous thrombosis of the lower extremities in high-risk pulmonary patients. Angiology. 1988;39(6):505-13. [pmid: 3377270].
Imberti D, Bianchi M, Farina A, Siragusa S, Silingardi M, Ageno W. Clinical experience with retrievable vena cava filters: results of a prospective observational multicenter study. J Thromb Haemost. 2005;3(7):1370-5. [pmid: 15978093].
Inada K, Shirai N, Hayashi M, Matsumoto K, Hirose M. Postoperative deep venous thrombosis in Japan. Incidence and prophylaxis. Am J Surg. 1983;145(6):775-9. [pmid: 6859416].
Iwama H, Suzuki M, Hojo M, Kaneda M, Akutsu I. Intermittent pneumatic compression on the calf improves peripheral circulation of the leg. J Crit Care. 2000;15(1):18-21. [pmid: 10757194].
Jaffe D, Noff M, Peer A, Chen D, Bass A, Halperin N. Prophylaxis against deep-vein thrombosis in total knee replacement: comparison of low molecular weight heparin and the A-V Impulse System. Journal of Bone and Joint Surgery British Volume. 1999;81(Suppl 1):71.
Jain V, Dhal AK, Dhaon BK, Pradhan G. Deep vein thrombosis after total hip arthroplasty in Indian patients with and without enoxaparin. J Orthop Surg (Hong Kong). 2004;12(2):173-7. [pmid: 15621902].
Janjua M, Omran FM, Kastoon T, Alshami M, Abbas AE. Inferior vena cava filter migration: updated review and case presentation. J Invasive Cardiol. 2009;21(11):606-10. [pmid: 19901418].
Janni W, Bergauer F, Rjosk D, Lohscheidt K, Hagena F-W. A randomized controlled study evaluating the safety and efficacy of different low molecular weight heparins for high risk patients: Prospektiv randomisierte studie zum vergleich der wirksamkeit und der vertraglichkeit verschiedener niedermolekularer heparine bei hochrisikopatienten. Zentralbl. Chir. 2001;126(1):32-8. [pmid: 11227291].
Jensen CD, Steval A, Partington PF, Reed MR, Muller SD. Return to theatre following total hip and knee replacement, before and after the introduction of rivaroxaban: a retrospective cohort study. J Bone Joint Surg Br. 2011;93(1):91-5. [pmid: 21196550].
Jeong GK, Gruson KI, Egol KA, et al. Thromboprophylaxis after hip fracture: evaluation of 3 pharmacologic agents. Am J Orthop (Belle Mead NJ). 2007;36(3):135-40. [pmid: 17461395].
Joffe S. Drug prevention of postoperative deep vein thrombosis. A compararative study of calcium heparinate and sodium pentosan polysulfate. Arch Surg. 1976;111(1):37-40. [pmid: 1244812].
Johnson MS, Nemcek AA Jr, Benenati JF, et al. The safety and effectiveness of the retrievable option inferior vena cava filter: a United States prospective multicenter clinical study. J Vasc Interv Radiol. 2010;21(8):1173-84. [pmid: 20598570].
Johnson R, Green JR, Charnley J. Pulmonary embolism and its prophylaxis following the Charnley total hip replacement. Clin Orthop Relat Res. 1977;(127):123-32. [pmid: 912966].
Jones B, Fink JA, Donovan DL, Sharp WV. Analysis of benefit of anticoagulation after placement of Kimray-Greenfield filter. Surg Gynecol Obstet. 1989;169(5):400-2. [pmid: 2814749].
Jorgensen PS, Knudsen JB, Broeng L, et al. The thromboprophylactic effect of low molecular weight heparin (Fragmin) in hip fracture surgery. A placebo controlled trial. Ugeskr Laeger. 1993;155(10):706-8. [pmid: 8384388].
Jorgensen PS, Knudsen JB, Broeng L, et al. The thromboprophylactic effect of a low-molecular-weight heparin (Fragmin) in hip fracture surgery. A placebo-controlled study. Clin Orthop Relat Res. 1992;(278):95-100. [pmid: 1314147].
Jorgensen PS, Strandberg C, Wille-Jorgensen P, et al. Early preoperative thromboprophylaxis with Klexane(registered trademark) in hip fracture surgery: A placebo-controlled study. Clin. Appl. Thromb. Hemost. 1998;4(2):140-2.
Jorgensen PS, Warming T, Hansen K, et al. Low molecular weight heparin (Innohep) as thromboprophylaxis in outpatients with a plaster cast: a venografic controlled study. Thromb Res. 2002;105(6):477-80. [pmid: 12091045].
Josefsson G, Dahlqvist A, Bodfors B. Prevention of thromboembolism in total hip replacement. Aspirin versus dihydroergotamine-heparin. Acta Orthop Scand. 1987;58(6):626-9. [pmid: 3327353].
Kahn SR, Panju A, Geerts W, et al. Multicenter evaluation of the use of venous thromboembolism prophylaxis in acutely ill medical patients in Canada. Thromb Res. 2007;119(2):145-55. [pmid: 16516275].
Kakkar A, Brenner B, Dahl O, Eriksson B, RECORD2 Investigators, et al. Extended duration rivaroxaban versus short-term enoxaparin for the prevention of venous thromboembolism after total hip arthroplasty: a double-blind, randomised controlled trial: Extended duration rivaroxaban versus short-term enoxaparin for the prevention of venous thromboembolism after total hip arthroplasty: a double-blind, randomised controlled trial. Lancet, The (USA). 2008;372:31-9.
Kakkar AK, Brenner B, Dahl OE, et al. Extended duration rivaroxaban versus short-term enoxaparin for the prevention of venous thromboembolism after total hip arthroplasty: a double-blind, randomised controlled trial. Lancet. 2008;372(9632):31-9. [pmid: 18582928].
Kakkar VV, et al. Prevention of fatal postoperative pulmonary embolism by low doses of heparin. Lancet. 1975;2:45-51. [pmid: 49649].
Kakkar VV, Boeckl O, Boneu B, et al. Efficacy and safety of a low-molecular-weight heparin and standard unfractionated heparin for prophylaxis of postoperative venous thromboembolism: European multicenter trial. World J Surg. 1997;21(1):2-8. discussion 8-9. [pmid: 8943170].
Kakkar VV, Cohen AT, Edmonson RA, et al. Lancet. Low molecular weight versus standard heparin for prevention of venous thromboembolism after major abdominal surgery. 1993;341:259-65. [pmid: 8093915].
Kakkar VV, Cohen AT, Edmonson RA, et al. Low molecular weight versus standard heparin for prevention of venous thromboembolism after major abdominal surgery. The Thromboprophylaxis Collaborative Group. Lancet. 1993;341(8840):259-65. [pmid: 8093915].
Kakkar VV, Corrigan TP, Fossard DP, Sutherland I, Thirwell J. Prevention of Fatal Postoperative pulmonary embolism by low doses of heparin. Reappraisal of results of international multicentre trial. Lancet. 1977;1(8011):567-9. [pmid: 65660].
Kakkar VV, Field ES, Nicolaides AN, Flute PT. Low doses of heparin in prevention of deep-vein thrombosis. Lancet. 1971;2(7726):669-71. [pmid: 4105708].
Kakkar VV, Howes J, Sharma V, Kadziola Z. A comparative double-blind, randomised trial of a new second generation LMWH (bemiparin) and UFH in the prevention of post-operative venous thromboembolism. The Bemiparin Assessment group. Thromb Haemost. 2000;83(4):523-9. [pmid: 10780310].
Kakkar VV, Howes J, Sharma V, Kadziola Z. A comparative, double-blind, randomised trial of a new second generation LMWH (Bemiparin) and UFH in the prevention of post-operative venous thromboembolism. Thromb. Haemost. 2000;83(4):523-9. [pmid: 10780310].
Kakkar VV, Kakkar S, Sanderson RM, Peers CE. Efficacy and safety of two regimens of low molecular weight heparin fragment (Fragmin) in preventing postoperative venous thrombolism. Haemostasis. Suppl 2. 1986;16:19-24. [pmid: 3744132].
Kakkar VV, Lawrence D, Bentley PG, de Haas HA, Ward VP, Scully MF. A comparative study of low doses of heparin and a heparin analogue in the prevention of postoperative deep vein thrombosis. Thromb Res. 1978;13(1):111-22. [pmid: 694829].
Kakkar VV, Murray WJ. Efficacy and safety of low-molecular-weight heparin (CY216) in preventing postoperative venous thrombo-embolism: a co-operative study. Br J Surg. 1985;72(10):786-91. [pmid: 3899240].
Kalka C, Spirk D, Siebenrock KA, et al. Lack of extended venous thromboembolism prophylaxis in high-risk patients undergoing major orthopaedic or major cancer surgery. Electronic Assessment of VTE Prophylaxis in High-Risk Surgical Patients at Discharge from Swiss Hospitals (ESSENTIAL). Thromb Haemost. 2009;102(1):56-61. [pmid: 19572068].
Kalva SP, Athanasoulis CA, Fan CM, et al. “Recovery” vena cava filter: experience in 96 patients. Cardiovasc Intervent Radiol. 2006;29(4):559-64. [pmid: 16565794].
Kalva SP, Marentis TC, Yeddula K, Somarouthu B, Wicky S, Stecker MS. Long-term safety and effectiveness of the “OptEase” vena cava filter. Cardiovasc Intervent Radiol. 2011;34(2):331-7. [pmid: 20820780].
Kalva SP, Wicky S, Waltman AC, Athanasoulis CA. TrapEase vena cava filter: experience in 751 patients. J Endovasc Ther. 2006;13(3):365-72. [pmid: 16784325].
Kaufman HH, Satterwhite T, McConnell BJ, et al. Deep vein thrombosis and pulmonary embolism in head injured patients. Angiology. 1983;34(10):627-38. [pmid: 6226216].
Kawaji H, Ishii M, Tamaki Y, et al. Postoperative prophylactic effect of fondaparinux for prevention of deep venous thrombosis after cemented total hip replacement: a comparative study. Mod Rheumatol. 2011.
Keeling WB, Haines K, Stone PA, Armstrong PA, Murr MM, Shames ML. Current indications for preoperative inferior vena cava filter insertion in patients undergoing surgery for morbid obesity. Obes Surg. 2005;15(7):1009-12. [pmid: 16105398].
Keeney JA, Clohisy JC, Curry MC, Maloney WJ. Efficacy of combined modality prophylaxis including short-duration warfarin to prevent venous thromboembolism after total hip arthroplasty. J Arthroplasty. 2006;21(4):469-75. [pmid: 16781396].
Kennedy J, Soffe K, Rogers B, et al. Deep vein thrombosis prophylaxis in hip fractures: a comparison of the arteriovenous impulse system and aspirin… including commentary by Connolly JF. Journal of Trauma. 2000;48(2):268-72. [pmid: 10697085].
Kennedy JG, Soffe KE, Rogers BW, et al. Deep vein thrombosis prophylaxis in hip fractures: a comparison of the arteriovenous impulse system and aspirin. J Trauma. 2000;48(2):268-72. [pmid: 10697085].
Kew J, Lee YL, Davey IC, Ho SY, Fung KC, Metreweli C. Deep vein thrombosis in elderly Hong Kong Chinese with hip fractures detected with compression ultrasound and Doppler imaging: incidence and effect of low molecular weight heparin. Arch Orthop Trauma Surg. 1999;119(3-4):156-8. [pmid: 10392509].
Khaldi A, Helo N, Schneck MJ, Origitano TC. Venous thromboembolism: deep venous thrombosis and pulmonary embolism in a neurosurgical population. J Neurosurg. 2011;114(1):40-6. [pmid: 20815694].
Khaw FM, Moran CG, Pinder IM, Smith SR. The incidence of fatal pulmonary embolism after knee replacement with no prophylactic anticoagulation. J Bone Joint Surg Br. 1993;75(6):940-1. [pmid: 8245087].
Khouli H, Shapiro J, Pham VP, et al. Efficacy of deep venous thrombosis prophylaxis in the medical intensive care unit. J Intensive Care Med. 2006;21(6):352-8. [pmid: 17095499].
Kiil J, Kiil J, Axelsen F, Andersen D. Prophylaxis against postoperative pulmonary embolism and deep-vein thrombosis by low-dose heparin. Lancet. 1978;1(8074):1115-6. [pmid: 77413].
Kim YH, Choi IY, Park MR, Park TS, Cho JL. Prophylaxis for deep vein thrombosis with aspirin or low molecular weight dextran in Korean patients undergoing total hip replacement. A randomized controlled trial. Int Orthop. 1998;22(1):6-10. [pmid: 9549575].
Kim YH, Kim JS. Incidence and natural history of deep-vein thrombosis after total knee arthroplasty. A prospective, randomised study. J Bone Joint Surg Br. 2002;84(4):566-70. [pmid: 12043780].
Kimura K, Ohtani S, Okamura H, Ishii N, Kishimoto C, Konishi K. Anticoagulation therapy with heparin and warfarin in total knee arthroplasty for osteoarthritis knee. Clin Appl Thromb Hemost. 2009;15(1):109-12. [pmid: 19150995].
Kleindienst A, Mater E, Bronst J, et al. Prophylaxis against thromboembolism in neurosurgical intensive care patients: Analysis of safety and efficacy of early certoparin. Intensivmed. Notf.Med. 2003;40(6):494-8.
Kock HJ, Schmit-Neuerburg KP, Hanke J, Rudofsky G, Hirche H. Thromboprophylaxis with low-molecular-weight heparin in outpatients with plaster-cast immobilisation of the leg. Lancet. 1995;346(8973):459-61. [pmid: 7637478].
Koike S. Study on postoperative deep venous thrombosis with reference to prevention. Nihon Geka Gakkai Zasshi. 1988;89(2):270-81. [pmid: 3362130].
Komericki P, Grims R, Kranke B, Aberer W. Acute generalized exanthematous pustulosis from dalteparin. J Am Acad Dermatol. 2007;57(4):718-21. [pmid: 17610994].
Kosir MA, Kozol RA, Perales A, et al. Is DVT prophylaxis overemphasized? A randomized prospective study. J Surg Res. 1996;60(2):289-92. [pmid: 8598656].
Kothari SN, Lambert PJ, Mathiason MA, Best Poster Award. A comparison of thromboembolic and bleeding events following laparoscopic gastric bypass in patients treated with prophylactic regimens of unfractionated heparin or enoxaparin. Am J Surg. 2007;194(6):709-11. [pmid: 18005758].
Krotenberg R, Adler U, Pomeranz B, Miller JD, Russell MW. Dalteparin vs. enoxaparin as prophylaxis for deep-vein thrombosis after total hip or knee arthroplasty: a retrospective analysis. Am J Phys Med Rehabil. 2001;80(12):889-95. [pmid: 11821667].
Kucher N, Koo S, Quiroz R, et al. Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med. 2005;352(10):969-77. [pmid: 15758007].
Kudrnova Z, Kvasnicka J, Kudrna K, et al. Favorable coagulation profile with fondaparinux after hip surgery in elderly patients. Int J Hematol. 2009;90(4):476-82. [pmid: 19838769].
Kucera T, Maly R, Urban K, Sponer P. Venous thromboembolism prophylaxis after total hip arthroplasty: Prevence tromboembolické nemoci po implantaci totální endoprotézy kyčelního kloubu. 2011;78(2):101-5.
Kurtoglu M, Aydin E, Necefli A, Guloglu R, Poyanli A. Applications of the inferior vena cava filter for the prevention of the risk for pulmonary emboli. Ulus Travma Derg. 2001;7(1):35-9. [pmid: 11705171].
Kwong LM, Happe LE, Horblyuk R, Farrelly E. Decreased venous thromboembolism with injectable vs oral anticoagulation after discharge for major orthopedic surgery. J Arthroplasty. 2008;23(6 Suppl 1):25-30. [pmid: 18722300].
Labarere J, Bosson JL, Brion JP, et al. Validation of a clinical guideline on prevention of venous thromboembolism in medical inpatients: a before-and-after study with systematic ultrasound examination. J Intern Med. 2004;256(4):338-48. [pmid: 15367177].
Labarere J, Bosson JL, Sevestre MA, Boge G, Terriat B. Thromboprophylaxis with graduated compression stockings for elderly inpatients: more evidence is needed. J Thromb Haemost. 2006;4(8):1838-40. [pmid: 16879231].
Labarere J, Sevestre MA, Belmin J, et al. Low-molecular-weight heparin prophylaxis of deep vein thrombosis for older patients with restricted mobility: propensity analyses of data from two multicentre, cross-sectional studies. Drugs Aging. 2009;26(3):263-71. [pmid: 19358621].
Lacherade JC, Cook D, Heyland D, Chrusch C, Brochard L, Brun-Buisson C. Prevention of venous thromboembolism in critically ill medical patients: a Franco-Canadian cross-sectional study. J Crit Care. 2003;18(4):228-37. [pmid: 14691896].
Lachiewicz PF, Kelley SS, Haden LR. Two mechanical devices for prophylaxis of thromboembolism after total knee arthroplasty. A prospective, randomised study. J Bone Joint Surg Br. 2004;86(8):1137-41. [pmid: 15568526].
Lachiewicz PF, Soileau ES. Mechanical calf compression and aspirin prophylaxis for total knee arthroplasty. Clin Orthop Relat Res. 2007;464:61-4. [pmid: 17632417].
Lachiewicz PF, Soileau ES. Multimodal prophylaxis for THA with mechanical compression. Clin Orthop Relat Res. 2006;453:225-30. [pmid: 17006365].
Lacut K, Bressollette L, Le Gal G, et al. Prevention of venous thrombosis in patients with acute intracerebral hemorrhage. Neurology. 2005;65(6):865-9. [pmid: 16186525].
Laguardia AM, Caroli GC. Prevention of deep vein thrombosis in orthopaedic surgery. Comparison of two different treatment protocols with low molecular weight heparin (‘Fluxum’). Curr Med Res Opin. 1992;12(9):584-93. [pmid: 1316259].
Lahnborg G, Bergstrom K, Friman L, Lagergren H. Effect of low-dose heparin on incidence of postoperative pulmonary embolism detected by photoscanning. Lancet. 1974;1(7853):329-31. [pmid: 4131170].
Larson CM, MacMillan DP, Lachiewicz PF. Thromboembolism after total knee arthroplasty: intermittent pneumatic compression and aspirin prophylaxis. J South Orthop Assoc. 2001;10(3):155-63. discussion 163. [pmid: 12132827].
Lassen HK. Preoperative and postoperative anticoagulant prophylaxis to reduce fatal pulmonary embolism at a mixed surgical department. Acta Chir Scand. 1968;134(7):525-9. [pmid: 4183330].
Lassen MR, Ageno W, Borris LC, et al. Rivaroxaban versus enoxaparin for thromboprophylaxis after total knee arthroplasty. N Engl J Med. 2008;358(26):2776-86. [pmid: 18579812].
Lassen MR, Bauer KA, Eriksson BI, Turpie AG. Postoperative fondaparinux versus preoperative enoxaparin for prevention of venous thromboembolism in elective hip-replacement surgery: a randomised double-blind comparison. Lancet. 2002;359(9319):1715-20. [pmid: 12049858].
Lassen MR, Bauer KA, Eriksson BI, Turpie AGG. Postoperative fondaparinux versus preoperative enoxaparin for prevention of venous thromboembolism in elective hip-replacement surgery: A randomised double-blind comparison. Lancet. 2002;359(9319):1715-20. [pmid: 12049858].
Lassen MR, Borris LC, Christiansen HM, et al. Heparin/dihydroergotamine for venous thrombosis prophylaxis: comparison of low-dose heparin and low molecular weight heparin in hip surgery. Br J Surg. 1988;75(7):686-9. [pmid: 2843255].
Lassen MR, Borris LC, Christiansen HM, et al. Prevention of thromboembolism in 190 hip arthroplasties. Comparison of LMW heparin and placebo. Acta Orthop Scand. 1991;62(1):33-8. [pmid: 1848385].
Lassen MR, Borris LC, Christiansen HM, et al. Prevention of thromboembolism in hip-fracture patients. Comparison of low-dose heparin and low-molecular-weight heparin combined with dihydroergotamine. Arch Orthop Trauma Surg. 1989;108(1):10-3. [pmid: 2913977].
Lassen MR, Dahl O, Mismetti P, Zielske D, Turpie AG. SR123781A: a new once-daily synthetic oligosaccharide anticoagulant for thromboprophylaxis after total hip replacement surgery: the DRIVE (Dose Ranging Study in Elective Total Hip Replacement Surgery) study. J Am Coll Cardiol. 2008;51(15):1498-504. [pmid: 18402906].
Lassen MR, Dahl OE, Mismetti P, Destree D, Turpie AG. AVE5026, a new hemisynthetic ultra-low-molecular-weight heparin for the prevention of venous thromboembolism in patients after total knee replacement surgery--TREK: a dose-ranging study. J Thromb Haemost. 2009;7(4):566-72. [pmid: 19187076].
Lassen MR, Davidson BL, Gallus A, Pineo G, Ansell J, Deitchman D. The efficacy and safety of apixaban, an oral, direct factor Xa inhibitor, as thromboprophylaxis in patients following total knee replacement. J Thromb Haemost. 2007;5(12):2368-75. [pmid: 17868430].
Lassen MR, Davidson BL, Gallus A, Pineo G, Ansell J, Deitchman D. The efficacy and safety of apixaban, an oral, direct factor Xa inhibitor, as thromboprophylaxis in patients following total knee replacement. J Thromb Haemost. 2007;5(12):2368-75. [pmid: 17868430].
Lassen MR, Davidson BL, Gallus A, Pineo G, Ansell J, Deitchman D. The efficacy and safety of apixaban, an oral, direct factor Xa inhibitor, as thromboprophylaxis in patients following total knee replacement. J Thromb Haemost. 2007;5(12):2368-75. [pmid: 17868430].
Lassen MR, Gallus A, Raskob GE, Pineo G, Chen D, Ramirez LM. Apixaban versus enoxaparin for thromboprophylaxis after hip replacement. N Engl J Med. 2010;363(26):2487-98. [pmid: 21175312].
Lassen MR, Gallus AS, Pineo GF, Raskob GE. Late breaking clinical trial: The ADVANCE-2 study: A randomized double-blind trial comparing apixaban with enoxaparin for thromboprophylaxis after total knee replacement. J. Thromb. Haemost. 2009;7(S2):1203-4.
Lassen MR, Raskob GE, Gallus A, Pineo G, Chen D, Hornick P. Apixaban versus enoxaparin for thromboprophylaxis after knee replacement (ADVANCE-2): a randomised double-blind trial. Lancet. 2010;375(9717):807-15. [pmid: 20206776].
Lassen MR, Raskob GE, Gallus A, Pineo G, Chen D, Portman RJ. Apixaban or enoxaparin for thromboprophylaxis after knee replacement. N Engl J Med. 2009;361(6):594-604. [pmid: 19657123].
Le Blanche AF, Benazzouz A, Reynaud P, et al. The VenaTech LP permanent caval filter: effectiveness and safety in the prevention of pulmonary embolism--a European multicenter study. J Vasc Interv Radiol. 2008;19(4):509-15. [pmid: 18375294].
Leali A, Fetto J, Moroz A. Prevention of thromboembolic disease after non-cemented hip arthroplasty. A multimodal approach. Acta Orthop Belg. 2002;68(2):128-34. [pmid: 12050997].
Leclerc JR, Geerts WH, Desjardins L, et al. Prevention of deep vein thrombosis after major knee surgery--a randomized, double-blind trial comparing a low molecular weight heparin fragment (enoxaparin) to placebo. Thromb Haemost. 1992;67(4):417-23. [pmid: 1321509].
Leclerc JR, Geerts WH, Desjardins L, et al. Prevention of venous thromboembolism after knee arthroplasty. A randomized, double-blind trial comparing enoxaparin with warfarin. Ann Intern Med. 1996;124(7):619-26. [pmid: 8607589].
Leclerc JR, Geerts WH, Desjardins L, et al. Prevention of venous thromboembolism after knee arthroplasty. A randomized, double-blind trial comparing enoxaparin with warfarin. Ann Intern Med. 1996;124(7):619-26. [pmid: 8607589].
Leclerc JR, Gent M, Hirsh J, Geerts WH, Ginsberg JS. The incidence of symptomatic venous thromboembolism after enoxaparin prophylaxis in lower extremity arthroplasty: A cohort study of 1,984 patients. Chest. 1998;114(2 SUPPL. II):115S-8S. [pmid: 9726704].
Lederle FA, Sacks JM, Fiore L, et al. The prophylaxis of medical patients for thromboembolism pilot study. Am J Med. 2006;119(1):54-9. [pmid: 16431185].
Lee JA, Zierler BK. Prevention and clinical outcomes in older inpatients with suspected venous thromboembolism. J Gerontol Nurs. 2010;36(4):40-8. [pmid: 20128525].
Lee JA, Zierler BK. The use of prophylaxis in patients undergoing diagnostic tests for suspected venous thromboembolism. Phlebology. 2010;25(2):85-93. [pmid: 20348455].
Leizorovicz A, Cohen A, Turpie AGG, Olsson CG, Vaitkus PT, Goldhaber SZ. A randomized placebo controlled trial of dalteparin for the prevention of venous thromboembolism in 3706 acutely ill medical patients: the PREVENT medical thromboprophylaxis study. Journal of Thrombosis & Haemostasis. 2003;1(Suppl 1 July). Abstract no: OC 396.
Leizorovicz A, Cohen AT, Turpie AG, et al. Randomized, placebo-controlled trial of dalteparin for the prevention of venous thromboembolism in acutely ill medical patients. Circulation. 2004;110(7):874-9. [pmid: 15289368].
Leizorovicz A, Cohen AT, Turpie AG, Olsson CG, Vaitkus R, Goldhaber SZ. A randomised placebo-controlled trial of dalteparin for the prevention of venous thromboembolism in acutely ill medical patients. 2003.
Leizorovicz A, Cohen AT, Turpie AGG, Olsson C-G, Vaitkus PT, Goldhaber SZ. Randomized, placebo-controlled trial of dalteparin for the prevention of venous thromboembolism in acutely ill medical patients. Circulation. 2004;110(7):874-9. [pmid: 15289368].
Leon L, Rodriguez H, Tawk RG, Ondra SL, Labropoulos N, Morasch MD. The prophylactic use of inferior vena cava filters in patients undergoing high-risk spinal surgery. Ann. Vasc. Surg. 2005;19(3):442-7. [pmid: 15864473].
Lereun C, Wells P, Diamantopoulos A, Rasul F, Lees M, Sengupta N. An indirect comparison, via enoxaparin, of rivaroxaban with dabigatran in the prevention of venous thromboembolism after hip or knee replacement. J Med Econ. 2011;14(2):238-44. [pmid: 21385145].
Levine MN, Gent M, Hirsh J, et al. Ardeparin (low-molecular-weight heparin) vs graduated compression stockings for the prevention of venous thromboembolism. A randomized trial in patients undergoing knee surgery. Arch Intern Med. 1996;156(8):851-6. [pmid: 8774203].
Levine MN, Hirsh J, Gent M, et al. Prevention of deep vein thrombosis after elective hip surgery. A randomized trial comparing low molecular weight heparin with standard unfractionated heparin. Ann Intern Med. 1991;114(7):545-51. [pmid: 1848054].
Levine MN, Planes A, Hirsh J, Goodyear M, Vochelle N, Gent M. The relationship between anti-factor Xa level and clinical outcome in patients receiving enoxaparine low molecular weight heparin to prevent deep vein thrombosis after hip replacement. Thromb Haemost. 1989;62(3):940-4. [pmid: 2556813].
Leyvraz P, Bachmann F, Bohnet J, et al. Thromboembolic prophylaxis in total hip replacement: a comparison between the low molecular weight heparinoid Lomoparan and heparin-dihydroergotamine. Br J Surg. 1992;79(9):911-4. [pmid: 1422754].
Leyvraz P, Bachmann F, Vuilleumier B, Berthet S, Bohnet J, Haller E. Adjusted subcutaneous heparin versus heparin plus dihydroergotamine in prevention of deep vein thrombosis after total hip arthroplasty. J Arthroplasty. 1988;3(1):81-6. [pmid: 3361324].
Leyvraz PF, Bachmann F, Hoek J, et al. Prevention of deep vein thrombosis after hip replacement: randomised comparison between unfractionated heparin and low molecular weight heparin. BMJ. 1991;303(6802):543-8. [pmid: 1655136].
Leyvraz PF, Richard J, Bachmann F, et al. Adjusted versus fixed-dose subcutaneous heparin in the prevention of deep-vein thrombosis after total hip replacement. N Engl J Med. 1983;309(16):954-8. [pmid: 6621623].
Leyvraz PF, Richard J, Bachmann F, Melle GV, Candardjis G, et al. Adjusted versus fixed dose subcutaneous heparin in the prevention of deep vein thrombosis after total hip replacement: Adjusted versus fixed dose subcutaneous heparin in the prevention of deep vein thrombosis after total hip replacement. New England Journal of Medicine (USA). 1983;309:954-8.
Li XL, Lu WJ, Yu NS. Prophylaxis for deep vein thrombosis with low molecular weight heparin following hip and knee surgery. Zhongguo Xiu Fu Chong Jian Wai Ke Za Zhi. 2001;15(1):39-41. [pmid: 12563929].
Lieberman DV, Lieberman D. Proximal deep vein thrombosis after hip fracture surgery in elderly patients despite thromboprophylaxis. Am J Phys Med Rehabil. 2002;81(10):745-50. [pmid: 12362114].
Lieberman JR, Huo MM, Hanway J, Salvati EA, Sculco TP, Sharrock NE. A comparison of pneumatic compression boots and aspirin versus aspirin alone in prevention of deep venous thrombosis after total hip arthroplasty: A randomized prospective trial [Abstract]. Orthopaedic Transactions. 1992;16(3):712-3.
Lieberman JR, Sung R, Dorey F, Thomas BJ, Kilgus DJ, Finerman GA. Low-dose warfarin prophylaxis to prevent symptomatic pulmonary embolism after total knee arthroplasty. J Arthroplasty. 1997;12(2):180-4. [pmid: 9139100].
Lieberman JR, Wollaeger J, Dorey F, et al. The efficacy of prophylaxis with low-dose warfarin for prevention of pulmonary embolism following total hip arthroplasty. J Bone Joint Surg Am. 1997;79(3):319-25. [pmid: 9070518].
Liezorovicz A, Picolet H, Peyrieux JC, Boissel JP. Prevention of perioperative deep vein thrombosis in general surgery: a multicentre double blind study comparing two doses of Logiparin and standard heparin. H.B.P.M. Research Group. Br J Surg. 1991;78(4):412-6. [pmid: 1851649].
Lingaas US, Storen EJ, Myhre HO. The practive of prophylactic anticoagulation in surgical patients. J Oslo City Hosp. 1972;22(7):109-17. [pmid: 5045731].
Linsenmaier U, Rieger J, Schenk F, Rock C, Mangel E, Pfeifer KJ. Indications, management, and complications of temporary inferior vena cava filters. Cardiovasc Intervent Radiol. 1998;21(6):464-9. [pmid: 9853163].
Loew D, Brucke P, Simma W, Vinazzer H, Dienstl E, Boehme K. Acetylsalicylic acid, low dose heparin, and a combination of both substances in the prevention of postoperative thromboembolism. A double blind study. Thromb Res. 1977;11(1):81-6. [pmid: 329468].
Lombardi AV Jr, Berend KR, Tucker TL. The incidence and prevention of symptomatic thromboembolic disease following unicompartmental knee arthroplasty. Orthopedics. 2007;30(5 Suppl):46-8. [pmid: 17549868].
Looby S, Given MF, Geoghegan T, McErlean A, Lee MJ. Gunther Tulip retrievable inferior vena caval filters: indications, efficacy, retrieval, and complications. Cardiovasc Intervent Radiol. 2007;30(1):59-65. [pmid: 17122885].
Lotke PA, Lonner JH. The benefit of aspirin chemoprophylaxis for thromboembolism after total knee arthroplasty. Clin Orthop Relat Res. 2006;452:175-80. [pmid: 16957642].
Lotke PA, Palevsky H, Keenan AM, et al. Aspirin and warfarin for thromboembolic disease after total joint arthroplasty. Clin Orthop Relat Res. 1996;(324):251-8. [pmid: 8595765].
Low-molecular-weight heparin (enoxaparin) vs dextran 70. The prevention of postoperative deep vein thrombosis after total hip replacement. The Danish Enoxaparin Study Group. Arch Intern Med. 1991;151(8):1621-4. [pmid: 1714709].
Lyon SM, Riojas GE, Uberoi R, et al. Short- and long-term retrievability of the Celect vena cava filter: results from a multi-institutional registry. J Vasc Interv Radiol. 2009;20(11):1441-8. [pmid: 19875061].
Macdonald RL, Amidei C, Lin G, et al. Safety of perioperative subcutaneous heparin for prophylaxis of venous thromboembolism in patients undergoing craniotomy. Neurosurgery. 1999;45(2):245-52. [pmid: 10449068].
Magee CJ, Barry J, Javed S, MacAdam R, Kerrigan D. Extended thromboprophylaxis reduces incidence of postoperative venous thromboembolism in laparoscopic bariatric surgery. Surg. Obes. Relat. Dis. 2010;6(3):322-5. [pmid: 20510295].
Magnant JG, Walsh DB, Juravsky LI, Cronenwett JL. Current use of inferior vena cava filters. J Vasc Surg. 1992;16(5):701-6. [pmid: 1433657].
Mahe I, Drouet L, Chassany O, Grenard AS, Caulin C, Bergmann JF. Low molecular weight heparin for the prevention of deep venous thrombosis: a suitable monitoring in elderly patients?. Pathophysiol Haemost Thromb. 2002;32(3):134-6. [pmid: 12372928].
Mahe I, Gouin-Thibault I, Drouet L, et al. Elderly medical patients treated with prophylactic dosages of enoxaparin: influence of renal function on anti-Xa activity level. Drugs Aging. 2007;24(1):63-71. [pmid: 17233548].
Makela EA, Myllynen P, Rokkanen P. Prophylaxis of thromboembolism in orthopaedics and traumatology. Ann Chir Gynaecol. 1991;80(4):363-7. [pmid: 1726036].
Manganelli D, Pazzagli M, Mazzantini D, et al. Prolonged prophylaxis with unfractioned heparin is effective to reduce delayed deep vein thrombosis in total hip replacement. Respiration; International Review of Thoracic Diseases. 1998;65(5):369-74.
Mant MJ, Russell DB, Johnston DW, Donahue PA. Intraoperative heparin in addition to postoperative low-molecular-weight heparin for thromboprophylaxis in total knee replacement. J Bone Joint Surg Br. 2000;82(1):48-9. [pmid: 10697313].
Mantilla CB, Horlocker TT, Schroeder DR, Berry DJ, Brown DL. Risk factors for clinically relevant pulmonary embolism and deep venous thrombosis in patients undergoing primary hip or knee arthroplasty. Anesthesiology. 2003;99(3):552-60. discussion 5A. [pmid: 12960538].
Markel DC, Morris GD. Effect of external sequential compression devices on femoral venous blood flow. J South Orthop Assoc. 2002;11(1):2-9. quiz 10. [pmid: 12741580].
Marlovits S, Striessnig G, Schuster R, et al. Extended-duration thromboprophylaxis with enoxaparin after arthroscopic surgery of the anterior cruciate ligament: a prospective, randomized, placebo-controlled study. Arthroscopy. 2007;23(7):696-702. [pmid: 17637403].
Martin B, Martyak TE, Stoughton TL, Collazo WA, Pearl W. Experience with the Gianturco-Roehm Bird's Nest vena cava filter. Am J Cardiol. 1990;66(17):1275-7. [pmid: 2239739].
Martyn DT, Janes JM. Continuous intravenous administration of heparin. Mayo Clin Proc. 1971;46(5):347-51. [pmid: 5578647].
Masri BA, Dunlop DJ, McEwen JA, Garbuz DS, Duncan CP. Can a new design of pneumatic compression device reduce variations in delivered therapy for the mechanical prophylaxis of thromboembolic disease after total hip arthroplasty?. Can J Surg. 2004;47(4):263-9. [pmid: 15362328].
Matzsch T, Bergqvist D, Fredin H, Hedner U. Safety and efficacy of a low molecular weight heparin (Logiparin) versus dextran as prophylaxis against thrombosis after total hip replacement. Acta Chir Scand Suppl. 1988;543:80-4. [pmid: 2461017].
May L, Hardwick M, Morris B. Deep vein thrombosis. Extended prophylaxis with enoxaparin following total hip replacement surgery. Journal of Care Management. 1998;4(5):8.
Maynard GA, Morris TA, Jenkins IH, et al. Optimizing prevention of hospital-acquired venous thromboembolism (VTE): prospective validation of a VTE risk assessment model. J Hosp Med. 2010;5(1):10-8. [pmid: 19753640].
Mayr AJ, Dunser M, Jochberger S, et al. Antifactor Xa activity in intensive care patients receiving thromboembolic prophylaxis with standard doses of enoxaparin. Thromb. Res. 2002;105(3):201-4. [pmid: 11927124].
McCowan TC, Ferris EJ, Carver DK, Baker ML. Amplatz vena caval filter: clinical experience in 30 patients. AJR Am J Roentgenol. 1990;155(1):177-81. [pmid: 2112841].
McGarry L, Thompson D. Retrospective database analysis of the prevention of venous thromboembolism with low-molecular-weight heparin in acutely ill medical inpatients in community practice: Retrospective database analysis of the prevention of venous thromboembolism with low-molecular-weight heparin in acutely ill medical inpatients in community practice. Clinical Therapeutics (USA). 2004;26:419-30.
McGarry LJ, Stokes ME, Thompson D. Outcomes of thromboprophylaxis with enoxaparin vs. unfractionated heparin in medical inpatients. Thromb J. 2006;4:17. [pmid: 17005045].
McGarry LJ, Thompson D. Retrospective database analysis of the prevention of venous thromboembolism with low-molecular-weight heparin in acutely III medical inpatients in community practice. Clin Ther. 2004;26(3):419-30. [pmid: 15110135].
McKenna R, Galante J, Bachmann F, Wallace DL, Kaushal PS, Meredith P. Prevention of venous thromboembolism after total knee replacement by high-dose aspirin or intermittent calf and thigh compression. Br Med J. 1980;280(6213):514-7. [pmid: 6989432].
Mehta KV, Lee HC, Loh JS. Mechanical thromboprophylaxis for patients undergoing hip fracture surgery. J Orthop Surg (Hong Kong). 2010;18(3):287-9. [pmid: 21187537].
Merli GJ, Doyle L, Crabbe S, Sciarra A, Herbison G, Ditunno J. [550] Prophylaxis for deep vein thrombosis in acute spinal cord injury comparing two doses of low molecular weight heparinoid in combination with external pneumatic compression. J. REHABIL. RES. DEV. 1991;28(1):434-5.
Michot M, Conen D, Holtz D, et al. Prevention of deep-vein thrombosis in ambulatory arthroscopic knee surgery: A randomized trial of prophylaxis with low--molecular weight heparin. Arthroscopy. 2002;18(3):257-63. [pmid: 11877611].
Mika P, Behounek J, Skotak M, Nevsimal L. Complications and risks associated with an anticoagulation therapy combining low molecular weight heparin and Warfarin after total replacement of large joints--our experience. Acta Chir Orthop Traumatol Cech. 2004;71(4):237-44. [pmid: 15456102].
Milbrink J, Bergqvist D. The incidence of symptomatic venous thromboembolic events in orthopaedic surgery when using routine thromboprophylaxis. Vasa. 2008;37(4):353-7. [pmid: 19003746].
Milch E, Berman L, Egan R. Use of bishydroxycoumarin (dicumarol) for prevention of postoperative thromboembolism; a study of twenty-seven hundred consecutive surgical patients. AMA Arch Surg. 1953;67(2):142-52. [pmid: 13064956].
Millward SF, Oliva VL, Bell SD, et al. Gunther Tulip Retrievable Vena Cava Filter: results from the Registry of the Canadian Interventional Radiology Association. J Vasc Interv Radiol. 2001;12(9):1053-8. [pmid: 11535767].
Milone F, Iaccarino V, Musella M, et al. Interruption of the inferior vena cava in the prevention of pulmonary embolism. Chir Ital. 2005;57(4):479-84. [pmid: 16060186].
Misra M, Roitberg B, Ebersole K, Charbel FT. Prevention of pulmonary embolism by combined modalities of thromboprophylaxis and intensive surveillance protocol. Neurosurgery. 2004;54(5):1099-102. discussion 1102-3. [pmid: 15113463].
Mission JF, Kerlan RK Jr, Tan JH, Fang MC. Rates and predictors of plans for inferior vena cava filter retrieval in hospitalized patients. J Gen Intern Med. 2010;25(4):321-5. [pmid: 20087675].
Mohan CR, Hoballah JJ, Sharp WJ, Kresowik TF, Lu CT, Corson JD. Comparative efficacy and complications of vena caval filters. J Vasc Surg. 1995;21(2):235-45. discussion 245-6. [pmid: 7853597].
Mommertz G, Sigala F, Glowka TR, et al. Differences of venous thromboembolic risks in vascular general and trauma surgery patients. J Cardiovasc Surg (Torino). 2007;48(6):727-33.
Monreal M, Lafoz E, Roca J, et al. Platelet count, antiplatelet therapy and pulmonary embolism--a prospective study in patients with hip surgery. Thromb Haemost. 1995;73(3):380-5. [pmid: 7667819].
Monreal M, Lafoz E, Salvador R, Roncales J, Navarro A. Adverse effects of three different forms of heparin therapy: thrombocytopenia, increased transaminases, and hyperkalaemia. Eur J Clin Pharmacol. 1989;37(4):415-8. [pmid: 2557219].
Morris GK, Henry AP, Preston BJ. Prevention of deep-vein thrombosis by low-dose heparin in patients undergoing total hip replacement. Lancet. 1974;2(7884):797-800. [pmid: 4138248].
Morris GK, Mitchell JR. Preventing venous thromboembolism in elderly patients with hip fractures: studies of low-dose heparin, dipyridamole, aspirin, and flurbiprofen. Br Med J. 1977;1(6060):535-7. [pmid: 843794].
Morris WT, Hardy AE. The effect of dihydroergotamine and heparin on the incidence of thromboembolic complications following total hip replacement: a randomized controlled clinical trial. Br J Surg. 1981;68(5):301-3. [pmid: 7013894].
Mosca S, Maselli A, Pozzilli P, et al. Comparison of Gunther, Filcard and LGM definitive caval filters. Our experience. Radiol Med. 1993;85(3):224-34. [pmid: 8493371].
Moser G, Krahenbuhl B, Barroussel R, Bene JJ, Donath A, Rohner A. Mechanical versus pharmacologic prevention of deep venous thrombosis. Surg Gynecol Obstet. 1981;152(4):448-50. [pmid: 7209773].
Motokawa S, Torigoshi T, Maeda Y, et al. IgG-class anti-PF4/heparin antibodies and symptomatic DVT in orthopedic surgery patients receiving different anti-thromboembolic prophylaxis therapeutics. BMC Musculoskelet Disord. 2011;12:22. [pmid: 21261941].
Mouret P. The oral direct thrombin inhibitor Ximelagatran Prophylaxis of venous thromboembolism in hip and knee replacement. Hamostaseologie. 2002;22(3):21-4. [pmid: 12215757].
Mueck W, Eriksson BI, Bauer KA, et al. Population pharmacokinetics and pharmacodynamics of rivaroxaban--an oral, direct factor Xa inhibitor--in patients undergoing major orthopaedic surgery. Clin Pharmacokinet. 2008;47(3):203-16. [pmid: 18307374].
Muhe E. Intermittent sequential high-pressure compression of the leg. A new method of preventing deep vein thrombosis. Am J Surg. 1984;147(6):781-5. [pmid: 6731693].
Muntz JE, O'Connor PJ, Yin H, Vogenberg FR. Factors associated with thromboprophylaxis for orthopedic patients and their impact on outcome. Am J Orthop (Belle Mead NJ). 2007;36(4):193-7. [pmid: 17515185].
Nassif JM, Ritter MA, Meding JB, Keating EM, Faris PM. The effect of intraoperative intravenous fixed-dose heparin during total joint arthroplasty on the incidence of fatal pulmonary emboli. J Arthroplasty. 2000;15(1):16-21. [pmid: 10654457].
Nathens AB, McMurray MK, Cuschieri J, et al. The practice of venous thromboembolism prophylaxis in the major trauma patient. J Trauma. 2007;62(3):557-62. discussion 562-3. [pmid: 17414328].
Navarro-Quilis A, Castellet E, Rocha E, Paz-Jimenez J, Planes A. Efficacy and safety of bemiparin compared with enoxaparin in the prevention of venous thromboembolism after total knee arthroplasty: a randomized, double-blind clinical trial. J Thromb Haemost. 2003;1(3):425-32. [pmid: 12871445].
Nazzal M, Chan E, Nazzal M, et al. Complications related to inferior vena cava filters: a single-center experience. Ann Vasc Surg. 2010;24(4):480-6. [pmid: 19900783].
Negus D, Friedgood A, Cox SJ, Peel AL, Wells BW. Ultra-low dose intravenous heparin in the prevention of postoperative deep-vein thrombosis. Lancet. 1980;1(8174):891-4. [pmid: 6103255].
Neu Lt Jr, Waterfield Jr, Ash Cj. Prophylactic Anticoagulant Therapy In The Orthopedic Patient. Ann Intern Med. 1965;62:463-7. [pmid: 14263094].
Northup PG, McMahon MM, Ruhl AP, et al. Coagulopathy does not fully protect hospitalized cirrhosis patients from peripheral venous thromboembolism. 2006;101(7):1524-8.
Novicoff WM, Brown TE, Cui Q, Mihalko WM, Slone HS, Saleh KJ. Mandated venous thromboembolism prophylaxis: possible adverse outcomes. J Arthroplasty. 2008;23(6 Suppl 1):15-9. [pmid: 18555656].
Nutescu EA, Shorr AF, Farrelly E, Horblyuk R, Happe LE, Franklin M. Burden of deep vein thrombosis in the outpatient setting following major orthopedic surgery. Ann Pharmacother. 2008;42(9):1216-21. [pmid: 18611992].
O'Brien CM, Eltigani T. Common peroneal nerve palsy as a possible sequelae of poorly fitting below-knee thromboembolic deterrent stockings (TEDS). Ann Plast Surg. 2006;57(3):356-7. [pmid: 16929214].
Oertli D, Hess P, Durig M, et al. Prevention of deep vein thrombosis in patients with hip fractures: low molecular weight heparin versus dextran. World J Surg. 1992;16(5):980-4. discussion 984-5. [pmid: 1281362].
Ohlund C, Fransson SG, Starck SA. Calf compression for prevention of thromboembolism following hip surgery. Acta Orthop Scand. 1983;54(6):896-9. [pmid: 6367345].
Onat L, Ganiyusufoglu AK, Mutlu A, et al. OptEase and TrapEase vena cava filters: a single-center experience in 258 patients. Cardiovasc Intervent Radiol. 2009;32(5):992-7. [pmid: 19449061].
O'Reilly RF, Burgess IA, Zicat B. The prevalence of venous thromboembolism after hip and knee replacement surgery. Med J Aust. 2005;182(4):154-9. [pmid: 15720169].
Orken DN, Kenangil G, Ozkurt H, et al. Prevention of deep venous thrombosis and pulmonary embolism in patients with acute intracerebral hemorrhage. Neurologist. 2009;15(6):329-31. [pmid: 19901711].
Otchy DP, Elliott BM. The malpositioned Greenfield filter: lessons learned. Am Surg. 1987;53(10):580-3. [pmid: 3674601].
Otero-Fernandez R, Gomez-Outes A, Martinez-Gonzalez J, Rocha E, Fontcuberta J. Evaluation of the effectiveness and safety of bemiparin in a large population of orthopedic patients in a normal clinical practice. Clin Appl Thromb Hemost. 2008;14(1):75-83. [pmid: 17895506].
Ozturk C, Ganiyusufoglu K, Alanay A, Aydogan M, Onat L, Hamzaoglu A. Efficacy of prophylactic placement of inferior vena cava filter in patients undergoing spinal surgery. Spine (Phila Pa 1976). 2010;35(20):1893-6. [pmid: 20802386].
Paiement G, Wessinger SJ, Waltman AC, Harris WH. Low-dose warfarin versus external pneumatic compression for prophylaxis against venous thromboembolism following total hip replacement. J Arthroplasty. 1987;2(1):23-6. [pmid: 3572408].
Paiement GD, Schutzer SF, Wessinger SJ, Harris WH. Influence of prophylaxis on proximal venous thrombus formation after total hip arthroplasty. J Arthroplasty. 1992;7(4):471-5. [pmid: 1282537].
Paiement GD, Wessinger SJ, Hughes R, Harris WH. Routine use of adjusted low-dose warfarin to prevent venous thromboembolism after total hip replacement. J Bone Joint Surg Am. 1993;75(6):893-8. [pmid: 8314829].
Pais SO, Mirvis SE, De Orchis DF. Percutaneous insertion of the Kimray-Greenfield filter: technical considerations and problems. Radiology. 1987;165(2):377-81. [pmid: 3659360].
Pais SO, Tobin KD, Austin CB, Queral L. Percutaneous insertion of the Greenfield inferior vena cava filter: experience with ninety-six patients. J Vasc Surg. 1988;8(4):460-4. [pmid: 3172383].
Pana C, Naftali Z, Gyongyosi M, et al. Prevention of postsurgical thromboembolism with small doses of heparin. Rev Chir Oncol Radiol O R L Oftalmol Stomatol Chir. 1978;27(6):421-6. [pmid: 752839].
Parry M, Wylde V, Blom AW. Ninety-day mortality after elective total hip replacement: 1549 patients using aspirin as a thromboprophylactic agent. J Bone Joint Surg Br. 2008;90(3):306-7. [pmid: 18310750].
Passos R, Conceicnullao LF, Valente L, et al. Antithrombotic prophylaxis in critically ill patients with renal failure. Intensive Care Med. 2009;35:S153.
Patel GK, Knight AG. Generalised cutaneous necrosis: a complication of low-molecular-weight heparin. Int Wound J. 2005;2(3):267-70. [pmid: 16618332].
Pearse EO, Caldwell BF, Lockwood RJ, Hollard J. Early mobilisation after conventional knee replacement may reduce the risk of postoperative venous thromboembolism. J Bone Joint Surg Br. 2007;89(3):316-22. [pmid: 17356141].
Pedegana LR, Burgess EM, Moore AJ, Carpenter ML. Prevention of thromboembolic disease by external pneumatic compression in patients undergoing total hip arthroplasty. Clin Orthop Relat Res. 1977;(128):190-3. [pmid: 598154].
Pellegrini VD Jr, Donaldson CT, Farber DC, Lehman EB, Evarts CM. The John Charnley Award: prevention of readmission for venous thromboembolic disease after total hip arthroplasty. Clin Orthop Relat Res. 2005;441:56-62. [pmid: 16330984].
Pellerin O, Barral FG, Lions C, Novelli L, Beregi JP, Sapoval M. Early and late retrieval of the ALN removable vena cava filter: results from a multicenter study. Cardiovasc Intervent Radiol. 2008;31(5):889-96. [pmid: 18493821].
Peters G, Whipple J, Eriksson U. Pharmacokinetics of H 376/95 (H): A novel oral direct thrombin inhibitor in patients undergoing total knee arthoplasty (TKA). 2001;69(2).
Pezzuoli G, Neri Serneri GG, Settembrini PG, et al. The use of low-molecular-weight heparin CY 216 in the prevention of fatal pulmonary embolism and thromboembolic death in general surgey. A multicentre, double-blind, randomized, controlled clinical trial versus placebo (STEP). Fraxiparine Second International Symposium Recent Pharmacological and Clinical Data. 1990:13-22.
Piazza G, Rosenbaum EJ, Pendergast W, et al. Physician alerts to prevent symptomatic venous thromboembolism in hospitalized patients. Circulation. 2009;119(16):2196-201. [pmid: 19364975].
Piazza G, Seddighzadeh A, Goldhaber SZ. Double trouble for 2,609 hospitalized medical patients who developed deep vein thrombosis: prophylaxis omitted more often and pulmonary embolism more frequent. Chest. 2007;132(2):554-61. [pmid: 17573518].
Pidala MJ, Donovan DL, Kepley RF. A prospective study on intermittent pneumatic compression in the prevention of deep vein thrombosis in patients undergoing total hip or total knee replacement. Surg Gynecol Obstet. 1992;175(1):47-51. [pmid: 1621199].
Pieri S, Agresti P, Morucci M, de' Medici L. Optional vena cava filters: preliminary experience with a new vena cava filter. Radiol Med. 2003;105(1-2):56-62. [pmid: 12700546].
Pierron RL. Prophylaxis of deep-vein thrombosis after total hip replacement. Dextran and external pneumatic compression compared with 1.2 or 0.3 grams of aspirin daily. J Bone Joint Surg Am. 1985;67(6):983. [pmid: 2410426].
Pietsch M, Kuhle J, Hamer H, Pitto RP. Mechanical versus drug prevention of thrombosis after total hip endoprosthesis implantation. A randomized, controlled clinical study. Biomed Tech (Berl). 2003;48(7-8):207-12. [pmid: 12910861].
Pingleton SK, Bone RC, Pingleton WW, Ruth WE. Prevention of pulmonary emboli in a respiratory intensive care unit: efficacy of low-dose heparin. Chest. 1981;79(6):647-50. [pmid: 6971738].
Pini M, Tagliaferri A, Manotti C, Lasagni F, Rinaldi E, Dettori AG. Low molecular weight heparin (Alfa LHWH) compared with unfractionated heparin in prevention of deep-vein thrombosis after hip fractures. Int Angiol. 1989;8(3):134-9. [pmid: 2556484].
Pinto DJ. Controlled trial of an anticoagulant (warfarin sodium) in the prevention of venous thrombosis following hip surgery. Br J Surg. 1970;57(5):349-52. [pmid: 5427880].
Pirone F, Tartaglione G, Melaragno E. Heparin prophylaxis of deep venous thrombosis and pulmonary embolism in medical patients. Clin Ter. 1988;126(4):267-71. [pmid: 2974396].
Pitto RP, Hamer H, Heiss-Dunlop W, Kuehle J. Mechanical prophylaxis of deep-vein thrombosis after total hip replacement a randomised clinical trial. J Bone Joint Surg Br. 2004;86(5):639-42. [pmid: 15274256].
Pitto RP, Young S. Foot pumps without graduated compression stockings for prevention of deep-vein thrombosis in total joint replacement: efficacy, safety and patient compliance. A comparative, prospective clinical trial. Int Orthop. 2008;32(3):331-6. [pmid: 17653546].
Planes A, Vochelle N, Fagola M, et al. Once-daily dosing of enoxaparin (a low molecular weight heparin) in prevention of deep vein thrombosis after total hip replacement. Acta Chir Scand Suppl. 1990;556:108-15. [pmid: 1963015].
Planes A, Vochelle N, Fagola M, Bellaud M. Comparison of two low-molecular-weight heparins for the prevention of postoperative venous thromboembolism after elective hip surgery. Reviparin Study Group. Blood Coagul Fibrinolysis. 1998;9(6):499-505. [pmid: 9819000].
Planes A, Vochelle N, Ferru J, et al. Enoxaparine low molecular weight heparin: its use in the prevention of deep venous thrombosis following total hip replacement. Haemostasis. 1986;16(2):152-8. [pmid: 3710293].
Planes A, Vochelle N, Mazas F, et al. Enoxaparin versus standard heparin in the prophylaxis of deep vein thrombosis after total hip replacement: A double-blind randomized trial. REV. MED. INTERNE. 1988;9(3):327-33. [pmid: 2841742].
Planes A. Comparison of antithrombotic efficacy and haemorrhagic side-effects of Clivarin versus enoxaparin in patients undergoing total hip replacement surgery. Blood Coagul Fibrinolysis. Suppl 1. 1993;4:S33-5. discussion S37-8. [pmid: 8180327].
Platz A, Hoffmann R, Kohler A, Bischof T, Trentz O. Prevention of thromboembolism in hip fracture: unfractionated heparin versus low molecular weight heparin ( a prospective, randomized study). Z Unfallchir Versicherungsmed. 1993;86(3):184-8. [pmid: 8130009].
Poletti PA, Becker CD, Prina L, et al. Long-term results of the Simon nitinol inferior vena cava filter. Eur Radiol. 1998;8(2):289-94. [pmid: 9477285].
Poli D, Antonucci E, Lombardi A, et al. Low rate of bleeding and thrombotic complications of oral anticoagulant therapy independent of age in the real-practice of an anticoagulation clinic. Blood Coagul Fibrinolysis. 2003;14(3):269-75. [pmid: 12695750].
Polto F, Musumeci S, Vadala G, Morici V, Rizza G. Graduated and constant compression of the lower extremities in the prevention of postoperative deep venous thrombosis and of pulmonary thromboembolism. Clinical trial. Chir Ital. 1979;31(5):996-1007. [pmid: 396049].
Potron G, Barre J, Droulle C, Baudrillard JC, Barbier P, Kher A. Thrombosis prophylaxis with low molecular weight heparin (Kabi 2165) and calcium heparin in patients with total hip replacement. Thrombosis and Haemostasis. 1987;58(1):118. Abstract no:. 421.
Powers PJ, Gent M, Jay RM, Julian DH, Hirsh J, et al. Randomized trial of less intense postoperative warfarin or aspirin therapy in the prevention of venous thromboembolism after surgery for fractured hip: Randomized trial of less intense postoperative warfarin or aspirin therapy in the prevention of venous thromboembolism after surgery for fractured hip. Archives of Internal Medicine (USA). 1989;149:771-4.
Prandoni P, Bruchi O, Sabbion P, et al. Prolonged thromboprophylaxis with oral anticoagulants after total hip arthroplasty: a prospective controlled randomized study. Arch Intern Med. 2002;162(17):1966-71. [pmid: 12230419].
Prandoni P, Siragusa S, Girolami B, Fabris F. The incidence of heparin-induced thrombocytopenia in medical patients treated with low-molecular-weight heparin: a prospective cohort study. Blood. 2005;106(9):3049-54. [pmid: 16030191].
Prejbeanu R, Vermesan H, Dragulescu SI, et al. Thromboembolic risk after knee endoprosthesis. Eur Rev Med Pharmacol Sci. 2007;11(5):297-300. [pmid: 18074938].
Prevention of deep vein thrombosis with low molecular-weight heparin in patients undergoing total hip replacement. A randomized trial. The German Hip Arthroplasty Trial (GHAT) Group. Arch Orthop Trauma Surg. 1992;111(2):110-20. [pmid: 1314065].
Prevention of fatal postoperative pulmonary embolism by low doses of heparin. An international multicentre trial. Lancet. 1975;2(7924):45-51. [pmid: 49649].
Prevention of pulmonary embolism and deep vein thrombosis with low dose aspirin: Pulmonary Embolism Prevention (PEP) trial. Lancet. 2000;355(9212):1295-302. [pmid: 10776741].
Prevention of pulmonary embolism and deep vein thrombosis with low dose aspirin: Pulmonary Embolism Prevention (PEP) trial: Prevention of pulmonary embolism and deep vein thrombosis with low dose aspirin: Pulmonary Embolism Prevention (PEP) trial. Lancet (England). 2000;355:1295-302.
Prevention of venous thrombosis after total hip replacement. N Engl J Med. 1984;310(14):927-8. [pmid: 6700686].
Proctor MC, Greenfield LJ, Wakefield TW, Zajkowski PJ. A clinical comparison of pneumatic compression devices: the basis for selection. J Vasc Surg. 2001;34(3):459-63. discussion 463-4. [pmid: 11533598].
Rabbat CG, Cook DJ, Crowther MA, et al. Dalteparin thromboprophylaxis for critically ill medical-surgical patients with renal insufficiency. J Crit Care. 2005;20(4):357-63. [pmid: 16310608].
Rader CP, Kramer C, Konig A, Hendrich C, Eulert J. Low-molecular-weight heparin and partial thromboplastin time-adjusted unfractionated heparin in thromboprophylaxis after total knee and total hip arthroplasty. J Arthroplasty. 1998;13(2):180-5. [pmid: 9526211].
Radmilovic A, Boric Z, Naumovic T, Stamenkovic M, Musikic P. Shunt thrombosis prevention in hemodialysis patients--a double-blind, randomized study: pentoxifylline vs placebo. Angiology. 1987;38(7):499-506. [pmid: 3304027].
Ragucci MV, Leali A, Moroz A, Fetto J. Comprehensive deep venous thrombosis prevention strategy after total-knee arthroplasty. Am J Phys Med Rehabil. 2003;82(3):164-8. [pmid: 12595766].
Raskob G, Cohen AT, Eriksson BI, et al. Oral direct factor Xa inhibition with edoxaban for thromboprophylaxis after elective total hip replacement. A randomised double-blind dose-response study. Thromb Haemost. 2010;104(3):642-9. [pmid: 20589317].
Ray CE Jr, Mitchell E, Zipser S, Kao EY, Brown CF, Moneta GL. Outcomes with retrievable inferior vena cava filters: a multicenter study. J Vasc Interv Radiol. 2006;17(10):1595-604. [pmid: 17057000].
RD heparin compared with warfarin for prevention of venous thromboembolic disease following total hip or knee arthroplasty. RD Heparin Arthroplasty Group. J Bone Joint Surg Am. 1994;76(8):1174-85. [pmid: 8056798].
Reitman RD, Emerson RH, Higgins LL, Tarbox TR. A multimodality regimen for deep venous thrombosis prophylaxis in total knee arthroplasty. J Arthroplasty. 2003;18(2):161-8. [pmid: 12629605].
Rem JA, Gratzl O, Follath F, Pult I. Ergotism as complication of thromboembolic prophylaxis with heparin-dihydroergotamine. Lancet. 1987;1(8526):219. [pmid: 2880045].
RE-MOBILIZE Writing Committee, Ginsberg JS, Davidson BL, et al. Oral thrombin inhibitor dabigatran etexilate vs North American enoxaparin regimen for prevention of venous thromboembolism after knee arthroplasty surgery. The Journal of Arthroplasty. 2009;24(1):1-9. [pmid: 18534438].
Renney JT, O'Sullivan EF. Dipyridamole (“Persantin”) and aspirin and the prevention of post-operative deep-vein thrombosis. Thromb Diath Haemorrh Suppl. 1973;55:267-71. [pmid: 4804075].
Riess H, Haas S, Tebbe U, et al. A randomized, double-blind study of certoparin vs. unfractionated heparin to prevent venous thromboembolic events in acutely ill, non-surgical patients: CERTIFY Study. J Thromb Haemost. 2010;8(6):1209-15. [pmid: 20218984].
Riess H, Haas S, Tebbe U, et al. CERTIFY - Certoparin versus UFH to prevent venous thromboembolic events in acutely ill, hospitalized, medical patients: A randomized, double-blind, multicentre study. Onkologie. 2010;33(6):51-2.
Roberts VC, Cotton LT. Failure of low-dose heparin to improve efficacy of peroperative intermittent calf compression in preventing postoperative deep vein thrombosis. Br Med J. 1975;3(5981):458-60. [pmid: 1098726].
Robertson KA, Bertot AJ, Wolfe MW, Barrack RL. Patient compliance and satisfaction with mechanical devices for preventing deep venous thrombosis after joint replacement. J South Orthop Assoc. 2000;9(3):182-6. [pmid: 12135300].
Robinson S, Zincuk A, Strom T, Larsen TB, Rasmussen B, Toft P. Enoxaparin, effective dosage for intensive care patients: double-blinded, randomised clinical trial. Crit Care. 2010;14(2):R41. [pmid: 20298591].
Robinson S, Zincuk A, Toft P. Enoxaparin: Effective dosage for ICU patients. Acta Anaesthesiol. Scand. Suppl. 2009;53(119):72-3.
Rocha ATC, Braga P, Ritt G, Lopes AA. Inadequacy of thromboprophylaxis in hospitalized medical patients: Inadequacao de tromboprofilaxia venosa em pacientes clinicos hospitalizados. Rev. Assoc. Med. Bras. 2006;52(6):441-6. [pmid: 17242783].
Rocha E, Alfaro MJ, Paramo JA, Canadell JM. Preoperative identification of patients at high risk of deep venous thrombosis despite prophylaxis in total hip replacement. Thromb Haemost. 1988;59(1):93-5. [pmid: 3363536].
Rocko JM, Mikhail F, Trilles F, Timmes JJ. The safety of low dose heparin prophylaxis. Am J Surg. 1978;135(6):798-800. [pmid: 665904].
Rodriguez Jornet A, Monasterio Aspiri J, Millan B, et al. Low molecular weight heparin in hemodialysis patients with chronic renal failure: Utilizacion De Heparina Fraccionada En Insuficiencia Renal Cronica En Hemodialisis Periodica. 1993;13(4):336-46.
Rohrer MJ, Scheidler MG, Wheeler HB, Cutler BS. Extended indications for placement of an inferior vena cava filter. J Vasc Surg. 1989;10(1):44-9. discussion 49-50. [pmid: 2501522].
Rommers MK, Van der Lely N, Egberts TC, van den Bemt PM. Anti-Xa activity after subcutaneous administration of dalteparin in ICU patients with and without subcutaneous oedema: a pilot study. Crit Care. 2006;10(3):R93. [pmid: 16790078].
Rose BS, Simon DC, Hess ML, Van Aman ME. Percutaneous transfemoral placement of the Kimray-Greenfield vena cava filter. Radiology. 1987;165(2):373-6. [pmid: 3659359].
Rosengarten DS, Laird J, Jeyasingh K, Martin P. The failure of compression stockings (Tubigrip) to prevent deep venous thrombosis after operation. Br J Surg. 1970;57(4):296-9. [pmid: 5437927].
Rosenthal D, Swischuk JL, Cohen SA, Wellons ED. OptEase retrievable inferior vena cava filter: initial multicenter experience. Vascular. 2005;13(5):286-9. [pmid: 16288703].
Rutherford EJ, Schooler WG, Sredzienski E, Abrams JE, Skeete DA. Optimal dose of enoxaparin in critically ill trauma and surgical patients. J Trauma. 2005;58(6):1167-70. [pmid: 15995464].
Ryan MG, Westrich GH, Potter HG, et al. Effect of mechanical compression on the prevalence of proximal deep venous thrombosis as assessed by magnetic resonance venography. J Bone Joint Surg Am. 2002;84-A(11):1998-2004. [pmid: 12429761].
Rybachuk OI, Besiedyns'kyi SM, Huliaiev DV. The prevention of postoperative deep venous thrombosis in orthopedic surgery. Lik Sprava. 1999;(6):95-9. [pmid: 10626456].
Sachs RA, Smith JH, Kuney M, Paxton L. Does anticoagulation do more harm than good?: A comparison of patients treated without prophylaxis and patients treated with low-dose warfarin after total knee arthroplasty. J Arthroplasty. 2003;18(4):389-95. [pmid: 12820078].
Saeed I, Garcia M, McNicholas K. Right ventricular migration of a recovery IVC filter's fractured wire with subsequent pericardial tamponade. Cardiovasc Intervent Radiol. 2006;29(4):685-6. [pmid: 16604409].
Sag AA, Stavas JM, Burke CT, Dixon RG, Marquess JS, Mauro MA. Analysis of tilt of the Gunther Tulip filter. J Vasc Interv Radiol. 2008;19(5):669-76. [pmid: 18440454].
Sagar S, Nairn D, Stamatakis JD, et al. Efficacy of low-dose heparin in prevention of extensive deep-vein thrombosis in patients undergoing total-hip replacement. Lancet. 1976;1(7970):1151-4. [pmid: 58199].
Salcuni P, Azzarone M. The use of LMW heparin in the prevention of thromboembolic disease in surgical patients: a controlled comparison with nonfractionated heparin. Boll Chim Farm. 1987;126(12):2S-7S. [pmid: 2843203].
Salvati EA, Lachiewicz P. Thromboembolism following total hip-replacement arthroplasty. The efficicy of dextran-aspirin and dextran-warfarin in prophylaxis. J Bone Joint Surg Am. 1976;58(7):921-5. [pmid: 977621].
Salzman EW, Harris WH, DeSanctis RW. Anticoagulation for prevention of thromboembolism following fractures of the hip. N Engl J Med. 1966;275(3):122-30. [pmid: 5938857].
Salzman EW, McManama GP, Shapiro AH, et al. Effect of optimization of hemodynamics on fibrinolytic activity and antithrombotic efficacy of external pneumatic calf compression. Ann Surg. 1987;206(5):636-41. [pmid: 3314750].
Samama CM, Vray M, Barre J, et al. Extended venous thromboembolism prophylaxis after total hip replacement: a comparison of low-molecular-weight heparin with oral anticoagulant. Arch Intern Med. 2002;162(19):2191-6. [pmid: 12390061].
Samama CM, Vray M, Barré J, et al. Extended venous thromboembolism prophylaxis after total hip replacement: a comparison of low-molecular-weight heparin with oral anticoagulant. Archives of Internal Medicine. 2002;162(19):2191-6. [pmid: 12390061].
Samama M, Bernard P, Bonnardot JP, Combe-Tamzali S, Lanson Y, Tissot E. Low molecular weight heparin compared with unfractionated heparin in prevention of postoperative thrombosis. Br J Surg. 1988;75(2):128-31. [pmid: 2832030].
Samama MM, Cohen AT, Darmon JY, et al. A comparison of enoxaparin with placebo for the prevention of venous thromboembolism in acutely ill medical patients. Prophylaxis in Medical Patients with Enoxaparin Study Group. N Engl J Med. 1999;341(11):793-800. [pmid: 10477777].
Santori FS, Vitullo A, Stopponi M, Santori N, Ghera S. Prophylaxis against deep-vein thrombosis in total hip replacement. Comparison of heparin and foot impulse pump. J Bone Joint Surg Br. 1994;76(4):579-83. [pmid: 8027144].
Sarani B, Chun A, Venbrux A. Role of optional (retrievable) IVC filters in surgical patients at risk for venous thromboembolic disease. J Am Coll Surg. 2005;201(6):957-64. [pmid: 16310701].
Sarmiento A, Goswami A. Thromboembolic disease prophylaxis in total hip arthroplasty. Clin Orthop Relat Res. 2005;(436):138-43. [pmid: 15995432].
Sarmiento A, Goswami AD. Thromboembolic prophylaxis with use of aspirin, exercise, and graded elastic stockings or intermittent compression devices in patients managed with total hip arthroplasty. J Bone Joint Surg Am. 1999;81(3):339-46. [pmid: 10199271].
Sasaki S, Miyakoshi N, Matsuura H, et al. Prospective study on the efficacies of fondaparinux and enoxaparin in preventing venous thromboembolism after hip fracture surgery. J Orthop Sci. 2011;16(1):64-70. [pmid: 21293896].
Sato H, Izuta S, Misumi T, et al. Incidence and clinical characteristics of perioperative pulmonary thromboembolism under the use of intermittent pneumatic compression as a preventive measure. Masui. 2003;52(12):1300-4. [pmid: 14733080].
Schellong S, Hesselschwerdt HJ, Paar WD, von Hanstein KL. Rates of proximal deep vein thrombosis as assessed by compression ultrasonography in patients receiving prolonged thromboprophylaxis with low molecular weight heparin after major orthopedic surgery. Thromb Haemost. 2005;94(3):532-6. [pmid: 16268468].
Schellong SM, Gerlach HE, Tebbe U, et al. Certoparin versus UFH to prevent venous thromboembolic events in the very elderly patient: An analysis of the CERTIFY study. Thromb Res. 2011.
Schellong SM, Haas S, Greinacher A, et al. An open-label comparison of the efficacy and safety of certoparin versus unfractionated heparin for the prevention of thromboembolic complications in acutely ill medical patients: CERTAIN. Expert Opin Pharmacother. 2010;11(18):2953-61. [pmid: 20950224].
Schellong SM, Hull RD, Tapson VF, et al. Extended-Duration Enoxaparin for Venous Thromboembolism Prophylaxis in Acutely Ill Medical Patients: An Evaluation of the EXCLAIM Study Based on a Recently Recommended Composite Efficacy Endpoint [abstract]. Blood. 2007;110(11):554a.
Schiff RL, Kahn SR, Shrier I, et al. Identifying orthopedic patients at high risk for venous thromboembolism despite thromboprophylaxis. Chest. 2005;128(5):3364-71. [pmid: 16304285].
Schleich JM, Morla O, Laurent M, Langella B, Chaperon J, Almange C. Long-term follow-up percutaneous vena cava filters: A prospective study in 100 consecutive patients. 2001;21:450-7.
Schmelzer TM, Christmas AB, Taylor DA, Heniford BT, Sing RF. Vena cava filter retrieval in therapeutically anticoagulated patients. Am J Surg. 2008;196(6):944-6. discussion 946-7. [pmid: 19095114].
Schondorf TH. Heparin in the prevention of thromboembolism after elective hip-joint operations (author's transl). Dtsch Med Wochenschr. 1978;103(47):1877-81. [pmid: 710312].
Schuerer DJ, Whinney RR, Freeman BD, et al. Evaluation of the applicability, efficacy, and safety of a thromboembolic event prophylaxis guideline designed for quality improvement of the traumatically injured patient. J Trauma. 2005;58(4):731-9. [pmid: 15824649].
Schweizer J, Florek HJ, Kaulen R, Altmann E, Naning T, Kater M. Long-term results after caval filter implantation. Vasa. 1996;25(3):261-4. [pmid: 8967153].
Scurr JH, Coleridge-Smith PD, Hasty JH. Regimen for improved effectiveness of intermittent pneumatic compression in deep venous thrombosis prophylaxis. Surgery. 1987;102(5):816-20. [pmid: 3672322].
Sellier E, Labarere J, Bosson JL, et al. Effectiveness of a guideline for venous thromboembolism prophylaxis in elderly post-acute care patients: a multicenter study with systematic ultrasonographic examination. Arch Intern Med. 2006;166(19):2065-71. [pmid: 17060535].
Senaran H, Acaroglu E, Ozdemir HM, Atilla B. Enoxaparin and heparin comparison of deep vein thrombosis prophylaxis in total hip replacement patients. Arch Orthop Trauma Surg. 2006;126(1):1-5. [pmid: 16333632].
Setti M, Nespoli M, De Giacomi D, La Terra F, Terraneo F. Prophylaxis of thrombo/embolic complications in hip surgery. Ital J Orthop Traumatol. 1981;7(1):99-102. [pmid: 7327934].
Sevitt S. Anticoagulant prophylaxis against venous thrombosis and pulmonary embolism after injury. Thromb Diath Haemorrh Suppl. 1966;21:287-300. [pmid: 5969871].
Shaieb MD, Watson BN, Atkinson RE. Bleeding complications with enoxaparin for deep venous thrombosis prophylaxis. J Arthroplasty. 1999;14(4):432-8. [pmid: 10428223].
Sharnoff JG, De Blasio G, Breen SR, Tucci P. Pulmonary thromboembolism; prevention of fatal postoperative. Med Trial Tech Q. 1970;16(4):63-9. [pmid: 5425125].
Sharnoff JG, Kass HH, Mistica BA. A plan of heparinization of the surgical patient to prevent postoperative thromboembolism. Surg Gynecol Obstet. 1962;115:75-9. [pmid: 13911387].
Sharnoff JG, Rosen RL, Palazzo PJ, et al. Prevention of fatal pulmonary thromboembolism by small dose heparin prophylaxis in acute hip fracture surgery. Br J Clin Pract. 1981;35(11-12):390-2. 427. [pmid: 7306447].
Sharnoff JG, Rosen RL, Sadler AH, Ibarra-Isunza GC. Prevention of fatal pulmonary thromboembolism by heparin prophylaxis after surgery for hip fractures. J Bone Joint Surg Am. 1976;58(7):913-8. [pmid: 977620].
Sharnoff JG. A Plan of Heparinization of the Surgical Patient for the Successful Prevention of Thromboembolism. R I Med J. 1963;46:651. [pmid: 14086306].
Sharrock NE, Brien WW, Salvati EA, Mineo R, Garvin K, Sculco TP. The effect of intravenous fixed-dose heparin during total hip arthroplasty on the incidence of deep-vein thrombosis. A randomized, double-blind trial in patients operated on with epidural anesthesia and controlled hypotension. J Bone Joint Surg Am. 1990;72(10):1456-61. [pmid: 2254352].
Shawabkeh JS, Ghnaimat MM, Hijazi AM. Pharmacologic prophylaxis and treatment of venous thromboembolism after knee arthroplasty. Sultan Qaboos Univ Med J. 2007;7(1):47-50. [pmid: 21654945].
Shelgikar C, Mohebali J, Sarfati MR, Mueller MT, Kinikini DV, Kraiss LW. A design modification to minimize tilting of an inferior vena cava filter does not deliver a clinical benefit. J Vasc Surg. 2010;52(4):920-4. [pmid: 20630684].
Shen H-Y, Yang R, Tang Y, et al. Active regular exercises as early as possible in the prevention of deep venous thrombosis after total hip replacement: An incidence rate of 4.94% in 81 cases (92 hip joints). 2005;9(26):4-6.
Shepherd A, Mills C. Fatal pulmonary embolism following hip and knee replacement. A study of 2153 cases using routine mechanical prophylaxis and selective chemoprophylaxis. 2006;16(1):53-6.
Shorr AF, Kwong LM, Sarnes M, Happe L, Farrelly E, Mody-Patel N. Venous thromboembolism after orthopedic surgery: implications of the choice for prophylaxis. Thromb Res. 2007;121(1):17-24. [pmid: 17449088].
Shorr AF, Nutescu EA, Farrelly E, Horblyuk R, Happe LE, Franklin M. Postdischarge oral versus injectable anticoagulation following major orthopedic surgery. Ann Pharmacother. 2008;42(9):1222-8. [pmid: 18664606].
Shorr AF, Sarnes MW, Peeples PJ, Stanford RH, Happe LE, Farrelly E. Comparison of cost, effectiveness, and safety of injectable anticoagulants used for thromboprophylaxis after orthopedic surgery. Am J Health Syst Pharm. 2007;64(22):2349-55. [pmid: 17989444].
Shorr AF, Williams MD. Venous thromboembolism in critically ill patients. Observations from a randomized trial in sepsis. Thromb Haemost. 2009;101(1):139-44. [pmid: 19132200].
Siddiqui RA, Hans S. Double inferior vena cava filter implantation in a patient with a duplicate inferior vena cava. J Invasive Cardiol. 2008;20(2):91-2. [pmid: 18252974].
Silbersack Y, Taute BM, Hein W, Podhaisky H. Prevention of deep-vein thrombosis after total hip and knee replacement. Low-molecular-weight heparin in combination with intermittent pneumatic compression. J Bone Joint Surg Br. 2004;86(6):809-12. [pmid: 15330019].
Sing RF, Nguyen PH, Christmas AB, Jacobs DG, Heniford BT. Vena cava filter insertion and the general surgery armamentarium: a 13-year experience. Am Surg. 2010;76(7):713-7. [pmid: 20698376].
Singh P, Lai HM, Lerner RG, Chugh T, Aronow WS. Guidelines and the use of inferior vena cava filters: a review of an institutional experience. J Thromb Haemost. 2009;7(1):65-71. [pmid: 18983493].
Singh S, Verma M, Bahekar A, et al. Enoxaparin-induced skin necrosis: a fatal outcome. Am J Ther. 2007;14(4):408-10. [pmid: 17667218].
Skillman JJ, Collins RE, Coe NP, et al. Prevention of deep vein thrombosis in neurosurgical patients: a controlled, randomized trial of external pneumatic compression boots. Surgery. 1978;83(3):354-8. [pmid: 628896].
Smith OB, Stanfield JA, Young TR, Corpe RS, DiPiro JT. Preliminary evaluation of the safety and efficacy of enoxaparin versus warfarin in the prevention of deep vein thrombosis following total knee replacement surgery: Preliminary evaluation of the safety and efficacy of enoxaparin versus warfarin in the prevention of deep vein thrombosis following total knee replacement surgery. ASHP Midyear Clinical Meeting. 1993;28:P.
Smith RC, Elton RA, Orr JD, et al. Dextran and intermittent pneumatic compression in prevention of postoperative deep vein thrombosis: multiunit trial. Br Med J. 1978;1(6118):952-4. [pmid: 638545].
Snook GA, Chrisman OD, Wilson TC. Thromboembolism after surgical treatment of hip fractures. Clin Orthop Relat Res. 1981;(155):21-4. [pmid: 7014058].
Sorensen JV, Borris LC, Lassen MR, Christiansen HM, Schott P, Olsen AD. Levels of thrombin--antithrombin-III complex and factor VIII activity in relation to post-operative deep vein thrombosis and influence of prophylaxis with a low-molecular-weight heparin. Blood Coagul Fibrinolysis. 1990;1(4-5):389-92. [pmid: 1966794].
Sorensen TS, Jorgensen J. Mechanical prophylaxis against deep vein thrombosis in Charnley hip arthroplasty. Acta Orthop Scand. 1981;52(1):69-72. [pmid: 7211320].
Spain DA, Richardson JD, Polk HC Jr, Bergamini TM, Wilson MA, Miller FB. Venous thromboembolism in the high-risk trauma patient: do risks justify aggressive screening and prophylaxis?. J Trauma. 1997;42(3):463-7. discussion 467-9. [pmid: 9095114].
Spath G, Helber MU, Eisele R. Continuous long term heparin therapy--dosage problems using an Infusaid device. Life Support Syst. 1985;3(1):57-9. [pmid: 3990349].
Spiro TE, Johnson GJ, Christie MJ, et al. Efficacy and safety of enoxaparin to prevent deep venous thrombosis after hip replacement surgery. ANN. INTERN. MED. 1994;121(2):81-9. [pmid: 8017740].
Spiro TE, Johnson GJ, Christie MJ, et al. Efficacy and safety of enoxaparin to prevent deep venous thrombosis after hip replacement surgery. Enoxaparin Clinical Trial Group. Ann Intern Med. 1994;121(2):81-9. [pmid: 8017740].
Stannard JP, Riley RS, McClenney MD, Lopez-Ben RR, Volgas DA, Alonso JE. Mechanical prophylaxis against deep-vein thrombosis after pelvic and acetabular fractures. J Bone Joint Surg Am. 2001;83-A(7):1047-51. [pmid: 11451974].
Stern SH, Wixson RL, O'Connor D. Evaluation of the safety and efficacy of enoxaparin and warfarin for prevention of deep vein thrombosis after total knee arthroplasty. J Arthroplasty. 2000;15(2):153-8. [pmid: 10708078].
Stone MH, Limb D, Campbell P, Stead D, Culleton G. A comparison of intermittent calf compression and enoxaparin for thromboprophylaxis in total hip replacement. A pilot study. Int Orthop. 1996;20(6):367-9. [pmid: 9049766].
Sugano N, Miki H, Nakamura N, Aihara M, Yamamoto K, Ohzono K. Clinical efficacy of mechanical thromboprophylaxis without anticoagulant drugs for elective hip surgery in an Asian population. J Arthroplasty. 2009;24(8):1254-7. [pmid: 19577898].
Summaria L, Caprini JA, McMillan R, et al. Relationship between postsurgical fibrinolytic parameters and deep vein thrombosis in surgical patients treated with compression devices. Am Surg. 1988;54(3):156-60. [pmid: 3279880].
Suomalainen O, Kettunen K, Rissanen V, Karjalainen P, Lansimies E, Tanska S. Postoperative thromboembolism and risk factors in elective hip surgery. Ann Chir Gynaecol. 1983;72(4):207-13. [pmid: 6638905].
Suomalainen O, Makela AE, Harju A, Jaroma H. Prevention of fatal pulmonary embolism with warfarin after total hip replacement. Int Orthop. 1996;20(2):75-9. [pmid: 8739697].
Svend-Hansen H, Bremerskov V, Gotrik J, Ostri P. Low-dose heparin in proximal femoral fractures. Failure to prevent deep-vein thrombosis. Acta Orthop Scand. 1981;52(1):77-80. [pmid: 7010893].
Swierstra BA, Stibbe J, Schouten HJ. Prevention of thrombosis after hip arthroplasty. A prospective study of preoperative oral anticoagulants. Acta Orthop Scand. 1988;59(2):139-43. [pmid: 3364181].
Swierstra BA, van Oosterhout FJ, Ausema B, Bakker WH, van der Pompe WB, Schouten HJ. Oral anticoagulants and dextran for prevention of venous thrombosis in orthopaedics. Acta Orthop Scand. 1984;55(3):251-3. [pmid: 6204501].
Taberner DA, Poller L, Thomson JM, Lemon G, Weighill FJ. Randomized study of adjusted versus fixed low dose heparin prophylaxis of deep vein thrombosis in hip surgery. Br J Surg. 1989;76(9):933-5. [pmid: 2804589].
Taberner DA, Poller L, Thomson JM. Adjusted versus fixed dose subcutaneous heparin in preventing deep vein thrombosis in hip surgery. British Journal of Haematology. 1988;69:115.
Tapson VF, Decousus H, Pini M, et al. Venous thromboembolism prophylaxis in acutely ill hospitalized medical patients: findings from the International Medical Prevention Registry on Venous Thromboembolism. Chest. 2007;132(3):936-45. [pmid: 17573514].
Tardy B, Mismetti P, Page Y, et al. Symptomatic inferior vena cava filter thrombosis: Clinical study of 30 consecutive cases. 1996;9:2012-6.
Tebbe U, Schellong SM, Haas S, et al. Certoparin versus unfractionated heparin to prevent venous thromboembolic events in patients hospitalized because of heart failure: a subgroup analysis of the randomized, controlled CERTIFY study. Am Heart J. 2011;161(2):322-8. [pmid: 21315215].
Thaler HW, Roller RE, Greiner N, Sim E, Korninger C. Thromboprophylaxis with 60 mg enoxaparin is safe in hip trauma surgery. J Trauma. 2001;51(3):518-21. [pmid: 11535902].
Thromboprophylaxis in hip fracture surgery: a pilot study comparing danaparoid, enoxaparin and dalteparin.The TIFDED Study Group. Haemostasis. 1999;29(6):310-7. [pmid: 10844404].
Tiwari A, Saw C, Li M, et al. Use of inferior vena cava filters in a tertiary referral centre in Australia. ANZ J Surg. 2010;80(5):364-7. [pmid: 20557513].
Torgerson WR. Three years of experience with total hip replacement. Clin Orthop Relat Res. 1973;(95):151-7. [pmid: 4201903].
Torholm C, Broeng L, Jorgensen PS, et al. Thromboprophylaxis by low-molecular-weight heparin in elective hip surgery. A placebo controlled study. J Bone Joint Surg Br. 1991;73(3):434-8. [pmid: 1670445].
Torngren S. Low dose heparin and compression stockings in the prevention of postoperative deep venous thrombosis. Br J Surg. 1980;67(7):482-4. [pmid: 6998538].
Turpie A, Bauer K, Eriksson B, Lassen M, PENTATHLON 2000 Study Steering. Postoperative fondaparinux versus postoperative enoxaparin for prevention of venous thromboembolism after elective hip-replacement surgery: a randomised double-blind trial: Postoperative fondaparinux versus postoperative enoxaparin for prevention of venous thromboembolism after elective hip-replacement surgery: a randomised double-blind trial. Lancet, The (USA). 2002;359:1721-6.
Turpie A, Bauer K, Eriksson B, Lassen M. Superiority of fondaparinux over enoxaparin in preventing venous thromboembolism in major orthopedic surgery using different efficacy end points. CHEST. 2004;126(2):501-8. [pmid: 15302737].
Turpie A, Lassen M, Davidson B, Bauer K, RECORD4 Investigators, et al. Rivaroxaban versus enoxaparin for thromboprophylaxis after total knee arthroplasty (RECORD4): a randomised trial: Rivaroxaban versus enoxaparin for thromboprophylaxis after total knee arthroplasty (RECORD4): a randomised trial. Lancet, The (USA). 373:1673.
Turpie AG, Bauer KA, Davidson BL, et al. A randomized evaluation of betrixaban, an oral factor Xa inhibitor, for prevention of thromboembolic events after total knee replacement (EXPERT). Thromb Haemost. 2009;101(1):68-76. [pmid: 19132191].
Turpie AG, Bauer KA, Eriksson BI, Lassen MR, PENTATHALON 2000 Study Steering Committee. Postoperative fondaparinux versus postoperative enoxaparin for prevention of venous thromboembolism after elective hip-replacement surgery: a randomised double-blind trial. Lancet. 2002;359(9319):1721-6. [pmid: 12049860].
Turpie AG, Bauer KA, Eriksson BI, Lassen MR. Postoperative fondaparinux versus postoperative enoxaparin for prevention of venous thromboembolism after elective hip-replacement surgery: a randomised double-blind trial. Lancet. 2002;359(9319):1721-6. [pmid: 12049860].
Turpie AG, Bauer KA, Eriksson BI, Lassen MR. Superiority of fondaparinux over enoxaparin in preventing venous thromboembolism in major orthopedic surgery using different efficacy end points. Chest. 2004;126(2):501-8. [pmid: 15302737].
Turpie AG, Fisher WD, Bauer KA, et al. BAY 59-7939: an oral, direct factor Xa inhibitor for the prevention of venous thromboembolism in patients after total knee replacement. A phase II dose-ranging study. J Thromb Haemost. 2005;3(11):2479-86. [pmid: 16241946].
Turpie AG, Gallus AS, Hoek JA. A synthetic pentasaccharide for the prevention of deep-vein thrombosis after total hip replacement. N Engl J Med. 2001;344(9):619-25. [pmid: 11228275].
Turpie AG, Hirsh J, Gent M, Julian D, Johnson J. Prevention of deep vein thrombosis in potential neurosurgical patients. A randomized trial comparing graduated compression stockings alone or graduated compression stockings plus intermittent pneumatic compression with control. Arch Intern Med. 1989;149(3):679-81. [pmid: 2645846].
Turpie AG, Lassen MR, Davidson BL, et al. Rivaroxaban versus enoxaparin for thromboprophylaxis after total knee arthroplasty (RECORD4): a randomised trial. Lancet. 2009;373(9676):1673-80. [pmid: 19411100].
Turpie AG, Levine MN, Hirsh J, et al. A randomized controlled trial of a low-molecular-weight heparin (enoxaparin) to prevent deep-vein thrombosis in patients undergoing elective hip surgery. N Engl J Med. 1986;315(15):925-9. [pmid: 3531851].
Turpie AG. Dose effect in prevention of venous thromboembolism in major orthopedic surgery, of ORG-31540/SR-90107A, the first selective factor X\LC/a\UC/ inhibitor: Dose effect in prevention of venous thromboembolism in major orthopedic surgery, of ORG-31540/SR-90107A, the first selective factor X\LC/a\UC/ inhibitor. ASHP Midyear Clinical Meeting. PPR. 2000;35:13.
Turpie AG. Efficacy of a postoperative regimen of enoxaparin in deep vein thrombosis prophylaxis. American Journal of Surgery. 1991;161(4):532-6. [pmid: 1852136].
Turpie AG. Efficacy of a postoperative regimen of enoxaparin in deep vein thrombosis prophylaxis. Am J Surg. 1991;161(4):532-6. [pmid: 1852136].
Turpie AG. Enoxaparin prophylaxis in elective hip surgery. Acta Chir Scand Suppl. 1990;556:103-7. [pmid: 1963014].
Turpie AG. The American journal of cardiology. Thrombosis prophylaxis in the acutely ill medical patient: insights from the prophylaxis in MEDical patients with ENOXaparin (MEDENOX) trial. 2000;86:48M-52M.
Turpie AGG, Bauer KA, Davidson BL, et al. A randomized evaluation of betrixaban, an oral factor Xa inhibitor, for prevention of thromboembolic events after total knee replacement (EXPERT). Thromb. Haemost. 2009;101(1):68-76. [pmid: 19132191].
Turpie AGG, Bauer KA, Eriksson BI, Lassen MR. Postoperative fondaparinux versus postoperative enoxaparin for prevention of venous thromboembolism after elective hip-replacement surgery: A randomised double-blind trial. Lancet. 2002;359(9319):1721-6. [pmid: 12049860].
Turpie AGG, Levine MN, Hirsch J. A randomized controlled trial of a low-molecular-weight heparin (enoxaparin) to prevent deep-vein thrombosis in patients undergoing elective hip surgery. NEW ENGL. J. MED. 1986;315(15):925-9. [pmid: 3531851].
Unay K, Akan K, Sener N, Cakir M, Poyanli O. Evaluating the effectiveness of a deep-vein thrombosis prophylaxis protocol in orthopaedics and traumatology. J Eval Clin Pract. 2009;15(4):668-74. [pmid: 19674218].
Usoh F, Hingorani A, Ascher E, et al. Prospective randomized study comparing the clinical outcomes between inferior vena cava Greenfield and TrapEase filters. J Vasc Surg. 2010;52(2):394-9. [pmid: 20570472].
Vaitkus PT, Leizorovicz A, Cohen AT, Turpie AG, Olsson CG, Goldhaber SZ. Mortality rates and risk factors for asymptomatic deep vein thrombosis in medical patients. Thromb Haemost. 2005;93(1):76-9. [pmid: 15630494].
Valladares JB, Hankinson J. Incidence of lower extremity deep vein thrombosis in neurosurgical patients. Neurosurgery. 1980;6(2):138-41. [pmid: 7366805].
Vallano A, Arnau JM, Miralda GP, Perez-Bartoli J. Use of venous thromboprophylaxis and adherence to guideline recommendations: a cross-sectional study. Thromb J. 2004;2(1):3. [pmid: 15059286].
Valle I, Sola G, Origone A. Controlled clinical study of the efficacy of a new low molecular weight heparin administered subcutaneously to prevent post-operative deep venous thrombosis. Curr Med Res Opin. 1988;11(2):80-6. [pmid: 2851413].
Valles JA, Vallano A, Torres F, Arnau JM, Laporte JR. Multicentre hospital drug utilization study on the prophylaxis of venous thromboembolism. The Venous Thromboembolism Study Group of the Spanish Society of Clinical Pharmacology. Br J Clin Pharmacol. 1994;37(3):255-9. [pmid: 8198934].
Van Ha TG, Chien AS, Funaki BS, et al. Use of retrievable compared to permanent inferior vena cava filters: a single-institution experience. Cardiovasc Intervent Radiol. 2008;31(2):308-15. [pmid: 17955289].
Van PY, Cho SD, Underwood SJ, Morris MS, Watters JM, Schreiber MA. Thrombelastography versus AntiFactor Xa levels in the assessment of prophylactic-dose enoxaparin in critically ill patients. J Trauma. 2009;66(6):1509-15. discussion 1515-7. [pmid: 19509608].
van Vroonhoven TJ, van Zijl J, Muller H. Low-dose subcutaneous heparin versus oral anticoagulants in the prevention of postoperative deep-venous thrombosis. A controlled clinical trial. Lancet. 1974;1(7854):375-8. [pmid: 4131031].
Vinazzer H, Loew D, Simma W, Brucke P. Prophylaxis of postoperative thromboembolism by low dose heparin and by acetylsalicylic acid given simultaneously. A double blind study. Thromb Res. 1980;17(1-2):177-84. [pmid: 7376128].
Vives MJ, Hozack WJ, Sharkey PF, Moriarty L, Sokoloff B, Rothman RH. Fixed minidose versus-adjusted low-dose warfarin after total joint arthroplasty: a randomized prospective study. J Arthroplasty. 2001;16(8):1030-7. [pmid: 11740759].
Vresilovic EJ Jr, Hozack WJ, Booth RE, Rothman RH. Incidence of pulmonary embolism after total knee arthroplasty with low-dose coumadin prophylaxis. Clin Orthop Relat Res. 1993;(286):27-31. [pmid: 8425357].
Vresilovic EJ, Hozack WJ, Booth RE Jr, Rothman RH. Comparative risk of early postoperative pulmonary embolism after cemented total knee versus total hip arthroplasty with low-dose warfarin prophylaxis. Am J Knee Surg. 1996;9(1):2-6. [pmid: 8835022].
Vukovich T, Proidl S, Teufelsbauer H, et al. Laboratory monitoring of thromboprophylaxis with low molecular weight and standard heparin. Thromb Res. 1992;66(6):735-43. [pmid: 1519232].
Wang CJ, Wang JW, Weng LH, Hsu CC, Huang CC, Yu PC. Prevention of deep-vein thrombosis after total knee arthroplasty in Asian patients. Comparison of low-molecular-weight heparin and indomethacin. J Bone Joint Surg Am. 2004;86-A(1):136-40. [pmid: 14711956].
Wang TJ, Mort EA, Nordberg P, et al. The potential role of fondaparinux as venous thromboembolism prophylaxis after total hip or knee replacement or hip fracture surgery. Arch. Intern. Med. 2002;162(16):1806-8. [pmid: 12196077].
Ward WG, Olin MD. Simple, hybrid deep venous thrombosis/pulmonary embolus prophylaxis after total hip arthroplasty. J South Orthop Assoc. 1999;8(1):14-9. [pmid: 12132847].
Warkentin TE, Levine MN, Hirsh J, et al. Heparin-induced thrombocytopenia in patients treated with low-molecular-weight heparin or unfractionated heparin. N Engl J Med. 1995;332(20):1330-5. [pmid: 7715641].
Warwick D, Bannister GC, Glew D, et al. Perioperative low-molecular-weight heparin. Is it effective and safe. J Bone Joint Surg Br. 1995;77(5):715-9. [pmid: 7559695].
Warwick D, Friedman RJ, Agnelli G, et al. Insufficient duration of venous thromboembolism prophylaxis after total hip or knee replacement when compared with the time course of thromboembolic events: findings from the Global Orthopaedic Registry. J Bone Joint Surg Br. 2007;89(6):799-807. [pmid: 17613508].
Webb LX, Rush PT, Fuller SB, Meredith JW. Greenfield filter prophylaxis of pulmonary embolism in patients undergoing surgery for acetabular fracture. J Orthop Trauma. 1992;6(2):139-45. [pmid: 1602332].
Weber K, Zuckerman J, Watters W3, Turkelson C. Deep vein thrombosis prophylaxis. CHEST. 2009;136(6):1699-700. [pmid: 19995776].
Weitz JI, Cao C, Eriksson BI, et al. A dose-finding study with TAK-442, an oral factor Xa inhibitor, in patients undergoing elective total knee replacement surgery. Thromb Haemost. 2010;104(6):1150-7. [pmid: 20886185].
Welch TJ, Stanson AW, Sheedy PF 2nd, Johnson CM, Miller WE, Johnson CD. Percutaneous placement of the Greenfield vena caval filter. Mayo Clin Proc. 1988;63(4):343-7. [pmid: 3352317].
Welin-Berger T, Bygdeman S, Mebius C. Deep vein thrombosis following hip surgery. Relation to activated factor X inhibitor activity: effect of heparin and dextran. Acta Orthop Scand. 1982;53(6):937-45. [pmid: 6184938].
Wells PS, Borah BJ, Sengupta N, Supina D, McDonald HP, Kwong LM. Analysis of venous thromboprophylaxis duration and outcomes in orthopedic patients. Am J Manag Care. 2010;16(11):857-63. [pmid: 21348557].
Welzel D, Wolf H, Koppenhagen K. Antithrombotic defense during the postoperative period. Clinical documentation of low molecular weight heparin. Arzneimittelforschung. 1988;38(1):120-3. [pmid: 2835055].
Wen DY, Hall WA. Complications of subcutaneous low-dose heparin therapy in neurosurgical patients. Surg Neurol. 1998;50(6):521-5. [pmid: 9870811].
Wenzl ME, Hasse W, Seide K, Wolter D. Prevention of thromboembolism with low-molecular-weight heparin in orthopedic surgery: a 5-year experience. Clin Appl Thromb Hemost. 2004;10(1):1-4. [pmid: 14979398].
Werbel GB, Shybut GT. Acute compartment syndrome caused by a malfunctioning pneumatic-compression boot. A case report. J Bone Joint Surg Am. 1986;68(9):1445-6. [pmid: 3782217].
Westermann K, Trentz O, Pretschner P, Mellmann J. Thromboembolism after hip surgery. Int Orthop. 1981;4(4):253-7. [pmid: 6164655].
Westrich GH, Bottner F, Windsor RE, Laskin RS, Haas SB, Sculco TP. VenaFlow plus Lovenox vs VenaFlow plus aspirin for thromboembolic disease prophylaxis in total knee arthroplasty. J Arthroplasty. 2006;21(6 Suppl 2):139-43. [pmid: 16950076].
Westrich GH, Menezes A, Sharrock N, Sculco TP. Thromboembolic disease prophylaxis in total knee arthroplasty using intraoperative heparin and postoperative pneumatic foot compression. J Arthroplasty. 1999;14(6):651-6. [pmid: 10512434].
Westrich GH, Rana AJ, Terry MA, Taveras NA, Kapoor K, Helfet DL. Thromboembolic disease prophylaxis in patients with hip fracture: a multimodal approach. J Orthop Trauma. 2005;19(4):234-40. [pmid: 15795571].
Westrich GH, Salvati EA, Sharrock N, Potter HG, Sanchez PM, Sculco TP. The effect of intraoperative heparin administered during total hip arthroplasty on the incidence of proximal deep vein thrombosis assessed by magnetic resonance venography. J Arthroplasty. 2005;20(1):42-50. [pmid: 15660059].
Westrich GH, Sculco TP. Prophylaxis against deep venous thrombosis after total knee arthroplasty. Pneumatic plantar compression and aspirin compared with aspirin alone. J Bone Joint Surg Am. 1996;78(6):826-34. [pmid: 8666599].
Widmer BJ, Bassora R, Warrender WJ, Abboud JA. Thromboembolic Events Are Uncommon After Open Treatment of Proximal Humerus Fractures Using Aspirin and Compression Devices. Clin Orthop Relat Res. 2011.
Williams AM, Davies PR, Sweetnam DI, Harper G, Pusey R, Lightowler CD. Knee-length versus thigh-length graduated compression stockings in the prevention of deep vein thrombosis. Br J Surg. 1996;83(11):1553. [pmid: 9014671].
Williams JW, Eikman EA, Greenberg SH, et al. Failure of low dose heparin to prevent pulmonary embolism after hip surgery or above the knee amputation. Ann Surg. 1978;188(4):468-74. [pmid: 697431].
Wilson MG, Pei LF, Malone KM, Polak JF, Creager MA, Goldhaber SZ. Fixed low-dose versus adjusted higher-dose warfarin following orthopedic surgery. A randomized prospective trial. J Arthroplasty. 1994;9(2):127-30. [pmid: 8014642].
Winchell RJ, Hoyt DB, Walsh JC, et al. Risk factors associated with pulmonary embolism despite routine prophylaxis: Implications for improved protection. 1994;37:600-6.
Windisch C, Kolb W, Kolb K, Grutzner P, Venbrocks R, Anders J. Pneumatic compression with foot pumps facilitates early postoperative mobilisation in total knee arthroplasty. Int Orthop. 2011;35(7):995-1000. [pmid: 20652250].
Wingerd M, Bernhard VM, Maddison F, Towne JB. Comparison of caval filters in the management of venous thromboembolism. Arch Surg. 1978;113(11):1264-71. [pmid: 708247].
Wirth T, Schneider B, Misselwitz F, et al. Prevention of venous thromboembolism after knee arthroscopy with low-molecular weight heparin (reviparin): Results of a randomized controlled trial. Arthroscopy. 2001;17(4):393-9. [pmid: 11288011].
Wolf H, Encke A, Haas S, Welzel D. Comparison of the efficacy and safety of Sandoz low molecular weight heparin and unfractionated heparin: interim analysis of a multicenter trial. Semin Thromb Hemost. 1991;17(4):343-6. [pmid: 1666454].
Woolson ST, Robinson RK, Khan NQ, Roqers BS, Maloney WJ. Deep venous thrombosis prophylaxis for knee replacement: warfarin and pneumatic compression. Am J Orthop (Belle Mead NJ). 1998;27(4):299-304. [pmid: 9586729].
Woolson ST, Watt JM. Intermittent pneumatic compression to prevent proximal deep venous thrombosis during and after total hip replacement. A prospective, randomized study of compression alone, compression and aspirin, and compression and low-dose warfarin. J Bone Joint Surg Am. 1991;73(4):507-12. [pmid: 2013589].
Woolson ST. Intermittent pneumatic compression prophylaxis for proximal deep venous thrombosis after total hip replacement. J Bone Joint Surg Am. 1996;78(11):1735-40. [pmid: 8934490].
Yen D, Weiss W. Results of adjusted-dose heparin for thromboembolism prophylaxis in knee replacement compared to those found for its use in hip fracture surgery and elective hip replacement. Iowa Orthop J. 2007;27:47-51. [pmid: 17907429].
Yokote R, Matsubara M, Hirasawa N, Hagio S, Ishii K, Takata C. Is routine chemical thromboprophylaxis after total hip replacement really necessary in a Japanese population?. J Bone Joint Surg Br. 2011;93(2):251-6. [pmid: 21282767].
Ziegler JW, Dietrich GJ, Cohen SA, Sterling K, Duncan J, Samotowka M. PROOF trial: protection from pulmonary embolism with the OptEase filter. J Vasc Interv Radiol. 2008;19(8):1165-70. [pmid: 18656008].
Zwaan M, Kagel C, Marienhoff N, et al. First experiences with temporary vena cava filters. Rofo. 1995;163(2):171-6. [pmid: 7670020].

## Not Conducted in Humans

Becker J, Borgstrom S. Incidence of thrombosis associated with epsilon-aminocaproic acid administration and with combined epsilon-aminocaproic acid and subcutaneous heparin therapy. A study in experimental animals and in clinical material. Acta Chir Scand. 1968;134(5):343-9. [pmid: 5731268].
Davis WC, McManus WF, Freeman DE, LeVeen RF. Evaluation of inferior vena caval occlusion to prevent pulmonary emboli. Am Surg. 1972;38(5):268-73. [pmid: 5026669].
Green L, Lawrie AS, Patel S, et al. The impact of elective knee/hip replacement surgery and thromboprophylaxis with rivaroxaban or dalteparin on thrombin generation. Br J Haematol. 2010;151(5):469-76. [pmid: 20950405].
Jeske WP, Walenga JM, Samama MM, Hoppensteadt D, Mayuga M, Fareed J. Functionality of fondaparinux (pentasaccharide) depends on clinical antithrombin levels. Blood Coagul Fibrinolysis. 2011;22(3):206-10. [pmid: 21297455].
Mobin-Uddin K, McLean R, Jude JR. A new catheter technique of interruption of inferior vena cava for prevention of pulmonary embolism. Am Surg. 1969;35(12):889-94. [pmid: 5355250].
Walenga JM, Jeske WP, Litinas E, et al. Sustained antithrombotic activity of LMWHS compared to FXa inhibitors. J. Thromb. Haemost. 2009;7(S2):1063.

## No Original Data

LMWH and UFH in direct comparison. Consent: CERTIFY. MMW Fortschr Med. 2007;149(20):53.
Abad JI. Prophylaxis of venous thromboembolism in orthopaedic surgery. Pathophysiol Haemost Thromb. 2002;32(5-6):403-5. [pmid: 13679686].
Ageno W, Squizzato A, Ambrosini F, et al. Thrombosis prophylaxis in medical patients: a retrospective review of clinical practice patterns. Haematologica. 2002;87(7):746-50. discussion 250. [pmid: 12091126].
Agnelli G. Prevention of venous thromboembolism after neurosurgery. Thromb Haemost. 1999;82(2):925-30. [pmid: 10605805].
Agu O, Hamilton G, Baker D. Br J Surg. Graduated compression stockings in the prevention of venous thromboembolism. 1999;86:992-1004. [pmid: 10460633].
Agudelo JF, Morgan SJ, Smith WR. Venous thromboembolism in orthopedic trauma patients. Orthopedics. 2005;28(10):1164-71. quiz 1172-3. [pmid: 16237881].
Albino P. Inferior vena cava interruption: a 17-years experience (1989-2006). Rev Port Cir Cardiotorac Vasc. 2006;13(3):165-71. [pmid: 17057821].
Anderson DR, Gross M, Robinson KS, Wells PS, Pedell L, Bergqvist D. Enoxaparin as prophylaxis against thromboembolism after total hip replacement [2]. NEW ENGL. J. MED. 1997;336(8):585-6. [pmid: 9036310].
Ansell J. Long-term follow-up of patients with vena cava filters for the prevention of pulmonary embolism. Curr Hematol Rep. 2005;4(5):375-7. [pmid: 16131438].
Asakawa K, Takenaga N, Takizawa K. Prophylaxis for post-operative thrombosis. Nihon Rinsho. Suppl 10. 2004;62:653-6. [pmid: 15535326].
Asch MR. Initial experience in humans with a new retrievable inferior vena cava filter. Radiology. 2002;225(3):835-44. [pmid: 12461269].
Aziz F, Comerota AJ. Inferior vena cava filters. Ann Vasc Surg. 2010;24(7):966-79. [pmid: 20832003].
Baglin T. Evidence-based management of deep vein thrombosis and pulmonary embolus. Clin Med. 2001;1(6):438-41. [pmid: 11792080].
Baker LD. Prevention of thrombi after arteriotomy. N Engl J Med. 1969;280(11):619. [pmid: 5764838].
Banarer S, Schillaci G, Pasqualini L, et al. Ximelagatran versus warfarin after total knee replacement…. New England Journal of Medicine. 2004;350(6):616-7. [pmid: 14762192]. Francis CW, Berkowitz SD, Comp PC, et al. Comparison of ximelagatran with warfarin for the prevention of venous thromboembolism after total knee replacement. N Engl J Med. 2003;349:1703-12. [pmid: 14585938].
Baumuller E. Prevention of thromboembolism. Med Klin (Munich). 1952;47(5):161-3. [pmid: 14918981].
Belding HH. Use of anticoagulants in the prevention of venous thromboembolic disease in postoperative patients. Arch Surg. 1965;90:566-73. [pmid: 14267658].
Benson EA. Prevention of fatal postoperative thromboembolism by heparin prophylaxis. Lancet. 1970;2(7683):1135. [pmid: 4097935].
Bergqvist D. Intermittent thigh compression as prophylaxis against deep venous thrombosis. Lakartidningen. 1979;76(34):2790-2. [pmid: 529909].
Bergqvist D. Inferior vena cava filters. World J Surg. 2007;31(2):265-6. [pmid: 16847709].
Berlanga JR, Llamas P, Caramelo C. Nephrotic syndrome and coagulation: preventive approach. Nefrologia. 2001;21(5):514-5. [pmid: 11795026].
Blann AD, Lip GY. Venous thromboembolism. BMJ. 2006;332(7535):215-9. [pmid: 16439400].
Blombery PA. Dose of enoxaparin in review of rivaroxaban versus enoxaparin for prophylaxis of venous thromboembolism. Thromb Res. 2011.
Blumenthal JB. Use of low dose heparin in preventing venous thrombosis. J Med Assoc Ga. 1973;62(6):239-40. [pmid: 4715331].
Bonn J, Cho KJ, Cipolle M, et al. Journal of Vascular Surgery. Recommended reporting standards for vena caval filter placement and patient follow-up. 1999;30:573-9. [pmid: 10477662].
Borris L. Oral rivaroxaban for the prevention of symptomatic venous thromboembolism after elective hip and knee replacement: The RECORD study programme. Pathophysiol. Haemost. Thromb. 2010;37:P105.
Borris LC, Lassen MR, Andersen BS, Poulsen A, Hansen BR. Low molecular weight heparin (enoxaparin) versus standard heparin in the prevention of venous thromboembolism in operatively treated hip fracture patients. Thrombosis and Haemostasis. 1993;69(6):1118. Abstract no:. 2058.
Bounameaux Y. Pharmacodynamic prevention of thrombosis. Rev Med Liege. 1971;26(19):637-46. [pmid: 5125111].
Brenner M, Bochicchio G, Bochicchio K, Scalea T. Inferior vena cava filters in spinal cord injury patients: Necessary or discretionary?. Crit. Care Med. 2010;38:A167.
Breyer HG, Hahn F, Koppenhagen K. Prevention of deep vein thrombosis in orthopedic surgery: Fragmin versus heparin-DHE. Thrombosis Research. 1987;(Suppl VII):23. [pmid: 3424283].
Browse NL. Prevention of venous tromboembolism. N Engl J Med. 1972;287(3):145-6. [pmid: 5032274].
Browse NL. Prophylaxis of pulmonary embolism. Br Med J. 1970;2(5712):780-2. [pmid: 5428746].
Burian R. Thromboembolism prophylaxis with low molecular weight heparins in surgical patients: Adjustment of dose and duration in risky situations!: Thromboembolie-prophylaxe mit NMH bei operierten patienten: Dosierung und dauer der risikosituation anpassen!. Med. Welt. 2005;56(9):406-7.
Byrne JJ. Prevention of pulmonary embolism. Am J Surg. 1968;116(3):396-402. [pmid: 5675909].
Calderon-Gerstein W, Famularo G, Minisola G, De Simone C, Francis C. Prophylaxis for throboembolism in hospitalized medical patients. N Engl J Med. 2007;356:1438-44. [pmid: 17409325]. New England Journal of Medicine. 2007;357(3):304-6. [pmid: 17634471].
Chiche P, Dahan D, Dupuis R. Anticoagulant treatment and prevention of venous-pulmonary thromboembolic complications. Coeur Med Interne. 1978;17(4):605-14. [pmid: 738003].
Chopard P, Spirk D, Bounameaux H. Identifying acutely ill medical patients requiring thromboprophylaxis. J Thromb Haemost. 2006;4(4):915-6. [pmid: 16634771].
Cimminiello C, Planes A, Samama MM. Prevention of venous thromboembolism after orthopedic surgery: the EXPRESS study. J Thromb Haemost. 2004;2(11):2036-40. [pmid: 15550036].
Cios D, Fanikos J. Rivaroxaban to prevent pulmonary embolism after hip or knee replacement. Circulation. 2012;125(14):e542-4. [pmid: 22492951].
Clagett GP, Anderson Jr FA, Geerts W, et al. Prevention of venous thromboembolism. 1998;114:531S-60S.
Clagett GP, Salzman EW. Prevention of venous thromboembolism in surgical patients. N Engl J Med. 1974;290(2):93-6. [pmid: 4585841].
Cohen AT, Bailey CS, Alikhan R, Cooper DJ. Extended thromboprophylaxis with low molecular weight heparin reduces symptomatic venous thromboembolism following lower limb arthroplasty--a meta-analysis. Thromb Haemost. 2001;85(5):940-1. [pmid: 11372694].
Cohn SM, Moller BA, Burns GA, Feinstein AJ, Ginzburg E, Hammers L. Prospective trial of lower molecular weight heparin versus unfractionated heparin in moderately injured patients. 1998;114(4 SUPPL.):392S-3S.
Colwell CW Jr, Spiro TE, Trowbridge AA, et al. Use of enoxaparin, a low-molecular-weight heparin, and unfractionated heparin for the prevention of deep venous thrombosis after elective hip replacement. A clinical trial comparing efficacy and safety. Enoxaparin Clinical Trial Group. J Bone Joint Surg Am. 1994;76(1):3-14. [pmid: 8288662].
Colwell CW Jr. DVT prevention: mobile compression device vs low-molecular-weight heparin. Orthopedics. 2010;33(5):317-8. [pmid: 20507033].
Colwell CW Jr. Venous thrombosis prophylaxis with low-molecular-weight heparin in hip and knee arthroplasty. Instr Course Lect. 2002;51:487-9. [pmid: 12064138].
Compression stockings prevent DVT, but not SVT. Pharm. J. 2005;274(7354):750.
Cook D, Crowther MA, Douketis J. Thromboprophylaxis in medical-surgical intensive care unit patients. J Crit Care. 2005;20(4):320-3. [pmid: 16310602].
Cook DJ, Crowther MA, Meade MO, Douketis J. Prevalence, incidence, and risk factors for venous thromboembolism in medical-surgical intensive care unit patients. J. Crit. Care. 2005;20(4):309-13. [pmid: 16310600].
Costet JM. Value and limitations of preventive anticoagulant therapy in orthopedics of the lower limbs. Statistical study on 10 years. Phlebologie. 1966;19(3):211-2. [pmid: 5967519].
Couinaud C, Cerceau F, Goddio A. Preventive treatment of thrombo-emboly in general surgery. A report of 5 242 observations (author's transl). Ann Chir. 1979;33(7):455-60. [pmid: 507714].
Cull DL, Wheeler JR, Gregory RT, Synder SO Jr, Gayle RG, Parent FN 3rd. The Vena Tech filter: evaluation of a new inferior vena cava interruption device. J Cardiovasc Surg (Torino). 1991;32(5):691-6.
Davenport A. Low-molecular-weight heparin for routine hemodialysis. Hemodial Int. Suppl 2. 2008;12:S34-7. [pmid: 18837768].
Davies GC. Ultra-low dose intravenous heparin. Lancet. 1980;2(8184):35. [pmid: 6104244].
De Montrichard, Verne JM. Combined prevention (anticoagulant and venomotor) of thromboembolism in general surgery. Mission and responsibility of the anesthetist-resuscitator. Simplified prevention without laboratory tests. Sem Hop Ther Paris. 1962;38:404-9. [pmid: 14475583].
De Montrichard, Verne JM. Mixed prevention (anticoagulants and venomotor) of thromboembolism in general surgery. Mission and responsibility of anesthetist-resuscitator. Simplified prevention without laboratory tests. Sem Hop. 1961;37:3412-7. [pmid: 14475584].
De Takats G. Heparin in prevention of thrombosis. Lancet. 1972;2(7772):327-8. [pmid: 4115055].
DeLoughery TG, Potyk D. DVT prophylaxis in total hip replacement. 1993;8(11):641-2.
Di Nisio M, Middeldorp S, Buller HR. Direct thrombin inhibitors. N Engl J Med. 2005;353(10):1028-40. [pmid: 16148288].
El-Solh AA. Clinical approach to the critically ill, morbidly obese patient. Am J Respir Crit Care Med. 2004;169(5):557-61. [pmid: 14982823].
Emter M, Alexander K. Prevention of thrombosis with anti-thrombosis stockings and intermittent compression. Vasa Suppl. 1991;33:220. [pmid: 1788681].
Enyart JJ, Jones RJ. Low-dose warfarin for prevention of symptomatic thromboembolism after orthopedic surgery. Ann Pharmacother. 2005;39(6):1002-7. [pmid: 15886295].
Erdi A, Baranyai L. Incidence of pulmonary embolism at our clinic following introduction of heparin therapy by small subcutaneous doses. Orv Hetil. 1978;119(7):395-7. [pmid: 625413].
Erichsen J. Methods and results in prevention of thrombosis in general surgery. Med Welt. 1973;24(35):1325-7. [pmid: 4777003].
Eriksson B, Bauer KA, Lassen MR, Turpie AGG. Current management of venous thromboembolism prophylaxis after major orthopedic surgery in North America and Europe: Lessons from the pentasaccharide (Fondaparinux, Arixtra-«) database. 2001;98(11 PART I).
Eriksson B, Dahl A. Prevention of venous thromboembolism following orthopaedic surgery - Clinical potential of direct thrombin inhibitors: Prevention of venous thromboembolism following orthopaedic surgery - Clinical potential of direct thrombin inhibitors. Drugs (New Zealand). 2004;64:577-95.
Eriksson B, Risberg B. A prospective double-blind trial of a low molecular weight heparin once daily compared with a conventional low-dose heparin three times daily prevent pulmonary embolism and venous thrombosis in patients with hip fracture. The Journal of Trauma. 1990;30(6):753-4. [pmid: 2161934].
Favre-Gilly J, Ithier S, Blanc R, Borel-Milhet Mf, Croizat P, Froment R. Anti-coagulant drugs in the prevention and therapy of postoperative vascular disorders. Lyon Chir. 1952;47(7):825-44. [pmid: 13024143].
Fernsebner B, Baum P, Bartlett C. Surgical prevention of pulmonary emboli: vena caval interruption… a vena caval filter… home study program. AORN Journal. 1984;39(1):56. [pmid: 6559562].
Ferris EJ, McCowan TC, Carver DK, McFarland DR. Percutaneous inferior vena caval filters: follow-up of seven designs in 320 patients. Radiology. 1993;188(3):851-6. [pmid: 8351361].
Fetzer E. Additional experiences in prophylaxia and therapy of thrombosis and embolism. Med Klin (Munich). 1952;47(20):686-7. [pmid: 14956627].
Fleischhacker H. Prophylaxis of vascular diseases. Wien Med Wochenschr. 1953;103(27):493-6. [pmid: 13090718].
Galasko CSB, Edwards DH, Fearn CBD'. A controlled clinical trial to investigate the use of low dosage heparin for the prevention of thromboembolism in patients with fractured femoral necks [Abstract]. Journal of Bone and Joint Surgery - British Volume. 1973;55(1):213-4.
Gallus AS, Hirsh J. The diagnosis and prevention of post operative venous thrombosis. Thromb Diath Haemorrh Suppl. 1973;56:145-55. [pmid: 4617329].
Gassanov N, Caglayan E, Erdmann E, Er F. Prophylaxis of thrombembolic diseases with rivaroxaban. Dtsch Med Wochenschr. 2010;135(44):2189-92. [pmid: 20979005].
Gaston EA. Incorrect placement of intracaval prosthesis for pulmonary embolism. JAMA. 1970;214(13):2338. [pmid: 5536897].
Genton E, Gent M, Hirsh J, Harker LA. Platelet-inhibiting drugs in the prevention of clinical thrombotic disease (third of three parts). N Engl J Med. 1975;293(25):1296-300. [pmid: 1102986].
Gillespie DL. Anticoagulation is the most appropriate method of prophylaxis against venous thromboembolic disease in high-risk trauma patients. Dis Mon. 2010;56(11):628-36. [pmid: 21081193].
Goinard P, Belleville J, Thouverez JP. The application of subcutaneous heparin in general surgery. Mem Acad Chir (Paris). 1967;93(26):803-7. [pmid: 5590790].
Goinard P, Pelissier G, Bernollin F. Our current practice of preventive anticoagulant therapy. Mem Acad Chir (Paris). 1961;87:486-91. [pmid: 13706341].
Goldhaber SZ, Fanikos J. Cardiology patient pages. Prevention of deep vein thrombosis and pulmonary embolism. Circulation. 2004;110(16):e445-7. [pmid: 15492324].
Grandi A, Parodi JC, Rotondaro D, Soffer F, Alle E. Prevention of post-operative phlebothrombosis. Medicina (B Aires). 1979;39(3):379-83. [pmid: 514058].
Greep JM, Martis EE, Van Alkemadep, Prinsen JE. Thrombosis Prevention With Anticoagulants. Ned Tijdschr Geneeskd. 1963;107:2085-91. [pmid: 14097756].
Gruber UF, Hohl M, Sturm V. Intra- and postoperative prevention of thrombosis. Klin Anasthesiol Intensivther. 1975;9:17-35. [pmid: 1234606].
Gruber UF. Postoperative prophylaxis of thrombosis (author's transl). Schweiz Rundsch Med Prax. 1975;64(45):1440-5. [pmid: 1181586].
Gruber UF. Dextran and the prevention of postoperative thromboembolic complications. Surg Clin North Am. 1975;55(3):679-96. [pmid: 1169822].
Guimbretiere J, Lebeaupin R, Pannier M. Heparin therapy and burns. Anesth Analg (Paris). 1977;34(6):1339-44. [pmid: 613885].
Haas SB, Barrack RL, Westrich G, Lachiewicz PF. Venous thromboembolic disease after total hip and knee arthroplasty. J Bone Joint Surg Am. 2008;90(12):2764-80. [pmid: 19047723].
Hallen LG. Early therapy or prevention of thromboembolism. Nord Med. 1951;46(47):1752-3. [pmid: 14899778].
Ham JM, Lawrence J. Small doses of heparin in the prevention of deep venous thrombosis. Lancet. 1971;2(7721):428. [pmid: 4105194].
Harris S, Chen D, Green D. Enoxaparin for thromboembolism prophylaxis in spinal injury: preliminary report on experience with 105 patients. Am J Phys Med Rehabil. 1996;75(5):326-7. [pmid: 8873697].
Heinzl S. Thrombosis prevention in the intensive care unit: Dalteparin and unfractionated heparin are similarly effective: Thromboseprophylaxe auf der intensivstation. Dalteparin und unfraktioniertes Heparin +ñhnlich effektiv. 2011;108(17).
Hejl CG, Leclerc T, Bargues L, Samson T, Foissaud V. Incidence and features of heparin-induced thrombocytopenia (HIT) in burn patients: a retrospective study. Thromb Haemost. 2008;99(5):974-6. [pmid: 18449436].
Henke PK, Pannucci CJ. Venous thromboembolism risk factor assessment and prophylaxis. Phlebology. 2010;25(5):219-23. [pmid: 20870868].
Hirsh J, Lotke PA, Ecker ML, Hull RD, Pineo GF. Low-molecular-weight heparin vs. warfarin for prophylaxis against deep- vein thrombosis [2]. 1994;330(12):862-3.
Hirsh J, Warkentin TE, Raschke R, Granger C, Ohman EM, Dalen JE. Chest. Heparin and low-molecular-weight heparin: Mechanisms of action, Pharmacokinetics, dosing considerations, monitoring, efficacy, and safety. 1998;114:489S-510S. [pmid: 9822059].
Holmgren E, Haglund G. Prevention of thrombosis using heparin in neurosurgical intervention. Lakartidningen. 1980;77(7):499-500. [pmid: 7374281].
Howard DP. Acute thromboembolism in medical inpatients: the need for a focus on prevention rather than cure. Clin Med. 2006;6(1):117-8. [pmid: 16521369].
Hull RD, Raskob GE. Prophylaxis of venous thromboembolic disease following hip and knee surgery. J Bone Joint Surg Am. 1986;68(1):146-50. [pmid: 2416763].
Hull RD. Venous thromboembolism in spinal cord injury patients. Chest. 1992;102(6 Suppl):658S-63S. [pmid: 1451542].
Hull RD, Pineo GF. Intermittent pneumatic compression for the prevention of venous thromboembolism. Chest. 1996;109:6-9. [pmid: 8549219].
Ickx BE. Preoperative stop or continue? New antithrombotic and anticoagulants. Acta Anaesthesiol Belg. 2001;52(4):385-93. [pmid: 11799571].
Insinger FG. Prophylactic use of anticoagulants. Ned Tijdschr Geneeskd. 1957;101(47):2240-2. [pmid: 13504292].
Jackson DR, Harrower HW. Pulmonary embolization following inferior vena caval interruption. Vasc Surg. 1969;3(3):129-37. [pmid: 4901052].
Johow R. Favorable and untoward results in anticoagulant prophylaxis of thrombosis and embolism, with special reference to the use of dicumarol. Geburtshilfe Frauenheilkd. 1950;10(12):898-914. [pmid: 14802740].
Johs S. Preventive anticoagulant therapy in surgery. Tidsskr Nor Laegeforen. 1969;89(19):1501-2. [pmid: 5383703].
Kakkar VV, Stamatakis JD, Bentley PG, Lawrence D, de Haas HA, Ward VP. Prophylaxis for postoperative deep-vein thrombosis. Synergistic effect of heparin and dihydroergotamine. JAMA. 1979;241(1):39-42. [pmid: 758493].
Kakkar VV. Low-doses of heparin in the prevention of deep vein thrombosis. Bull Schweiz Akad Med Wiss. 1973;29(4):235-43. [pmid: 4771352].
Kastan DJ, Forcler NJ, Kahn ML. Simon nitinol vena cava filter: preliminary observations and suggested procedural modifications. J Vasc Interv Radiol. 1991;2(1):123-4. [pmid: 1799741].
Kay NR. Some complications of total hip replacement. Clin Orthop Relat Res. 1973;(95):73-9. [pmid: 4201905].
Kearon C, Hirsh J. Management of anticoagulation before and after elective surgery. N Engl J Med. 1997;336(21):1506-11. [pmid: 9154771].
Kearon C. Duration of venous thromboembolism prophylaxis after surgery. Chest. 2003;124(6 Suppl):386S-92S. [pmid: 14668422].
King MS. Preventing deep venous thrombosis in hospitalized patients. 1994;49(6):1389-96.
Knezevic S. Role Of Anticoagulant Therapy In The Prevention Of Venous Thrombosis And Pulmonary Embolism. Med Glas. 1964;18:217-9. [pmid: 14271404].
Korzinek K. The results of prophylactic use of prothrombinopenic agents in orthopedics and traumatology (author's transl). Lijec Vjesn. 1981;103(6):248-52. [pmid: 7321749].
Kovacic M, Pistotnik M, Grgcevic D, Krivec O, Radej M, Parazajder J. Prevention of postoperative thromboembolic disease. Lijec Vjesn. 1975;97(11):607-10. [pmid: 1226048].
Koya MP, Manoharan M, Kim SS, Soloway MS. Venous thromboembolism in radical prostatectomy: is heparinoid prophylaxis warranted?. BJU Int. 2005;96(7):1019-21. [pmid: 16225520].
Kozek-Langenecker SA. Thrombosis prophylaxis with new anticoagulants: Routine and specific risk groups. Wien. Med. Wochenschr. 2011;161(3-4):53. [pmid: 21404138].
Kucher N. Clinical practice. Deep-vein thrombosis of the upper extremities. N Engl J Med. 2011;364(9):861-9. [pmid: 21366477].
Kuijjer Pj, Leeksma Ch. Prophylaxis Of Venous Thromboembolic Complications Using Anticoagulants. Ned Tijdschr Geneeskd. 1965;109:1480-4. [pmid: 14341812].
Kuklina AS, Leibzon ND, Monakova EA, Naumenko VG, Shcherbakova EA. Pulmonary artery thromboembolism and the state of the blood coagulation system in severe cranio-cerebral trauma. Vopr Neirokhir. 1972;36(4):25-8. [pmid: 5085148].
Kuzin MI, Dreizina AM. Prevention of postoperative thromboembolic complications. Sov Med. 1975;(11):32-8. [pmid: 1221525].
Labarere J, Bosson J-L, Pernod G. More on: Incorrect use of thromboprophylaxis for venous thromboembolism in medical and surgical patients: Results of a multicentric, observational, and cross-sectional study in Brazil. 2006;4(12):2737-8.
Lahey SJ, Meyer LP, Karchmer AW, et al. Misplaced caval filter and subsequent pericardial tamponade. Ann Thorac Surg. 1991;51(2):299-300. discussion 301. [pmid: 1989549].
Lavrik AS, Tyvonchuk AS, Bubalo AF, Zgonnik AIu. Prophylaxis of thromboembolic complications in bariatric surgery. Klin Khir. 2007;(8):39-42. [pmid: 18318070].
Lavrinovitsch TS, Petuchova LI, Slutskii LI. A comparative investigation of acetylsalicyclic acid and indirect anticoagulants for the prophylaxis of venous thromboses in patients with an orthopedic-traumatologic case history (author's transl). Z Orthop Ihre Grenzgeb. 1976;114(5):769-72. [pmid: 997731].
Lee BY, Trainor FS, Thoden WR, Kavner D, Madden JL. Prevention of deep venous thrombosis: intermittent pneumatic compression. Compr Ther. 1979;5(11):68-75. [pmid: 509912].
Lee HN. Best evidence in anesthetic practice: prevention: fondaparinux is better than enoxaparin for prevention of major venous thromboembolism after orthopedic surgery. Can J Anaesth. 2003;50(8):764-6. [pmid: 14598801].
Lehmann J. Prevention of thromboembolism with a hirudoid ointment foam rubber bandage. Dtsch Med Wochenschr. 1954;79(41):1516-7. [pmid: 13220107].
Lereun C, Wells P, Diamantopoulos A, Rasul F, Lees M, Sengupta N. An indirect comparison, via enoxaparin, of rivaroxaban with dabigatran in the prevention of venous thromboembolism after hip or knee replacement. J Med Econ. 2011;14(2):238-44. [pmid: 21385145].
Levin PE, Colwell CW Jr, Morris B, et al. Use of enoxaparin, a low-molecular-weight heparin, and unfractionated heparin for the prevention of deep venous thrombosis after elective hip replacement. A clinical trial comparing efficacy and safety [1]. J. BONE JT. SURG. SER. A. 1994;76(11):1752.
Levine MN, Hirsh J, Landefeld S, Raskob G. Hemorrhagic complications of anticoagulant treatment. 1992;102:352S-63S.
Levy JH, Key NS, Shorr AF, Kurz MA, Marder VJ. VTE prophylaxis with desirudin in patients with thrombocytopenia: Insights from the DESIRABLE trial. Blood. 2011;118(21).
Levy JH. Novel intravenous antithrombins. Am Heart J. 2001;141(6):1043-7. [pmid: 11376322].
Lewandowski RJ, Ryu RK, Riaz A, et al. A prospective study of 467 IVC filter placements: Is there a difference between optional and permanent filters?. J. Vasc. Intervent. Radiol. 2012;23(3):S25.
Lieberman JR, Barnes CL, Lachiewicz PF, Hanssen AD, Clarke HD, Pellegrini VD Jr. Venous thromboembolism debate in joint arthroplasty. J Bone Joint Surg Am. Suppl 5. 2009;91:29-32. [pmid: 19648620].
Lieberman JR, Geerts WH. Prevention of venous thromboembolism after total hip and knee arthroplasty. J Bone Joint Surg Am. 1994;76(8):1239-50. [pmid: 8056805].
Loew D, Boehme K, Artik N. A model for studying the antithrombotic effect of acetylsalicylic acid in the prevention of postoperative thrombo-embolism (author's transl). Dtsch Med Wochenschr. 1974;99(12):558 p. [pmid: 4835525].
Lorenz D, Reichold H. Prevention and therapy of postoperative thrombosis in the surgical hospitals of the German Federal Republic. Results of an inquiry. Med Klin. 1966;61(21):849-51. [pmid: 5988334].
Lyon LJ, Nevins MA. Prevention of thromboembolism after hip fracture. Geriatrics. 1973;28(1):107-10. [pmid: 4566617].
Magrini M. Preventive treatment of thromboembolic disease in the postoperative period and during resucitation. Acta Anaesthesiol. Suppl 7. 1968;19:157+. [pmid: 5757447].
Maratea D, Fadda V, Trippoli S, Messori A. Prevention of venous thromboembolism after major orthopedic surgery: indirect comparison of three new oral anticoagulants. J Thromb Haemost. 2011.
Marble EL. Complications with heparin therapy. Am Heart J. 1979;97(1):130. [pmid: 758737].
Maresch P. Prophylaxis of thromboembolism in orthopedics: Profylaxia tromboemb+¦lie v ortop+_dii. 2005;54(2):74-7.
Marinigh R, Lane D, Lip G. Severe renal impairment and stroke prevention in atrial fibrillation implications for thromboprophylaxis and bleeding risk. Journal of the American College of Cardiology (JACC). 2011;57(12):1339-48.
Markwardt F. Prevention of thrombosis by means of toning of the veins. Folia Haematol Int Mag Klin Morphol Blutforsch. 1979;106(5-6):656-8. [pmid: 94860].
Masekowitz B. Convincing study results of rivaroxaban for thrombosis prophylaxis: Thromboseprophylaxe. Rivaroxaban uberzeugt in studien. Pharm. Ztg. 2008;153(19):38.
Mayer W. Prevention of thromboembolism in surgery. Results--problems. Thromb Diath Haemorrh Suppl. 1967;23:1-86. [pmid: 5602353].
McCarthy ST. Low-dose heparin after stroke. Lancet. 1978;1(8062):500-1. [pmid: 76042].
McGarry L, Thompson D. Retrospective database analysis of the prevention of venous thromboembolism with low-molecular-weight heparin in acutely ill medical inpatients in community practice: Retrospective database analysis of the prevention of venous thromboembolism with low-molecular-weight heparin in acutely ill medical inpatients in community practice. Clinical Therapeutics (USA). 2004;26:419-30.
McKeown L. In hospitalized patients … LMWH cuts thromboembolism risk by 50%: In hospitalized patients … LMWH cuts thromboembolism risk by 50%. Pharmacy Practice News (USA). 2003;30:6.
McLafferty RB. Retrievable vena cava filters are indicated in high-risk trauma patients. Dis Mon. 2010;56(11):619-27. [pmid: 21081192].
McNally M. Insufficient duration of venous thromboembolism prophylaxis after total hip or knee replacement when compared with the time course of thromboembolic events…. J Bone Joint Surg Br. Jun. 2007;89(6):799-807. [pmid: 17613508]. Journal of Bone & Joint Surgery, British Volume. 2007;89B(10):1409-10.
McNally MA. Insufficient duration of venous thromboembolism prophylaxis after total hip or knee replacement when compared with the time course of thromboembolic events [1]. 2007;89(10):1409.
Medrano Ortega FJ, Calderon Sandubete EJ, Alonso Ortiz del Rio C, del Villar Conde E, Gonzalez de la Puente MA, Marin Leon I. Assessing the use of low-molecular-weight heparins fo venous thromboembolism prophylaxis in internal medicine patients: Evaluacion de la utilizacion de heparinas de bajo peso molecular como profilaxis de tromboembolismo venoso en pacientes de medicina interna. Farm Hosp. 2005;29(1):69-70. author reply 70-71. [pmid: 15773805].
Mensdorf B. Prevention of thromboembolism: compression dressing yields best results. Pflege Z. 1999;52(11):776-80. [pmid: 10788930].
Merle D'aubigne R, Tubiana R, Duparc J. Thromboembolic complications in orthopedic surgery and traumatology; their frequency and prevention. Mem Acad Chir (Paris). 1955;81(33-34):1011-21. [pmid: 13287868].
Merli GJ, Crabbe S, Paluzzi RG, Fritz D. Etiology, incidence, and prevention of deep vein thrombosis in acute spinal cord injury. Arch Phys Med Rehabil. 1993;74(11):1199-205. [pmid: 8239962].
Meyer S. Leg compression and pharmacologic prophylaxis for venous thromboembolism prevention in high-risk patients. Am Fam Physician. 2010;81(3):284. [pmid: 20112885].
Meyerowitz BR. Pulmonary embolism in surgical patients: is embolectomy superior to prophylaxis?. Surgery. 1966;60(3):521-35. [pmid: 5913774].
Mills G. Venous thromboembolism prophylaxis in hospitalized medical patients. 2012;156(6):473.
Mismetti P, Laporte-Simitsidis S, Tardy B, et al. Prevention of venous thromboembolism in internal medicine with unfractionated or low-molecular-weight heparins: A meta-analysis of randomised clinical trials. 2000;83:14-9.
Monreal M. A prospective double-blind trial of a low molecular weight heparin once daily compared with conventional low-dose heparin three times daily to prevent pulmonary embolism and venous thrombosis in patients with hip fracture [letter; comment]. Journal of Trauma: Injury, Infection and Critical Care. 1990;30:754.
Montenbruck U. Patient education. Improved prevention of thrombosis: improved knowledge. Krankenpfl Soins Infirm. 2011;104(2):32. [pmid: 21404504].
Morris CS, Rogers FB, Najarian KE, Bhave AD, Shackford SR. Current trends in vena caval filtration with the introduction of a retrievable filter at a level I trauma center. J Trauma. 2004;57(1):32-6. [pmid: 15284544].
Muir KW. The PREVAIL trial and low-molecular-weight heparin for prevention of venous thromboembolism. Stroke. 2008;39(7):2174-6. [pmid: 18436873].
Nafziger AN, Bertino JS Jr. Desirudin dosing and monitoring in moderate renal impairment. J Clin Pharmacol. 2010;50(6):614-22. [pmid: 19915180].
National Institute for Health and Clinical Excellence. Dabigatran etexilate for the prevention of venous thromboembolism after hip or knee replacement surgery in adults (Structured abstract). London. National Institute for Health and Clinical Excellence (NICE). 2008.
Negus D. Ultra-low dose intravenous heparin. Lancet. 1980;2(8184):35-6. [pmid: 6104245].
Nerurkar J, Wade WE, Martin BC. Cost/death averted with venous thromboembolism prophylaxis in patients undergoing total knee replacement or knee arthroplasty. Pharmacotherapy. 2002;22(8):990-1000. [pmid: 12173802].
Nieto J, Valle R, Lopez-Saez J. Extended-duration venous thromboembolism prophylaxis for medical patients…. Ann Intern Med. Jul. 6. 2010;153(1):8-18. [pmid: 20621900]. Annals of Internal Medicine. 2010;153(10):688-9.
Obergassel L, Miketic S, Carlsson J, Tebbe U. Pulmonary embolism prophylaxis with vena cava filters. Dtsch Med Wochenschr. 1996;121(34-35):1060-5. [pmid: 8829908].
O'Brien CM, Eltigani T. Common peroneal nerve palsy as a possible sequelae of poorly fitting below-knee thromboembolic deterrent stockings (TEDS). Ann Plast Surg. 2006;57(3):356-7. [pmid: 16929214].
O'Connor MB, Pokrovskaya O, Burns M, et al. Prevention of venous thromboembolic disease in medical and surgical hospital patients in a single university teaching hospital. 2011;180(1):303-4.
OLOVSON T. Postoperative use of heparin in prophylaxis against thrombosis. J Int Coll Surg. 1949;12(6):843-5. [pmid: 15398682].
Olwin JH, Koppel JL. Phleboembolism in orthopaedic trauma. Clin Orthop Relat Res. 1963;28:89-94. [pmid: 5889045].
Paciaroni M, Ageno W, Agnelli G. Prevention of venous thromboembolism after acute spinal cord injury with low-dose heparin or low-molecular-weight heparin. Thromb Haemost. 2008;99(5):978-80. [pmid: 18449438].
Paiement GD, Bell D, Wessinger SJ, Harris WH. The Otto Aufranc Award paper. New advances in the prevention, diagnosis, and cost effectiveness of venous thromboembolic disease in patients with total hip replacement. Hip. 1987:94-119. [pmid: 3102409].
Parra RO, Farber R, Feigl A. Pressure necrosis from intermittent-pneumatic-compression stockings. N Engl J Med. 1989;321(23):1615. [pmid: 2586562].
Peterson EA, Yenson PR, Liu D, Lee AWJ, Lee AY. Reasons for failure to remove inferior vena cava filters: Retrospective study in a tertiary care and trauma centre. Blood. 2011;118(21).
Petruska DA. Prophylactic anticoagulation in patients with traumatic brain injury. 2011;213(6):809.
Pettila V. Abnormal coagulation in critical care patients. Duodecim. 2004;120(14):1745-52. [pmid: 15497308].
Phillips S, Rogers B, Foote J. Rivaroxaban for thromboembolism prophylaxis after orthopaedic surgery…. Anaesthesia. Jun. 2010;65(6):552-5. [pmid: 20565391]. Anaesthesia. 2010;65(10):1043-4. [pmid: 21198472].
Piazza G, Goldhaber SZ. Acute pulmonary embolism: part II: treatment and prophylaxis. Circulation. 2006;114(3):e42-7. [pmid: 16847156].
Pokrovskaia EV. Novel antithrombotic drugs. From the 19th Congress of the International Society on Thrombosis and Haemostasis. Kardiologiia. 2004;44(3):70-4. [pmid: 15489831].
Popov-Cenic S. Directed preventive and therapeutic anticoagulant therapy in surgery. Med Klin. 1966;61(30):1186-9. [pmid: 5993139].
Potti A, Danielson B, Badreddine R, Ortel T. Potassium homeostasis in patients receiving prophylactic dose enoxaparin therapy [10]. J. Thromb. Haemost. 2004;2(7):1208-9. [pmid: 15219219].
Prevention of postoperative venous thrombosis. N Engl J Med. 1971;285(11):634-5.
Prevention of venous thrombosis after total hip replacement. N Engl J Med. 1984;310(14):927-8. [pmid: 6700686].
Prevention of venous thrombosis. Lancet. 1970;1(7643):395-6. [pmid: 4189693].
Pribyl T, Altschul J. Prevention of venous thromboembolism in orthopaedics (author's transl). Acta Chir Orthop Traumatol Cech. 1980;47(6):548-52. [pmid: 7211086].
Proceedings and abstracts of the 7th National Conference on Anticoagulant Therapy. San Francisco, California, USA. 8-10 May 2003. J Thromb Thrombolysis. 2003;16(1-2):5-109.
Prophylactic measures to reduce the risk of venous thromboembolism in bariatric surgery patients. Surg Obes Relat Dis. 2007;3(5):494-5. [pmid: 17903767].
Prophylaxis of venous thrombosis. Lancet. 1971;1(7690):121-2. [pmid: 4099612].
Raby C. Preventive anticoagulant therapy in surgery. Angeiologie. 1968;20(3):17-21. [pmid: 5744423].
Reich A, Bialynicki-Birula R, Szepietowski JC. Drug-induced subacute cutaneous lupus erythematosus resulting from ticlopidine. Int J Dermatol. 2006;45(9):1112-4. [pmid: 16961527].
Reinisch JF, Bresnick SD, Walker JW, Rosso RF. Deep venous thrombosis and pulmonary embolus after face lift: a study of incidence and prophylaxis. Plast Reconstr Surg. 2001;107(6):1570-5. discussion 1576-7. [pmid: 11335838].
Richard III H, Widlus DM, Scalea TM. Inferior vena cava filters in trauma: Balancing pulmonary embolism prevention with the risk of deep venous thrombosis. J. Trauma Inj. Infect. Crit. Care. 2010;69(4):1003.
Richardson J, Sabanathan S, Bergmann J-F, Segrestaa J-M, Caulin C, Lowe GDO. Prophylaxis against venous thromboembolism [3]. 1992;305(6862):1156.
Richardson JD, Cocanour CS, Kern JA, et al. Perioperative risk assessment in elderly and high-risk patients. J Am Coll Surg. 2004;199(1):133-46. [pmid: 15217641].
Roberts VC, Sabri S, Cotton LT. Prevention of deep-vein thrombosis. Lancet. 1971;2(7728):821. [pmid: 4106639].
Rocha E, Gomez-Outes A, Martinez Gonzalez J, Kakkar VV. Effect of unfractionated heparin and long-term treatment with low-molecular-weight heparin, bemiparin, on potassium levels. Thromb Haemost. 2005;94(5):1109-10. [pmid: 16363259].
Rodriguez A, Vallano A. Prophylaxis of venous thromboembolism in acutely ill medical patients. Med Clin (Barc). 2006;126(19):754-6. [pmid: 16759593].
Rowland CH, Woodford PA, De Lisle-Hammond J, Nair B. Heparin-induced thrombocytopenia-thrombosis syndrome and bilateral adrenal haemorrhage after prophylactic heparin use. Aust N Z J Med. 1999;29(5):741-2. [pmid: 10630659].
Saggau W, Encke A, Schmidt U. Prevention of thromboembolism using subcutaneous heparin. Chirurg. 1974;45(9):407-9. [pmid: 4425325].
Sajid MS, Desai M, Morris RW, Hamilton G. Knee length versus thigh length graduated compression stockings for prevention of deep vein thrombosis. Cochrane Database Syst. Rev. 2008;(2).
Sangwaiya MJ, Marentis TC, Walker TG, Stecker M, Wicky ST, Kalva SP. Safety and effectiveness of the celect inferior vena cava filter: preliminary results. J Vasc Interv Radiol. 2009;20(9):1188-92. [pmid: 19631561].
Sarani B, Chun A, Venbrux A. Role of optional (retrievable) IVC filters in surgical patients at risk for venous thromboembolic disease. J Am Coll Surg. 2005;201(6):957-64. [pmid: 16310701].
Sauvageon M, Lecoeur A, Levy R, Lebas-Certain M, Le Mercier F. Dabigatran etexilate: First step in its use in an orthopaedic surgery department. Int. J. Clin. Pharm. 2011;33(2):440.
Savel'ev VS. Postoperative venous thromboembolic complications: a fatal inevitability or a controllable danger?. Khirurgiia (Mosk). 1999;(6):60-3. [pmid: 10410521].
Scholz PM, Jones RH, Sabiston DC Jr. Prophylaxis of thromboembolism. Adv Surg. 1979;13:115-43. [pmid: 391002].
Sharnoff JG, DeBLASIO G. Some implications in the successful heparin prophylaxis of sudden cardiopulmonary arrest by thrombosis and embolism. Am Heart J. 1970;80(6):848-50. [pmid: 5477633].
Sharnoff JG. Heparin prophylaxis. Lancet. 1971;1(7700):650. [pmid: 4101259].
Sharnoff JG. Postoperative deep-vein thrombosis. Lancet. 1969;1(7601):946. [pmid: 4180927].
Sharnoff JG. Prevention of venous thrombosis. Lancet. 1970;1(7647):617. [pmid: 4190568].
Shelley OP, Weiler-Mithoff E. DIEP flap perforators and prophylaxis--X marks the spot. J Plast Reconstr Aesthet Surg. 2006;59(8):891. [pmid: 16876097].
Siemens HJ. Perioperative prophylaxis of thrombosis [2]: Perioperative thromboseprophylaxe. Gynakologe. 2002;35(2):195-6.
Siguret V, Pautas E, Gouin I. Low molecular weight heparin treatment in elderly subjects with or without renal insufficiency: New insights between June 2002 and March 2004. 2004;10:366-70.
Silver JR. Prophylactic anticoagulant therapy in the prevention of pulmonary emboli in patients with acute spinal injuries. Proc Veterans Adm Spinal Cord Inj Conf. 1971;18:184-8. [pmid: 5161625].
Sjalander A, Jansson JH, Bergqvist D, Eriksson H, Svensson P. Evidence for thrombosis prophylaxis to high-risk patients. Lakartidningen. 2007;104(20-21):1585-7. [pmid: 17564265].
Stroh C, Birk D, Flade-Kuthe R, et al. Evidence of thromboembolism prophylaxis in bariatric surgery-results of a quality assurance trial in bariatric surgery in Germany from 2005 to 2007 and review of the literature. Obes Surg. 2009;19(7):928-36. [pmid: 19415404].
Sturm V, Gruber UF. Prevention of postoperative thromboembolic complications. Hippokrates. 1977;48(1):52-61. [pmid: 845041].
Swann KW, Black PM. Deep vein thrombosis and pulmonary emboli in neurosurgical patients: a review. J Neurosurg. 1984;61(6):1055-62. [pmid: 6389785].
Taks AC, Duchateau AM, Janelli FI, Merkus FW. Letter: Postoperative thrombosis prevention with low doses of heparin administered subcutaneously. Ned Tijdschr Geneeskd. 1976;120(12):530-1. [pmid: 1250441].
Thies HA. Thrombosis prevention in surgery. Med Klin. 1970;65(46):2009-11. [pmid: 5521075].
Thies HA. Value and risks of general prophylaxis of thrombosis. Langenbecks Arch Klin Chir Ver Dtsch Z Chir. 1954;279:246-9. [pmid: 13234489].
Thomas S, Phillips P, Hughes G. CLOTS: an opportunity missed…. Lancet. Jun. 6. 2009;373(9679):1958-65. [pmid: 19477503]. Lancet. 2009;374(9696):1143-4. [pmid: 19801084].
Toker S, Hak DJ, Morgan SJ. Deep vein thrombosis prophylaxis in trauma patients. Thromb. 2011.
Tong LM. Ximelagatran-an oral direct thrombin inhibitor. Prog Cardiovasc Nurs. 2004;19(4):168-73. [pmid: 15539981].
Torras Barba J, Junca Piera J, Pales Argullos A, Duran Suarez JR, Monasterio Aspiri J, Triginer Boixeda J. Heparin prophylaxis and hypercoagulability in traumatology. Rev Clin Esp. 1981;163(5):319-21. [pmid: 7342189].
Trimble IR, Lynn DH. Elastic compression in the prophylaxis of postoperative thrombo-embolism; a critical study. Ann Surg. 1952;135(5):681-9. [pmid: 14924522].
Tseng CW, Huntington J. Enoxaparin for the prevention of VT in acutely ill patients. J Fam Pract. 1999;48(12):940-1. [pmid: 10628571].
Turpie A, Bauer K, Eriksson B, Lassen M. Superiority of fondaparinux over enoxaparin in preventing venous thromboembolism in major orthopedic surgery using different efficacy end points. CHEST. 2004;126(2):501-8. [pmid: 15302737].
Turpie AG. The American journal of cardiology. Thrombosis prophylaxis in the acutely ill medical patient: insights from the prophylaxis in MEDical patients with ENOXaparin (MEDENOX) trial. 2000;86:48M-52M.
Unstable angina: diagnosis and management. United States Department of Health and Human Services Public Health Service. 1994. (Clinical practice guideline; number 10.
Upchurch GR Jr, Demling RH, Davies J, Gates JD, Knox JB. Efficacy of subcutaneous heparin in prevention of venous thromboembolic events in trauma patients. Am Surg. 1995;61(9):749-55. [pmid: 7661468].
Vaitkus PT, Leizorovicz A, Goldhaber SZ. Rationale and design of a clinical trial of a low-molecular-weight heparin in preventing clinically important venous thromboembolism in medical patients: the prospective evaluation of dalteparin efficacy for prevention of venous thromboembolism in immobilized patients trial (the PREVENT study). Vasc Med. 2002;7(4):269-73. [pmid: 12710842].
Van Ha TG. Retrievable filters: Maximizing retrieval rates. Semin Roentgenol. 2011;46(2):154-8. [pmid: 21338840].
Vaziri K, Bhanot P, Hungness ES, Morasch MD, Prystowsky JB, Nagle AP. Retrievable inferior vena cava filters in high-risk patients undergoing bariatric surgery. Surg Endosc. 2009;23(10):2203-7. [pmid: 19184212].
Venous thromboembolic disease. Obstet Gynecol. 2004;104(4 Suppl):118S-27S. [pmid: 15458942].
Verstraete M. The prevention of deep vein thrombosis: De Preventie Van Diepe Veneuze Trombose. 1995;51(3):163-74.
Vincenzi B, Santini D, Avvisati G, Borzomati D, Tonini G. Enoxaparin effect depends on body-weight and current doses may be inadequate in obese patients. Br J Surg. 2003;90:547-548. [3]. 2003; 90(9):1165-6. [pmid: 12734859].
Warner GT, Perry CM. Enoxaparin: in the prevention of venous thromboembolism in medical patients. Am J Cardiovasc Drugs. 2001;1(6):477-81. discussion 483-4. [pmid: 14728009].
Warwick D. New concepts in orthopaedic thromboprophylaxis. J Bone Joint Surg Br. 2004;86(6):788-92. [pmid: 15330015].
Wasielewski S. Fewer thromboembolisms occurring with fondaparinux: Fewer thromboembolisms occurring with fondaparinux. Deutsche Apotheker-Zeitung (Germany). 2002;142:37-P2.
Watson N. Anti-coagulant therapy in the prevention of venous thrombosis and pulmonary embolism in the spinal cord injury. Paraplegia. 1978;16(3):265-9. [pmid: 733308].
Weber K, Zuckerman J, Watters W3, Turkelson C. Deep vein thrombosis prophylaxis. CHEST. 2009;136(6):1699-700. [pmid: 19995776].
Weitz J, Michelsen J, Gold K, Owen J, Carpenter D. Effects of intermittent pneumatic calf compression on postoperative thrombin and plasmin activity. Thromb Haemost. 1986;56(2):198-201. [pmid: 2949390].
White RH, Sadeghi B, Strater A, et al. Comparative effectiveness of low molecular weight heparin (LMWH) prophylaxis in morbidly obese and less obese patients undergoing total knee arthroplasty (TKA). J. Thromb. Haemost. 2011;9:412. [pmid: 21073652].
Wieberdink J. Preventive anticoagulation in surgery. Ned Tijdschr Geneeskd. 1965;109(47):2221-3. [pmid: 5848402].
Winslow KA, Hartmannsgruber MW, Chung JH, Perrino AC Jr. Combination of two standard pneumatic calf compression devices to fit the morbidly obese. Anesthesiology. 2000;93(4):1159. [pmid: 11020783].
Wolf F, Thurnher S, Lammer J. Simon nitinol vena cava filters: effectiveness and complications. Rofo. 2001;173(10):924-30. [pmid: 11588681].
Wolowacz SE, Roskell NS, Plumb JM, Caprini JA, Eriksson BI. Efficacy and safety of dabigatran etexilate for the prevention of venous thromboembolism following total hip or knee arthroplasty. A meta-analysis. Thromb Haemost. 2009;101(1):77-85. [pmid: 19132192].
Wu QH. Application of anticoagulating medicine after surgery of cavity of pelvis and abdomen. Zhonghua Wai Ke Za Zhi. 2006;44(19):1297-9. [pmid: 17217810].
Yett HS, Skillman JJ, Salzman EW. The hazards of aspirin plus heparin. N Engl J Med. 1978;298(19):1092. [pmid: 643024].
Zielinsky A, Hirsh J. Prevention of deep vein thrombosis and pulmonary thromboembolism. Medicina (B Aires). 1981;41(4):485-98. [pmid: 6175882].

## No Populations of Interest

Prevention of fatal pulmonary embolism with a low dose of heparin. Orv Hetil. 1976;117(2):92-4. [pmid: 1244597].
Abraham-Inpijn L. Preventive treatment of surgical patients with low dose heparin. Tijdschr Ziekenverpl. 1978;31(11):502-4. [pmid: 248253].
Acuna DL, Berg GM, Harrison BL, Wray T, Dorsch D, Sook C. Assessing the use of venous thromboembolism risk assessment profiles in the trauma population: is it necessary?. Am Surg. 2011;77(6):783-9. [pmid: 21679651].
Adams JT, Feingold BE, DeWeese JA. Comparative evaluation of ligation and partial interruption of the inferior vena cava. Arch Surg. 1971;103(2):272-6. [pmid: 4935098].
Aglietti P, Mendes DG, Salvati EA, Wilson PD Jr. Thromboembolic complications following total hip prosthesis. Study of 478 cases of relative efficacy of 3 preventive methods. Rev Chir Orthop Reparatrice Appar Mot. 1974;60(6):429-40. [pmid: 4282159].
Aidinian G, Fox CJ, White PW, Cox MW, Adams ED, Gillespie DL. Intravascular ultrasound--guided inferior vena cava filter placement in the military multitrauma patients: a single-center experience. Vasc Endovascular Surg. 2009;43(5):497-501. [pmid: 19640915].
Allemann BH, Gerber H, Gruber UF. Perispinal anesthesia and subcutaneous administration of low-dose heparin-dihydergot for prevention of thromboembolism. Anaesthesist. 1983;32(2):80-3. [pmid: 6189414].
Allen TL, Carter JL, Morris BJ, Harker CP, Stevens MH. Retrievable vena cava filters in trauma patients for high-risk prophylaxis and prevention of pulmonary embolism. Am J Surg. 2005;189(6):656-61. [pmid: 15910715].
Altintas F, Gurbuz H, Erdemli B, et al. Venous thromboembolism prophylaxis in major orthopaedic surgery: A multicenter, prospective, observational study. Acta Orthop Traumatol Turc. 2008;42(5):322-7. [pmid: 19158452].
Amendolara M, Perri S, Capellari F, Ciccia B, Battocchio F, Gelmi G. Surgical prophylaxis of pulmonary embolism using caval filters. Preliminary study: Profilassi chirurgica dell'embolia polmonare con l'impiego dei filtri cavali. Studio preliminare. 1997;10(3):236-40.
Amin A, Lin J, Ryan A. VTE Prophylaxis across the continuum of care in us orthopedic surgery patients. Blood. 2009;114(22).
Amin A, Varker H, Lin J, Thompson S, Johnston S. Duration of risk of venous thromboembolism in real-world U.S. patients hospitalized for medical illness. J. Hosp. Med. 2011;6(4):S5-S6.
Andrassy K, Salzmann W, Saggau W, Storch H, Ritz E. Is more heparin necessary for low-dose heparin prophylaxis in uremic patients?. Thromb Haemost. 1981;46(4):740-2. [pmid: 7330827].
Angelides NS. Prevention of deep vein thrombosis. From the surgical clinic of the Nicosia General Hospital. J Med Liban. 1974;27(3):305-12. [pmid: 4419746].
Anglen JO, Bagby C, George R. A randomized comparison of sequential-gradient calf compression with intermittent plantar compression for prevention of venous thrombosis in orthopedic trauma patients: preliminary results. Am J Orthop (Belle Mead NJ). 1998;27(1):53-8. [pmid: 9452837].
Antlitz AM, Valle NG, Kosai MF. The effect of prophylactic anticoagulant therapy on the incidence of postoperative pulmonary infarction. South Med J. 1968;61(3):307-10.
Arcangeli A, Rocca B, Salvatori G, Ciancia M, De Cristofaro R, Antonelli M. Heparin versus prostacyclin in continuous hemodiafiltration for acute renal failure: Effects on platelet function in the systemic circulation and across the filter. Thromb. Res. 2010;126(1):24-31. [pmid: 20185164].
Arcelus JI, Traverso CI, López-Cantarero M, et al. Prevention of postoperative deep vein thrombosis in general surgery. Comparative study of heparin at low-doses, dextran 70 and heparin dihydroergotamine. Cirugía Española. 1989;46(4):537-43.
Arnulf G. Value of postoperative thromboembolism prevention by anticoagulants (in 2,506 surgically treated cases). Lyon Chir. 1967;63(4):597-9. [pmid: 5613087].
Arochena L, Ruiz-Garcia M, Andregnette-Roscigno V, De Las Heras M. Delayed-type hypersensitivity to low molecular weight heparin. Allergy Eur. J. Allergy Clin. Immunol. 2009;64:287.
Azarbal AF, Rowell S, Lewis J, et al. Deep Venous Thrombosis (DVT) in critically ill trauma patients: There are no low-risk patients. J. Vasc. Surg. 2010;51(6):64S-5S.
Baille Y, Monties JR, Blanc T, et al. Surgery under heparin I. Prevention of early postoperative thrombosis by heparin (250 cases). Agressologie. 1968;9(5):625-33. [pmid: 5710179].
Bajardi G, Ricevuto G, Mastrandrea G, et al. Post-operative venous thromboembolism in bariatric surgery: le tromboembolie venose post-chirurgiche in chirurgia bariatrica. 1993;48:539-42.
Bakir N, Sluiter WJ, Ploeg RJ, van Son WJ, Tegzess AM. Primary renal graft thrombosis. Nephrol Dial Transplant. 1996;11(1):140-7. [pmid: 8649623].
Bakkevold K. Small subcutaneous doses of heparin in the prevention of venous thrombosis and pulmonary embolism in surgical patients. Tidsskr Nor Laegeforen. 1976;96(11):634-5. 629. [pmid: 1265720].
Balbir A, Odeh M, Atias D, Oliven A. Ticlopidine-induced neutropenia. Harefuah. 1996;130(12):822-4. 879. [pmid: 8885506].
Barata JD, Oliveira C, Bruges M, et al. Prevention of thrombogenesis in the extracorporeal circuit of hemodialysis with a low molecular heparin: standardization of the dosage with a better hemorrhagic risk/effectiveness ratio. Acta Med Port. 1992;5(2):65-70. [pmid: 1317657].
Barnett HG, Clifford JR, Llewellyn RC. Journal of Neurosurgery. Safety of mini-dose heparin administration for neurosurgical patients. 1977;47:27-30. [pmid: 864504].
Baroletti S, Labreche M, Niles M, Fanikos J, Goldhaber SZ. Prescription of fondaparinux in hospitalised patients. Thromb Haemost. 2009;101(6):1091-4. [pmid: 19492152].
Barsotti J, Benhamou AC, Guerois C, Gratteau B, Guilmot JL, Jolidon C. White clot syndrome. Arterial and venous thromboses during heparin therapy with thrombopenia after bone surgery. J Mal Vasc. 1983;8(2):139-42. [pmid: 6875393].
Basey AJ, Pradham S. Factors influencing appropriate prescription of venous thromboembolism prophylaxis for medical patients. Int. J. Pharm. Pract. 2010;18:6-7.
Bastos M, Caiafa JS, Moura LK, Raimundo S. A Brazilian registry establishing risk factors for venous thromboembolic events and use of thromboprophylaxis in hospitalized medical and surgical patients. 2001;98(11 PART I).
Becker HM. Pulmonary Embolism. Incidence And Preventive Measures At The Munich University Surgical Hospital. Munch Med Wochenschr. 1965;107:766-72. [pmid: 14331805].
Becker S, Schenk S, Ogon M. Thrombosis prophylaxis in spinal surgery: Thromboseprophylaxe bei wirbelsauleneingriffen. Wien. Klin. Wochenschr. Suppl. 2005;117(2):24-6.
Benko T, Cooke EA, McNally MA, Mollan RA. Graduated compression stockings: knee length or thigh length. Clin Orthop Relat Res. 2001;(383):197-203. [pmid: 11210954].
Berchtold R, Caplazi P, Wanger F. Prevention of thrombosis and embolism in surgical departments. Schweiz Med Wochenschr. 1966;96(48):1603-10. [pmid: 5973373].
Berges A, Laporte S, Epinat M, et al. Anti-factor Xa activity of enoxaparin administered at prophylactic dosage to patients over 75 years old. Br J Clin Pharmacol. 2007;64(4):428-38. [pmid: 17509040].
Bergqvist D, Efsing HO, Hallbook T, Lindblad B. Prevention of postoperative thromboembolic complications. A prospective comparison between dextran 70, dihydroergotamine heparin and a sulphated polysaccharide. Acta Chir Scand. 1980;146(8):559-68. [pmid: 6164204].
Bergqvist D, Frisell J, Hallbook T, et al. Swedish - Norwegian Multicenter trial: a randomized double blind study on the prevention of postoperative deep vein thrombosis (DVT) - Heparin fragment (fragmin) from the evening before surgery vs conventional low-dose heparin. Thrombosis Research. 1987;(Suppl VII):20. Abstract no: 16.
Bergqvist D. Intermittent thigh compression as prophylaxis against deep venous thrombosis. Lakartidningen. 1979;76(34):2790-2. [pmid: 529909].
Berland LL, Maddison FE, Bernhard VM. American Journal of Roentgenology. Radiologic follow-up of vena cava filter devices. 1980;134:1047-52. [pmid: 6768244].
Bern MM, Green J. Effect of sulfinpyrazone upon antithrombin III and platelet factor 4 in chronic renal failure. Thromb Res. 1982;27(4):457-65. [pmid: 7147215].
Best AJ, Williams S, Crozier A, Bhatt R, Gregg PJ, Hui AC. Graded compression stockings in elective orthopaedic surgery. An assessment of the in vivo performance of commercially available stockings in patients having hip and knee arthroplasty. J Bone Joint Surg Br. 2000;82(1):116-8. [pmid: 10697326].
Beyssac L. Analysis of thrombo-embolic complications in 14533 surgical operations. Results and failures of preventive treatment. Bull Soc Int Chir. 1968;27(1):64-7. [pmid: 5742747].
Bhatt SH. Evaluation of compliance with low dose unfractionated heparin for venous thromboembolism prophylaxis in medically ill hospitalized patients at an academic medical center. J. Thromb. Haemost. 2009;7(S2):1092. [pmid: 19422446].
Bianchini AU, Mehta SN, Mulder DS, Barkun AN, Mayrand S. American Journal of Gastroenterology. Duodenal perforation by a Greenfield filter: Endoscopic diagnosis. 1997;92:686-7. [pmid: 9128325].
Bischoff M. Thrombosis prevention: Low molecular weight heparins are also applicable in kidney failure: Thromboseprophylaxe: Niedermolekulare heparine auch bei niereninsuffizienz einsetzbar. Vasomed. 2012;24(2):109.
Bisler H, Alemany J, Holling H. Early and late results in the prevention of pulmonary embolism and caval patency after implantation of caval clips according to Adams--De Weese as compared to Mobin-Uddin umbrella filters (author's transl). Thoraxchir Vask Chir. 1978;26(3):164-8. [pmid: 675652].
Black J, Nagle CJ, Strachan CJ. Prophylactic low-dose heparin by jet injection. Br Med J. 1978;2(6130):95. [pmid: 667580].
Blaeser-Kiel G. Thrombosis prevention: Dabigatran capsule instead of heparin injection: Thromboseprophylaxe: Dabigatrankapsel statt heparinspritze. Dtsch. Arztebl. 2008;105(33):A1748.
Blumenthal JB. Use of low dose heparin in preventing venous thrombosis. J Med Assoc Ga. 1973;62(6):239-40. [pmid: 4715331].
Bonn J, Cho KJ, Cipolle M, et al. Journal of Vascular Surgery. Recommended reporting standards for vena caval filter placement and patient follow-up. 1999;30:573-9. [pmid: 10477662].
Borghi B, Bugamelli S, deSimone N, Montebugnoli M, Ferrari S. Indobufen and calcium heparin for the prevention of thromboembolism in hip prosthesis surgery in patients who have undergone hemodilution. Minerva Anestesiol. 1990;56(10):1117-20. [pmid: 2290518].
Borgstroem S, Greitz T, Van Der Linden W, Molin J, Rudics I. Anticoagulant Prophylaxis Of Venous Thrombosis In Patients With Fractured Neck Of The Femur; A Controlled Clinical Trial Using Venous Phlebography. Acta Chir Scand. 1965;129:500-8. [pmid: 14296582].
Borgstrom S. Postoperative anticoagulant prophylaxis of venous thrombosis with dicoumarol. Zentralbl Phlebol. 1967;6(1):30-5. [pmid: 4167216].
Boskovic S, Musa M, Popovic M, Bakovic S, Saracevic N. Our 2-year-long experience with systematic prevention of thromboembolytic postoperative complications in surgery. Med Pregl. 1973;26(7):227-32. [pmid: 4793056].
Bosson JL, Olinic D, Franco G, et al. Partial interruption of the inferior vena cava: ten-year evolution in protocols at Grenoble University Hospital. Study of 621 patients. Vasa. 1995;24(1):34-41. [pmid: 7725777].
Braakman R. Traumatic cross-sectional spinal cord injuries. Ned Tijdschr Geneeskd. 1976;120(41):1717-21. [pmid: 980133].
Bramham K, Varrier M, Asgari E, Makanjuola D. Comparison of Tinzaparin and unfractionated heparin as anticoagulation on haemodialysis: equal safety, efficacy and economical parity. Nephron Clin Pract. 2008;110(2):c107-13. [pmid: 18824874].
Brenner M, Bochicchio G, Bochicchio K, Scalea T. Inferior vena cava filters in spinal cord injury patients: Necessary or discretionary?. Crit. Care Med. 2010;38:A167.
Bret P, Lecuire J, Lapras C, Deruty R, Desgeorges M, Prudhon JL. Subdural hematoma and anticoagulant therapy. Neurochirurgie. 1976;22(6):603-20. [pmid: 67569].
Breyer HG, van-de LJ, Koppenhagen K, et al. Prevention of deep-vein thrombosis with LMW heparin (CY 216) in patients with elective total hip arthroplasty. Annals of Hematology. 1991;62(Suppl 1):A40.
Bromig G. Postoperative prevention of thromboembolism without anticoagulants. Zentralbl Chir. 1967;92(20):689-92. [pmid: 4967285].
Brophy DF, Martin EJ, Best AM, Gehr TWB, Carr ME. Journal of Thrombosis and Haemostasis. Antifactor Xa activity correlates to thrombin generation time, platelet contractile force and clot elastic modulus following ex vivo enoxaparin exposure in patients with and without renal dysfunction. 2004;2:1299-304. [pmid: 15304034].
Brunie V, Chardon S, Boursier V, et al. Evaluation of good heparin use in routine hospital practice. Pharm. World Sci. 2010;32(5):682.
Brunner U. Prevention of venous thrombosis in surgery of the lower limbs. Various phases of an experience in a general traumatology service. Phlebologie. 1984;37(1):41-7. [pmid: 6718503].
Burger T, Halloul Z, Tautenhahn J, Lippert H. Value of the vena cava filter in treatment of deep venous thrombosis in the pelvis and leg. Zentralbl Chir. 1999;124(1):32-6. [pmid: 10091295].
Burian R. PROLONG and SONIC study on orthopedic rehabilitation patients: Reduced thrombosis rate by prolonged postoperative prophylaxis with enoxaparin: PROLONG- und SONIC-studie an orthopadischen REHA-patienten: Thromboserate gesenkt durch verlangerte postoperative prophylaxe mit enoxaparin. Med. Welt. 2004;55(11-12):80-1.
Burian R. Thromboembolism prophylaxis with low molecular weight heparins in surgical patients: Adjustment of dose and duration in risky situations!: Thromboembolie-prophylaxe mit NMH bei operierten patienten: Dosierung und dauer der risikosituation anpassen!. Med. Welt. 2005;56(9):406-7.
Burkhardt H, Roll G. Combined prevention of thrombosis. Combination of anticoagulant therapy with preparations inhibiting platelet aggregation. Med Welt. 1974;25(19):867-9. [pmid: 4464446].
Burns GA, Cohn SM, Frumento RJ, Degutis LC, Hammers L. Prospective ultrasound evaluation of venous thrombosis in high-risk trauma patients. J Trauma. 1993;35(3):405-8. [pmid: 8371299].
Burns S. Duplex ultrasound screening…. Archives of Physical Medicine & Rehabilitation. 2000;81(2):242. [pmid: 10668785]. Powell M, Kirschblum S, O'Connor KC. Duplex ultrasound screening for deep vein thrombosis in spinal cord injured patients at rehabilitation admission. Arch Phys Med Rehabil. 1999;80:1044-6. [pmid: 10489006].
Busche MN, Herold C, Kramer R, Knobloch K, Vogt PM, Rennekampff HO. Evaluation of prophylactic anticoagulation, deep venous thrombosis, and heparin-induced thrombocytopenia in 21 burn centers in Germany, Austria, and Switzerland. Ann Plast Surg. 2011;67(1):17-24. [pmid: 21629067].
Byrne JJ. Prevention of pulmonary embolism. Am J Surg. 1968;116(3):396-402. [pmid: 5675909].
Cade JF, Mills KW, Gallus AS, Murphy W. Preventing venous thrombosis (VT) with heparin alone or with heparin/dihydroergotamine after elective hip replacement, a double-blind, randomised, venogram end-point comparison. Thrombosis and Haemostasis. 1987;58(1):240. Abstract no:. 888.
Cadroy Y, Pourrat J, Baladre MF, et al. Delayed elimination of enoxaparine in patients with chronic renal insufficiency. 1991;63:385-90.
Calfon M, Seddighzadeh A, Piazza G, Goldhaber SZ. Deep vein thrombosis in orthopedic surgery. Clin Appl Thromb Hemost. 2009;15(5):512-6. [pmid: 19491122].
Canaveira Manso L, Milheiro A, Castro E, Sousa F. Prophylaxis of post-operatory thromboembolism, randomized prospective study: Profilaxia da tromboembolia pos-operatoria. Estudio prospectivo randomizado. ACTA MED. PORT. 1996;9(2-3):87-90. [pmid: 8967308].
Carmody BJ, Sugerman HJ, Kellum JM, et al. Pulmonary embolism complicating bariatric surgery: detailed analysis of a single institution's 24-year experience. J Am Coll Surg. 2006;203(6):831-7. [pmid: 17116551].
Carson M, Kuo Y. Extended-duration venous thromboembolism prophylaxis for medical patients…. Ann Intern Med. Jul. 6. 2010;153(1):8-18. Annals of Internal Medicine 2010; 153(10):689. [pmid: 20621900].
Cerrato D, Ariano C, Fiacchino F. Journal of Neurosurgery. Deep vein thrombosis and low-dose heparin prophylaxis in neurosurgical patients. 1978;49:378-81. [pmid: 681999].
Chandra PA, Nwokolo C, Chuprun D, Chandra AB. Cardiac tamponade caused by fracture and migration of inferior vena cava filter. 2008;101:1163-4.
Chiche P, Dahan D, Dupuis R. Anticoagulant treatment and prevention of venous-pulmonary thromboembolic complications. Coeur Med Interne. 1978;17(4):605-14. [pmid: 738003].
Chopard P, D+-ªrffler-Melly J, Hess U, et al. Venous thromboembolism prophylaxis in acutely ill medical patients: Definite need for improvement. 2005;257:352-7.
Chopin J, Lobera A, Schach R, Nonnenmacher J. Fractures of the upper tibia and thromboembolic risk. Agressologie. 1976;17(1):59-66. [pmid: 962029].
Christensen SW, Wille-Jorgensen P, Bjerg-Nielsen A, Kjaer L. Prevention of deep venous thrombosis following total hip replacement, using epidural analgesia. Acta Orthop Belg. 1989;55(1):58-61. [pmid: 2801064].
Christiansen HM, Lassen MR, Borris LC, et al. Biologic tolerance of two different low molecular weight heparins. Semin Thromb Hemost. 1991;17(4):450-4. [pmid: 1666460].
Chylarecki C, Hierholzer G, Rudofsky G. Atroflow-Device: A New Concept In Physical Methods For Thrombosis Prophylaxis. First Results. Physikalische Thromboseprophylaxe Mit Motorisierten Sprunggelenkbewegungsschienen. Erste Ergebnisse Einer Klinischen Studie. Unfallchirurgie. 1995;21(3):137-47. [pmid: 7638926].
Cimochowski GE, Evans RH, Zarins CK. Journal of Thoracic and Cardiovascular Surgery. Greenfield filter versus Mobin-Uddin umbrella: The continuing quest for the ideal method of vena cava interruption. 1980;79:358-65. [pmid: 6986511].
Clagett GP, Anderson FA Jr, Geerts W, et al. Prevention of venous thromboembolism. 1998;114:531S-60S.
Clark WB, MacGregor AB, Prescott RJ, Ruckley CV. Prevention of early post-operative deep vein thrombosis by compression of the leg during and after operation. Vasa. 1974;3(2):148-52. [pmid: 4831538].
Cofrancesco E, Cortellaro M, Leonardi P, Corradi A, Ravasi F, Bertocchi F. Markers of hemostatic system activation during thromboprophylaxis with recombinant hirudin in total hip replacement. Thromb Haemost. 1996;75(3):407-11. [pmid: 8701398].
Cohen AT, Skinner JA, Warwick D, Brenkel I. The use of graduated compression stockings in association with fondaparinux in surgery of the hip. A multicentre, multinational, randomised, open-label, parallel-group comparative study. J Bone Joint Surg Br. 2007;89(7):887-92. [pmid: 17673580].
Cohen AT, Spiro TE, Buller HR, et al. Rivaroxaban versus enoxaparin for the prevention of venous thromboembolism in acutely ill medical patients: Analysis of factors contributing to benefit and risk in MAGELLAN. J. Thromb. Haemost. 2011;9:961.
Cohen T, Spiro T, Buller H, et al. The magellan study methodology: Rivaroxaban compared with enoxaparin for the prevention of venous thromboembolism in hospitalized medically ill patients. Haematologica. 2010;95:66-7.
Collins R, Coe N, Goldstein E, et al. External pneumatic compression of the legs to prevent venous thromboembolism in neurosurgical patients. Thrombosis Et Diathesis Haemorrhagica. 1977;196.
Colwell CW, Berkowitz SD, Davidson BL, et al. Randomized, double-blind, comparison of ximelagatran, an oral direct thrombin inhibitor, and enoxaparin to prevent venous thromboembolism (VTE) after total hip arthroplasty (THA). 2001;98(11 PART I):706a-7a.
Colwell CW Jr. Length of thrombosis prophylaxis after orthopaedic surgery of the lower extremity. 2004;19(4):300-2.
Comp PC, Spiro TE, Friedman RJ, et al. Prolonged enoxaparin therapy to prevent venous thromboembolism after primary hip or knee replacement. Enoxaparin Clinical Trial Group. J Bone Joint Surg Am. 2001;83-A(3):336-45. [pmid: 11263636].
Compression stockings prevent DVT, but not SVT. Pharm. J. 2005;274(7354):750.
Cook D, Attia J, Weaver B, McDonald E, Meade M, Crowther M. Venous thromboembolic disease: an observational study in medical-surgical intensive care unit patients. J Crit Care. 2000;15(4):127-32. [pmid: 11138871].
Cook DJ, Crowther MA, Meade MO, Douketis J. Prevalence, incidence, and risk factors for venous thromboembolism in medical-surgical intensive care unit patients. J. Crit. Care. 2005;20(4):309-13. [pmid: 16310600].
Corriere MA, Sauve KJ, Ayerdi J, et al. Vena cava filters and inferior vena cava thrombosis. J Vasc Surg. 2007;45(4):789-94. [pmid: 17398389].
Corriere MA, Suave KJ, Ayerdi J, et al. Vena cava filters and inferior vena cava thrombosis. 2007;45:789-94.
Couinaud C, Cerceau F, Goddio A. Preventive treatment of thrombo-embolism in general surgery. A report of 5 242 observations (author's transl). Sem Hop. 1980;56(15-16):732-7. [pmid: 6246607].
Crochet D, Petitier H, Ricco JB, et al. Journal de Radiologie. Efficacy of the new caval filter (LEM) in the prevention of pulmonary embolism. Preliminary results of a French multicenter study. 1988;69:431-6. [pmid: 3047374].
Crochet DP, Brunel P, Trogrlic S, Grosset+-¼te R, Auget JL, Dary C. Long-term follow-up of Vena TechLGM filter: Predictors and frequency of caval occlusion. 1999;10:137-42.
Dahl OE, Eriksson BI, Homering M, et al. The effect of patient age, gender and weight on the efficacy and safety of rivaroxaban (bay 59-7939) for the prevention of venous thromboembolism after major orthopaedic surgery. The Journal of Bone and Joint Surgery (Proceedings). 2009;91-B(SUPP_I):76-a.
Davenport A. Low-molecular-weight heparin for routine hemodialysis. Hemodial Int. Suppl 2. 2008;12:S34-7. [pmid: 18837768].
David W, Gross WS, Colaiuta E, Gonda R, Osher D, Lanuti S. Pulmonary embolus after vena cava filter placement. Am Surg. 1999;65(4):341-6. [pmid: 10190360].
Davidson JE, Willms DC, Hoffman MS. Effect of intermittent pneumatic leg compression on intracranial pressure in brain-injured patients. Crit Care Med. 1993;21(2):224-7. [pmid: 8428473].
De Gregorio MA, Gamboa P, Bonilla DL, et al. Retrieval of G++nther Tulip optional vena cava filters 30 days after implantation: A prospective clinical study. 2006;17:1781-9.
de la Caffiniere JY, Mignot M, Bruch JM. The dangerous blood clot in orthopaedic surgery (author's transl). Rev Chir Orthop Reparatrice Appar Mot. 1981;67(1):47-58. [pmid: 6453395].
Montrichard De, Verne JM. Combined prevention (anticoagulant and venomotor) of thromboembolism in general surgery. Mission and responsibility of the anesthetist-resuscitator. Simplified prevention without laboratory tests. Sem Hop Ther Paris. 1962;38:404-9. [pmid: 14475583].
Montrichard De, Verne JM. Mixed prevention (anticoagulants and venomotor) of thromboembolism in general surgery. Mission and responsibility of anesthetist-resuscitator. Simplified prevention without laboratory tests. Sem Hop. 1961;37:3412-7. [pmid: 14475584].
de Mourgues G, Pagnier F, Clermont N, Ville D, Moyen B. Efficacy of subcutaneous heparin used according to 2 protocols in the prevention of postoperative venous thrombosis after total hip prothesis. Rev Chir Orthop Reparatrice Appar Mot. Suppl 2. 1979;65:74-6. [pmid: 158800].
De Servi S, Lettino M. The TRITON-TIMI 38 trial. G Ital Cardiol (Rome). 2008;9(3):149-54. [pmid: 18422094].
Decousus H, Tapson VF, Bergmann J-F, et al. Factors at admission associated with bleeding risk in medical patients: Findings from the improve investigators. 2011;139(1):69-79.
Descuns P, Garre H, Ramee A, Thevenot C. Anticoagulants and neurosurgery. Ann Chir. 1961;15:147-50. [pmid: 13722164].
Dh te R, Pellicer-Coeuret M, Belouet-Moreau C, Christoforov B, Vidal-Trecan G. Venous thromboembolism in medical inpatients: prophylaxis with low-weight heparin in a university hospital and prevalence of thromboembolic events. Clin Appl Thromb Hemost. 2001;7(1):16-20. [pmid: 11190898].
Diehm N. Effective prevention of thromboembolisms after knee joint replacement surgery: Wirkungsvolle prophylaxe von thromboembolien nach kniegelenksersatz- operationen. MMW-Fortschr. Med. 2010;152(15):30.
Dieter RA Jr, Asselmeier GH, McCray RM. Surgery and anticoagulation therapy. IMJ Ill Med J. 1973;144(3):205-7. passim. [pmid: 4147261].
Doran FS, White M, Drury M. A clinical trial designed to test the relative value of two simple methods of reducing the risk of venous stasis in the lower limbs during surgical operations, the danger of thrombosis, and a subsequent pulmonary embolus, with a survey of the problem. Br J Surg. 1970;57(1):20-30. [pmid: 4189930].
Eberle H. Anticoagulant prophylaxis of thromboembolism in fractures of the pelvic area. Discussion. Hefte Unfallheilkd. 1968;97:64. [pmid: 5712851].
Elster BB, Eisenstadt HB. Prolonged anticoagulant therapy for ambulatory patients. Tex State J Med. 1952;48(1):14-8. [pmid: 14893226].
Enoxaparin in postoperative prophylaxis: Synthese Des Etudes De L'enoxaparine En Prevention Post-Operatoire. Les Derniers Jours De L'heparine Standard Sont-Ils Comptes?. Concours Med. 1991;113(15):1263-7.
Erdi A, Baranyai L. Incidence of pulmonary embolism at our clinic following introduction of heparin therapy by small subcutaneous doses. Orv Hetil. 1978;119(7):395-7. [pmid: 625413].
Eriksson BI, Bauer KA, Lassen MR, Turpie AG. Fondaparinux compared with enoxaparin for the prevention of venous thromboembolism after hip-fracture surgery. N Engl J Med. 2001;345(18):1298-304. [pmid: 11794148].
Eriksson BI, Lassen MR. Duration of prophylaxis against venous thromboembolism with fondaparinux after hip fracture surgery: a multicenter, randomized, placebo-controlled, double-blind study. Arch Intern Med. 2003;163(11):1337-42. [pmid: 12796070].
Falga C, Capdevila JA, Soler S, et al. Clinical outcome of patients with venous thromboembolism and renal insufficiency. Findings from the RIETE registry. 2007;98:771-6.
Famularo G, Gasbarrone L, Minisola G, De Simone C. Systemic bleeding in a patient with enoxaparin-induced thrombocytopenia. Am J Emerg Med. 2009;27(6):756.e1-2. [pmid: 19751647].
Fargen KM, Bhasin RR, Murad GJ. Abdominal craniectomy implantation and thromboembolism prophylaxis resulting in wound hematoma. Neurosurgery. 2010;67(2):495-7. [pmid: 20644438].
Fecher AM, O'Mara MS, Goldfarb IW, et al. Analysis of deep vein thrombosis in burn patients. Burns. 2004;30(6):591-3. [pmid: 15302428].
Feldkamp AM. Thrombosis prevention: One year assessment of first oral factor Xa inhibitor rivaroxaban: Thromboseprophylaxe: 1-Jahres-bilanz des ersten oralen faktor-Xa-inhibitors rivaroxaban. Klinikartz. 2009;38(11):516-7.
Ferguson REH, Critchfield A, LeClaire A, Ajkay N, Vasconez HC. Current practice of thromboprophylaxis in the burn population: A survey study of 84 US burn centers. 2005;31:964-6.
Ferrell A, Byrne TK, Robison G. Placement of inferior vena cava filters in bariatric surgical patients - Possible indications and technical considerations. 2004;14:738-43.
Fetzer E. Additional experiences in prophylaxia and therapy of thrombosis and embolism. Med Klin (Munich). 1952;47(20):686-7. [pmid: 14956627].
Fiessinger JN, Aiach M, Housset E. Heparin therapy at low doses in the prevention of surgical phlebitis. Rev Prat. 1975;25(59):4727-30. [pmid: 766145].
Filipecki S, Hajduk B, Tomkowski W. Prevention of pulmonary thromboembolism using inferior vena cava filters: Profilaktyka zatorowosci plucnej przy uzyciu filtrow wprowadzanych przezskornie do zyly glownej dolnej. Pneumonol Alergol Pol. 1994;62(3-4):127-31. [pmid: 8061636].
Flanc C, Kakkar VV, Clarke MB. Lancet. Postoperative deep-vein thrombosis. Effect of intensive prophylaxis. 1969;1:477-8. [pmid: 4179566].
Foley PJ, Nathan DP, Wang GJ, et al. A “fall-back” technique for difficult inferior vena cava filter retrieval. J Vasc Surg. 2012.
Forette B, Wolmark Y. Calcium nadroparin in the prevention of thromboembolic disease in elderly subjects. Study of tolerance. Presse Med. 1995;24(12):567-71. [pmid: 7770402].
Fossard DP, Corrigan T, Spindler JJ, Kakkar VV. Low doses of heparin in the prevention of postoperative D.V.T.--a double-blind trial. Br J Surg. 1972;59(11):914. [pmid: 4564762].
Francis CW, Berkowitz SD, Comp PC, et al. Comparison of ximelagatran with warfarin for the prevention of venous thromboembolism after total knee replacement. N Engl J Med. 2003;349(18):1703-12. [pmid: 14585938].
Francis CW, Pellegrini VD, Stulberg BN, McCollister Evarts C, Totterman S, Marder VJ. Antithrombin III/Low dose heparin versus dextran 40 in prevention of venous thrombosis following total knee arthroplasty. Thrombosis and Haemostasis. 1989;62(1):41.
Franco RDM, Simezo V, Bortoleti RR, et al. Venous thromboembolism prophylaxis at a teaching hospital: Profilaxia para tromboembolismo venoso em um hospital de ensino. J. Vasc. Bras. 2006;5(2):131-8.
Freeark RJ, Boswick J, Fardin R. Archives of Surgery. Posttraumatic venous thrombosis. 1967;95:567-75. [pmid: 5006628].
Fryburg K, Nguyen HS, Cohen-Gadol AA. Spontaneous acute subdural hematoma due to fondaparinux: Report of two cases. Surg Neurol Int. 2011;2:44. [pmid: 21660271].
Funk L, Cohen A, Woodcock N, Roy B, Bradley JG. Comparison of the efficacy and safety of the A-V impulse system with that of enoxaparin in the prophylaxis of deep venous thrombosis in total knee arthroplasty. Journal of Bone and Joint Surgery - British Volume. 2000;82(Suppl 1):62.
Fuochi C, Furlan F, Pellegrini M, Moser E, Dalla Palma F. Criteri dell'utilizzazione e indicazioni all'uso dei filtri endocavali definitivi e temporanei con durata breve e media Esperienza personale e revisione della letteratura: Criteria for use and indications for definitive and short- and mid-duration temporary endocaval filters. Personal experience and literature review. 1996;92:431-7.
Gadzhiev MG. Hemostatic indices in combined injuries of the head and thorax. Vestn Khir Im I I Grek. 1984;132(2):54-6. [pmid: 6719722].
Garcia-Ortega P, Asencio J. Dabigatran offers the simplest solution for thromboprophylaxis after orthopaedic surgery in patients allergic to low-molecular-weight heparins. Br J Haematol. 2010;151(1):84-5. [pmid: 20618326].
Gehrmann G. Neurologic complications in anticoagulant therapy. Med Welt. 1971;9:327-9. [pmid: 4101784].
Gergen M, Spenrath I, Wagner E. Nature and prevention of thromboembolism in accident surgery. Chirurg. 1968;39(8):366-8. [pmid: 4971310].
Gerosa C, Calvani AB, Cornelli U, et al. A multicenter study of defibrotide in the prevention of deep venous thrombosis. Final results. Minerva Chir. 1989;44(10):1507-16. [pmid: 2671797].
Giehl HJ. On pulmonary embolism--with a report on first experiences with subcutaneous heparin prophylaxis. Dtsch Gesundheitsw. 1967;22(39):1829-32. [pmid: 5600033].
Given MF, McDonald BC, Brookfield P, et al. Retrievable Gunther Tulip inferior vena cava filter: experience in 317 patients. J Med Imaging Radiat Oncol. 2008;52(5):452-7. [pmid: 19032390].
Goinard P, Pelissier G, Bernollin F. Our current practice of preventive anticoagulant therapy. Mem Acad Chir (Paris). 1961;87:486-91. [pmid: 13706341].
Goinard P, Thouverez JP, Belleville JF, Croizat P. An effective heparin treatment by subcutaneous route in general surgery. Lyon Chir. 1967;63(4):600-3. [pmid: 5613088].
Goldman KA, Adelman MA. Cardiovascular Surgery: Retroperitoneal caval filter as a source of abdominal pain. 1994;2:85-7.
Golob JF Jr, Sando MJ, Kan JC, Yowler CJ, Malangoni MA, Claridge JA. Therapeutic anticoagulation in the trauma patient: is it safe?. Surgery. 2008;144(4):591-6. discussion 596-7. [pmid: 18847643].
Gonzalez-Martin G, Diaz-Molinas MS, Martinez AM, Ortiz M. Heparin-induced hyperkalemia: a prospective study. Int J Clin Pharmacol Ther Toxicol. 1991;29(11):446-50. [pmid: 1800392].
Goudable C, Ton That H, Damani A. Thrombosis Research: Low molecular weight heparin half life is prolonged in haemodialysed patients. 1986;43:1-5.
Gouin-Thibault I, Liard F, Van-Ganse E, Vespa L, Gaudin A-F, Nachit-Ouinekh F. Comparison of platelet monitoring in patients receiving thromboprophylaxis with fondaparinux or a low molecular weight heparin. The Ariane study: Etude Ariane : comparaison de la surveillance plaquettaire chez des patients recevant une thromboprophylaxie par fondaparinux ou HBPM. Presse Med. 2011.
Grace DL. Prophylactic low-dose aspirin therapy in patients having hip-fracture surgery or elective arthroplasty. J Bone Joint Surg Am. 2001;83-A(8):1277-8. [pmid: 11507140].
Grandi A, Parodi JC, Rotondaro D, Soffer F, Alle E. Prevention of post-operative phlebothrombosis. Medicina (B Aires). 1979;39(3):379-83. [pmid: 514058].
Green B, Greenwood M, Saltissi D, et al. Dosing strategy for enoxaparin in patients with renal impairment presenting with acute coronary syndromes. 2005;59:281-90.
Green D, Sullivan S, Simpson J, Soltysik RC, Yarnold PR. Evolving risk for thromboembolism in spinal cord injury (SPIRATE Study). Am J Phys Med Rehabil. 2005;84(6):420-2. [pmid: 15905655].
Green L, Lawri AS, Patel S, et al. A comparison of rivaroxaban and fragmin prophylaxis after high risk orthopaedic surgery on thrombin generation test. Br. J. Haematol. 2010;149:13.
Greenfield LJ, Cho KJ, Pais SO, Aman MV. Archives of Surgery: Preliminary clinical experience with the titanium Greenfield vena caval filter. 1989;124:657-9.
Greenfield LJ, Proctor MC, Fischer DF Jr. Journal of Vascular Surgery. Suprarenal filter placement. 1998;28:432-8. [pmid: 9737452].
Greenfield LJ, Proctor MC, Rodriguez JL, Luchette FA, Cipolle MD, Cho J. Posttrauma thromboembolism prophylaxis. J Trauma. 1997;42(1):100-3. [pmid: 9003265].
Greep Jm, Martis Ee, Van Alkemadep, Prinsen Je. Thrombosis Prevention With Anticoagulants. Ned Tijdschr Geneeskd. 1963;107:2085-91. [pmid: 14097756].
Greinacher A, Lubenow N, Eichler P. Anaphylactic and anaphylactoid reactions associated with lepirudin in patients with heparin-induced thrombocytopenia. Circulation. 2003;108(17):2062-5. [pmid: 14568897].
Gruber UF, Allemann U, Wettler H. 1st direct comparison of allergic side effects of dextran with and without hapten. Schweiz Med Wochenschr. 1982;112(17):605-12. [pmid: 6178151].
Gruber UF, Brun M, Brunner R, et al. S.c. heparin or i.v. dextran?. Helv Chir Acta. 1979;46(1-2):65-8. [pmid: 468583].
Gruber UF, Hohl M, Sturm V. Intra- and postoperative prevention of thrombosis. Klin Anasthesiol Intensivther. 1975;9:17-35. [pmid: 1234606].
Gruber UF. Dextran and the prevention of postoperative thromboembolic complications. Surg Clin North Am. 1975;55(3):679-96. [pmid: 1169822].
Gunduz S, Ogur E, Mohur H, Somuncu I, Acjksoz E, Ustunsoz B. Deep vein thrombosis in spinal cord injured patients. Paraplegia. 1993;31(9):606-10. [pmid: 8247603].
Haas S, Breyer HG, Misselwitz F, Weber J, Viktor N. Prevention of severe venous thromboembolism in patients undergoing total hip or knee replacement. A randomised comparison of low molecular weight heparin (reviparin) with unfractionated heparin. The echos trial. Annals of Hematology. 2002;81:A26.
Hainer JW, Sherrard DJ, Swan SK, et al. American Journal of Kidney Diseases. Intravenous and subcutaneous weight-based dosing of the low molecular weight heparin tinzaparin (Innohep) in end-stage renal disease patients undergoing chronic hemodialysis. 2002;40:531-8. [pmid: 12200805].
Hakki SI, Fareed J, Hoppensteadt DA, et al. Plasma tissue factor pathway inhibitor levels as a marker for postoperative bleeding after enoxaparin use in deep vein thrombosis prophylaxis in orthopedics and general surgery. Clin Appl Thromb Hemost. 2000;6(4):206-12. [pmid: 11030526].
Hameed MF, Browse DJ, Immelman EJ, Goldberg PA. Should knee-length replace thigh-length graduated compression stockings in the prevention of deep-vein thrombosis?. S Afr J Surg. 2002;40(1):15-6. [pmid: 12082962].
Harenberg J, Roebruck P, Heinrich F, Schmitz-Huebner J, Heene DL. A randomized double blind trial of low molecular weight heparin for prophylaxis of thromboembolism in medical inpatients. Thrombosis and Haemostasis. 1993;69(6):648. Abstract no: 380.
Harenberg J, Schomaker U, Flosbach CW. Enoxaparin is superior to unfractionated heparin in the prevention of thromboembolic events in medical patients at increased thromboembolic risk. 1999:94.
Harries SR, Wells IP, Roobottom CA. Clinical Radiology. Long-term follow-up of the Antheor inferior vena cava filter. 1998;53:350-2. [pmid: 9630273].
Harter HR, Burch JW, Majerus PW, Stanford N, Delmez JA, et al. Prevention of thrombosis in patients on hemodialysis by low dose aspirin: Prevention of thrombosis in patients on hemodialysis by low dose aspirin. New England Journal of Medicine (USA). 1979;301:577-9.
Hauck W, Seyfert UT. Comparison of body-weight adapted LMWH and fixed dosed LMWH in the prevention of thrombosis after prosthetic knee replacement therapy. Annals of Hematology. 2001;80:A25.
Hauptfleisch J, Hawkins M, Bratby M, Anthony S, Uberoi R. Retrievability of IVC filters. Cardiovasc. Intervent. Radiol. 2010;33:308.
Hawkins SP, Al-Kutoubi A. Clinical Radiology. The Simon nitinol inferior vena cava filter: Preliminary experience in the UK. 1992;46:378-80. [pmid: 1493649].
Hedlund T, Bergqvist D, Efsing HO, Hallbook T. Thromboembolism after elective and post-traumatic hip surgery. A controlled prophylactic trial with dextran and low-dose heparin. Acta Orthopaedica Scandinavica. 1980;51:382-3.
Heffline MS. Preventing vascular complications after gastric bypass. J Vasc Nurs. 2006;24(2):50-4. quiz 55. [pmid: 16737930].
Heinzl S. Intensive care unit: Dalteparin versus unfractionated heparin in the thrombosis prevention: Intensivstation: Dalteparin versus unfraktioniertes heparin in der thromboseprophylaxe. Krankenhauspharmazie. 2011;32(7):420.
Heit JA, Elliott CG, Trowbridge AA, Morrey BF, Gent M, Hirsh J. Ardeparin sodium for extended out-of-hospital prophylaxis against venous thromboembolism after total hip or knee replacement. A randomized, double-blind, placebo-controlled trial. Ann Intern Med. 2000;132(11):853-61. [pmid: 10836911].
Heizmann M, Baerlocher GM, Steinmann F, Horber FF, Wuillemin WA. Anti-Xa activity in obese patients after double standard dose of nadroparin for prophylaxis. 2002;106:179-81.
Hergenroeder GW, Levine RL, Miller CC III. Thromboembolism prophylaxis in end-stage renal disease. 2008;37(11):439-44.
Hernandez-Vaquero D. The risk of thromboembolism in prosthetic surgery of the hip, and its prevention by administration of individualized heparin dosages. Acta Orthop Belg. 1990;56(2):445-50. [pmid: 2239191].
Herner SJ, Paulson DC, Delate T, Witt DM, Vondracek TG. Evaluation of venous thromboembolism risk following hospitalization. J Thromb Thrombolysis. 2011;32(1):32-9. [pmid: 21193946].
Hildebrandt G, Stintz AR. Prevention of thromboembolism in accident surgery. Zentralbl Chir. 1969;94(47):1605-9. [pmid: 5370643].
Hill SL, Berry RE, Ruiz AJ. Deep venous thrombosis in the trauma patient. Am Surg. 1994;60(6):405-8. [pmid: 8198328].
Hiromatsu S, Nata S, Ohno T, et al. Non-permanent inferior vena cava filters for prophylaxis and treatment of lower limb venous thromboembolism. Vasc Endovascular Surg. 2010;44(8):668-73. [pmid: 20724287].
Hirsch DR, Ingenito EP, Goldhaber SZ. Prevalence of deep venous thrombosis among patients in medical intensive care. JAMA. 1995;274(4):335-7. [pmid: 7609264].
Hirsh J, Warkentin TE, Raschke R, Granger C, Ohman EM, Dalen JE. Chest. Heparin and low-molecular-weight heparin: Mechanisms of action, Pharmacokinetics, dosing considerations, monitoring, efficacy, and safety. 1998;114:489S-510S. [pmid: 9822059].
Hitos K, Rogers J, Soo G, et al. A prospective study on venous thromboembolism following spinal surgery: Use of thromboprophylaxis and associated bleeding complications. J. Thromb. Haemost. 2011;9:399-400.
Hlavaty TS, McCowan TC, Ferris EJ, Carver DK, Harris DL, Barnes RW. The Journal of the Arkansas Medical Society. Experience with the Kimray-Greenfield inferior vena caval filter. 1991;88:215-7. [pmid: 1804837].
Hoffmann R, Kohler A, Platz A, et al. Prevention of deep vein thrombosis (DVT) in hip surgery: Low molecular weight heparin (sandoparin) versus 3 × 5000 I.U. UF- heparin. Thrombosis and Haemostasis. 1993;69(6):1055. Abstract no:. 1823.
Hoffmann R, Largiader F. Thromboembolism prophylaxis and the surgeon - Two risk factors of postoperative bleeding?: Die Thromboembolieprophylaxe Und Der Chirurg - Zwei Risikofaktoren Der Postoperativen Blutung?. 1995;30(5):264-70.
Holmgren E, Haglund G. Prevention of thrombosis using heparin in neurosurgical intervention. Lakartidningen. 1980;77(7):499-500. [pmid: 7374281].
Hoppe H, Kaufman JA, Barton RE, et al. Safety of inferior vena cava filter retrieval in anticoagulated patients. Chest. 2007;132(1):31-6. [pmid: 17505040].
Hory B, Cachoux A, Saunier F, et al. Comparative study of heparin and a very low molecular-weight heparin in hemodialysis in chronic renal insufficiency. Presse Med. 1987;16(19):955-8. [pmid: 2954145].
Howard DP. Acute thromboembolism in medical inpatients: the need for a focus on prevention rather than cure. Clin Med. 2006;6(1):117-8. [pmid: 16521369].
Huk M, Lynsky D, O'Cahaghan T, Campbei R. Compliance of sequential compression device for deep vein thrombosis prophylaxis in the adult trauma patient: Surgical intensive care unit vs. intermediate care. 1998;26(1 SUPPL.).
Hull R, Carter C, Turpie AG, et al. A randomized trial of sequential pneumatic limb compression in the prevention of venous thromboembolism following elective hip surgery [abstract no:0190]. Thrombosis and Haemostasis. 1983;50(1):66.
Hull RD, Raskob GE, Pineo GF, American-Canadian Orthopedic Clinical Trials Group. Low molecular weight heparin (logiparin) compared with less intense warfarin prophylaxis against venous thromboembolism following major elective hip surgery. Clinical Research. 1992;40(2):318A.
Hull RD, Schellong SM, Tapson VF. Extended-duration venous thromboembolism (VTE) prophylaxis in acutely ill medical patients with recent reduced mobility: The EXCLAIM study. 2007;5:O. S-001.
Hume M, Acuna H. Method of prevention of pulmonary embolism with an individual therapy for each patient. Angiologia. 1980;32(4):158-64. [pmid: 7396236].
Huo M, Eriksson B, Dahl O, et al. Oral dabigatran versus enoxaparin for thromboprophylaxis after primary total hip arthroplasty: The re-novate II randomised trial. Haematologica. 2010;95:233.
Iablokov EG, Savel'ev SV, Kirienko AI, Maliutina IG, Matiushenko AA. Results of intravenous filter inplantation. Vestn Khir Im I I Grek. 1980;124(5):3-7. [pmid: 7423757].
Insinger FG. Prophylactic use of anticoagulants. Ned Tijdschr Geneeskd. 1957;101(47):2240-2. [pmid: 13504292].
Jackson DR, Harrower HW. Pulmonary embolization following inferior vena caval interruption. Vasc Surg. 1969;3(3):129-37. [pmid: 4901052].
Jaff MR, Goldhaber SZ, Tapson VF. High utilization rate of vena cava filters in deep vein thrombosis. Thromb Haemost. 2005;93(6):1117-9. [pmid: 15968397].
Jaffe D, Noff M, Peer A, Chen D, Bass A, Halperin N. Prophylaxis against deep-vein thrombosis in total knee replacement: comparison of low molecular weight heparin and the A-V Impulse System. Journal of Bone and Joint Surgery British Volume. 1999;81(Suppl 1):71.
Jancar P, Morgan T, Mrhar A, Kosnik M, Lainscak M. Venous thromboembolism prophylaxis in hospitalized patients with pneumonia: a prospective survey. Wien Klin Wochenschr. 2009;121(9-10):318-23. [pmid: 19562294].
Jansen H. Postoperative thromboembolism and its prevention with 500 ml dextran given during operation with a special study of the venous flow pattern in the lower extremities. Acta Chir Scand Suppl. 1972;427:1-73. [pmid: 4118154].
Jaras Hernandez, Agudo de Blas P, Gonzalez Polo J, et al. Low Molecular Weight Heparin use in Internal Medicine hospitalized patients. An Med Interna. 2006;23(7):347-54. [pmid: 17067238].
Jenkins I, Helmons PJ, Martin-Armstrong LM, Montazeri ME, Renvall M. High rates of venous thromboembolism prophylaxis did not increase the incidence of heparin-induced thrombocytopenia. Jt Comm J Qual Patient Saf. 2011;37(4):163-9. [pmid: 21500716].
Jeske WP, Walenga JM, Samama MM, Hoppensteadt D, Mayuga M, Fareed J. Functionality of fondaparinux (pentasaccharide) depends on clinical antithrombin levels. Blood Coagul Fibrinolysis. 2011;22(3):206-10. [pmid: 21297455].
Johansson H, Nordlund S, Holmqvist B. Prevention of thrombosis with heparin administered subcutaneously. Nord Med. 1961;66:1108-12. [pmid: 13790192].
Johnson Iii ON, Gillespie DL, Aidinian G, White PW, Adams E, Fox CJ. The use of retrievable inferior vena cava filters in severely injured military trauma patients. 2009;49:410-6.
Johnson SP, Raiken DP, Grebe PJ, Diffin DC, Leyendecker JR. Journal of Vascular and Interventional Radiology. Single institution prospective evaluation of the over-the-wire greenfield vena caval filter. 1998;9:766-73. [pmid: 9756064].
Johow R. Favorable and untoward results in anticoagulant prophylaxis of thrombosis and embolism, with special reference to the use of dicumarol. Geburtshilfe Frauenheilkd. 1950;10(12):898-914. [pmid: 14802740].
Juhan-Vague I, Aillaud MF, Serradimigni A. Natural inhibitors of fibrinolysis. Haemostasis. Suppl 4. 1986;16:16-20.
Juliard J-M. Prevention of thromboembolism after orthopedic surgery: Apixaban versus enoxaparin: Prevention des evenements thrombo-emboliques apres chirurgie orthopedique: Apixaban versus enoxaparine. Sang Thromb. Vaiss. 2010;22(1):9-10.
Kaempffe FA, Lifeso RM, Meinking C. Intermittent pneumatic compression versus coumadin. Prevention of deep vein thrombosis in lower-extremity total joint arthroplasty. Clin Orthop Relat Res. 1991;269:89-97. [pmid: 1864061].
Kahn SR, Panju A, Geerts W, et al. Multicenter evaluation of the use of venous thromboembolism prophylaxis in acutely ill medical patients in Canada. 2007;119:145-55.
Kakkar VV, Field ES, Nicolaides AN. Prevention of postoperative deep-vein thrombosis using heparin. Br J Surg. 1971;58(11):872-3. [pmid: 5124909].
Kakkar VV. Low-doses of heparin in the prevention of deep vein thrombosis. Bull Schweiz Akad Med Wiss. 1973;29(4):235-43. [pmid: 4771352].
Kakkar VV. The logistic problems encountered in the multicenter trial of low-dose heparin prophylaxis. Thromb Haemost. 1979;41(1):105-13. [pmid: 384580].
Kalva SP, Chlapoutaki C, Wicky S, Greenfield AJ, Waltman AC, Athanasoulis CA. Suprarenal inferior vena cava filters: a 20-year single-center experience. J Vasc Interv Radiol. 2008;19(7):1041-7. [pmid: 18589318].
Kanan PS, Schwartsmann CR, Boschin LC, Conrad S, Silva MF. Comparative study between rivaroxaban and enoxaparin in deep venous thromboembolism prophylaxis in patients submitted to total hip arthroplasty. Revista Brasileira De Ortopedia. 2008;43(8):319-28.
Kanazirski P, Denchev V, Levcheva V. Anticoagulant prevention of postoperative thrombo-embolic complications. Suvr Med (Sofiia). 1961;12(4-5):87-95. [pmid: 14453539].
Kantor A, Glanz S, Gordon DH, Sclafani SJ. American Journal of Roentgenology. Percutaneous insertion of the Kimray-Greenfield filter: incidence of femoral vein thrombosis. 1987;149:1065-6. [pmid: 3499776].
Kaplan J, Marciniak C, Chen D. Retrospective study comparing the safety and efficacy of enoxaparin vs tinzaparin in the prevention of venous thromboembolic disorders during rehabilitation following acute SCI. J. Spinal Cord Med. 2009;32(4):466.
Kappa JR, Fisher CA, Berkowitz HD, Cottrell ED, Addonizio VP Jr. Heparin-induced platelet activation in sixteen surgical patients: diagnosis and management. J Vasc Surg. 1987;5(1):101-9. [pmid: 2432283].
Kastan DJ, Forcler NJ, Kahn ML. Simon nitinol vena cava filter: preliminary observations and suggested procedural modifications. J Vasc Interv Radiol. 1991;2(1):123-4. [pmid: 1799741].
Kazmers A, Ramnauth S, Williams M. American Surgeon. Intraoperative insertion of Greenfield filters: Lessons learned in a personal series of 152 cases. 2002;68:877-82. [pmid: 12412714].
Khatod M, Inacio MC, Bini SA, Paxton EW. Pulmonary Embolism Prophylaxis in More Than 30, 000 Total Knee Arthroplasty Patients: Is There a Best Choice?. J Arthroplasty. 2011.
Kiesewetter Wb, Shumacker Hb Jr. An experimental study of the comparative efficacy of heparin and dicumarol in the prevention of arterial and venous thrombosis. Surg Gynecol Obstet. 1948;86(6):687-702. [pmid: 18915940].
Kiguchi M, McDonald KA, Govindarajan S, Makaroun MS, Chaer RA. Pharmacomechanical thrombolysis for renal salvage after filter migration and renal vein thrombosis. J Vasc Surg. 2011;53(5):1391-3. [pmid: 21215557].
Kiil J, Kiil J, Axelsen F. Heparin in low dosage as prophylaxis of postoperative pulmonary embolism and deep venous thrombosis. Ugeskr Laeger. 1978;140(21):1224-30. [pmid: 351904].
Kiil J, Moller JC. Postoperative deep venous thrombosis in lower limbs and preventive value of heparin in low dosage evaluated by phlebography. Ugeskr Laeger. 1978;140(21):1221-4. [pmid: 664072].
Kim D, Edelman RR, Margolin CJ, et al. Angiology. The Simon nitinol filter: Evaluation by MR and ultrasound. 1992;43:541-8. [pmid: 1626731].
Kim HS, Young MJ, Narayan AK, Hong K, Liddell RP, Streiff MB. A Comparison of Clinical Outcomes with Retrievable and Permanent Inferior Vena Cava Filters. 2008;19:393-9.
Klein-Weigel P, Richter J, Arendt U, et al. Quality management in the prophylaxis of venous thrombembolism--results of a survey including 464 medical and surgical patients. Vasa. 2011;40(2):123-30. [pmid: 21500177].
Knezevic S. Role Of Anticoagulant Therapy In The Prevention Of Venous Thrombosis And Pulmonary Embolism. Med Glas. 1964;18:217-9. [pmid: 14271404].
KNIEPKAMP G. Experience in postoperative prevention and therapy of thromboembolism with special reference to the double test; Quick test and heparin tolerance test. Geburtshilfe Frauenheilkd. 1957;17(9):845-51. [pmid: 13474239].
Kock HJ, Schmitt-Neuerburg KP, Hanke J, Hakmann A, Althoff M, Rudofsky G. Prophylaxis of venous thromboembolism with low molecular weight heparin in surgical outpatients with immobilization of the lower limb by plaster cast. Hamostaseologie. 1993;13(Suppl):S36-S39.
Koller F. Clinical evaluation of anticoagulants. Internist (Berl). 1969;10(1):8-15. [pmid: 4906439].
Kosch L. Three years of experience with medicinal postoperative thrombosis prevention. Zentralbl Gynakol. 1957;79(31):1221-5. [pmid: 13486885].
Kostler H. Therapy and prophylaxis of thrombosis with a new anticoagulant of the heparin group. Med Klin (Munich). 1956;51(15):646-9. [pmid: 13347888].
Kovacic M, Pistotnik M, Grgcevic D, Krivec O, Radej M, Parazajder J. Prevention of postoperative thromboembolic disease. Lijec Vjesn. 1975;97(11):607-10. [pmid: 1226048].
Kretzschmar G. Hazards of postoperative prevention of thrombosis. Beitr Orthop Traumatol. 1966;13(12):813-4. [pmid: 5984253].
Krueger Bj, Cramer W. Fatal pulmonary artery embolism and anticoagulant prophylaxis. Bruns Beitr Klin Chir. 1961;203:453-61. [pmid: 14459885].
Kruse-Blinkenberg HO, Gormsen J. Heparin concentration in blood pre- and postoperatively in surgical patients with low dosage heparin prophylaxis. Ugeskr Laeger. 1976;138(12):745-7. [pmid: 1258194].
Ku-ìera T, Mal++ R, Urban K, +áponer P. Venous thromboembolism prophylaxis after total hip arthroplasty: Prevence tromboembolick+_ nemoci po implantaci tot+íln+¡ endoprot+_zy ky-ìeln+¡ho kloubu. 2011;78(2):101-5.
Kucher N, Koo S, Quiroz R, et al. Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med. 2005;352(10):969-77. [pmid: 15758007].
Kucher N. Clinical practice. Deep-vein thrombosis of the upper extremities. N Engl J Med. 2011;364(9):861-9. [pmid: 21366477].
Kudrnova Z, Kvasnicka J, Kudrna K, et al. Favorable coagulation profile with fondaparinux after hip surgery in elderly patients. Int J Hematol. 2009;90(4):476-82. [pmid: 19838769].
Kuo PC, Plotkin JS, Stevens S, Cribbs A, Johnson LB. Outcomes of laparoscopic donor nephrectomy in obese patients. Transplantation. 2000;69(1):180-2. [pmid: 10653400].
Kushelevskii BP, Seliverstova GP. Prolonged therapeutic-prophylactic use of anticoagulants. Klin Med (Mosk). 1973;51(4):26-8. [pmid: 4704262].
Kushelevskii Bp, Shmidt Ed. Significance of thrombosis and embolism in general hospital mortality and preventive role of anticoagulants. Klin Med (Mosk). 1958;36(5):22-8. [pmid: 13550677].
Labarere J, Bosson J-L, Pernod G. More on: Incorrect use of thromboprophylaxis for venous thromboembolism in medical and surgical patients: Results of a multicentric, observational, and cross-sectional study in Brazil. 2006;4(12):2737-8.
Lacut K, Delluc A, Vignon P, et al. Intermittent pneumatic compression to prevent venous thromboembolism in patients hospitalized in intensive medical care units with high risk of bleeding: A randomized trial. J. Thromb. Haemost. 2011;9:302-3. [pmid: 21781266].
Lahnborg G, Bergstrom K, Friman L, Lagergren H. Effect of low-dose heparin on incidence of postoperative pulmonary embolism detected by photoscanning. Lancet. 1974;1(7853):329-31. [pmid: 4131170].
Lai JM, Yablon SA, Ivanhoe CB. Incidence and sequelae of symptomatic venous thromboembolic disease among patients with traumatic brain injury. Brain Inj. 1997;11(5):331-4. [pmid: 9146838].
Lai S, Barbano B, Cianci R, et al. The risk of bleeding associated with low molecular weight heparin in patients with renal failure. G Ital Nefrol. 2010;27(6):649-54. [pmid: 21132647].
Lande M, Paulet C, Pras N, Martignon N. Postoperative preventive anticoagulant therapy. Apropos of 1200 cases. Phlebologie. 1975;28(1):107-15. [pmid: 1202518].
Lassen ML, Borris LC, Christiansen HM, et al. Low molecular weight heparin in the prevention of thromboembolism in elective total hip replacement. Thrombosis and Haemostasis. 1989;62(1):126.
Lassen MR, Dahl OE, Mismetti P, Destree D, Turpie AG. AVE5026, a new hemisynthetic ultra-low-molecular-weight heparin for the prevention of venous thromboembolism in patients after total knee replacement surgery--TREK: a dose-ranging study. J Thromb Haemost. 2009;7(4):566-72. [pmid: 19187076].
Lassen MR, Davidson BL, Gallus A, Pineo GF, Ansell J, Deitchman D. A phase II randomized, double-blind, five-arm, parallel-group, dose-response study of a new oral directly-acting factor Xa inhibitor, razaxaban, for the prevention of deep vein thrombosis in knee replacement surgery. Blood. 2003;102(11):15a. Abstract 41.
Lassen MR, Eriksson BI, Bauer KA, et al. Pentasaccharide (fondaparinux, Arixtra) versus enoxaparin for the prevention of venous thromboembolism (VTE) in major orthopedic surgery: subgroup analyses on efficacy. Blood. 2001;98:266a. [pmid: 11435292].
Lavrinovich TS, Petukhova LI, Slutskii LI. Clinical trial of indirect-action anticoagulants in orthopedics and traumatology. Ortop Travmatol Protez. 1976;3:32-5. [pmid: 790254].
Le Quesne LP, Bramble J, Gordon-Smith IC, Grundy D, Newcombe J. A trial of two different regimes of subcutaneous heparin in the prophylaxis of deep-vein thrombosis. Br J Surg. 1972;59(4):300. [pmid: 4553588].
Leclerc J, Geerts W, Desjardins L, Jobin F, Delorme F, Bourgouin J. A randomized trial of enoxaparin for the prevention of deep vein thrombosis after major knee surgery. Thrombosis and Haemostasis. 1991;65(6):753.
Leclerc JR, Geerts WH, Desjardins L, et al. Prevention of venous thromboembolism (VTE) after knee arthroplasty - a randomized, double-blind trial, comparing a low molecular weight heparin fragment (enoxaparin) to warfarin. Blood. 1994;84(Suppl 1):246a. Abstract no: 969.
Leclerc JR, Gent M, Hirsh DR. The incidence of symptomatic venous thromboembolism during and after prophylaxis with enoxaparin. 1998;127:439-45.
Lehmann J. Prevention of thromboembolism with a hirudoid ointment foam rubber bandage. Dtsch Med Wochenschr. 1954;79(41):1516-7. [pmid: 13220107].
Leizorovicz A. Comparison of two doses of low molecular weight heparin and standard low dose heparin in the prevention of post-operative vein thrombosis (DVT). Thrombosis and Haemostasis. 1989;62(1):521. Abstract no: 1641.
Lentine KL, Flavin KA, Gould MK. Chest. Variability in the use of thromboprophylaxis and outcomes in critically ill medical patients. 2002:122. [pmid: 12114347].
Lenzini PA, Grice GR, Milligan PE, et al. Laboratory and clinical outcomes of pharmacogenetic vs. clinical protocols for warfarin initiation in orthopedic patients. J Thromb Haemost. 2008;6(10):1655-62. [pmid: 18662264].
Lewalle J. Application in the surgical service of the postoperative prevention of thromboembolic accidents by means of anticoagulants. Acta Chir Belg. 1961;60:684-7. [pmid: 14464810].
Lidagoster MI, Widmann WD, Chevinsky AH. Journal of Vascular Surgery. Superior vena cava occlusion after filter insertion [3]. 1994;20:158-9. [pmid: 8028084].
Lie SA, Engesaeter LB, Havelin LI, Furnes O, Vollset SE. Early postoperative mortality after 67,548 total hip replacements: causes of death and thromboprophylaxis in 68 hospitals in Norway from 1987 to 1999. Acta Orthop Scand. 2002;73(4):392-9. [pmid: 12358110].
Lieberman DV, Lieberman D. Proximal deep vein thrombosis after hip fracture surgery in elderly patients despite thromboprophylaxis. Am J Phys Med Rehabil. 2002;81(10):745-50. [pmid: 12362114].
Lieberman JR, Huo MM, Hanway J, Salvati EA, Sculco TP, Sharrock NE. A comparison of pneumatic compression boots and aspirin versus aspirin alone in prevention of deep venous thrombosis after total hip arthroplasty: A randomized prospective trial [Abstract]. Orthopaedic Transactions. 1992;16(3):712-3.
Lingaas US, Storen EJ, Myhre HO. The practive of prophylactic anticoagulation in surgical patients. J Oslo City Hosp. 1972;22(7):109-17. [pmid: 5045731].
Looby S, Given MF, Geoghegan T, McErlean A, Lee MJ. Gunther Tulip retrievable inferior vena caval filters: Indications, efficacy, retrieval, and complications. 2007;30:59-65.
Looby S, Given MF, Geoghegan T, McErlean A, Lee MJ. Gunther Tulip retrievable inferior vena caval filters: indications, efficacy, retrieval, and complications. Cardiovasc Intervent Radiol. 2007;30(1):59-65. [pmid: 17122885].
Lorenz D, Reichold H. Prevention and therapy of postoperative thrombosis in the surgical hospitals of the German Federal Republic. Results of an inquiry. Med Klin. 1966;61(21):849-51. [pmid: 5988334].
Lotke PA, Callaghan JJ, Dorr LD, et al. Oral direct thrombin inhibitor ximelagatran compared with warfarin for the prevention of venous thromboembolism after total knee arthroplasty [9]. J. Bone Jt. Surg. Ser. A. 2006;88(5):1163.
Luders K, Konold P, Otten G, Koslowski L. Prevention of postoperative thromboembolism. Randomized, prospective study of the comparison of thromboembolism prevention using anticoagulants (Heparin-Marcumar) and dextran 60 (Macrodex). Chirurg. 1973;44(12):563-9. [pmid: 4594859].
Lund T. Routine measures in the prevention of postoperative thrombosis and embolism. Based on a multicentre trial of about 4000 patients with dextran or low-dose heparin prevention. Tidsskr Nor Laegeforen. 1980;100(22):1267-9. [pmid: 6160644].
Lynch FC. A method for following patients with retrievable inferior vena cava filters: results and lessons learned from the first 1,100 patients. J Vasc Interv Radiol. 2011;22(11):1507-12. [pmid: 21903414].
Lyon LJ, Nevins MA. Prevention of thromboembolism after hip fracture. Geriatrics. 1973;28(1):107-10. [pmid: 4566617].
Macouillard G, Castagnera L, Claverie JP, Janvier G, Maurette P. Prevention of deep venous thrombosis in spinal surgery: Comparison of intermittent sequential pneumatic compression versus low molecular weight heparin. Thrombosis and Haemostasis. 1993;69(6):646. Abstract no: 373.
Mahe I, Gouin-Thibault I, Drouet L, et al. Elderly medical patients treated with prophylactic dosages of enoxaparin: influence of renal function on anti-Xa activity level. Drugs Aging. 2007;24(1):63-71. [pmid: 17233548].
Mahlfeld K, Franke J, Schaeper O, Kayser R, Grasshoff H. Heparin-induced thrombocytopenia as a complication of postoperative prevention of thromboembolism with unfractionated heparin/low molecular weight heparin after hip and knee prosthesis implantation. Unfallchirurg. 2002;105(4):327-31. [pmid: 12066471].
Malinoski D, Ewing T, Patel MS, et al. Risk factors for venous thromboembolism in critically ill trauma patients who cannot receive chemical prophylaxis. Injury. 2011.
Malita IM, Cheveresan A, Dumitrascu V. Extended prophylaxis of venous thromboembolism, after hospital discharge, in Patients with knee arthroplasty. Basic Clin. Pharmacol. Toxicol. 2009;105:125.
Manktelow AR, Haddad FS, Powles DP. An unexpected complication of DVT prophylaxis. Acta Orthop Belg. 1997;63(2):134-5. [pmid: 9265802].
Mannucci PM, Citterio LE, Panajotopoulos N. Low-dose heparin and deep-vein thrombosis after total hip replacement. Thromb Haemost. 1976;36(1):157-64. [pmid: 1036806].
Marciniak CM, Kaplan J, Welty L, Chen D. Enoxaparin versus tinzaparin for venous thromboembolic prophylaxis during rehabilitation after acute spinal cord injury: a retrospective cohort study comparing safety and efficacy. PM R. 2012;4(1):11-7. [pmid: 22269449].
Maresch P. Prophylaxis of thromboembolism in orthopedics: Profylaxia tromboemb+¦lie v ortop+_dii. 2005;54(2):74-7.
Mariani F, Marone EM, Gasbarro V, et al. Multicenter randomized trial comparing compression with elastic stocking versus bandage after surgery for varicose veins. J Vasc Surg. 2011;53(1):115-22. [pmid: 21050700].
Markel DC, Morris GD. Effect of external sequential compression devices on femoral venous blood flow. J South Orthop Assoc. 2002;11(1):2-9. quiz 10. [pmid: 12741580].
Markwardt F. Prevention of thrombosis by means of toning of the veins. Folia Haematol Int Mag Klin Morphol Blutforsch. 1979;106(5-6):656-8. [pmid: 94860].
Marmor DB, Merli GJ, Whellan DJ, et al. Relationship of inferior vena cava filter usage in post-surgical patients by various surgical and medical subspecialists. Am J Cardiol. 2008;102(2):226-30. [pmid: 18602527].
Martyn DT, Janes JM. Continuous intravenous administration of heparin. Mayo Clin Proc. 1971;46(5):347-51. [pmid: 5578647].
Marx A, Huhle G, Hoffmann U, et al. Heparin-induced thrombocytopenia after elective hip joint replacement with postoperative prevention of thromboembolism with low-molecular-weight heparin. Z Orthop Ihre Grenzgeb. 1999;137(6):536-9. [pmid: 10666863].
Masekowitz B. Convincing study results of rivaroxaban for thrombosis prophylaxis: Thromboseprophylaxe: Rivaroxaban uberzeugt in studien. Pharm. Ztg. 2008;153(19):38.
Matis P, Mayer W, Nagel W. On the problem of occurrence of thromboembolism and hemorrhages during preventive inhibition of coagulation. Med Welt. 1961;37:1891-4. [pmid: 14471179].
Matis P. Results Of Alternate Anticoagulant Prophylaxis In Surgery. Acta Orthop Belg. 1962;28:582-7. [pmid: 13933675].
Mayer W. Prevention of thromboembolism in surgery. Results--problems. Thromb Diath Haemorrh Suppl. 1967;23:1-86. [pmid: 5602353].
McCarthy ST, Turner JJ, Robertson D, Hawkey CJ, Macey DJ. Low-dose heparin as a prophylaxis against deep-vein thrombosis after acute stroke. Lancet. 1977;2(8042):800-1. [pmid: 71605].
McDowall RAW. Pulmonary embolism and deep venous thrombosis in burned patients. 1973;26:176-7.
McKeown L. In hospitalized patients … LMWH cuts thromboembolism risk by 50%: In hospitalized patients … LMWH cuts thromboembolism risk by 50%. Pharmacy Practice News (USA). 2003;30:6.
Mehra A, Jadhav A, Lone N, et al. Gender variations in venous thromboembolism pharmacologic prophylaxis and clinical outcomes. Chest. 2010;138(4).
Melon E, Keravel Y, Gaston A, Huet Y, Combes S. Anesthesiology. Deep venous thrombosis prophylaxis by low molecular weight heparin in neurosurgical patients. 75.
Mesfin A, Lum YW, Nayfeh T, Mears SC. Compartment syndrome in patients with massive venous thrombosis after inferior vena cava filter placement. Orthopedics. 2011;34(3):229. [pmid: 21410121].
Messmer JM, Greenfield LJ. Radiology. Greenfield caval filters: Long-term radiographic follow-up study. 1985;156:613-8. [pmid: 4023218].
Meyer CS, Blebea J, Davis Jr K, Fowl RJ, Kempczinski RF. Annals of Vascular Surgery. Surveillance venous scans for deep venous thrombosis in multiple trauma patients. 1995;9:109-14. [pmid: 7703054].
Meyerowitz BR. Pulmonary embolism in surgical patients: is embolectomy superior to prophylaxis?. Surgery. 1966;60(3):521-35. [pmid: 5913774].
Milch E, Berman L, Egan Rw. Bishydroxycoumarin (Dicumarol) Prophylaxis. Use In The prevention of postoperative thromboembolic complications in surgical patients. Arch Surg. 1961;83:444-7. [pmid: 13770596].
Miller CL, Wechsler RJ. American Journal of Roentgenology. CT evaluation of Kimray-Greenfield filter complications. 1986;147:45-50. [pmid: 3487228].
Miller MT, Rovito PF. An approach to venous thromboembolism prophylaxis in laparoscopic Roux-en-Y gastric bypass surgery. Obes Surg. 2004;14(6):731-7. [pmid: 15318974].
Milone F, Iaccarino V, Musella M, et al. Interruption of the inferior vena cava in the prevention of pulmonary embolism. Chir Ital. 2005;57(4):479-84. [pmid: 16060186].
Mismetti P, Laporte-Simitsidis S, Tardy B, et al. Prevention of venous thromboembolism in internal medicine with unfractionated or low-molecular-weight heparins: A meta-analysis of randomised clinical trials. 2000;83:14-9.
Montesinos L, Gomez-Garrido A, Lluisa T-B, Lopez-F S, Angel G-VM, Ramirez L. Venous thromboembolism in patients with acute spinal cord injury. PM R. 2010;2(9):S172.
Montserrat I, Lopez D, Zuazu-Jausoro I, Perez M, de Moragas JM, Fontcuberta J. Low-molecular-weight subcutaneous heparin-induced skin necrosis. Blood Coagul Fibrinolysis. 1990;1(6):751-2. [pmid: 1966800].
Montserrat I, Oliver A, Zuazu-Jausoro I, et al. Clotting parameters and fibrinolysis variations in the prophylaxis with standard heparin and low-molecular-weight heparin in orthopedic surgery. Sangre. 1991;36(Suppl 2):122.
Monzo Abad E, Riesgo Benito MJ, Diaz-Penalver Merchan J. Measures and drugs used in preventing thromboembolic complications in postoperative and multiple injury patients. Rev Esp Anestesiol Reanim. 1983;30(3):119-23. [pmid: 6612047].
Moriniere P, Dieval J, Bayrou B, et al. Low-molecular-weight heparin Fraxiparin in chronic hemodialysis. A dose-finding study. Blood Purif. 1989;7(6):301-8. [pmid: 2558691].
Morishita H, Yamagami T, Matsumoto T, Takeuchi Y, Sato O, Nishimura T. Endovascular repair of a perforation of the vena caval wall caused by the retrieval of a Gunther Tulip filter after long-term implantation. Cardiovasc Intervent Radiol. Suppl 2. 2011;34:S321-3. [pmid: 21140262].
Morris CS, Rogers FB, Najarian KE, Bhave AD, Shackford SR. Current trends in vena caval filtration with the introduction of a retrievable filter at a level I trauma center. J Trauma. 2004;57(1):32-6. [pmid: 15284544].
Mosca S, Maselli A, Pozzilli P, et al. Comparison of Gunther, Filcard and LGM definitive caval filters. Our experience. Radiol Med. 1993;85(3):224-34. [pmid: 8493371].
Moser G, Krahenbuhl B, Donath A. Prevention of deep venous thrombosis (TVP) and pulmonary embolism. Comparison of heparin (3 × 5000 IU/day), heparin (2 × 5000 IU/day) + 0.5 mg dihydroergot, and physiotherapy (intermittent compression stockings + physical exercise). Value of Doppler diagnosis in systematic detection of TVP compared with phlebography and scanning of the legs using labelled fibrinogen. Helv Chir Acta. 1980;47(1-2):145-9. [pmid: 7440192].
Mourelo R, Kaidar-Person O, Fajnwaks P, et al. Hemorrhagic and thromboembolic complications after bariatric surgery in patients receiving chronic anticoagulation therapy. 2008;18:167-70.
Muckle DS, Forney HJ, Bentley G. The value of prophylactic anticoagulant therapy with warfarin after hip surgery. Acta Orthop Scand. 1974;45(3):412-20. [pmid: 4407250].
Muntz JE, O'Connor PJ, Yin H, Vogenberg FR. Factors associated with thromboprophylaxis for orthopedic patients and their impact on outcome. Am J Orthop (Belle Mead NJ). 2007;36(4):193-7. [pmid: 17515185].
Napolitano LM, Garlapati VS, Heard SO, et al. Asymptomatic deep venous thrombosis in the trauma patient: is an aggressive screening protocol justified?. J Trauma. 1995;39(4):651-7. discussion 657-9. [pmid: 7473949].
Nguyen NT, Cronan M, Braley S, Rivers R, Wolfe BM. Duplex ultrasound assessment of femoral venous flow during laparoscopic and open gastric bypass. 2003;17:285-90.
Niazi AU, Umer M, Umar M. Prophylaxis of DVT with enoxaparin in patients undergoing total knee replacement. J Pak Med Assoc. 2006;56(2):72-5. [pmid: 16555639].
Nicolaides AN, Kakkar VV, Field ES, Fish P. British Medical Journal. Optimal electrical stimulus for prevention of deep vein thrombosis. 1972;3:756-8. [pmid: 5077921].
Nienhaus K, Wenig C, Pfordt L, Taubert W, Meyer I, Wenzel E. Value of a new photometric method for the control of the efficacy of a low-dose heparin therapy. Verh Dtsch Ges Inn Med. 1978;84:1383-8. [pmid: 741973].
Nilsson PE, Bergqvist D, Benoni G, et al. The post-discharge prophylactic management of the orthopedic patient with low-molecular-weight heparin: enoxaparin. Orthopedics. 1997;20(Suppl):22-5. [pmid: 9048404].
Northup PG, McMahon MM, Ruhl AP, et al. Coagulopathy does not fully protect hospitalized cirrhosis patients from peripheral venous thromboembolism. 2006;101(7):1524-8.
Novicoff WM, Brown TE, Cui Q, Mihalko WM, Slone HS, Saleh KJ. Mandated venous thromboembolism prophylaxis: possible adverse outcomes. J Arthroplasty. 2008;23(6 Suppl 1):15-9. [pmid: 18555656].
Nowak W. Anticoagulants as therapeutic agents, or, on the prevention of thromboebolism in accident injuries. Z Arztl Fortbild (Jena). 1967;61(23):1233-5. [pmid: 5591393].
Nurmohamed MT, Verhaeghe R, Haas S, et al. Comparative trial of a low molecular weight heparin (enoxaparin) for the prophylaxis of postoperative deepvein thrombosis in general surgery. Thrombosis and Haemostasis. 1993;69(6):649. Abstract no: 384.
Nutescu EA, Shorr AF, Farrelly E, Horblyuk R, Happe LE, Franklin M. Burden of deep vein thrombosis in the outpatient setting following major orthopedic surgery. Ann Pharmacother. 2008;42(9):1216-21. [pmid: 18611992].
Oakley MJ, Wheelwright EF, James PJ. BJM. Pneumatic compression boots for prophylaxis against deep vein thrombosis: beware occult arterial disease. 1998;316:454-5.
O'Connor MB, Pokrovskaya O, Burns M, et al. Prevention of venous thromboembolic disease in medical and surgical hospital patients in a single university teaching hospital. 2011;180(1):303-4.
O'Malley KF, Ross SE. Journal of Trauma. Pulmonary embolism in major trauma patients. 1990;30:748-50. [pmid: 2352304].
Ongen G, Yilmaz A, Cirak AK, et al. Venous Thromboembolism Risk and Thromboprophylaxis Among Hospitalized Patients: Data From the Turkish Arm of the ENDORSE Study. Clin Appl Thromb Hemost. 2010.
Orsini RA, Jarrell BE. Suprarenal placement of vena caval filters: indications, techniques, and results. J Vasc Surg. 1984;1(1):124-35. [pmid: 6481860].
Ortiz Diaz-Miguel R, Sanchez Casado M, Pedrosa Guerrero A, et al. Prevention of venous thromboembolism in critical care patients with multiorganic failure: Are we using appropriate dosage?. Intensive Care Med. 2009;35:S161.
Otchy DP, Elliott BM. The malpositioned Greenfield filter: lessons learned. Am Surg. 1987;53(10):580-3. [pmid: 3674601].
Ottone MC, Semino G, Perotti GF. Incidence of thromboembolic complications in hip replacement surgery: Incidenza delle complicanze tromboemboliche nella chirurgia protesica dell'anca. MINERVA ORTOP. TRAUMATOL. 1997;48(1-2):25-30.
Paige JT, Gouda BP, Gaitor-Stampley V, et al. No correlation between anti-factor Xa levels, low-molecular-weight heparin, and bleeding after gastric bypass. Surg Obes Relat Dis. 2007;3(4):469-75. [pmid: 17567541].
Palareti G, Borghi B, Coccheri S, et al. Postoperative versus preoperative initiation of deep-vein thrombosis prophylaxis with a low-molecular-weight heparin (nadroparin) in elective hip replacement. Clinical and Applied Thrombosis/Hemostasis. 1996;2(1):18-24.
Pana C, Naftali Z, Gyongyosi M, et al. Prevention of postsurgical thromboembolism with small doses of heparin. Rev Chir Oncol Radiol O R L Oftalmol Stomatol Chir. 1978;27(6):421-6. [pmid: 752839].
Panfilo ADI, Cornette M. Echo doppler post total hip arthroplasty: Retrospective study of 111 patients at CHBAH: Etude r+_trospective de l'+_cho-doppler veineux dans 111 cas de proth+¿se totale de hanche op+_r+_s en 2001 au CHBAH. 2004;59(9):497-503.
Parkin E, Serracino-Inglott F, Chalmers N, Smyth V. Symptomatic perforation of a retrievable inferior vena cava filter after a dwell time of 5 years. J Vasc Surg. 2009;50(2):417-9. [pmid: 19631878].
Parra RO, Farber R, Feigl A. Pressure necrosis from intermittent-pneumatic-compression stockings. N Engl J Med. 1989;321(23):1615. [pmid: 2586562].
Passos R, Conceicnullao LF, Valente L, et al. Antithrombotic prophylaxis in critically ill patients with renal failure. Intensive Care Med. 2009;35:S153.
Patel R, Cook DJ, Meade MO, et al. Burden of illness in venous thromboembolism in critical care: a multicenter observational study. J Crit Care. 2005;20(4):341-7. [pmid: 16310605].
Payne K, Mehta U. Spinal/epidural haematomas associated with neuraxial anaesthesia in the presence of heparin and low-molecular-weight heparins. S Afr Med J. 2000;90(6):604. [pmid: 10918889].
Pearse EO, Caldwell BF, Lockwood RJ, Hollard J. Early mobilisation after conventional knee replacement may reduce the risk of postoperative venous thromboembolism. J Bone Joint Surg Br. 2007;89(3):316-22. [pmid: 17356141].
Peetz D, Hafner G, Hansen M, et al. Dose-adjusted thrombosis prophylaxis in trauma surgery according to levels of D-Dimer. Thromb Res. 2000;98(6):473-83. [pmid: 10899346].
Pellegrini VD Jr, Clement D, Lush-Ehmann C, Keller GS, Evarts CM. The John Charnley Award. Natural history of thromboembolic disease after total hip arthroplasty. Clin Orthop Relat Res. 1996;333:27-40. [pmid: 8981880].
Pelosio L, Marasco A, Puopolo G. Therapy and prevention of thromboembolic diseases: anticoagulants and fibrinolytics. Clin Ter. 1982;100(4):417-25. [pmid: 7044661].
Peng YG, Eikelboom JW, Tenni P, McQuillan A, Thom J. Renal Function, Peak Anti-Xa Levels and Enoxaparin Dosing. 2004;34:14-7.
Perez-Rada FJ, Cerda-Arteaga JM, Villanueva-Guzman E, Sanchez-Nava VM, Fernandez-Rangel E. Thromboembolic risk factors and thromboprophylaxis in a medical-surgical ICU in Mexico. Crit. Care. 2009;13:S179.
Pernod G, Sevestre M, Labarere J, et al. D-dimer and duration of anticoagulation…. New England Journal of Medicine. 2007;356(4):421-3. [pmid: 17251543]. Palareti G, Cosmi B, Legnani C, et al. D-Dimer testing to determine the duration of anticoagulation therapy. N Engl J Med. 2006;355:1780-9. [pmid: 17065639].
Perrin M. Skin necrosis as a complication of compression in the treatment of venous disease and in prevention of venous thromboembolism. Phlebolymphology. 2008;15(1):27-30.
Perry JN, Wells IP. A long term follow-up of Gunther vena caval filters. Clin Radiol. 1993;48(1):35-7. [pmid: 8370217].
Peters G, Whipple J, Eriksson U. Pharmacokinetics of H 376/95 (H): A novel oral direct thrombin inhibitor in patients undergoing total knee arthoplasty (TKA). 2001;69(2).
Petrov NS, Kotsiubinskii NN. Prevention of thromboses in severe mechanical injuries. Voen Med Zh. 1978;12:24-8. [pmid: 734955].
Pezzuoli G, Neri Serneri GG, Settembrini PG, et al. The use of low-molecular-weight heparin CY 216 in the prevention of fatal pulmonary embolism and thromboembolic death in general surgey. A multicentre, double-blind, randomized, controlled clinical trial versus placebo (STEP). Fraxiparine Second International Symposium Recent Pharmacological and Clinical Data. 1990:13-22.
Pidhorz L, Munafo-Dauccia R, Badatcheff F, Galland F. Prevention of thromboembolic complications during total hip arthroplasty by pre- and postoperative heparinotherapy with adapted doses. Apropos of 356 cases. Rev Chir Orthop Reparatrice Appar Mot. 1988;74(7):593-603. [pmid: 3241890].
Pierron RL. Prophylaxis of deep-vein thrombosis after total hip replacement. Dextran and external pneumatic compression compared with 1.2 or 0.3 grams of aspirin daily. J Bone Joint Surg Am. 1985;67(6):983. [pmid: 2410426].
Pini M, Aiello S, Manotti C, et al. Low molecular weight heparin versus warfarin in the prevention of recurrences after deep vein thrombosis. Thromb Haemost. 1994;72(2):191-7. [pmid: 7831650].
Planes A, Chastang C, Vochelle N, Desmichels D, Fiessinger JN, Clivarin Study Group. An equivalence study of two low-molecular-weight heparins (LMWH) in the prevention of deep vein thrombosis (DVT), after total hip replacement (THR) (440 patients). Thrombosis and Haemostasis. 1993;69(6):651. Abstract no: 394.
Planes A, Vochelle N, Mansat C. Prevention of deep vein thrombosis (DVT) after total hip replacement (THR) by enoxaparine (Lovenox): One daily injection of 40 mg versus two daily injections of 20 mg. Thrombosis and Haemostasis. 1987;58(1):117. Abstract no:. 415.
Politowski M, Janda R, Cencora A, Kleczynski S. Early prophylactic anticoagulant treatment after reconstructive operations on arteries and some associated problems. Pol Tyg Lek. 1970;25(22):807-10. [pmid: 5425428].
Polto F, Musumeci S, Vadala G, Morici V, Rizza G. Graduated and constant compression of the lower extremities in the prevention of postoperative deep venous thrombosis and of pulmonary thromboembolism. Clinical trial. Chir Ital. 1979;31(5):996-1007. [pmid: 396049].
Poniewierski M, Barthels M, Poliwoda H. The safety and efficacy of a low molecular weight heparin (fragmin) in the prevention of deep vein thrombosis in medical patients: a randomized double-blind trial. Thrombosis and Haemostasis. 1987;58(1):119. Abstract no:. 425.
Potron G, Seys A, Lardennois B. Mini-dose heparin therapy. Protocol for a preoperative prophylaxis of thrombophlebitis. Cah Med. 1973;14(3):219-23. [pmid: 4730893].
Pouzol P, Dechelette E, Jurkovitz C, Kuentz F, Polack B. Prevention of clotting with enoxaparin in extracorporeal circulation during haemodialysis. REV. MED. INTERNE. 1988;9(3):321-6. [pmid: 2841741].
Prandoni P, Bruchi O, Sabbion P, et al. Prolonged thromboprophylaxis with oral anticoagulants after total hip arthroplasty: a prospective controlled randomized study. Arch Intern Med. 2002;162(17):1966-71. [pmid: 12230419].
Prevention of postoperative pulmonary embolism by low doses of heparin. 1975;2:45-51.
Printen KJ, Miller EV, Mason EE, Barnes RW. Venous thromboembolism in the morbidly obese. Surg Gynecol Obstet. 1978;147(1):63-4. [pmid: 663811].
Proceedings and abstracts of the 7th National Conference on Anticoagulant Therapy. San Francisco, California, USA. 8-10 May 2003. J Thromb Thrombolysis. 2003;16(1-2):5-109.
Proctor MC, Greenfield LJ, Wakefield TW, Zajkowski PJ. A clinical comparison of pneumatic compression devices: the basis for selection?. J Vasc Surg. 2001;34(3):459-63. discussion 463-4. [pmid: 11533598].
Prophylaxis of venous thrombosis. Lancet. 1971;1(7690):121-2. [pmid: 4099612].
Pryor HI, Lin E, Singleton A, Vaziri K. High-risk bariatric venous thromboembolism prophylaxis practice patterns. Surg. Endosc. Interv. Tech. 2011;25:S244.
Raby C. Preventive anticoagulant therapy in surgery. Angeiologie. 1968;20(3):17-21. [pmid: 5744423].
Rader CP, Kramer C, Konig A, Gohlke F, Eulert J. Comparison between low-molecular and unfractionated heparin in the prevention of thrombosis in patients with total endoprosthetic replacement of hip and knee joint. Z Orthop Ihre Grenzgeb. 1997;135(1):52-7. [pmid: 9199074].
Ramchandani P, Koolpe HA, Zeit RM. American Journal of Roentgenology. Splaying of titanium Greenfield inferior vena caval filter. 1990;155:1103-4. [pmid: 2120943].
Rassler R. Postoperative anticoagulant prophylaxis; investigations of its effect on women with abnormal physical conditions, those with cardiovascular defects, and those with double diseases. Dtsch Gesundheitsw. 1955;10(44):1434-6. [pmid: 13277420].
Rebuck J, Makkar K, Prusch A, Walls J, Solski L. Minimizing adverse drug reactions related to enoxaparin therapy in high risk patients. Crit. Care Med. 2009;37(12):A423.
Reich A, Bialynicki-Birula R, Szepietowski JC. Drug-induced subacute cutaneous lupus erythematosus resulting from ticlopidine. Int J Dermatol. 2006;45(9):1112-4. [pmid: 16961527].
Reiertsen O, Larsen S, Storkson R, et al. Safety of enoxaparin and dextran-70 in the prevention of venous thromboembolism in digestive surgery. A play-the-winner-designed study. Scand J Gastroenterol. 1993;28(11):1015-20. [pmid: 7506841].
Rem J, Duckert F, Fridrich R, Gruber UF. Subkutane Kleine Heparindosen Zur Thromboseprophylaxe In Der Allgemeinen Chirurgie Und Urologie: Small doses of subcutaneous heparin for the prevention of thrombotic complications in general surgery and urology. 1975;105:827-35.
Remvig L, Mortensen SA, Als OS, Mentzel V, Holm G. Low-dose heparin therapy in the prevention of deep venous thrombosis in acute myocardial infarction. A controlled clinical trial. Ugeskr Laeger. 1983;145(14):1053-6. [pmid: 6346624].
Ribaudo JM, Hoellrich RG, McKinnon WM, Shuler SE. Evaluation of mini-dose heparin administration as a prophylaxis against postoperative pulmonary embolization: a prospective double-blind study. Rev Surg. 1975;32(4):297-9. [pmid: 1198038].
Ricco JB, Crochet D, Sebilotte P, et al. Annals of Vascular Surgery. Percutaneous transvenous caval interruption with the “LGM” filter: early results of a multicenter trial. 1988;2:242-7. [pmid: 3056484].
Richard III H, Widlus DM, Scalea TM. Inferior vena cava filters in trauma: Balancing pulmonary embolism prevention with the risk of deep venous thrombosis. J. Trauma Inj. Infect. Crit. Care. 2010;69(4):1003.
Richenbacher WE, Atnip RG, Campbell DB, Waldhausen JA. World Journal of Surgery. Recurrent pulmonary embolism after inferior vena caval interruption with a Greenfield filter. 1989;13:623-9. [pmid: 2815806].
Riess H, Haas S, Tebbe U, et al. CERTIFY - Certoparin versus UFH to prevent venous thromboembolic events in acutely ill, hospitalized, medical patients: A randomized, double-blind, multicentre study. Onkologie. 2010;33(6):51-2.
Rimaud D, Boissier C, Calmels P. Evaluation of the effects of compression stockings using venous plethysmography in persons with spinal cord injury. J Spinal Cord Med. 2008;31(2):202-7. [pmid: 18581669].
Rimon U, Bensaid P, Golan G, et al. Optease vena cava filter optimal indwelling time and retrievability. Cardiovasc Intervent Radiol. 2011;34(3):532-5. [pmid: 20556385].
Riou B, Rothmann C, Lecoules N, et al. Incidence and risk factors for venous thromboembolism in patients with nonsurgical isolated lower limb injuries. Am J Emerg Med. 2007;25(5):502-8. [pmid: 17543652].
Robinson S, Zincuk A, Toft P. Enoxaparin: Effective dosage for ICU patients. Acta Anaesthesiol. Scand. Suppl. 2009;53(119):72-3.
Rocha AT, Araujo DM, Cardoso DNR, Pereira A, Messeder O. Improving evaluation of risk factors for venous thromboembolism and use of prophylaxis in medical intensive care patients. Chest. 2009;136(4).
Rocha E, Gomez-Outes A, Martinez Gonzalez J, Kakkar VV. Effect of unfractionated heparin and long-term treatment with low-molecular-weight heparin, bemiparin, on potassium levels. Thromb Haemost. 2005;94(5):1109-10. [pmid: 16363259].
Roehm Jr JOF, Johnsrude IS, Barth MH, Gianturco C. Radiology. The bird's nest inferior vena cava filter: Progress report. 1988;168:745-9. [pmid: 3043548].
Rosner MK, Kuklo TR, Tawk R, Moquin R, Ondra SL. Prophylactic placement of an inferior vena cava filter in high-risk patients undergoing spinal reconstruction. Neurosurg Focus. 2004;17(4):E6. [pmid: 15633992].
Rothberg MB, Lahti M, Pekow PS, Lindenauer PK. Venous thromboembolism prophylaxis among medical patients at US hospitals. J Gen Intern Med. 2010;25(6):489-94. [pmid: 20352366].
Sabry A, Taha M, Nada M, Al Fawzan F, Alsaran K. Anticoagulation therapy during haemodialysis: a comparative study between two heparin regimens. Blood Coagul Fibrinolysis. 2009;20(1):57-62. [pmid: 20523166].
Saggau W, Encke A, Schmidt U. Prevention of thromboembolism using subcutaneous heparin. Chirurg. 1974;45(9):407-9. [pmid: 4425325].
Salem M, Elrefai S, Shrit MA, Warkentin TE. Fondaparinux thromboprophylaxis-associated heparin-induced thrombocytopenia syndrome complicated by arterial thrombotic stroke. Thromb Haemost. 2010;104(5):1071-2. [pmid: 20806120].
Saltissi D, Morgan C, Westhuyzen J, Healy H. Nephrology Dialysis Transplantation. Comparison of low-molecular-weight heparin (enoxaparin sodium) and standard unfractionated heparin for haemodialysis anticoagulation. 1999;14:2698-703.
Sanchez-Ballester J, Smith M, Hassan K, Kershaw S, Elsworth CS, Jacobs L. Wound infection in the management of hip fractures: a comparison between low-molecular weight heparin and mechanical prophylaxis. Acta Orthop Belg. 2005;71(1):55-9. [pmid: 15792208].
Sandor T, Laszlo E, Magyary F, et al. Prophylaxis of postoperative thromboembolism with heparin-dihydroergotamine combination. Phlebology. 1986;1:57-64.
Sarich TC, Teng R, Peters GR, et al. No influence of obesity on the pharmacokinetics and pharmacodynamics of melagatran, the active form of the oral direct thrombin inhibitor ximelagatran. Clin Pharmacokinet. 2003;42(5):485-92. [pmid: 12739986].
Sato DT, Robinson KD, Gregory RT, et al. Duplex directed caval filter insertion in multi-trauma and critically ill patients. 1999;13:365-71.
Saturno PJ, Gama ZA, Fonseca YA. Prevention of venous thromboembolism and safe use of heparin in Spanish hospitals. Int J Qual Health Care. 2011;23(2):117-25. [pmid: 21242163].
Sauvageon M, Lecoeur A, Levy R, Lebas-Certain M, Le Mercier F. Dabigatran etexilate: First step in its use in an orthopaedic surgery department. Int. J. Clin. Pharm. 2011;33(2):440.
Scannapieco G, Ageno W, Airoldi A, et al. Incidence and predictors of venous thromboembolism in post-acute care patients. A prospective cohort study. Thromb Haemost. 2010;104(4):734-40. [pmid: 20664897].
Schadenbock R, Schlag G. Anticoagulant prophylaxis of thromboembolism in fractures of the pelvic area. Hefte Unfallheilkd. 1968;97:60-3. [pmid: 5712849].
Schanzer H, Schanzer A. Guidewire entrapment during deployment of the over-the-guidewire stainless steel Greenfield filter: a device design-related complication. J Vasc Surg. 2000;31(3):607-10. [pmid: 10709077].
Scharpff E, Seitz R. Extended thrombo-embolic prophylaxis with anticoagulants in internal medicine. Medizinische. 1955:27-8. 976. 9.
Schleich JM, Laurent M, Le Helloco A, Langella B, Ramee A, Almange C. American Journal of Roentgenology. Short-term follow-up of inferior vena caval filters: Comparison of imaging techniques. 1993;161:799-803. [pmid: 8372763].
Schmidt Wj. Not Available. Ned Tijdschr Geneeskd. 1956;100(28):1968-76. [pmid: 13369606].
Schneider PA, Geissbuhler P, Piguet JC, Bounameaux H. Follow-up after partial interruption of the vena cava with the Gunther filter. Cardiovasc Intervent Radiol. 1990;13(6):378-80. [pmid: 2126997].
Scholz PM, Jones RH, Sabiston DC Jr. Prophylaxis of thromboembolism. Adv Surg. 1979;13:115-43. [pmid: 391002].
Schondorf TH. Thrombosis prevention with heparin and acetylsalicylic acid in elective hip joint surgery. Med Welt. 1979;30(5):170-3. [pmid: 759806].
Schreiber B, Dvorak V, Novotny A. Use Of A Point System In The Prevention Of Thromboembolic Disease. Cas Lek Cesk. 1963;102:951-5. [pmid: 14051526].
Schuerer DJ, Whinney RR, Freeman BD, et al. Evaluation of the applicability, efficacy, and safety of a thromboembolic event prophylaxis guideline designed for quality improvement of the traumatically injured patient. J Trauma. 2005;58(4):731-9. [pmid: 15824649].
Schwartsmann CR, Cavalieri Costa R, Drumond SN, et al. Randomized, comparative, open study to assess the efficacy and safety of enoxaparin compared with unfractionated heparin in the prophylaxis of venous thromboembolism in patients undergoing total hip arthroplasty: Estudo aberto, randomizado, comparativo, para avaliar a eficacia e seguranca da enoxaparina comparada a heparina nao fracionada na profilaxia do trombembolismo venoso em pacientes submetidos a artroplastia total do quadril. REV. BRAS. ORTOP. 1996;31(10):797-808.
Scott JR, Klein MB, Gernsheimer T, Honari S, Gibbons J, Gibran NS. Arterial and venous complications of heparin-induced thrombocytopenia in burn patients. J Burn Care Res. 2007;28(1):71-5. [pmid: 17211203].
Scurr JH, Robbe IJ, Ellis H, Goldsmith HS. Simple mechanical method for decreasing the incidence of thromboembolism. Am J Surg. 1981;141(5):582-5. [pmid: 7223954].
Segesser D, Gruber UF. Efficacy of sodium heparin as compared to calcium heparin for preventing thromboembolic complications. Arzneimittelforschung. 1977;27(11):2157-63. [pmid: 580021].
Sellier E, Labarere J, Bosson JL, et al. Effectiveness of a guideline for venous thromboembolism prophylaxis in elderly post-acute care patients: a multicenter study with systematic ultrasonographic examination. Arch Intern Med. 2006;166(19):2065-71. [pmid: 17060535].
Sevitt S, Gallagher N. Venous thrombosis and pulmonary embolism. A clinico-pathological study in injured and burned patients. 1961;48:475-89.
Sharnoff JG, De Blasio G, Breen SR, Tucci P. Pulmonary thromboembolism; prevention of fatal postoperative. Med Trial Tech Q. 1970;16(4):63-9. [pmid: 5425125].
Sharnoff Jg, Kass Hh, Mistica Ba. A plan of heparinization of the surgical patient to prevent postoperative thromboembolism. Surg Gynecol Obstet. 1962;115:75-9. [pmid: 13911387].
Sharnoff Jg. A Plan Of Heparinization Of The Surgical Patient For The Successful Prevention Of Thromboembolism. R I Med J. 1963;46:651. [pmid: 14086306].
Sharnoff JG. Prevention of venous thrombosis. Lancet. 1970;1(7647):617. [pmid: 4190568].
Sharpe RP, Gupta R, Gracias VH, et al. Journal of Trauma - Injury, Infection and Critical Care. Incidence and natural history of below-knee deep venous thrombosis in high-risk trauma patients. 2002;53:1048-52.
Shelley OP, Weiler-Mithoff E. DIEP flap perforators and prophylaxis--X marks the spot. J Plast Reconstr Aesthet Surg. 2006;59(8):891. [pmid: 16876097].
Sher MH. Complications in the application of the inferior vena cava umbrella technique. Arch Surg. 1971;103(6):688-90. [pmid: 5120193].
Siemens HJ. Perioperative prophylaxis of thrombosis [2]: Perioperative thromboseprophylaxe. Gynakologe. 2002;35(2):195-6.
Siguret V, Pautas E, Gouin I. Low molecular weight heparin treatment in elderly subjects with or without renal insufficiency: New insights between June 2002 and March 2004. 2004;10:366-70.
Silbernagel G, Brechtel K, Strolin A, Balletshofer B. Infrarenal implantation of vena cava filters: two case reports. Dtsch Med Wochenschr. 2010;135(50):2539. [pmid: 21154194].
Silver JR, Morris WR, Otfinowski JS. Associated injuries in patients with spinal injury. Injury. 1980;12(3):219-24. [pmid: 7228385].
Simon M, Athanasoulis CA, Kim D, et al. Radiology. Simon nitinol inferior vena cava filter: Initial clinical experience. Work in progress. 1989;172:99-103. [pmid: 2662259].
Simpson HK, Baird J, Allison M, et al. Long-term use of the low molecular weight heparin tinzaparin in haemodialysis. Haemostasis. 1996;26(2):90-7. [pmid: 9119288].
Smith JA, Atkinson NR, Walters NA, Thomson KR. Medical Journal of Australia. Early experience with the bird's nest inferior vena-caval filter. 1989;150:164-5. [pmid: 2716589].
Spencer FA, Gore JM, Lessard D, et al. Thrombosis and Haemostasis. Venous thromboembolism in the elderly a community-based perspective. 2008;100:780-8. [pmid: 18989521].
Spieler U, Preter B, Brunner U. Prevention of thromboses in lower leg fractures. Helv Chir Acta. 1972;39(5):679-83. [pmid: 4652328].
Spiro TE, Colwell CW, Bona RD, et al. A clinical trial comparing the efficacy and safety of enoxaparin a low molecular weight heparin and unfractionated heparin for the prevention of deep venous thrombosis after elective knee replacement surgery. Blood. 1993;82(10 Suppl 1):410a.
Spiro TE. A randomized, trial of enoxaparin administered post operatively for the prevention of deep vein thrombosis following elective hip replacement surgery. Thrombosis and Haemostasis. 1991;65(6):927.
Spivack S, Kalker E, Samuels D, Orron DE. Filter placement in duplicated inferior vena cava. Isr Med Assoc J. 2001;3(6):459-60. [pmid: 11433647].
Staffen A, Schurer-Waldheim H. 3 years of general embolism prophylaxis in nailed femoral neck fractures by anticoagulants. Wien Klin Wochenschr. 1970;82(44):793-4. [pmid: 5476162].
Stamatakis JD, Kakkar VV, Lawrence D, Bentley PG, Nairn D, et al. Failure of aspirin to prevent postoperative deep vein thrombosis in patients undergoing total hip replacement: Failure of aspirin to prevent postoperative deep vein thrombosis in patients undergoing total hip replacement. British Medical Journal (England). 1978;1:1031.
Stannard JP, Singhania AK, Lopez-Ben RR, et al. Deep-vein thrombosis in high-energy skeletal trauma despite thromboprophylaxis. J Bone Joint Surg Br. 2005;87(7):965-8. [pmid: 15972912].
Stedry V, Slavik M, Ort J, Janotova H, Kapounek B. Prevention of thromboembolic disease in patients after total endoprosthesis hip joint surgery using small doses of heparin. Acta Chir Orthop Traumatol Cech. 1982;49(5):406-12. [pmid: 7158196].
Stehlik J, Karpas K, Urban K. Comparison of thromboembolic prophylaxis with heparin and fraxiparine after total endoprostheses of the hip joint. Acta Chir Orthop Traumatol Cech. 1995;62(1):36-9. [pmid: 20470484].
Stephens PH, Healy MT, Smith M, Jewkes DA. British Journal of Neurosurgery. Prophylaxis against thromboembolism in neurosurgical patients: A survey of current practice in the United Kingdom. 1995;9:159-63. [pmid: 7632361].
Stern SH, Wixson RL, O'Connor D. Evaluation of the safety and efficacy of enoxaparin and warfarin for prevention of deep vein thrombosis after total knee arthroplasty. J Arthroplasty. 2000;15(2):153-8. [pmid: 10708078].
Stewart JR, Peyton JWR, Crute SL, Greenfield LJ. Surgery. Clinical results of suprarenal placement of the Greenfield vena cava filter. 1982;92:1-4. [pmid: 7089859].
Sturm V, Gruber UF. Prevention of postoperative thromboembolic complications. Hippokrates. 1977;48(1):52-61. [pmid: 845041].
Stutz P, Gruber UF. Relationship between various forms of prevention of thromboembolic complications and location of deep vein thrombi (author's transl). Schweiz Rundsch Med Prax. 1978;67(37):1355-8. [pmid: 693462].
Sue LP, Davis JW, Parks SN. Iliofemoral venous injuries: an indication for prophylactic caval filter placement. J Trauma. 1995;39(4):693-5. [pmid: 7473957].
Taberner DA, Poller L, Thomson JM. Adjusted versus fixed dose subcutaneous heparin in preventing deep vein thrombosis in hip surgery. British Journal of Haematology. 1988;69:115.
Taks AC, Duchateau AM, Janelli FI, Merkus FW. Letter: Postoperative thrombosis prevention with low doses of heparin administered subcutaneously. Ned Tijdschr Geneeskd. 1976;120(12):530-1. [pmid: 1250441].
Tapson VF, Decousus H, Pini M, et al. Venous thromboembolism prophylaxis in acutely ill hospitalized medical patients: findings from the International Medical Prevention Registry on Venous Thromboembolism. Chest. 2007;132(3):936-45. [pmid: 17573514].
Teitelbaum GP, Jones DL, Van Breda A, et al. Radiology. Vena caval filter splaying: Potential complication of use of the titanium Greenfield filter. 1989;173:809-14. [pmid: 2813790].
Textor HJ, Strunk H, Schild HH. Temporary vena cave filter: critical comments. Rofo. 1996;165(4):371-4. [pmid: 8963050].
The German Hip Arthroplasty Trial (GHAT) Group. Prevention of deep vein thrombosis with low molecular-weight heparin in patients undergoing total hip replacement. Archives of Orthopaedic and Trauma Surgery. 1992;111(2):110-20. [pmid: 1314065].
Thies HA. Thromboembolism in the framework of post-traumatic intensive care. Klin Med Osterr Z Wiss Prakt Med. 1967;22(8):342-5. [pmid: 5632403].
Thomas Iii WO, Ferrara JJ, Rodning CB. A retrospective analysis of inferior vena caval filtration for prevention of pulmonary embolization. 1988;54:726-30.
Thomas JH, Cornell KM, Siegel EL, Sparks C, Rosenthal SJ. American Journal of Surgery. Vena caval occlusion after bird's nest filter placement. 1998;176:598-600. [pmid: 9926797].
Thromboprophylaxis in hip fracture surgery: a pilot study comparing danaparoid, enoxaparin and dalteparin. The TIFDED Study Group. Haemostasis. 1999;29(6):310-7. [pmid: 10844404].
Tilsner V, Eifrig B, Schontag H, Reuter H. Intraoperative coagulation activity--a defined group of trauma surgery patients. Folia Haematol Int Mag Klin Morphol Blutforsch. 1989;116(6):915-25. [pmid: 2483711].
Tinmouth A, Morrow B, Cruickshank M, Moore P, Kovacs M. Dalteparin as periprocedure anticoagulation for patients on warfarin and at high risk of thrombosis. Annals of Pharmacotherapy. 2001;35(6):669-74. [pmid: 11408982].
Tobin KD, Pais SO, Austin CB. Investigative Radiology. Femoral vein thrombosis following percutaneous placement of the Greenfield filter. 1989;24:442-5. [pmid: 2521124].
Toll A, Gallardo F, Abella ME, Fontcuberta J, Barranco C, Pujol RM. Low-molecular-weight heparin-induced skin necrosis: a potential association with pre-existent hypercoagulable states. Int J Dermatol. 2005;44(11):964-6. [pmid: 16336536].
Touzard RC. Prevention of thrombo-embolic complications (100 patients with hip surgery). Sem Hop. 1969;45(40):2481-3. [pmid: 4310897].
Trigilio-Black CM, Ringley CD, McBride CL, et al. Inferior vena cava filter placement for pulmonary embolism risk reduction in super morbidly obese undergoing bariatric surgery. Surg Obes Relat Dis. 2007;3(4):461-4. [pmid: 17544921].
Tubiana R, Duparc J. Frequency and prevention of thromboembolic complications in orthopedic surgery. Acta Orthop Belg. 1962;28:605-11. [pmid: 13994658].
Tukallo K, Wilczek W, Lukomski J. Use of small doses of heparin for prevention of thrombophlebitis. Chir Narzadow Ruchu Ortop Pol. 1980;45(1):77-80. [pmid: 7379626].
Turpie AG, Gallus AS, Hoek JA. A synthetic pentasaccharide for the prevention of deep-vein thrombosis after total hip replacement. N Engl J Med. 2001;344(9):619-25. [pmid: 11228275].
Ulehlova J, Slavik L, Krcova V, Prochazkova J, Hlusi A, Cech L. Laboratory monitoring of dabigatran during orthopedic surgery. J. Thromb. Haemost. 2009;7(S2):674.
Upchurch GR Jr, Demling RH, Davies J, Gates JD, Knox JB. Efficacy of subcutaneous heparin in prevention of venous thromboembolic events in trauma patients. Am Surg. 1995;61(9):749-55. [pmid: 7661468].
Vallano A, Arnau JM, Miralda GP, Perez-Bartoli J. Use of venous thromboprophylaxis and adherence to guideline recommendations: a cross-sectional study. Thromb J. 2004;2(1):3. [pmid: 15059286].
van Vroonhoven TJ. Low doses subcutaneously administered heparin as thrombosis prevention in surgery. Ned Tijdschr Geneeskd. 1976;120(4):159-63. [pmid: 1107860].
Vaziri K, Bhanot P, Hungness ES, Morasch MD, Prystowsky JB, Nagle AP. Retrievable inferior vena cava filters in high-risk patients undergoing bariatric surgery. Surg Endosc. 2009;23(10):2203-7. [pmid: 19184212].
Verardi S, Cortese F, Baroni B, Boffo V, Palazzini E, et al. Deep vein thrombosis prevention in surgical patients: effectiveness and safety of a new low-molecular-weight heparin: Deep vein thrombosis prevention in surgical patients: effectiveness and safety of a new low-molecular-weight heparin. Current Therapeutic Research (USA). 1989;46:366-72.
Verne Jm, De Montrichard C, Chevillard L, Ranson M. Mixed Prophylaxis Of Postoperative Thrombo-Embolic Disease In General Surgery. Prevention By Anticoagulant And Vasomotor Phlebotropic Therapy. Pharmacodynamic And Clinical Study Of Ruscus Aculeatus Extract. Ann Chir. 1960;14:1221-51. [pmid: 13780954].
Verstraete M. Critical evaluation of the usefulness of drugs inhibiting platelet function in the prevention of postoperative deep venous thrombosis and in ischemic cardiopathy. Recenti Prog Med. 1980;68(4):361-81. [pmid: 6992244].
Vignon P, Dequin P-F, Benzekri-Lefevre D, et al. Intermittent pneumatic compression to prevent venousthrom-boembolism in patients hospitalized in intensive care units with high risk of bleeding: A randomized trial. Intensive Care Med. 2011;37:S230.
Vimlati L, Rozsa I, Sas G. Low-dose prophylactic heparin in the prevention of postoperative pulmonary complications. Orv Hetil. 1980;121(49):2997-9. [pmid: 7220016].
von Huben R, Roth H. Comparative study on the prevention of postoperative thromboembolism. Schweiz Med Wochenschr. 1970;100(8):380-2. [pmid: 5524938].
Vorwerk D, Hollmann J, Gunther R. Long-term follow-up of vena cava filters: real-time sonography and the native x-ray image. Rofo. 1987;146(5):558-62. [pmid: 3035643].
Vukovich T, Proidl S, Teufelsbauer H, et al. Laboratory monitoring of thromboprophylaxis with low molecular weight and standard heparin. Thromb Res. 1992;66(6):735-43. [pmid: 1519232].
Walsh PN, Rogers PH, Marder VJ, Gagnatelli G, Escovitz ES, Sherry S. Platelet coagulant activities and venous thrombosis after hip surgery. Trans Assoc Am Physicians. 1974;87:140-52. [pmid: 4617363].
Wang CJ, Wang JW, Weng LH, Hsu CC, Huang CC, Yu PC. Prevention of deep-vein thrombosis after total knee arthroplasty in Asian patients. Comparison of low-molecular-weight heparin and indomethacin. J Bone Joint Surg Am. 2004;86-A(1):136-40. [pmid: 14711956].
Wardrop M, Lube M, Du Coin C. Platelet counts in trauma patients admitted to the intensive care unit that receive enoxaparin (Lovenox) for venous thrombo-embolism prophylaxis. Crit. Care Med. 2010;38:A57.
Warkentin TE, Roberts RS, Hirsh J, Kelton JG. Heparin-induced skin lesions and other unusual sequelae of the heparin-induced thrombocytopenia syndrome: a nested cohort study. Chest. 2005;127(5):1857-61. [pmid: 15888871].
Warwick D, Bannister GC, Glew D, et al. Perioperative low-molecular-weight heparin. Is it effective and safe. J Bone Joint Surg Br. 1995;77(5):715-9. [pmid: 7559695].
Weber U, Koppenhagen K, Malzer H, Matthes M. Different effectiveness of two preparations of low molecular weight heparin in patients with elective hip joint replacement. Langenbecks Arch Chir. 1991;376(3):147-51. [pmid: 1651434].
Westrich GH, Salvati EA, Sharrock N, Potter HG, Sanchez PM, Sculco TP. The effect of intraoperative heparin administered during total hip arthroplasty on the incidence of proximal deep vein thrombosis assessed by magnetic resonance venography. J Arthroplasty. 2005;20(1):42-50. [pmid: 15660059].
Wickramasinghe LS, Basu SK, Bansal SK. Long-term oral anticoagulant therapy in elderly patients. Age Ageing. 1988;17(6):388-96. [pmid: 3149144].
Wicky J, Couson F, Ambrosetti P, Didier D, Rohner A, Bounameaux H. Thrombosis and Haemostasis. Postoperative deep venous thrombosis (DVT) and low-molecular weight heparin (LMWH) type and dosage [2]. 1993;69:402-3. [pmid: 8388582].
Wieberdink J. Preventive anticoagulation in surgery. Ned Tijdschr Geneeskd. 1965;109(47):2221-3. [pmid: 5848402].
Wilhelm K, Brader JJ, Beer HP, Lauterjung KL, Messmer K. Thrombosis prophylaxis with low doses of dextran 60 (author's transl). MMW Munch Med Wochenschr. 1978;120(7):223-6. [pmid: 304984].
Wille E. Effectivity of anticoagulation and extension of long-term anticoagulant therapy. Z Allgemeinmed. 1974;50(33):1521-5. [pmid: 4218413].
Williams RW, Schenk WG Jr. A removable intracaval filter for prevention of pulmonary embolism: early experience with the use of the Eichelter catheter in patients. Surgery. 1970;68(6):999-1008. [pmid: 5483252].
Wilson B, Hawkins ML, Mansberger AR Jr. Posttraumatic phlegmasia cerulea dolens: an indication for the Greenfield filter. South Med J. 1989;82(6):780-2. [pmid: 2734642].
Winchell RJ, Hoyt DB, Walsh JC, et al. Risk factors associated with pulmonary embolism despite routine prophylaxis: Implications for improved protection. 1994;37:600-6.
Winchell RJ, Hoyt DB, Walsh JC, Simons RK, Eastman AB. Risk factors associated with pulmonary embolism despite routine prophylaxis: implications for improved protection. J Trauma. 1994;37(4):600-6. [pmid: 7932891].
Windisch C, Kolb W, Kolb K, Grutzner P, Venbrocks R, Anders J. Pneumatic compression with foot pumps facilitates early postoperative mobilisation in total knee arthroplasty. Int Orthop. 2011;35(7):995-1000. [pmid: 20652250].
Wirth T, Misselwitz F, Schneider B, et al. Low molecular weight heparin (reviparin) for the prevention of venous thromboembolism after knee arthroscopy. Results of a randomized controlled trial. Annals of Hematology. 2001;80:A72.
Wolf F, Thurnher S, Lammer J. Simon Nitinol-vena-cava-Filter: Wirksamkeit und Komplikationen: Simon Nitinol vena cava filters: Effectiveness and complications. 2001;173:924-30.
Wyss PA, Gruber UF. Does bandaging of legs or elastic stockings prevent postoperative deep venous thrombosis. Vasa. 1977;6(4):376-80. [pmid: 930296].
Yelnik A, Denys P, Schouman-Claeys E, Frija G, Held JP. Prevention of venous thrombosis in paraplegic patients. An open study of fraxiparin. Ann Med Interne (Paris). 1989;140(7):647. [pmid: 2692496].
Yelnik A, Dizien O, Bussel B, et al. Systematic lower limb phlebography in acute spinal cord injury in 147 patients. Paraplegia. 1991;29(4):253-60. [pmid: 1870890].
Yogaratnam D, Smith BS, Angood PB, Gandhi PJ. Antifactor Xa levels in four patients with burn injuries who received enoxaparin to prevent venous thromboembolism. Pharmacotherapy. 2004;24(12):1793-9. [pmid: 15585445].
Yoshida WB, Rollo HA, Giannini M, Sobreira ML, Moura R. Preliminary experience with a new vena cava filter: Results of 15 implantations. 2008;7(3):282-8.
Younas F, Janjua M, Chughtai H, et al. Outcome with inferior vena cava filters. Vasc. Med. 2010;15(2):156-7.
Zaczek T, Palczak R. Attempted analysis of the preventive action of anticoagulants according to surgical material of a provincial hospital. Przegl Lek. 1966;22(6):445-6. [pmid: 5916716].
Zenahlikova Z, Kvasnicka J, Kudrnova Z, et al. FXa inhibition and coagulation changes during DVT prophylaxis by enoxaparin over the course of a 15-day follow-up in septic patients. Clin Appl Thromb Hemost. 2010;16(5):584-90. [pmid: 19850587].
Ziemski JM, Kostrzewska E, Marchlewski S, et al. Efficacy of small doses of heparin given during 2 to 6 days in the prevention of postoperative deep vein thrombosis. Pol Tyg Lek. 1979;34(5):161-4. [pmid: 432128].
Zwaan M, Kagel Ch, Marienhoff N, et al. First results with temporary vena cava filters: Erste Erfahrungen Mit Temporaren Vena-Cava-Filtern. Rofo Fortschr. Geb. Rontgenstr. Neuen Bildgebenden Verfahren. 1995;163(2):171-6.

## Non-USA Drugs

Alt W. Clinical Experiences With Essaven In The Prevention And Therapy Of Thrombosis Of The Lower Extremities. Ther Ggw. 1964;103:1147-54. [pmid: 14337915].
Bischoff M. Thrombosis prevention: Low molecular weight heparins are also applicable in kidney failure: Thromboseprophylaxe: Niedermolekulare heparine auch bei niereninsuffizienz einsetzbar. Vasomed. 2012;24(2):109.
Cole CW, Shea B, Bormanis J. Ancrod as prophylaxis or treatment for thromboembolism in patients with multiple trauma. Can J Surg. 1995;38(3):249-54. [pmid: 7788603].
Cotter SA, Cantrell W, Fisher B, Shopnick R. Efficacy of venous thromboembolism prophylaxis in morbidly obese patients undergoing gastric bypass surgery. Obes Surg. 2005;15(9):1316-20. [pmid: 16259895].
Dahl OE, Eriksson BI, Agnelli G, et al. Postoperative Melagatran/Ximelagatran for the Prevention of Venous Thromboembolism following Major Elective Orthopaedic Surgery : Effects of Timing of First Dose and Risk Factors for Thromboembolism and Bleeding Complications on Efficacy and Safety. Clin Drug Investig. 2005;25(1):65-77.
Eriksson BI, Turpie AG, Lassen MR, et al. A dose escalation study of YM150, an oral direct factor Xa inhibitor, in the prevention of venous thromboembolism in elective primary hip replacement surgery. J Thromb Haemost. 2007;5(8):1660-5. [pmid: 17663737].
Forestieri P, Quarto G, De Caterina M, et al. Prophylaxis of thromboembolism in bariatric surgery with parnaparin. Obes Surg. 2007;17(12):1558-62. [pmid: 18004632].
Greenfield LJ, Proctor MC, Cho KJ, et al. Journal of Vascular Surgery. Extended evaluation of the titanium Greenfield vena caval filter. 1994;20:458-65. [pmid: 8084040].
Harenberg J, Roebruck P, Heene DL. Subcutaneous low-molecular-weight heparin versus standard heparin and the prevention of thromboembolism in medical inpatients. The Heparin Study in Internal Medicine Group. Haemostasis. 1996;26(3):127-39. [pmid: 8738587].
Kaufmann P. Comparison between anticoagulants & butazolidin in prevention of thromboembolism. Schweiz Med Wochenschr. 1957;87(Suppl 24):755-9. [pmid: 13454742].
Kirienko AI, Zolotukhin IA. Clexane in prevention of acute venous thrombosis and pulmonary thromboembolism. Ter Arkh. 1998;70(11):78-80. [pmid: 9949471].
Lassen MR, Dahl O, Mismetti P, Zielske D, Turpie AG. SR123781A: a new once-daily synthetic oligosaccharide anticoagulant for thromboprophylaxis after total hip replacement surgery: the DRIVE (Dose Ranging Study in Elective Total Hip Replacement Surgery) study. J Am Coll Cardiol. 2008;51(15):1498-504. [pmid: 18402906].
Lassen MR, Gallus A, Raskob GE, Pineo G, Chen D, Ramirez LM. Apixaban versus enoxaparin for thromboprophylaxis after hip replacement. N Engl J Med. 2010;363(26):2487-98. [pmid: 21175312].
Lavrentieva A, Kontakiotis T, Bitzani M, et al. The efficacy of antithrombin administration in the acute phase of burn injury. Thrombosis and Haemostasis. 2008;100(2):286-90. [pmid: 18690349].
Leil TA, Feng Y, Zhang L, Paccaly A, Mohan P, Pfister M. Quantification of apixaban's therapeutic utility in prevention of venous thromboembolism: selection of phase III trial dose. Clin Pharmacol Ther. 2010;88(3):375-82. [pmid: 20686477].
Matis P, Mayer W. Thrombocid, a heparin simulant, in therapy & prevention of thrombosis. Zentralbl Chir. 1957;82(21):875-83. [pmid: 13457139].
Murakami M, McDill TL, Cindrick-Pounds L, et al. Deep venous thrombosis prophylaxis in trauma: improved compliance with a novel miniaturized pneumatic compression device. J Vasc Surg. 2003;38(5):923-7. [pmid: 14603195].
Nurmohamed MT, Knipscheer HC, Stevens P, et al. Clinical experience with a new antithrombotic (dermatan sulfate) in chronic hemodialysis patients. Clin Nephrol. 1993;39(3):166-71. [pmid: 8462205].
Prystowsky JB, Morasch MD, Eskandari MK, Hungness ES, Nagle AP. Prospective analysis of the incidence of deep venous thrombosis in bariatric surgery patients. Surgery. 2005;138(4):759-63. discussion 763-5. [pmid: 16269306].
Quebbemann B, Akhondzadeh M, Dallal R. Continuous intravenous heparin infusion prevents peri-operative thromboembolic events in bariatric surgery patients. Obes Surg. 2005;15(9):1221-4. [pmid: 16273676].
Raskob G, Cohen AT, Eriksson BI, et al. Oral direct factor Xa inhibition with edoxaban for thromboprophylaxis after elective total hip replacement. A randomised double-blind dose-response study. Thromb Haemost. 2010;104(3):642-9. [pmid: 20589317].
Sevitt S. Anticoagulant prophylaxis against venous thrombosis and pulmonary embolism after injury. Thromb Diath Haemorrh Suppl. 1966;21:287-300. [pmid: 5969871].
Silver JR. Prophylactic anticoagulant therapy in the prevention of pulmonary emboli in patients with acute spinal injuries. Proc Veterans Adm Spinal Cord Inj Conf. 1971;18:184-8. [pmid: 5161625].
Turpie AG, Bauer KA, Davidson BL, et al. A randomized evaluation of betrixaban, an oral factor Xa inhibitor, for prevention of thromboembolic events after total knee replacement (EXPERT). Thromb Haemost. 2009;101(1):68-76. [pmid: 19132191].
Verne Jm, De Montrichard C, Chevillard L, Ranson M. Mixed prophylaxis of postoperative thrombo-embolic disease in general surgery. Prevention by anticoagulant and vasomotor phlebotropic therapy. Pharmacodynamic and clinical study of Ruscus aculeatus extract. Ann Chir. 1960;14:1221-51. [pmid: 13780954].
Warembourg H, Delbecque H. Clinical trial of an anticoagulant: acenocoumarol. Lille Med. Suppl. 1967;12(8):855-61. [pmid: 5622513].

## Not Relevant to Key Questions

Prevention of fatal pulmonary embolism with a low dose of heparin. Orv Hetil. 1976;117(2):92-4. [pmid: 1244597].
Abraham-Inpijn L. Preventive treatment of surgical patients with low dose heparin. Tijdschr Ziekenverpl. 1978;31(11):502-4. [pmid: 248253].
Acuna DL, Berg GM, Harrison BL, Wray T, Dorsch D, Sook C. Assessing the use of venous thromboembolism risk assessment profiles in the trauma population: is it necessary?. Am Surg. 2011;77(6):783-9. [pmid: 21679651].
Adams JT, Feingold BE, DeWeese JA. Comparative evaluation of ligation and partial interruption of the inferior vena cava. Arch Surg. 1971;103(2):272-6. [pmid: 4935098].
Aglietti P, Mendes DG, Salvati EA, Wilson PD Jr. Thromboembolic complications following total hip prosthesis. Study of 478 cases of relative efficacy of 3 preventive methods. Rev Chir Orthop Reparatrice Appar Mot. 1974;60(6):429-40. [pmid: 4282159].
Aidinian G, Fox CJ, White PW, Cox MW, Adams ED, Gillespie DL. Intravascular ultrasound--guided inferior vena cava filter placement in the military multitrauma patients: a single-center experience. Vasc Endovascular Surg. 2009;43(5):497-501. [pmid: 19640915].
Allemann BH, Gerber H, Gruber UF. Perispinal anesthesia and subcutaneous administration of low-dose heparin-dihydergot for prevention of thromboembolism. Anaesthesist. 1983;32(2):80-3. [pmid: 6189414].
Allen TL, Carter JL, Morris BJ, Harker CP, Stevens MH. Retrievable vena cava filters in trauma patients for high-risk prophylaxis and prevention of pulmonary embolism. Am J Surg. 2005;189(6):656-61. [pmid: 15910715].
Altintas F, Gurbuz H, Erdemli B, et al. Venous thromboembolism prophylaxis in major orthopaedic surgery: A multicenter, prospective, observational study. Acta Orthop Traumatol Turc. 2008;42(5):322-7. [pmid: 19158452].
Amendolara M, Perri S, Capellari F, Ciccia B, Battocchio F, Gelmi G. Surgical prophylaxis of pulmonary embolism using caval filters. Preliminary study: Profilassi chirurgica dell'embolia polmonare con l'impiego dei filtri cavali. Studio preliminare. 1997;10(3):236-40.
Amin A, Lin J, Ryan A. VTE Prophylaxis across the continuum of care in us orthopedic surgery patients. Blood. 2009;114(22).
Amin A, Varker H, Lin J, Thompson S, Johnston S. Duration of risk of venous thromboembolism in real-world U.S. patients hospitalized for medical illness. J. Hosp. Med. 2011;6(4):S5-S6.
Andrassy K, Salzmann W, Saggau W, Storch H, Ritz E. Is more heparin necessary for low-dose heparin prophylaxis in uremic patients?. Thromb Haemost. 1981;46(4):740-2. [pmid: 7330827].
Angelides NS. Prevention of deep vein thrombosis. From the surgical clinic of the Nicosia General Hospital. J Med Liban. 1974;27(3):305-12. [pmid: 4419746].
Anglen JO, Bagby C, George R. A randomized comparison of sequential-gradient calf compression with intermittent plantar compression for prevention of venous thrombosis in orthopedic trauma patients: preliminary results. Am J Orthop (Belle Mead NJ). 1998;27(1):53-8. [pmid: 9452837].
Antlitz AM, Valle NG, Kosai MF. The effect of prophylactic anticoagulant therapy on the incidence of postoperative pulmonary infarction. South Med J. 1968;61(3):307-10.
Arcangeli A, Rocca B, Salvatori G, Ciancia M, De Cristofaro R, Antonelli M. Heparin versus prostacyclin in continuous hemodiafiltration for acute renal failure: Effects on platelet function in the systemic circulation and across the filter. Thromb. Res. 2010;126(1):24-31. [pmid: 20185164].
Arcelus JI, Traverso CI, López-Cantarero M, et al. Prevention of postoperative deep vein thrombosis in general surgery. Comparative study of heparin at low-doses, dextran 70 and heparin dihydroergotamine. Cirugía Española. 1989;46(4):537-43.
Arnulf G. Value of postoperative thromboembolism prevention by anticoagulants (in 2,506 surgically treated cases). Lyon Chir. 1967;63(4):597-9. [pmid: 5613087].
Arochena L, Ruiz-Garcia M, Andregnette-Roscigno V, De Las Heras M. Delayed-type hypersensitivity to low molecular weight heparin. Allergy Eur. J. Allergy Clin. Immunol. 2009;64:287.
Azarbal AF, Rowell S, Lewis J, et al. Deep Venous Thrombosis (DVT) in critically ill trauma patients: There are no low-risk patients. J. Vasc. Surg. 2010;51(6):64S-5S.
Baille Y, Monties JR, Blanc T, et al. Surgery under heparin. I. Prevention of early postoperative thrombosis by heparin (250 cases). Agressologie. 1968;9(5):625-33. [pmid: 5710179].
Bajardi G, Ricevuto G, Mastrandrea G, et al. Post-operative venous thromboembolism in bariatric surgery: LE TROMBOEMBOLIE VENOSE POST-CHIRURGICHE IN CHIRURGIA BARIATRICA. 1993;48:539-42.
Bakir N, Sluiter WJ, Ploeg RJ, van Son WJ, Tegzess AM. Primary renal graft thrombosis. Nephrol Dial Transplant. 1996;11(1):140-7. [pmid: 8649623].
Bakkevold K. Small subcutaneous doses of heparin in the prevention of venous thrombosis and pulmonary embolism in surgical patients. Tidsskr Nor Laegeforen. 1976;96(11):634-5. 629. [pmid: 1265720].
Balbir A, Odeh M, Atias D, Oliven A. Ticlopidine-induced neutropenia. Harefuah. 1996;130(12):822-4. 879. [pmid: 8885506].
Barata JD, Oliveira C, Bruges M, et al. Prevention of thrombogenesis in the extracorporeal circuit of hemodialysis with a low molecular heparin: standardization of the dosage with a better hemorrhagic risk/effectiveness ratio. Acta Med Port. 1992;5(2):65-70. [pmid: 1317657].
Barnett HG, Clifford JR, Llewellyn RC. Journal of Neurosurgery. Safety of mini-dose heparin administration for neurosurgical patients. 1977;47:27-30. [pmid: 864504].
Baroletti S, Labreche M, Niles M, Fanikos J, Goldhaber SZ. Prescription of fondaparinux in hospitalised patients. Thromb Haemost. 2009;101(6):1091-4. [pmid: 19492152].
Barsotti J, Benhamou AC, Guerois C, Gratteau B, Guilmot JL, Jolidon C. White clot syndrome. Arterial and venous thromboses during heparin therapy with thrombopenia after bone surgery. J Mal Vasc. 1983;8(2):139-42. [pmid: 6875393].
Basey AJ, Pradham S. Factors influencing appropriate prescription of venous thromboembolism prophylaxis for medical patients. Int. J. Pharm. Pract. 2010;18:6-7.
Bastos M, Caiafa JS, Moura LK, Raimundo S. A Brazilian registry establishing risk factors for venous thromboembolic events and use of thromboprophylaxis in hospitalized medical and surgical patients. 2001;98(11 PART I).
Becker Hm. Pulmonary Embolism. Incidence And Preventive Measures At The Munich University Surgical Hospital. Munch Med Wochenschr. 1965;107:766-72. [pmid: 14331805].
Becker S, Schenk S, Ogon M. Thrombosis prophylaxis in spinal surgery: Thromboseprophylaxe bei wirbelsauleneingriffen. Wien. Klin. Wochenschr. Suppl. 2005;117(2):24-6.
Benko T, Cooke EA, McNally MA, Mollan RA. Graduated compression stockings: knee length or thigh length. Clin Orthop Relat Res. 2001;383:197-203. [pmid: 11210954].
Berchtold R, Caplazi P, Wanger F. Prevention of thrombosis and embolism in surgical departments. Schweiz Med Wochenschr. 1966;96(48):1603-10. [pmid: 5973373].
Berges A, Laporte S, Epinat M, et al. Anti-factor Xa activity of enoxaparin administered at prophylactic dosage to patients over 75 years old. Br J Clin Pharmacol. 2007;64(4):428-38. [pmid: 17509040].
Bergqvist D, Efsing HO, Hallbook T, Lindblad B. Prevention of postoperative thromboembolic complications. A prospective comparison between dextran 70, dihydroergotamine heparin and a sulphated polysaccharide. Acta Chir Scand. 1980;146(8):559-68. [pmid: 6164204].
Bergqvist D, Frisell J, Hallbook T, et al. Swedish - Norwegian Multicenter trial: a randomized double blind study on the prevention of postoperative deep vein thrombosis (DVT) - Heparin fragment (fragmin) from the evening before surgery vs conventional low-dose heparin. Thrombosis Research. 1987;(Suppl VII):20. Abstract no: 16.
Bergqvist D. Intermittent thigh compression as prophylaxis against deep venous thrombosis. Lakartidningen. 1979;76(34):2790-2. [pmid: 529909].
Berland LL, Maddison FE, Bernhard VM. American Journal of Roentgenology. Radiologic follow-up of vena cava filter devices. 1980;134:1047-52. [pmid: 6768244].
Bern MM, Green J. Effect of sulfinpyrazone upon antithrombin III and platelet factor 4 in chronic renal failure. Thromb Res. 1982;27(4):457-65. [pmid: 7147215].
Best AJ, Williams S, Crozier A, Bhatt R, Gregg PJ, Hui AC. Graded compression stockings in elective orthopaedic surgery. An assessment of the in vivo performance of commercially available stockings in patients having hip and knee arthroplasty. J Bone Joint Surg Br. 2000;82(1):116-8. [pmid: 10697326].
Beyssac L. Analysis of thrombo-embolic complications in 14533 surgical operations. Results and failures of preventive treatment. Bull Soc Int Chir. 1968;27(1):64-7. [pmid: 5742747].
Bhatt SH. Evaluation of compliance with low dose unfractionated heparin for venous thromboembolism prophylaxis in medically ill hospitalized patients at an academic medical center. J. Thromb. Haemost. 2009;7(S2):1092. [pmid: 19422446].
Bianchini AU, Mehta SN, Mulder DS, Barkun AN, Mayrand S. American Journal of Gastroenterology. Duodenal perforation by a Greenfield filter: Endoscopic diagnosis. 1997;92:686-7. [pmid: 9128325].
Bischoff M. Thrombosis prevention: Low molecular weight heparins are also applicable in kidney failure: Thromboseprophylaxe: Niedermolekulare heparine auch bei niereninsuffizienz einsetzbar. Vasomed. 2012;24(2):109.
Bisler H, Alemany J, Holling H. Early and late results in the prevention of pulmonary embolism and caval patency after implantation of caval clips according to Adams--De Weese as compared to Mobin-Uddin umbrella filters (author's transl). Thoraxchir Vask Chir. 1978;26(3):164-8. [pmid: 675652].
Black J, Nagle CJ, Strachan CJ. Prophylactic low-dose heparin by jet injection. Br Med J. 1978;2(6130):95. [pmid: 667580].
Blaeser-Kiel G. Thrombosis prevention: Dabigatran capsule instead of heparin injection: Thromboseprophylaxe: Dabigatrankapsel statt heparinspritze. Dtsch. Arztebl. 2008;105(33):A1748.
Blumenthal JB. Use of low dose heparin in preventing venous thrombosis. J Med Assoc Ga. 1973;62(6):239-40. [pmid: 4715331].
Bonn J, Cho KJ, Cipolle M, et al. Journal of Vascular Surgery. Recommended reporting standards for vena caval filter placement and patient follow-up. 1999;30:573-9. [pmid: 10477662].
Borghi B, Bugamelli S, deSimone N, Montebugnoli M, Ferrari S. Indobufen and calcium heparin for the prevention of thromboembolism in hip prosthesis surgery in patients who have undergone hemodilution. Minerva Anestesiol. 1990;56(10):1117-20. [pmid: 2290518].
Borgstroem S, Greitz T, Van Der Linden W, Molin J, Rudics I. Anticoagulant Prophylaxis Of Venous Thrombosis In Patients With Fractured Neck Of The Femur; A Controlled Clinical Trial Using Venous Phlebography. Acta Chir Scand. 1965;129:500-8. [pmid: 14296582].
Borgstrom S. Postoperative anticoagulant prophylaxis of venous thrombosis with dicoumarol. Zentralbl Phlebol. 1967;6(1):30-5. [pmid: 4167216].
Boskovic S, Musa M, Popovic M, Bakovic S, Saracevic N. Our 2-year-long experience with systematic prevention of thromboembolytic postoperative complications in surgery. Med Pregl. 1973;26(7):227-32. [pmid: 4793056].
Bosson JL, Olinic D, Franco G, et al. Partial interruption of the inferior vena cava: ten-year evolution in protocols at Grenoble University Hospital. Study of 621 patients. Vasa. 1995;24(1):34-41. [pmid: 7725777].
Braakman R. Traumatic cross-sectional spinal cord injuries. Ned Tijdschr Geneeskd. 1976;120(41):1717-21. [pmid: 980133].
Bramham K, Varrier M, Asgari E, Makanjuola D. Comparison of Tinzaparin and unfractionated heparin as anticoagulation on haemodialysis: equal safety, efficacy and economical parity. Nephron Clin Pract. 2008;110(2):c107-13. [pmid: 18824874].
Brenner M, Bochicchio G, Bochicchio K, Scalea T. Inferior vena cava filters in spinal cord injury patients: Necessary or discretionary?. Crit. Care Med. 2010;38:A167.
Bret P, Lecuire J, Lapras C, Deruty R, Desgeorges M, Prudhon JL. Subdural hematoma and anticoagulant therapy. Neurochirurgie. 1976;22(6):603-20. [pmid: 67569].
Breyer HG, van-de LJ, Koppenhagen K, et al. Prevention of deep-vein thrombosis with LMW heparin (CY 216) in patients with elective total hip arthroplasty. Annals of Hematology. 1991;62(Suppl 1):A40.
Bromig G. Postoperative prevention of thromboembolism without anticoagulants. Zentralbl Chir. 1967;92(20):689-92. [pmid: 4967285].
Brophy DF, Martin EJ, Best AM, Gehr TWB, Carr ME. Journal of Thrombosis and Haemostasis. Antifactor Xa activity correlates to thrombin generation time, platelet contractile force and clot elastic modulus following ex vivo enoxaparin exposure in patients with and without renal dysfunction. 2004;2:1299-304. [pmid: 15304034].
Brunie V, Chardon S, Boursier V, et al. Evaluation of good heparin use in routine hospital practice. Pharm. World Sci. 2010;32(5):682.
Brunner U. Prevention of venous thrombosis in surgery of the lower limbs. Various phases of an experience in a general traumatology service. Phlebologie. 1984;37(1):41-7. [pmid: 6718503].
Burger T, Halloul Z, Tautenhahn J, Lippert H. Value of the vena cava filter in treatment of deep venous thrombosis in the pelvis and leg. Zentralbl Chir. 1999;124(1):32-6. [pmid: 10091295].
Burian R. PROLONG and SONIC study on orthopedic rehabilitation patients: Reduced thrombosis rate by prolonged postoperative prophylaxis with enoxaparin: PROLONG- und SONIC-studie an orthopadischen REHA-patienten: Thromboserate gesenkt durch verlangerte postoperative prophylaxe mit enoxaparin. Med. Welt. 2004;55(11-12):80-1.
Burian R. Thromboembolism prophylaxis with low molecular weight heparins in surgical patients: Adjustment of dose and duration in risky situations!: Thromboembolie-prophylaxe mit NMH bei operierten patienten: Dosierung und dauer der risikosituation anpassen!. Med. Welt. 2005;56(9):406-7.
Burkhardt H, Roll G. Combined prevention of thrombosis. Combination of anticoagulant therapy with preparations inhibiting platelet aggregation. Med Welt. 1974;25(19):867-9. [pmid: 4464446].
Burns GA, Cohn SM, Frumento RJ, Degutis LC, Hammers L. Prospective ultrasound evaluation of venous thrombosis in high-risk trauma patients. J Trauma. 1993;35(3):405-8. [pmid: 8371299].
Burns S. Duplex ultrasound screening…. Archives of Physical Medicine & Rehabilitation. 2000;81(2):242. [pmid: 10668785]. Powell M, Kirschblum S, O'Connor KC. Duplex ultrasound screening for deep vein thrombosis in spinal cord injured patients at rehabilitation admission. Arch Phys Med Rehabil. 1999;80:1044-6. [pmid: 10489006].
Busche MN, Herold C, Kramer R, Knobloch K, Vogt PM, Rennekampff HO. Evaluation of prophylactic anticoagulation, deep venous thrombosis, and heparin-induced thrombocytopenia in 21 burn centers in Germany, Austria, and Switzerland. Ann Plast Surg. 2011;67(1):17-24. [pmid: 21629067].
Byrne JJ. Prevention of pulmonary embolism. Am J Surg. 1968;116(3):396-402. [pmid: 5675909].
Cade JF, Mills KW, Gallus AS, Murphy W. Preventing venous thrombosis (VT) with heparin alone or with heparin/dihydroergotamine after elective hip replacement, a double-blind, randomised, venogram end-point comparison. Thrombosis and Haemostasis. 1987;58(1):240. Abstract no:. 888.
Cadroy Y, Pourrat J, Baladre MF, et al. Delayed elimination of enoxaparine in patients with chronic renal insufficiency. 1991;63:385-90.
Calfon M, Seddighzadeh A, Piazza G, Goldhaber SZ. Deep vein thrombosis in orthopedic surgery. Clin Appl Thromb Hemost. 2009;15(5):512-6. [pmid: 19491122].
Canaveira Manso L, Milheiro A, Castro E, Sousa F. Prophylaxis of post-operatory thromboembolism, randomized prospective study: Profilaxia da tromboembolia pos-operatoria. Estudio prospectivo randomizado. ACTA MED. PORT. 1996;9(2-3):87-90. [pmid: 8967308].
Carmody BJ, Sugerman HJ, Kellum JM, et al. Pulmonary embolism complicating bariatric surgery: detailed analysis of a single institution's 24-year experience. J Am Coll Surg. 2006;203(6):831-7. [pmid: 17116551].
Carson M, Kuo Y. Extended-duration venous thromboembolism prophylaxis for medical patients…. Ann Intern Med. Jul. 6. 2010;153(1):8-18. Annals of Internal Medicine 2010; 153(10):689. [pmid: 20621900].
Cerrato D, Ariano C, Fiacchino F. Journal of Neurosurgery. Deep vein thrombosis and low-dose heparin prophylaxis in neurosurgical patients. 1978;49:378-81. [pmid: 681999].
Chandra PA, Nwokolo C, Chuprun D, Chandra AB. Cardiac tamponade caused by fracture and migration of inferior vena cava filter. 2008;101:1163-4.
Chiche P, Dahan D, Dupuis R. Anticoagulant treatment and prevention of venous-pulmonary thromboembolic complications. Coeur Med Interne. 1978;17(4):605-14. [pmid: 738003].
Chopard P, Dorffler-Melly J, Hess U, et al. Venous thromboembolism prophylaxis in acutely ill medical patients: Definite need for improvement. 2005;257:352-7.
Chopin J, Lobera A, Schach R, Nonnenmacher J. Fractures of the upper tibia and thromboembolic risk. Agressologie. 1976;17(1):59-66. [pmid: 962029].
Christensen SW, Wille-Jorgensen P, Bjerg-Nielsen A, Kjaer L. Prevention of deep venous thrombosis following total hip replacement, using epidural analgesia. Acta Orthop Belg. 1989;55(1):58-61. [pmid: 2801064].
Christiansen HM, Lassen MR, Borris LC, et al. Biologic tolerance of two different low molecular weight heparins. Semin Thromb Hemost. 1991;17(4):450-4. [pmid: 1666460].
Chylarecki C, Hierholzer G, Rudofsky G. Atroflow-Device: A New Concept In Physical Methods For Thrombosis Prophylaxis. First Results: Physikalische Thromboseprophylaxe Mit Motorisierten Sprunggelenkbewegungsschienen. Erste Ergebnisse Einer Klinischen Studie. Unfallchirurgie. 1995;21(3):137-47. [pmid: 7638926].
Cimochowski GE, Evans RH, Zarins CK. Journal of Thoracic and Cardiovascular Surgery. Greenfield filter versus Mobin-Uddin umbrella: The continuing quest for the ideal method of vena cava interruption. 1980;79:358-65. [pmid: 6986511].
Clagett GP, Anderson Jr FA, Geerts W, et al. Prevention of venous thromboembolism. 1998;114:531S-60S.
Clark WB, MacGregor AB, Prescott RJ, Ruckley CV. Prevention of early post-operative deep vein thrombosis by compression of the leg during and after operation. Vasa. 1974;3(2):148-52. [pmid: 4831538].
Cofrancesco E, Cortellaro M, Leonardi P, Corradi A, Ravasi F, Bertocchi F. Markers of hemostatic system activation during thromboprophylaxis with recombinant hirudin in total hip replacement. Thromb Haemost. 1996;75(3):407-11. [pmid: 8701398].
Cohen AT, Skinner JA, Warwick D, Brenkel I. The use of graduated compression stockings in association with fondaparinux in surgery of the hip. A multicentre, multinational, randomised, open-label, parallel-group comparative study. J Bone Joint Surg Br. 2007;89(7):887-92. [pmid: 17673580].
Cohen AT, Spiro TE, Buller HR, et al. Rivaroxaban versus enoxaparin for the prevention of venous thromboembolism in acutely ill medical patients: Analysis of factors contributing to benefit and risk in MAGELLAN. J. Thromb. Haemost. 2011;9:961.
Cohen T, Spiro T, Buller H, et al. The magellan study methodology: Rivaroxaban compared with enoxaparin for the prevention of venous thromboembolism in hospitalized medically ill patients. Haematologica. 2010;95:66-7.
Collins R, Coe N, Goldstein E, et al. External pneumatic compression of the legs to prevent venous thromboembolism in neurosurgical patients. Thrombosis Et Diathesis Haemorrhagica. 1977;196.
Colwell CW, Berkowitz SD, Davidson BL, et al. Randomized, double-blind, comparison of ximelagatran, an oral direct thrombin inhibitor, and enoxaparin to prevent venous thromboembolism (VTE) after total hip arthroplasty (THA). 2001;98(11 PART I):706a-7a.
Colwell CW Jr. Length of thrombosis prophylaxis after orthopaedic surgery of the lower extremity. 2004;19(4):300-2.
Comp PC, Spiro TE, Friedman RJ, et al. Prolonged enoxaparin therapy to prevent venous thromboembolism after primary hip or knee replacement. Enoxaparin Clinical Trial Group. J Bone Joint Surg Am. 2001;83-A(3):336-45. [pmid: 11263636].
Compression stockings prevent DVT, but not SVT. Pharm. J. 2005;274(7354):750.
Cook D, Attia J, Weaver B, McDonald E, Meade M, Crowther M. Venous thromboembolic disease: an observational study in medical-surgical intensive care unit patients. J Crit Care. 2000;15(4):127-32. [pmid: 11138871].
Cook DJ, Crowther MA, Meade MO, Douketis J. Prevalence, incidence, and risk factors for venous thromboembolism in medical-surgical intensive care unit patients. J. Crit. Care. 2005;20(4):309-13. [pmid: 16310600].
Corriere MA, Sauve KJ, Ayerdi J, et al. Vena cava filters and inferior vena cava thrombosis. J Vasc Surg. 2007;45(4):789-94. [pmid: 17398389].
Corriere MA, Suave KJ, Ayerdi J, et al. Vena cava filters and inferior vena cava thrombosis. 2007;45:789-94.
Couinaud C, Cerceau F, Goddio A. Preventive treatment of thrombo-embolism in general surgery. A report of 5 242 observations (author's transl). Sem Hop. 1980;56(15-16):732-7. [pmid: 6246607].
Crochet D, Petitier H, Ricco JB, et al. Journal de Radiologie. Efficacy of the new caval filter (LEM) in the prevention of pulmonary embolism. Preliminary results of a French multicenter study. 1988;69:431-6. [pmid: 3047374].
Crochet DP, Brunel P, Trogrlic S, Grosset+-¼te R, Auget JL, Dary C. Long-term follow-up of Vena TechLGM filter: Predictors and frequency of caval occlusion. 1999;10:137-42.
Dahl OE, Eriksson BI, Homering M, et al. The effect of patient age, gender and weight on the efficacy and safety of rivaroxaban (bay 59-7939) for the prevention of venous thromboembolism after major orthopaedic surgery. The Journal of Bone and Joint Surgery (Proceedings). 2009;91-B(SUPP_I):76-a.
Davenport A. Low-molecular-weight heparin for routine hemodialysis. Hemodial Int. Suppl 2. 2008;12:S34-7. [pmid: 18837768].
David W, Gross WS, Colaiuta E, Gonda R, Osher D, Lanuti S. Pulmonary embolus after vena cava filter placement. Am Surg. 1999;65(4):341-6. [pmid: 10190360].
Davidson JE, Willms DC, Hoffman MS. Effect of intermittent pneumatic leg compression on intracranial pressure in brain-injured patients. Crit Care Med. 1993;21(2):224-7. [pmid: 8428473].
De Gregorio MA, Gamboa P, Bonilla DL, et al. Retrieval of G++nther Tulip optional vena cava filters 30 days after implantation: A prospective clinical study. 2006;17:1781-9.
de la Caffiniere JY, Mignot M, Bruch JM. The dangerous blood clot in orthopaedic surgery (author's transl). Rev Chir Orthop Reparatrice Appar Mot. 1981;67(1):47-58. [pmid: 6453395].
Montrichard De, Verne JM. Combined prevention (anticoagulant and venomotor) of thromboembolism in general surgery. Mission and responsibility of the anesthetist-resuscitator. Simplified prevention without laboratory tests. Sem Hop Ther Paris. 1962;38:404-9. [pmid: 14475583].
Montrichard De, Verne JM. Mixed Prevention (Anticoagulants And Venomotor) Of Thromboembolism In General Surgery. Mission And Responsibility Of Anesthetist-Resuscitator. Simplified Prevention Without Laboratory Tests. Sem Hop. 1961;37:3412-7. [pmid: 14475584].
de Mourgues G, Pagnier F, Clermont N, Ville D, Moyen B. Efficacy of subcutaneous heparin used according to 2 protocols in the prevention of postoperative venous thrombosis after total hip prothesis. Rev Chir Orthop Reparatrice Appar Mot. Suppl 2. 1979;65:74-6. [pmid: 158800].
De Servi S, Lettino M. The TRITON-TIMI 38 trial. G Ital Cardiol (Rome). 2008;9(3):149-54. [pmid: 18422094].
Decousus H, Tapson VF, Bergmann J-F, et al. Factors at admission associated with bleeding risk in medical patients: Findings from the improve investigators. 2011;139(1):69-79.
Descuns P, Garre H, Ramee A, Thevenot C. Anticoagulants and neurosurgery. Ann Chir. 1961;15:147-50. [pmid: 13722164].
Dh te R, Pellicer-Coeuret M, Belouet-Moreau C, Christoforov B, Vidal-Trecan G. Venous thromboembolism in medical inpatients: prophylaxis with low-weight heparin in a university hospital and prevalence of thromboembolic events. Clin Appl Thromb Hemost. 2001;7(1):16-20. [pmid: 11190898].
Diehm N. Effective prevention of thromboembolisms after knee joint replacement surgery: Wirkungsvolle prophylaxe von thromboembolien nach kniegelenksersatz- operationen. MMW-Fortschr. Med. 2010;152(15):30.
Dieter RA Jr, Asselmeier GH, McCray RM. Surgery and anticoagulation therapy. IMJ Ill Med J. 1973;144(3):205-7 passim. [pmid: 4147261].
Doran FS, White M, Drury M. A clinical trial designed to test the relative value of two simple methods of reducing the risk of venous stasis in the lower limbs during surgical operations, the danger of thrombosis, and a subsequent pulmonary embolus, with a survey of the problem. Br J Surg. 1970;57(1):20-30. [pmid: 4189930].
Eberle H. Anticoagulant prophylaxis of thromboembolism in fractures of the pelvic area. Discussion. Hefte Unfallheilkd. 1968;97:64. [pmid: 5712851].
Elster BB, Eisenstadt HB. Prolonged anticoagulant therapy for ambulatory patients. Tex State J Med. 1952;48(1):14-8. [pmid: 14893226].
Enoxaparin In Postoperative Prophylaxis: Synthese Des Etudes De L'enoxaparine En Prevention Post-Operatoire. Les Derniers Jours De L'heparine Standard Sont-Ils Comptes?. Concours Med. 1991;113(15):1263-7.
Erdi A, Baranyai L. Incidence of pulmonary embolism at our clinic following introduction of heparin therapy by small subcutaneous doses. Orv Hetil. 1978;119(7):395-7. [pmid: 625413].
Eriksson BI, Bauer KA, Lassen MR, Turpie AG. Fondaparinux compared with enoxaparin for the prevention of venous thromboembolism after hip-fracture surgery. N Engl J Med. 2001;345(18):1298-304. [pmid: 11794148].
Eriksson BI, Lassen MR. Duration of prophylaxis against venous thromboembolism with fondaparinux after hip fracture surgery: a multicenter, randomized, placebo-controlled, double-blind study. Arch Intern Med. 2003;163(11):1337-42. [pmid: 12796070].
Falga C, Capdevila JA, Soler S, et al. Clinical outcome of patients with venous thromboembolism and renal insufficiency. Findings from the RIETE registry. 2007;98:771-6.
Famularo G, Gasbarrone L, Minisola G, De Simone C. Systemic bleeding in a patient with enoxaparin-induced thrombocytopenia. Am J Emerg Med. 2009;27(6):756.e1-2. [pmid: 19751647].
Fargen KM, Bhasin RR, Murad GJ. Abdominal craniectomy implantation and thromboembolism prophylaxis resulting in wound hematoma. Neurosurgery. 2010;67(2):495-7. [pmid: 20644438].
Fecher AM, O'Mara MS, Goldfarb IW, et al. Analysis of deep vein thrombosis in burn patients. Burns. 2004;30(6):591-3. [pmid: 15302428].
Feldkamp AM. Thrombosis prevention: One year assessment of first oral factor Xa inhibitor rivaroxaban: Thromboseprophylaxe: 1-Jahres-bilanz des ersten oralen faktor-Xa-inhibitors rivaroxaban. Klinikartz. 2009;38(11):516-7.
Ferguson REH, Critchfield A, LeClaire A, Ajkay N, Vasconez HC. Current practice of thromboprophylaxis in the burn population: A survey study of 84 US burn centers. 2005;31:964-6.
Ferrell A, Byrne TK, Robison G. Placement of inferior vena cava filters in bariatric surgical patients - Possible indications and technical considerations. 2004;14:738-43.
Fetzer E. Additional experiences in prophylaxia and therapy of thrombosis and embolism. Med Klin (Munich). 1952;47(20):686-7. [pmid: 14956627].
Fiessinger JN, Aiach M, Housset E. Heparin therapy at low doses in the prevention of surgical phlebitis. Rev Prat. 1975;25(59):4727-30. [pmid: 766145].
Filipecki S, Hajduk B, Tomkowski W. Prevention of pulmonary thromboembolism using inferior vena cava filters: Profilaktyka zatorowosci plucnej przy uzyciu filtrow wprowadzanych przezskornie do zyly glownej dolnej. Pneumonol Alergol Pol. 1994;62(3-4):127-31. [pmid: 8061636].
Flanc C, Kakkar VV, Clarke MB. Lancet. Postoperative deep-vein thrombosis. Effect of intensive prophylaxis. 1969;1:477-8. [pmid: 4179566].
Foley PJ, Nathan DP, Wang GJ, et al. A “fall-back” technique for difficult inferior vena cava filter retrieval. J Vasc Surg. 2012.
Forette B, Wolmark Y. Calcium nadroparin in the prevention of thromboembolic disease in elderly subjects. Study of tolerance. Presse Med. 1995;24(12):567-71. [pmid: 7770402].
Fossard DP, Corrigan T, Spindler JJ, Kakkar VV. Low doses of heparin in the prevention of postoperative D.V.T.--a double-blind trial. Br J Surg. 1972;59(11):914. [pmid: 4564762].
Francis CW, Berkowitz SD, Comp PC, et al. Comparison of ximelagatran with warfarin for the prevention of venous thromboembolism after total knee replacement. N Engl J Med. 2003;349(18):1703-12. [pmid: 14585938].
Francis CW, Pellegrini VD, Stulberg BN, McCollister Evarts C, Totterman S, Marder VJ. Antithrombin III/Low dose heparin versus dextran 40 in prevention of venous thrombosis following total knee arthroplasty. Thrombosis and Haemostasis. 1989;62(1):41.
Franco RDM, Simezo V, Bortoleti RR, et al. Venous thromboembolism prophylaxis at a teaching hospital: Profilaxia para tromboembolismo venoso em um hospital de ensino. J. Vasc. Bras. 2006;5(2):131-8.
Freeark RJ, Boswick J, Fardin R. Archives of Surgery. Posttraumatic venous thrombosis. 1967;95:567-75. [pmid: 5006628].
Fryburg K, Nguyen HS, Cohen-Gadol AA. Spontaneous acute subdural hematoma due to fondaparinux: Report of two cases. Surg Neurol Int. 2011;2:44. [pmid: 21660271].
Funk L, Cohen A, Woodcock N, Roy B, Bradley JG. Comparison of the efficacy and safety of the A-V impulse system with that of enoxaparin in the prophylaxis of deep venous thrombosis in total knee arthroplasty. Journal of Bone and Joint Surgery - British Volume. 2000;82(Suppl 1):62.
Fuochi C, Furlan F, Pellegrini M, Moser E, Dalla Palma F. Criteri dell'utilizzazione e indicazioni all'uso dei filtri endocavali definitivi e temporanei con durata breve e media. Esperienza personale e revisione della letteratura: Criteria for use and indications for definitive and short- and mid-duration temporary endocaval filters. Personal experience and literature review. 1996;92:431-7.
Gadzhiev MG. Hemostatic indices in combined injuries of the head and thorax. Vestn Khir Im I I Grek. 1984;132(2):54-6. [pmid: 6719722].
Garcia-Ortega P, Asencio J. Dabigatran offers the simplest solution for thromboprophylaxis after orthopaedic surgery in patients allergic to low-molecular-weight heparins. Br J Haematol. 2010;151(1):84-5. [pmid: 20618326].
Gehrmann G. Neurologic complications in anticoagulant therapy. Med Welt. 1971;9:327-9. [pmid: 4101784].
Gergen M, Spenrath I, Wagner E. Nature and prevention of thromboembolism in accident surgery. Chirurg. 1968;39(8):366-8. [pmid: 4971310].
Gerosa C, Calvani AB, Cornelli U, et al. A multicenter study of defibrotide in the prevention of deep venous thrombosis. Final results. Minerva Chir. 1989;44(10):1507-16. [pmid: 2671797].
Giehl HJ. On pulmonary embolism--with a report on first experiences with subcutaneous heparin prophylaxis. Dtsch Gesundheitsw. 1967;22(39):1829-32. [pmid: 5600033].
Given MF, McDonald BC, Brookfield P, et al. Retrievable Gunther Tulip inferior vena cava filter: experience in 317 patients. J Med Imaging Radiat Oncol. 2008;52(5):452-7. [pmid: 19032390].
Goinard P, Pelissier G, Bernollin F. Our current practice of preventive anticoagulant therapy. Mem Acad Chir (Paris). 1961;87:486-91. [pmid: 13706341].
Goinard P, Thouverez JP, Belleville JF, Croizat P. An effective heparin treatment by subcutaneous route in general surgery. Lyon Chir. 1967;63(4):600-3. [pmid: 5613088].
Goldman KA, Adelman MA. Cardiovascular Surgery. Retroperitoneal caval filter as a source of abdominal pain. 1994;2:85-7. [pmid: 8049932].
Golob JF Jr, Sando MJ, Kan JC, Yowler CJ, Malangoni MA, Claridge JA. Therapeutic anticoagulation in the trauma patient: is it safe?. Surgery. 2008;144(4):591-6. discussion 596-7. [pmid: 18847643].
Gonzalez-Martin G, Diaz-Molinas MS, Martinez AM, Ortiz M. Heparin-induced hyperkalemia: a prospective study. Int J Clin Pharmacol Ther Toxicol. 1991;29(11):446-50. [pmid: 1800392].
Goudable C, Ton That H, Damani A. Thrombosis Research: Low molecular weight heparin half life is prolonged in haemodialysed patients. 1986;43:1-5.
Gouin-Thibault I, Liard F, Van-Ganse E, Vespa L, Gaudin A-F, Nachit-Ouinekh F. Comparison of platelet monitoring in patients receiving thromboprophylaxis with fondaparinux or a low molecular weight heparin. The Ariane study: Etude Ariane : comparaison de la surveillance plaquettaire chez des patients recevant une thromboprophylaxie par fondaparinux ou HBPM. Presse Med. 2011.
Grace DL. Prophylactic low-dose aspirin therapy in patients having hip-fracture surgery or elective arthroplasty. J Bone Joint Surg Am. 2001;83-A(8):1277-8. [pmid: 11507140].
Grandi A, Parodi JC, Rotondaro D, Soffer F, Alle E. Prevention of post-operative phlebothrombosis. Medicina (B Aires). 1979;39(3):379-83. [pmid: 514058].
Green B, Greenwood M, Saltissi D, et al. Dosing strategy for enoxaparin in patients with renal impairment presenting with acute coronary syndromes. 2005;59:281-90.
Green D, Sullivan S, Simpson J, Soltysik RC, Yarnold PR. Evolving risk for thromboembolism in spinal cord injury (SPIRATE Study). Am J Phys Med Rehabil. 2005;84(6):420-2. [pmid: 15905655].
Green L, Lawri AS, Patel S, et al. A comparison of rivaroxaban and fragmin prophylaxis after high risk orthopaedic surgery on thrombin generation test. Br. J. Haematol. 2010;149:13.
Greenfield LJ, Cho KJ, Pais SO, Aman MV. Archives of Surgery. Preliminary clinical experience with the titanium Greenfield vena caval filter. 1989;124:657-9. [pmid: 2658916].
Greenfield LJ, Proctor MC, Fischer DF Jr. Journal of Vascular Surgery. Suprarenal filter placement. 1998;28:432-8. [pmid: 9737452].
Greenfield LJ, Proctor MC, Rodriguez JL, Luchette FA, Cipolle MD, Cho J. Posttrauma thromboembolism prophylaxis. J Trauma. 1997;42(1):100-3. [pmid: 9003265].
Greep Jm, Martis Ee, Van Alkemadep, Prinsen Je. Thrombosis Prevention With Anticoagulants. Ned Tijdschr Geneeskd. 1963;107:2085-91. [pmid: 14097756].
Greinacher A, Lubenow N, Eichler P. Anaphylactic and anaphylactoid reactions associated with lepirudin in patients with heparin-induced thrombocytopenia. Circulation. 2003;108(17):2062-5. [pmid: 14568897].
Gruber UF, Allemann U, Wettler H. 1st direct comparison of allergic side effects of dextran with and without hapten. Schweiz Med Wochenschr. 1982;112(17):605-12. [pmid: 6178151].
Gruber UF, Brun M, Brunner R, et al. S.c. heparin or i.v. dextran?. Helv Chir Acta. 1979;46(1-2):65-8. [pmid: 468583].
Gruber UF, Hohl M, Sturm V. Intra- and postoperative prevention of thrombosis. Klin Anasthesiol Intensivther. 1975;9:17-35. [pmid: 1234606].
Gruber UF. Dextran and the prevention of postoperative thromboembolic complications. Surg Clin North Am. 1975;55(3):679-96. [pmid: 1169822].
Gunduz S, Ogur E, Mohur H, Somuncu I, Acjksoz E, Ustunsoz B. Deep vein thrombosis in spinal cord injured patients. Paraplegia. 1993;31(9):606-10. [pmid: 8247603].
Haas S, Breyer HG, Misselwitz F, Weber J, Viktor N. Prevention of severe venous thromboembolism in patients undergoing total hip or knee replacement. A randomised comparison of low molecular weight heparin (reviparin) with unfractionated heparin. The echos trial. Annals of Hematology. 2002;81:A26.
Hainer JW, Sherrard DJ, Swan SK, et al. American Journal of Kidney Diseases. Intravenous and subcutaneous weight-based dosing of the low molecular weight heparin tinzaparin (Innohep) in end-stage renal disease patients undergoing chronic hemodialysis. 2002;40:531-8. [pmid: 12200805].
Hakki SI, Fareed J, Hoppensteadt DA, et al. Plasma tissue factor pathway inhibitor levels as a marker for postoperative bleeding after enoxaparin use in deep vein thrombosis prophylaxis in orthopedics and general surgery. Clin Appl Thromb Hemost. 2000;6(4):206-12. [pmid: 11030526].
Hameed MF, Browse DJ, Immelman EJ, Goldberg PA. Should knee-length replace thigh-length graduated compression stockings in the prevention of deep-vein thrombosis?. S Afr J Surg. 2002;40(1):15-6. [pmid: 12082962].
Harenberg J, Roebruck P, Heinrich F, Schmitz-Huebner J, Heene DL. A randomized double blind trial of low molecular weight heparin for prophylaxis of thromboembolism in medical inpatients. Thrombosis and Haemostasis. 1993;69(6):648. Abstract no: 380.
Harenberg J, Schomaker U, Flosbach CW. Enoxaparin is superior to unfractionated heparin in the prevention of thromboembolic events in medical patients at increased thromboembolic risk. 1999:94.
Harries SR, Wells IP, Roobottom CA. Clinical Radiology. Long-term follow-up of the Antheor inferior vena cava filter. 1998;53:350-2. [pmid: 9630273].
Harter HR, Burch JW, Majerus PW, Stanford N, Delmez JA, et al. Prevention of thrombosis in patients on hemodialysis by low dose aspirin: Prevention of thrombosis in patients on hemodialysis by low dose aspirin. New England Journal of Medicine (USA). 1979;301:577-9.
Hauck W, Seyfert UT. Comparison of body-weight adapted LMWH and fixed dosed LMWH in the prevention of thrombosis after prosthetic knee replacement therapy. Annals of Hematology. 2001;80:A25.
Hauptfleisch J, Hawkins M, Bratby M, Anthony S, Uberoi R. Retrievability of IVC filters. Cardiovasc. Intervent. Radiol. 2010;33:308.
Hawkins SP, Al-Kutoubi A. Clinical Radiology. The Simon nitinol inferior vena cava filter: Preliminary experience in the UK. 1992;46:378-80. [pmid: 1493649].
Hedlund T, Bergqvist D, Efsing HO, Hallbook T. Thromboembolism after elective and post-traumatic hip surgery. A controlled prophylactic trial with dextran and low-dose heparin. Acta Orthopaedica Scandinavica. 1980;51:382-3.
Heffline MS. Preventing vascular complications after gastric bypass. J Vasc Nurs. 2006;24(2):50-4. quiz 55. [pmid: 16737930].
Heinzl S. Intensive care unit: Dalteparin versus unfractionated heparin in the thrombosis prevention: Intensivstation: Dalteparin versus unfraktioniertes heparin in der thromboseprophylaxe. Krankenhauspharmazie. 2011;32(7):420.
Heit JA, Elliott CG, Trowbridge AA, Morrey BF, Gent M, Hirsh J. Ardeparin sodium for extended out-of-hospital prophylaxis against venous thromboembolism after total hip or knee replacement. A randomized, double-blind, placebo-controlled trial. Ann Intern Med. 2000;132(11):853-61. [pmid: 10836911].
Heizmann M, Baerlocher GM, Steinmann F, Horber FF, Wuillemin WA. Anti-Xa activity in obese patients after double standard dose of nadroparin for prophylaxis. 2002;106:179-81.
Hergenroeder GW, Levine RL, Miller III CC. Thromboembolism prophylaxis in end-stage renal disease. 2008;37(11):439-44.
Hernandez-Vaquero D. The risk of thromboembolism in prosthetic surgery of the hip, and its prevention by administration of individualized heparin dosages. Acta Orthop Belg. 1990;56(2):445-50. [pmid: 2239191].
Herner SJ, Paulson DC, Delate T, Witt DM, Vondracek TG. Evaluation of venous thromboembolism risk following hospitalization. J Thromb Thrombolysis. 2011;32(1):32-9. [pmid: 21193946].
Hildebrandt G, Stintz AR. Prevention of thromboembolism in accident surgery. Zentralbl Chir. 1969;94(47):1605-9. [pmid: 5370643].
Hill SL, Berry RE, Ruiz AJ. Deep venous thrombosis in the trauma patient. Am Surg. 1994;60(6):405-8. [pmid: 8198328].
Hiromatsu S, Nata S, Ohno T, et al. Non-permanent inferior vena cava filters for prophylaxis and treatment of lower limb venous thromboembolism. Vasc Endovascular Surg. 2010;44(8):668-73. [pmid: 20724287].
Hirsch DR, Ingenito EP, Goldhaber SZ. Prevalence of deep venous thrombosis among patients in medical intensive care. JAMA. 1995;274(4):335-7. [pmid: 7609264].
Hirsh J, Warkentin TE, Raschke R, Granger C, Ohman EM, Dalen JE. Chest. Heparin and low-molecular-weight heparin: Mechanisms of action, Pharmacokinetics, dosing considerations, monitoring, efficacy, and safety. 1998;114:489S-510S. [pmid: 9822059].
Hitos K, Rogers J, Soo G, et al. A prospective study on venous thromboembolism following spinal surgery: Use of thromboprophylaxis and associated bleeding complications. J. Thromb. Haemost. 2011;9:399-400.
Hlavaty TS, McCowan TC, Ferris EJ, Carver DK, Harris DL, Barnes RW. The Journal of the Arkansas Medical Society. Experience with the Kimray-Greenfield inferior vena caval filter. 1991;88:215-7. [pmid: 1804837].
Hoffmann R, Kohler A, Platz A, et al. Prevention of deep vein thrombosis (DVT) in hip surgery: Low molecular weight heparin (sandoparin) versus 3 × 5000 I.U. UF- heparin. Thrombosis and Haemostasis. 1993;69(6):1055. Abstract no:. 1823.
Hoffmann R, Largiader F. Thromboembolism prophylaxis and the surgeon - Two risk factors of Postoperative Bleeding?: Die Thromboembolieprophylaxe Und Der Chirurg - Zwei Risikofaktoren Der Postoperativen Blutung?. 1995;30(5):264-70.
Holmgren E, Haglund G. Prevention of thrombosis using heparin in neurosurgical intervention. Lakartidningen. 1980;77(7):499-500. [pmid: 7374281].
Hoppe H, Kaufman JA, Barton RE, et al. Safety of inferior vena cava filter retrieval in anticoagulated patients. Chest. 2007;132(1):31-6. [pmid: 17505040].
Hory B, Cachoux A, Saunier F, et al. Comparative study of heparin and a very low molecular-weight heparin in hemodialysis in chronic renal insufficiency. Presse Med. 1987;16(19):955-8. [pmid: 2954145].
Howard DP. Acute thromboembolism in medical inpatients: the need for a focus on prevention rather than cure. Clin Med. 2006;6(1):117-8. [pmid: 16521369].
Huk M, Lynsky D, O'Cahaghan T, Campbei R. Compliance of sequential compression device for deep vein thrombosis prophylaxis in the adult trauma patient: Surgical intensive care unit vs. intermediate care. 1998;26(1 SUPPL.).
Hull R, Carter C, Turpie AG, et al. A randomized trial of sequential pneumatic limb compression in the prevention of venous thromboembolism following elective hip surgery [abstract no:0190]. Thrombosis and Haemostasis. 1983;50(1):66.
Hull RD, Raskob GE, Pineo GF, American-Canadian Orthopedic Clinical Trials Group. Low molecular weight heparin (logiparin) compared with less intense warfarin prophylaxis against venous thromboembolism following major elective hip surgery. Clinical Research. 1992;40(2):318A.
Hull RD, Schellong SM, Tapson VF. Extended-duration venous thromboembolism (VTE) prophylaxis in acutely ill medical patients with recent reduced mobility: The EXCLAIM study. 2007;5:O. S-001.
Hume M, Acuna H. Method of prevention of pulmonary embolism with an individual therapy for each patient. Angiologia. 1980;32(4):158-64. [pmid: 7396236].
Huo M, Eriksson B, Dahl O, et al. Oral dabigatran versus enoxaparin for thromboprophylaxis after primary total hip arthroplasty: The re-novate II randomised trial. Haematologica. 2010;95:233.
Iablokov EG, Savel'ev SV, Kirienko AI, Maliutina IG, Matiushenko AA. Results of intravenous filter inplantation. Vestn Khir Im I I Grek. 1980;124(5):3-7. [pmid: 7423757].
INSINGER FG. Prophylactic use of anticoagulants. Ned Tijdschr Geneeskd. 1957;101(47):2240-2. [pmid: 13504292].
Jackson DR, Harrower HW. Pulmonary embolization following inferior vena caval interruption. Vasc Surg. 1969;3(3):129-37. [pmid: 4901052].
Jaff MR, Goldhaber SZ, Tapson VF. High utilization rate of vena cava filters in deep vein thrombosis. Thromb Haemost. 2005;93(6):1117-9. [pmid: 15968397].
Jaffe D, Noff M, Peer A, Chen D, Bass A, Halperin N. Prophylaxis against deep-vein thrombosis in total knee replacement: comparison of low molecular weight heparin and the A-V Impulse System. Journal of Bone and Joint Surgery British Volume. 1999;81(Suppl 1):71.
Jancar P, Morgan T, Mrhar A, Kosnik M, Lainscak M. Venous thromboembolism prophylaxis in hospitalized patients with pneumonia: a prospective survey. Wien Klin Wochenschr. 2009;121(9-10):318-23. [pmid: 19562294].
Jansen H. Postoperative thromboembolism and its prevention with 500 ml dextran given during operation with a special study of the venous flow pattern in the lower extremities. Acta Chir Scand Suppl. 1972;427:1-73. [pmid: 4118154].
Jaras Hernandez, Agudo de Blas P, Gonzalez Polo J, et al. Low Molecular Weight Heparin use in Internal Medicine hospitalized patients. An Med Interna. 2006;23(7):347-54. [pmid: 17067238].
Jenkins I, Helmons PJ, Martin-Armstrong LM, Montazeri ME, Renvall M. High rates of venous thromboembolism prophylaxis did not increase the incidence of heparin-induced thrombocytopenia. Jt Comm J Qual Patient Saf. 2011;37(4):163-9. [pmid: 21500716].
Jeske WP, Walenga JM, Samama MM, Hoppensteadt D, Mayuga M, Fareed J. Functionality of fondaparinux (pentasaccharide) depends on clinical antithrombin levels. Blood Coagul Fibrinolysis. 2011;22(3):206-10. [pmid: 21297455].
Johansson H, Nordlund S, Holmqvist B. Prevention of thrombosis with heparin administered subcutaneously. Nord Med. 1961;66:1108-12. [pmid: 13790192].
Johnson Iii ON, Gillespie DL, Aidinian G, White PW, Adams E, Fox CJ. The use of retrievable inferior vena cava filters in severely injured military trauma patients. 2009;49:410-6.
Johnson SP, Raiken DP, Grebe PJ, Diffin DC, Leyendecker JR. Journal of Vascular and Interventional Radiology. Single institution prospective evaluation of the over-the-wire greenfield vena caval filter. 1998;9:766-73. [pmid: 9756064].
JOHOW R. Favorable and untoward results in anticoagulant prophylaxis of thrombosis and embolism, with special reference to the use of dicumarol. Geburtshilfe Frauenheilkd. 1950;10(12):898-914. [pmid: 14802740].
Juhan-Vague I, Aillaud MF, Serradimigni A. Natural inhibitors of fibrinolysis. Haemostasis. Suppl 4. 1986;16:16-20.
Juliard J-M. Prevention of thromboembolism after orthopedic surgery: Apixaban versus enoxaparin: Prevention des evenements thrombo-emboliques apres chirurgie orthopedique: Apixaban versus enoxaparine. Sang Thromb. Vaiss. 2010;22(1):9-10.
Kaempffe FA, Lifeso RM, Meinking C. Intermittent pneumatic compression versus coumadin. Prevention of deep vein thrombosis in lower-extremity total joint arthroplasty. Clin Orthop Relat Res. 1991;269:89-97. [pmid: 1864061].
Kahn SR, Panju A, Geerts W, et al. Multicenter evaluation of the use of venous thromboembolism prophylaxis in acutely ill medical patients in Canada. 2007;119:145-55.
Kakkar VV, Field ES, Nicolaides AN. Prevention of postoperative deep-vein thrombosis using heparin. Br J Surg. 1971;58(11):872-3. [pmid: 5124909].
Kakkar VV. Low-doses of heparin in the prevention of deep vein thrombosis. Bull Schweiz Akad Med Wiss. 1973;29(4):235-43. [pmid: 4771352].
Kakkar VV. The logistic problems encountered in the multicenter trial of low-dose heparin prophylaxis. Thromb Haemost. 1979;41(1):105-13. [pmid: 384580].
Kalva SP, Chlapoutaki C, Wicky S, Greenfield AJ, Waltman AC, Athanasoulis CA. Suprarenal inferior vena cava filters: a 20-year single-center experience. J Vasc Interv Radiol. 2008;19(7):1041-7. [pmid: 18589318].
Kanan PS, Schwartsmann CR, Boschin LC, Conrad S, Silva MF. Comparative study between rivaroxaban and enoxaparin in deep venous thromboembolism prophylaxis in patients submitted to total hip arthroplasty. Revista Brasileira De Ortopedia. 2008;43(8):319-28.
Kanazirski P, Denchev V, Levcheva V. Anticoagulant Prevention Of Postoperative Thrombo-embolic complications. Suvr Med (Sofiia). 1961;12(4-5):87-95. [pmid: 14453539].
Kantor A, Glanz S, Gordon DH, Sclafani SJ. American Journal of Roentgenology. Percutaneous insertion of the Kimray-Greenfield filter: incidence of femoral vein thrombosis. 1987;149:1065-6. [pmid: 3499776].
Kaplan J, Marciniak C, Chen D. Retrospective study comparing the safety and efficacy of enoxaparin vs tinzaparin in the prevention of venous thromboembolic disorders during rehabilitation following acute SCI. J. Spinal Cord Med. 2009;32(4):466.
Kappa JR, Fisher CA, Berkowitz HD, Cottrell ED, Addonizio VP Jr. Heparin-induced platelet activation in sixteen surgical patients: diagnosis and management. J Vasc Surg. 1987;5(1):101-9. [pmid: 2432283].
Kastan DJ, Forcler NJ, Kahn ML. Simon nitinol vena cava filter: preliminary observations and suggested procedural modifications. J Vasc Interv Radiol. 1991;2(1):123-4. [pmid: 1799741].
Kazmers A, Ramnauth S, Williams M. American Surgeon. Intraoperative insertion of Greenfield filters: Lessons learned in a personal series of 152 cases. 2002;68:877-82. [pmid: 12412714].
Khatod M, Inacio MC, Bini SA, Paxton EW. Pulmonary Embolism Prophylaxis in More Than 30, 000 Total Knee Arthroplasty Patients: Is There a Best Choice?. J Arthroplasty. 2011.
Kiesewetter Wb, Shumacker Hb Jr. An experimental study of the comparative efficacy of heparin and dicumarol in the prevention of arterial and venous thrombosis. Surg Gynecol Obstet. 1948;86(6):687-702. [pmid: 18915940].
Kiguchi M, McDonald KA, Govindarajan S, Makaroun MS, Chaer RA. Pharmacomechanical thrombolysis for renal salvage after filter migration and renal vein thrombosis. J Vasc Surg. 2011;53(5):1391-3. [pmid: 21215557].
Kiil J, Kiil J, Axelsen F. Heparin in low dosage as prophylaxis of postoperative pulmonary embolism and deep venous thrombosis. Ugeskr Laeger. 1978;140(21):1224-30. [pmid: 351904].
Kiil J, Moller JC. Postoperative deep venous thrombosis in lower limbs and preventive value of heparin in low dosage evaluated by phlebography. Ugeskr Laeger. 1978;140(21):1221-4. [pmid: 664072].
Kim D, Edelman RR, Margolin CJ, et al. Angiology. The Simon nitinol filter: Evaluation by MR and ultrasound. 1992;43:541-8. [pmid: 1626731].
Kim HS, Young MJ, Narayan AK, Hong K, Liddell RP, Streiff MB. A Comparison of Clinical Outcomes with Retrievable and Permanent Inferior Vena Cava Filters. 2008;19:393-9.
Klein-Weigel P, Richter J, Arendt U, et al. Quality management in the prophylaxis of venous thrombembolism--results of a survey including 464 medical and surgical patients. Vasa. 2011;40(2):123-30. [pmid: 21500177].
Knezevic S. Role Of Anticoagulant Therapy In The Prevention Of Venous Thrombosis And Pulmonary Embolism. Med Glas. 1964;18:217-9. [pmid: 14271404].
Kniepkamp G. Experience in postoperative prevention and therapy of thromboembolism with special reference to the double test; Quick test and heparin tolerance test. Geburtshilfe Frauenheilkd. 1957;17(9):845-51. [pmid: 13474239].
Kock HJ, Schmitt-Neuerburg KP, Hanke J, Hakmann A, Althoff M, Rudofsky G. Prophylaxis of venous thromboembolism with low molecular weight heparin in surgical outpatients with immobilization of the lower limb by plaster cast. Hamostaseologie. 1993;13(Suppl):S36-S39.
Koller F. Clinical evaluation of anticoagulants. Internist (Berl). 1969;10(1):8-15. [pmid: 4906439].
Kosch L. Three Years Of Experience With Medicinal Postoperative Thrombosis Prevention. Zentralbl Gynakol. 1957;79(31):1221-5. [pmid: 13486885].
Kostler H. Therapy And Prophylaxis Of Thrombosis With A New Anticoagulant Of The Heparin Group. Med Klin (Munich). 1956;51(15):646-9. [pmid: 13347888].
Kovacic M, Pistotnik M, Grgcevic D, Krivec O, Radej M, Parazajder J. Prevention of postoperative thromboembolic disease. Lijec Vjesn. 1975;97(11):607-10. [pmid: 1226048].
Kretzschmar G. Hazards of postoperative prevention of thrombosis. Beitr Orthop Traumatol. 1966;13(12):813-4. [pmid: 5984253].
Krueger Bj, Cramer W. Fatal pulmonary artery embolism and anticoagulant prophylaxis. Bruns Beitr Klin Chir. 1961;203:453-61. [pmid: 14459885].
Kruse-Blinkenberg HO, Gormsen J. Heparin concentration in blood pre- and postoperatively in surgical patients with low dosage heparin prophylaxis. Ugeskr Laeger. 1976;138(12):745-7. [pmid: 1258194].
Kucera T, Maly R, Urban K, Sponer P. Venous thromboembolism prophylaxis after total hip arthroplasty: Prevence tromboembolické nemoci po implantaci totální endoprotézy kyčelního kloubu. 2011;78(2):101-5.
Kucher N, Koo S, Quiroz R, et al. Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med. 2005;352(10):969-77. [pmid: 15758007].
Kucher N. Clinical practice. Deep-vein thrombosis of the upper extremities. N Engl J Med. 2011;364(9):861-9. [pmid: 21366477].
Kudrnova Z, Kvasnicka J, Kudrna K, et al. Favorable coagulation profile with fondaparinux after hip surgery in elderly patients. Int J Hematol. 2009;90(4):476-82. [pmid: 19838769].
Kuo PC, Plotkin JS, Stevens S, Cribbs A, Johnson LB. Outcomes of laparoscopic donor nephrectomy in obese patients. Transplantation. 2000;69(1):180-2. [pmid: 10653400].
Kushelevskii BP, Seliverstova GP. Prolonged therapeutic-prophylactic use of anticoagulants. Klin Med (Mosk). 1973;51(4):26-8. [pmid: 4704262].
Kushelevskii BP, Shmidt ED. Significance of thrombosis and embolism in general hospital mortality and preventive role of anticoagulants. Klin Med (Mosk). 1958;36(5):22-8. [pmid: 13550677].
Labarere J, Bosson J-L, Pernod G. More on: Incorrect use of thromboprophylaxis for venous thromboembolism in medical and surgical patients: Results of a multicentric, observational, and cross-sectional study in Brazil. 2006;4(12):2737-8.
Lacut K, Delluc A, Vignon P, et al. Intermittent pneumatic compression to prevent venous thromboembolism in patients hospitalized in intensive medical care units with high risk of bleeding: A randomized trial. J. Thromb. Haemost. 2011;9:302-3. [pmid: 21781266].
Lahnborg G, Bergstrom K, Friman L, Lagergren H. Effect of low-dose heparin on incidence of postoperative pulmonary embolism detected by photoscanning. Lancet. 1974;1(7853):329-31. [pmid: 4131170].
Lai JM, Yablon SA, Ivanhoe CB. Incidence and sequelae of symptomatic venous thromboembolic disease among patients with traumatic brain injury. Brain Inj. 1997;11(5):331-4. [pmid: 9146838].
Lai S, Barbano B, Cianci R, et al. The risk of bleeding associated with low molecular weight heparin in patients with renal failure. G Ital Nefrol. 2010;27(6):649-54. [pmid: 21132647].
Lande M, Paulet C, Pras N, Martignon N. Postoperative preventive anticoagulant therapy. Apropos of 1200 cases. Phlebologie. 1975;28(1):107-15. [pmid: 1202518].
Lassen ML, Borris LC, Christiansen HM, et al. Low molecular weight heparin in the prevention of thromboembolism in elective total hip replacement. Thrombosis and Haemostasis. 1989;62(1):126.
Lassen MR, Dahl OE, Mismetti P, Destree D, Turpie AG. AVE5026, a new hemisynthetic ultra-low-molecular-weight heparin for the prevention of venous thromboembolism in patients after total knee replacement surgery--TREK: a dose-ranging study. J Thromb Haemost. 2009;7(4):566-72. [pmid: 19187076].
Lassen MR, Davidson BL, Gallus A, Pineo GF, Ansell J, Deitchman D. A phase II randomized, double-blind, five-arm, parallel-group, dose-response study of a new oral directly-acting factor Xa inhibitor, razaxaban, for the prevention of deep vein thrombosis in knee replacement surgery. Blood. 2003;102(11):15a. Abstract 41.
Lassen MR, Eriksson BI, Bauer KA, et al. Pentasaccharide (fondaparinux, Arixtra) versus enoxaparin for the prevention of venous thromboembolism (VTE) in major orthopedic surgery: subgroup analyses on efficacy. Blood. 2001;98:266a. [pmid: 11435292].
Lavrinovich TS, Petukhova LI, Slutskii LI. Clinical trial of indirect-action anticoagulants in orthopedics and traumatology. Ortop Travmatol Protez. 1976;3:32-5. [pmid: 790254].
Le Quesne LP, Bramble J, Gordon-Smith IC, Grundy D, Newcombe J. A trial of two different regimes of subcutaneous heparin in the prophylaxis of deep-vein thrombosis. Br J Surg. 1972;59(4):300. [pmid: 4553588].
Leclerc J, Geerts W, Desjardins L, Jobin F, Delorme F, Bourgouin J. A randomized trial of enoxaparin for the prevention of deep vein thrombosis after major knee surgery. Thrombosis and Haemostasis. 1991;65(6):753.
Leclerc JR, Geerts WH, Desjardins L, et al. Prevention of venous thromboembolism (VTE) after knee arthroplasty - a randomized, double-blind trial, comparing a low molecular weight heparin fragment (enoxaparin) to warfarin. Blood. 1994;84(Suppl 1):246a. Abstract no: 969.
Leclerc JR, Gent M, Hirsh DR. The incidence of symptomatic venous thromboembolism during and after prophylaxis with enoxaparin. 1998;127:439-45.
LEHMANN J. Prevention of thromboembolism with a hirudoid ointment foam rubber bandage. Dtsch Med Wochenschr. 1954;79(41):1516-7. [pmid: 13220107].
Leizorovicz A. Comparison of two doses of low molecular weight heparin and standard low dose heparin in the prevention of post-operative vein thrombosis (DVT). Thrombosis and Haemostasis. 1989;62(1):521. Abstract no: 1641.
Lentine KL, Flavin KA, Gould MK. Chest. Variability in the use of thromboprophylaxis and outcomes in critically ill medical patients. 2002:122. [pmid: 12114347].
Lenzini PA, Grice GR, Milligan PE, et al. Laboratory and clinical outcomes of pharmacogenetic vs. clinical protocols for warfarin initiation in orthopedic patients. J Thromb Haemost. 2008;6(10):1655-62. [pmid: 18662264].
Lewalle J. Application in the surgical service of the postoperative prevention of thromboembolic accidents by means of anticoagulants. Acta Chir Belg. 1961;60:684-7. [pmid: 14464810].
Lidagoster MI, Widmann WD, Chevinsky AH. Journal of Vascular Surgery. Superior vena cava occlusion after filter insertion [3]. 1994;20:158-9. [pmid: 8028084].
Lie SA, Engesaeter LB, Havelin LI, Furnes O, Vollset SE. Early postoperative mortality after 67,548 total hip replacements: causes of death and thromboprophylaxis in 68 hospitals in Norway from 1987 to 1999. Acta Orthop Scand. 2002;73(4):392-9. [pmid: 12358110].
Lieberman DV, Lieberman D. Proximal deep vein thrombosis after hip fracture surgery in elderly patients despite thromboprophylaxis. Am J Phys Med Rehabil. 2002;81(10):745-50. [pmid: 12362114].
Lieberman JR, Huo MM, Hanway J, Salvati EA, Sculco TP, Sharrock NE. A comparison of pneumatic compression boots and aspirin versus aspirin alone in prevention of deep venous thrombosis after total hip arthroplasty: A randomized prospective trial [Abstract]. Orthopaedic Transactions. 1992;16(3):712-3.
Lingaas US, Storen EJ, Myhre HO. The practive of prophylactic anticoagulation in surgical patients. J Oslo City Hosp. 1972;22(7):109-17. [pmid: 5045731].
Looby S, Given MF, Geoghegan T, McErlean A, Lee MJ. Gunther Tulip retrievable inferior vena caval filters: Indications, efficacy, retrieval, and complications. 2007;30:59-65.
Looby S, Given MF, Geoghegan T, McErlean A, Lee MJ. Gunther Tulip retrievable inferior vena caval filters: indications, efficacy, retrieval, and complications. Cardiovasc Intervent Radiol. 2007;30(1):59-65. [pmid: 17122885].
Lorenz D, Reichold H. Prevention and therapy of postoperative thrombosis in the surgical hospitals of the German Federal Republic. Results of an inquiry. Med Klin. 1966;61(21):849-51. [pmid: 5988334].
Lotke PA, Callaghan JJ, Dorr LD, et al. Oral direct thrombin inhibitor ximelagatran compared with warfarin for the prevention of venous thromboembolism after total knee arthroplasty [9]. J. Bone Jt. Surg. Ser. A. 2006;88(5):1163.
Luders K, Konold P, Otten G, Koslowski L. Prevention of postoperative thromboembolism. Randomized, prospective study of the comparison of thromboembolism prevention using anticoagulants (Heparin-Marcumar) and dextran 60 (Macrodex). Chirurg. 1973;44(12):563-9. [pmid: 4594859].
Lund T. Routine measures in the prevention of postoperative thrombosis and embolism. Based on a multicentre trial of about 4000 patients with dextran or low-dose heparin prevention. Tidsskr Nor Laegeforen. 1980;100(22):1267-9. [pmid: 6160644].
Lynch FC. A method for following patients with retrievable inferior vena cava filters: results and lessons learned from the first 1,100 patients. J Vasc Interv Radiol. 2011;22(11):1507-12. [pmid: 21903414].
Lyon LJ, Nevins MA. Prevention of thromboembolism after hip fracture. Geriatrics. 1973;28(1):107-10. [pmid: 4566617].
Macouillard G, Castagnera L, Claverie JP, Janvier G, Maurette P. Prevention of deep venous thrombosis in spinal surgery: Comparison of intermittent sequential pneumatic compression versus low molecular weight heparin. Thrombosis and Haemostasis. 1993;69(6):646. Abstract no: 373.
Mahe I, Gouin-Thibault I, Drouet L, et al. Elderly medical patients treated with prophylactic dosages of enoxaparin: influence of renal function on anti-Xa activity level. Drugs Aging. 2007;24(1):63-71. [pmid: 17233548].
Mahlfeld K, Franke J, Schaeper O, Kayser R, Grasshoff H. Heparin-induced thrombocytopenia as a complication of postoperative prevention of thromboembolism with unfractionated heparin/low molecular weight heparin after hip and knee prosthesis implantation. Unfallchirurg. 2002;105(4):327-31. [pmid: 12066471].
Malinoski D, Ewing T, Patel MS, et al. Risk factors for venous thromboembolism in critically ill trauma patients who cannot receive chemical prophylaxis. Injury. 2011.
Malita IM, Cheveresan A, Dumitrascu V. Extended prophylaxis of venous thromboembolism, after hospital discharge, in Patients with knee arthroplasty. Basic Clin. Pharmacol. Toxicol. 2009;105:125.
Manktelow AR, Haddad FS, Powles DP. An unexpected complication of DVT prophylaxis. Acta Orthop Belg. 1997;63(2):134-5. [pmid: 9265802].
Mannucci PM, Citterio LE, Panajotopoulos N. Low-dose heparin and deep-vein thrombosis after total hip replacement. Thromb Haemost. 1976;36(1):157-64. [pmid: 1036806].
Marciniak CM, Kaplan J, Welty L, Chen D. Enoxaparin versus tinzaparin for venous thromboembolic prophylaxis during rehabilitation after acute spinal cord injury: a retrospective cohort study comparing safety and efficacy. PM R. 2012;4(1):11-7. [pmid: 22269449].
Maresch P. Prophylaxis of thromboembolism in orthopedics: Profylaxia tromboemb+¦lie v ortop+_dii. 2005;54(2):74-7.
Mariani F, Marone EM, Gasbarro V, et al. Multicenter randomized trial comparing compression with elastic stocking versus bandage after surgery for varicose veins. J Vasc Surg. 2011;53(1):115-22. [pmid: 21050700].
Markel DC, Morris GD. Effect of external sequential compression devices on femoral venous blood flow. J South Orthop Assoc. 2002;11(1):2-9. quiz 10. [pmid: 12741580].
Markwardt F. Prevention of thrombosis by means of toning of the veins. Folia Haematol Int Mag Klin Morphol Blutforsch. 1979;106(5-6):656-8. [pmid: 94860].
Marmor DB, Merli GJ, Whellan DJ, et al. Relationship of inferior vena cava filter usage in post-surgical patients by various surgical and medical subspecialists. Am J Cardiol. 2008;102(2):226-30. [pmid: 18602527].
Martyn DT, Janes JM. Continuous intravenous administration of heparin. Mayo Clin Proc. 1971;46(5):347-51. [pmid: 5578647].
Marx A, Huhle G, Hoffmann U, et al. Heparin-induced thrombocytopenia after elective hip joint replacement with postoperative prevention of thromboembolism with low-molecular-weight heparin. Z Orthop Ihre Grenzgeb. 1999;137(6):536-9. [pmid: 10666863].
Masekowitz B. Convincing study results of rivaroxaban for thrombosis prophylaxis: Thromboseprophylaxe: Rivaroxaban uberzeugt in studien. Pharm. Ztg. 2008;153(19):38.
Matis P, Mayer W, Nagel W. On the problem of occurrence of thromboembolism and hemorrhages during preventive inhibition of coagulation. Med Welt. 1961;37:1891-4. [pmid: 14471179].
Matis P. Results of Alternate Anticoagulant Prophylaxis In Surgery. Acta Orthop Belg. 1962;28:582-7. [pmid: 13933675].
Mayer W. Prevention of thromboembolism in surgery. Results--problems. Thromb Diath Haemorrh Suppl. 1967;23:1-86. [pmid: 5602353].
McCarthy ST, Turner JJ, Robertson D, Hawkey CJ, Macey DJ. Low-dose heparin as a prophylaxis against deep-vein thrombosis after acute stroke. Lancet. 1977;2(8042):800-1. [pmid: 71605].
McDowall RAW. Pulmonary embolism and deep venous thrombosis in burned patients. 1973;26:176-7.
McKeown L. In hospitalized patients … LMWH cuts thromboembolism risk by 50%: In hospitalized patients … LMWH cuts thromboembolism risk by 50%. Pharmacy Practice News (USA). 2003;30:6.
Mehra A, Jadhav A, Lone N, et al. Gender variations in venous thromboembolism pharmacologic prophylaxis and clinical outcomes. Chest. 2010;138(4).
Melon E, Keravel Y, Gaston A, Huet Y, Combes S. Anesthesiology. Deep venous thrombosis prophylaxis by low molecular weight heparin in neurosurgical patients. 75.
Mesfin A, Lum YW, Nayfeh T, Mears SC. Compartment syndrome in patients with massive venous thrombosis after inferior vena cava filter placement. Orthopedics. 2011;34(3):229. [pmid: 21410121].
Messmer JM, Greenfield LJ. Radiology. Greenfield caval filters: Long-term radiographic follow-up study. 1985;156:613-8. [pmid: 4023218].
Meyer CS, Blebea J, Davis Jr K, Fowl RJ, Kempczinski RF. Annals of Vascular Surgery. Surveillance venous scans for deep venous thrombosis in multiple trauma patients. 1995;9:109-14. [pmid: 7703054].
Meyerowitz BR. Pulmonary embolism in surgical patients: is embolectomy superior to prophylaxis?. Surgery. 1966;60(3):521-35. [pmid: 5913774].
Milch E, Berman L, Egan Rw. Bishydroxycoumarin (Dicumarol) prophylaxis. Use in the prevention of postoperative thromboembolic complications in surgical patients. Arch Surg. 1961;83:444-7. [pmid: 13770596].
Miller CL, Wechsler RJ. American Journal of Roentgenology. CT evaluation of Kimray-Greenfield filter complications. 1986;147:45-50. [pmid: 3487228].
Miller MT, Rovito PF. An approach to venous thromboembolism prophylaxis in laparoscopic Roux-en-Y gastric bypass surgery. Obes Surg. 2004;14(6):731-7. [pmid: 15318974].
Milone F, Iaccarino V, Musella M, et al. Interruption of the inferior vena cava in the prevention of pulmonary embolism. Chir Ital. 2005;57(4):479-84. [pmid: 16060186].
Mismetti P, Laporte-Simitsidis S, Tardy B, et al. Prevention of venous thromboembolism in internal medicine with unfractionated or low-molecular-weight heparins: A meta-analysis of randomised clinical trials. 2000;83:14-9.
Montesinos L, Gomez-Garrido A, Lluisa T-B, Lopez-F S, Angel G-VM, Ramirez L. Venous thromboembolism in patients with acute spinal cord injury. PM R. 2010;2(9):S172.
Montserrat I, Lopez D, Zuazu-Jausoro I, Perez M, de Moragas JM, Fontcuberta J. Low-molecular-weight subcutaneous heparin-induced skin necrosis. Blood Coagul Fibrinolysis. 1990;1(6):751-2. [pmid: 1966800].
Montserrat I, Oliver A, Zuazu-Jausoro I, et al. Clotting parameters and fibrinolysis variations in the prophylaxis with standard heparin and low-molecular-weight heparin in orthopedic surgery. Sangre. 1991;36(Suppl 2):122.
Monzo Abad E, Riesgo Benito MJ, Diaz-Penalver Merchan J. Measures and drugs used in preventing thromboembolic complications in postoperative and multiple injury patients. Rev Esp Anestesiol Reanim. 1983;30(3):119-23. [pmid: 6612047].
Moriniere P, Dieval J, Bayrou B, et al. Low-molecular-weight heparin Fraxiparin in chronic hemodialysis. A dose-finding study. Blood Purif. 1989;7(6):301-8. [pmid: 2558691].
Morishita H, Yamagami T, Matsumoto T, Takeuchi Y, Sato O, Nishimura T. Endovascular repair of a perforation of the vena caval wall caused by the retrieval of a Gunther Tulip filter after long-term implantation. Cardiovasc Intervent Radiol. Suppl 2. 2011;34:S321-3. [pmid: 21140262].
Morris CS, Rogers FB, Najarian KE, Bhave AD, Shackford SR. Current trends in vena caval filtration with the introduction of a retrievable filter at a level I trauma center. J Trauma. 2004;57(1):32-6. [pmid: 15284544].
Mosca S, Maselli A, Pozzilli P, et al. Comparison of Gunther, Filcard and LGM definitive caval filters. Our experience. Radiol Med. 1993;85(3):224-34. [pmid: 8493371].
Moser G, Krahenbuhl B, Donath A. Prevention of deep venous thrombosis (TVP) and pulmonary embolism. Comparison of heparin (3 × 5000 IU/day), heparin (2 × 5000 IU/day) + 0.5 mg dihydroergot, and physiotherapy (intermittent compression stockings + physical exercise). Value of Doppler diagnosis in systematic detection of TVP compared with phlebography and scanning of the legs using labelled fibrinogen. Helv Chir Acta. 1980;47(1-2):145-9. [pmid: 7440192].
Mourelo R, Kaidar-Person O, Fajnwaks P, et al. Hemorrhagic and thromboembolic complications after bariatric surgery in patients receiving chronic anticoagulation therapy. 2008;18:167-70.
Muckle DS, Forney HJ, Bentley G. The value of prophylactic anticoagulant therapy with warfarin after hip surgery. Acta Orthop Scand. 1974;45(3):412-20. [pmid: 4407250].
Muntz JE, O'Connor PJ, Yin H, Vogenberg FR. Factors associated with thromboprophylaxis for orthopedic patients and their impact on outcome. Am J Orthop (Belle Mead NJ). 2007;36(4):193-7. [pmid: 17515185].
Napolitano LM, Garlapati VS, Heard SO, et al. Asymptomatic deep venous thrombosis in the trauma patient: is an aggressive screening protocol justified?. J Trauma. 1995;39(4):651-7. discussion 657-9. [pmid: 7473949].
Nguyen NT, Cronan M, Braley S, Rivers R, Wolfe BM. Duplex ultrasound assessment of femoral venous flow during laparoscopic and open gastric bypass. 2003;17:285-90.
Niazi AU, Umer M, Umar M. Prophylaxis of DVT with enoxaparin in patients undergoing total knee replacement. J Pak Med Assoc. 2006;56(2):72-5. [pmid: 16555639].
Nicolaides AN, Kakkar VV, Field ES, Fish P. British Medical Journal. Optimal electrical stimulus for prevention of deep vein thrombosis. 1972;3:756-8. [pmid: 5077921].
Nienhaus K, Wenig C, Pfordt L, Taubert W, Meyer I, Wenzel E. Value of a new photometric method for the control of the efficacy of a low-dose heparin therapy. Verh Dtsch Ges Inn Med. 1978;84:1383-8. [pmid: 741973].
Nilsson PE, Bergqvist D, Benoni G, et al. The post-discharge prophylactic management of the orthopedic patient with low-molecular-weight heparin: enoxaparin. Orthopedics. 1997;20(Suppl):22-5. [pmid: 9048404].
Northup PG, McMahon MM, Ruhl AP, et al. Coagulopathy does not fully protect hospitalized cirrhosis patients from peripheral venous thromboembolism. 2006;101(7):1524-8.
Novicoff WM, Brown TE, Cui Q, Mihalko WM, Slone HS, Saleh KJ. Mandated venous thromboembolism prophylaxis: possible adverse outcomes. J Arthroplasty. 2008;23(6 Suppl 1):15-9. [pmid: 18555656].
Nowak W. Anticoagulants as therapeutic agents, or, on the prevention of thromboebolism in accident injuries. Z Arztl Fortbild (Jena). 1967;61(23):1233-5. [pmid: 5591393].
Nurmohamed MT, Verhaeghe R, Haas S, et al. Comparative trial of a low molecular weight heparin (enoxaparin) for the prophylaxis of postoperative deepvein thrombosis in general surgery. Thrombosis and Haemostasis. 1993;69(6):649. Abstract no: 384.
Nutescu EA, Shorr AF, Farrelly E, Horblyuk R, Happe LE, Franklin M. Burden of deep vein thrombosis in the outpatient setting following major orthopedic surgery. Ann Pharmacother. 2008;42(9):1216-21. [pmid: 18611992].
Oakley MJ, Wheelwright EF, James PJ. BJM. Pneumatic compression boots for prophylaxis against deep vein thrombosis: beware occult arterial disease. 1998;316:454-5.
O'Connor MB, Pokrovskaya O, Burns M, et al. Prevention of venous thromboembolic disease in medical and surgical hospital patients in a single university teaching hospital. 2011;180(1):303-4.
O'Malley KF, Ross SE. Journal of Trauma. Pulmonary embolism in major trauma patients. 1990;30:748-50. [pmid: 2352304].
Ongen G, Yilmaz A, Cirak AK, et al. Venous Thromboembolism Risk and Thromboprophylaxis Among Hospitalized Patients: Data From the Turkish Arm of the ENDORSE Study. Clin Appl Thromb Hemost. 2010.
Orsini RA, Jarrell BE. Suprarenal placement of vena caval filters: indications, techniques, and results. J Vasc Surg. 1984;1(1):124-35. [pmid: 6481860].
Ortiz Diaz-Miguel R, Sanchez Casado M, Pedrosa Guerrero A, et al. Prevention of venous thromboembolism in critical care patients with multiorganic failure: Are we using appropriate dosage?. Intensive Care Med. 2009;35:S161.
Otchy DP, Elliott BM. The malpositioned Greenfield filter: lessons learned. Am Surg. 1987;53(10):580-3. [pmid: 3674601].
Ottone MC, Semino G, Perotti GF. Incidence of thromboembolic complications in hip replacement surgery: Incidenza delle complicanze tromboemboliche nella chirurgia protesica dell'anca. MINERVA ORTOP. TRAUMATOL. 1997;48(1-2):25-30.
Paige JT, Gouda BP, Gaitor-Stampley V, et al. No correlation between anti-factor Xa levels, low-molecular-weight heparin, and bleeding after gastric bypass. Surg Obes Relat Dis. 2007;3(4):469-75. [pmid: 17567541].
Palareti G, Borghi B, Coccheri S, et al. Postoperative versus preoperative initiation of deep-vein thrombosis prophylaxis with a low-molecular-weight heparin (nadroparin) in elective hip replacement. Clinical and Applied Thrombosis/Hemostasis. 1996;2(1):18-24.
Pana C, Naftali Z, Gyongyosi M, et al. Prevention of postsurgical thromboembolism with small doses of heparin. Rev Chir Oncol Radiol O R L Oftalmol Stomatol Chir. 1978;27(6):421-6. [pmid: 752839].
Panfilo ADI, Cornette M. Echo doppler post total hip arthroplasty: Retrospective study of 111 patients at CHBAH: Etude r+_trospective de l'+_cho-doppler veineux dans 111 cas de proth+¿se totale de hanche op+_r+_s en 2001 au CHBAH. 2004;59(9):497-503.
Parkin E, Serracino-Inglott F, Chalmers N, Smyth V. Symptomatic perforation of a retrievable inferior vena cava filter after a dwell time of 5 years. J Vasc Surg. 2009;50(2):417-9. [pmid: 19631878].
Parra RO, Farber R, Feigl A. Pressure necrosis from intermittent-pneumatic-compression stockings. N Engl J Med. 1989;321(23):1615. [pmid: 2586562].
Passos R, Conceicnullao LF, Valente L, et al. Antithrombotic prophylaxis in critically ill patients with renal failure. Intensive Care Med. 2009;35:S153.
Patel R, Cook DJ, Meade MO, et al. Burden of illness in venous thromboembolism in critical care: a multicenter observational study. J Crit Care. 2005;20(4):341-7. [pmid: 16310605].
Payne K, Mehta U. Spinal/epidural haematomas associated with neuraxial anaesthesia in the presence of heparin and low-molecular-weight heparins. S Afr Med J. 2000;90(6):604. [pmid: 10918889].
Pearse EO, Caldwell BF, Lockwood RJ, Hollard J. Early mobilisation after conventional knee replacement may reduce the risk of postoperative venous thromboembolism. J Bone Joint Surg Br. 2007;89(3):316-22. [pmid: 17356141].
Peetz D, Hafner G, Hansen M, et al. Dose-adjusted thrombosis prophylaxis in trauma surgery according to levels of D-Dimer. Thromb Res. 2000;98(6):473-83. [pmid: 10899346].
Pellegrini VD Jr, Clement D, Lush-Ehmann C, Keller GS, Evarts CM. The John Charnley Award. Natural history of thromboembolic disease after total hip arthroplasty. Clin Orthop Relat Res. 1996;333:27-40. [pmid: 8981880].
Pelosio L, Marasco A, Puopolo G. Therapy and prevention of thromboembolic diseases: anticoagulants and fibrinolytics. Clin Ter. 1982;100(4):417-25. [pmid: 7044661].
Peng YG, Eikelboom JW, Tenni P, McQuillan A, Thom J. Renal Function, Peak Anti-Xa Levels and Enoxaparin Dosing. 2004;34:14-7.
Perez-Rada FJ, Cerda-Arteaga JM, Villanueva-Guzman E, Sanchez-Nava VM, Fernandez-Rangel E. Thromboembolic risk factors and thromboprophylaxis in a medical-surgical ICU in Mexico. Crit. Care. 2009;13:S179.
Pernod G, Sevestre M, Labarere J, et al. D-dimer and duration of anticoagulation…. New England Journal of Medicine. 2007;356(4):421-3. [pmid: 17251543]. Palareti G, Cosmi B, Legnani C, et al. D-Dimer testing to determine the duration of anticoagulation therapy. N Engl J Med. 2006;355:1780-9. [pmid: 17065639].
Perrin M. Skin necrosis as a complication of compression in the treatment of venous disease and in prevention of venous thromboembolism. Phlebolymphology. 2008;15(1):27-30.
Perry JN, Wells IP. A long term follow-up of Gunther vena caval filters. Clin Radiol. 1993;48(1):35-7. [pmid: 8370217].
Peters G, Whipple J, Eriksson U. Pharmacokinetics of H 376/95 (H): A novel oral direct thrombin inhibitor in patients undergoing total knee arthoplasty (TKA). 2001;69(2).
Petrov NS, Kotsiubinskii NN. Prevention of thromboses in severe mechanical injuries. Voen Med Zh. 1978;12:24-8. [pmid: 734955].
Pezzuoli G, Neri Serneri GG, Settembrini PG, et al. The use of low-molecular-weight heparin CY 216 in the prevention of fatal pulmonary embolism and thromboembolic death in general surgey. A multicentre, double-blind, randomized, controlled clinical trial versus placebo (STEP). Fraxiparine Second International Symposium Recent Pharmacological and Clinical Data. 1990:13-22.
Pidhorz L, Munafo-Dauccia R, Badatcheff F, Galland F. Prevention of thromboembolic complications during total hip arthroplasty by pre- and postoperative heparinotherapy with adapted doses. Apropos of 356 cases. Rev Chir Orthop Reparatrice Appar Mot. 1988;74(7):593-603. [pmid: 3241890].
Pierron RL. Prophylaxis of deep-vein thrombosis after total hip replacement. Dextran and external pneumatic compression compared with 1.2 or 0.3 grams of aspirin daily. J Bone Joint Surg Am. 1985;67(6):983. [pmid: 2410426].
Pini M, Aiello S, Manotti C, et al. Low molecular weight heparin versus warfarin in the prevention of recurrences after deep vein thrombosis. Thromb Haemost. 1994;72(2):191-7. [pmid: 7831650].
Planes A, Chastang C, Vochelle N, Desmichels D, Fiessinger JN, Clivarin Study Group. An equivalence study of two low-molecular-weight heparins (LMWH) in the prevention of deep vein thrombosis (DVT), after total hip replacement (THR) (440 patients). Thrombosis and Haemostasis. 1993;69(6):651. Abstract no: 394.
Planes A, Vochelle N, Mansat C. Prevention of deep vein thrombosis (DVT) after total hip replacement (THR) by enoxaparine (Lovenox): One daily injection of 40 mg versus two daily injections of 20 mg. Thrombosis and Haemostasis. 1987;58(1):117. Abstract no:. 415.
Politowski M, Janda R, Cencora A, Kleczynski S. Early prophylactic anticoagulant treatment after reconstructive operations on arteries and some associated problems. Pol Tyg Lek. 1970;25(22):807-10. [pmid: 5425428].
Polto F, Musumeci S, Vadala G, Morici V, Rizza G. Graduated and constant compression of the lower extremities in the prevention of postoperative deep venous thrombosis and of pulmonary thromboembolism. Clinical trial. Chir Ital. 1979;31(5):996-1007. [pmid: 396049].
Poniewierski M, Barthels M, Poliwoda H. The safety and efficacy of a low molecular weight heparin (fragmin) in the prevention of deep vein thrombosis in medical patients: a randomized double-blind trial. Thrombosis and Haemostasis. 1987;58(1):119. Abstract no:. 425.
Potron G, Seys A, Lardennois B. Mini-dose heparin therapy. Protocol for a preoperative prophylaxis of thrombophlebitis. Cah Med. 1973;14(3):219-23. [pmid: 4730893].
Pouzol P, Dechelette E, Jurkovitz C, Kuentz F, Polack B. Prevention of clotting with enoxaparin in extracorporeal circulation during haemodialysis. REV. MED. INTERNE. 1988;9(3):321-6. [pmid: 2841741].
Prandoni P, Bruchi O, Sabbion P, et al. Prolonged thromboprophylaxis with oral anticoagulants after total hip arthroplasty: a prospective controlled randomized study. Arch Intern Med. 2002;162(17):1966-71. [pmid: 12230419].
Prevention of postoperative pulmonary embolism by low doses of heparin. 1975;2:45-51.
Printen KJ, Miller EV, Mason EE, Barnes RW. Venous thromboembolism in the morbidly obese. Surg Gynecol Obstet. 1978;147(1):63-4. [pmid: 663811].
Proceedings and abstracts of the 7th National Conference on Anticoagulant Therapy. San Francisco, California, USA. 8-10 May 2003. J Thromb Thrombolysis. 2003;16(1-2):5-109.
Proctor MC, Greenfield LJ, Wakefield TW, Zajkowski PJ. A clinical comparison of pneumatic compression devices: the basis for selection. J Vasc Surg. 2001;34(3):459-63. discussion 463-4. [pmid: 11533598].
Prophylaxis of venous thrombosis. Lancet. 1971;1(7690):121-2. [pmid: 4099612].
Pryor HI, Lin E, Singleton A, Vaziri K. High-risk bariatric venous thromboembolism prophylaxis practice patterns. Surg. Endosc. Interv. Tech. 2011;25:S244.
Raby C. Preventive anticoagulant therapy in surgery. Angeiologie. 1968;20(3):17-21. [pmid: 5744423].
Rader CP, Kramer C, Konig A, Gohlke F, Eulert J. Comparison between low-molecular and unfractionated heparin in the prevention of thrombosis in patients with total endoprosthetic replacement of hip and knee joint. Z Orthop Ihre Grenzgeb. 1997;135(1):52-7. [pmid: 9199074].
Ramchandani P, Koolpe HA, Zeit RM. American Journal of Roentgenology. Splaying of titanium Greenfield inferior vena caval filter. 1990;155:1103-4. [pmid: 2120943].
Rassler R. Postoperative anticoagulant prophylaxis; investigations of its effect on women with abnormal physical conditions, those with cardiovascular defects, and those with double diseases. Dtsch Gesundheitsw. 1955;10(44):1434-6. [pmid: 13277420].
Rebuck J, Makkar K, Prusch A, Walls J, Solski L. Minimizing adverse drug reactions related to enoxaparin therapy in high risk patients. Crit. Care Med. 2009;37(12):A423.
Reich A, Bialynicki-Birula R, Szepietowski JC. Drug-induced subacute cutaneous lupus erythematosus resulting from ticlopidine. Int J Dermatol. 2006;45(9):1112-4. [pmid: 16961527].
Reiertsen O, Larsen S, Storkson R, et al. Safety of enoxaparin and dextran-70 in the prevention of venous thromboembolism in digestive surgery. A play-the-winner-designed study. Scand J Gastroenterol. 1993;28(11):1015-20. [pmid: 7506841].
Rem J, Duckert F, Fridrich R, Gruber Uf. Subkutane Kleine Heparindosen Zur Thromboseprophylaxe In Der Allgemeinen Chirurgie Und Urologie: Small doses of subcutaneous heparin for the prevention of thrombotic complications in general surgery and urology. 1975;105:827-35.
Remvig L, Mortensen SA, Als OS, Mentzel V, Holm G. Low-dose heparin therapy in the prevention of deep venous thrombosis in acute myocardial infarction. A controlled clinical trial. Ugeskr Laeger. 1983;145(14):1053-6. [pmid: 6346624].
Ribaudo JM, Hoellrich RG, McKinnon WM, Shuler SE. Evaluation of mini-dose heparin administration as a prophylaxis against postoperative pulmonary embolization: a prospective double-blind study. Rev Surg. 1975;32(4):297-9. [pmid: 1198038].
Ricco JB, Crochet D, Sebilotte P, et al. Annals of Vascular Surgery. Percutaneous transvenous caval interruption with the “LGM” filter: early results of a multicenter trial. 1988;2:242-7. [pmid: 3056484].
Richard III H, Widlus DM, Scalea TM. Inferior vena cava filters in trauma: Balancing pulmonary embolism prevention with the risk of deep venous thrombosis. J. Trauma Inj. Infect. Crit. Care. 2010;69(4):1003.
Richenbacher WE, Atnip RG, Campbell DB, Waldhausen JA. World Journal of Surgery. Recurrent pulmonary embolism after inferior vena caval interruption with a Greenfield filter. 1989;13:623-9. [pmid: 2815806].
Riess H, Haas S, Tebbe U, et al. CERTIFY - Certoparin versus UFH to prevent venous thromboembolic events in acutely ill, hospitalized, medical patients: A randomized, double-blind, multicentre study. Onkologie. 2010;33(6):51-2.
Rimaud D, Boissier C, Calmels P. Evaluation of the effects of compression stockings using venous plethysmography in persons with spinal cord injury. J Spinal Cord Med. 2008;31(2):202-7. [pmid: 18581669].
Rimon U, Bensaid P, Golan G, et al. Optease vena cava filter optimal indwelling time and retrievability. Cardiovasc Intervent Radiol. 2011;34(3):532-5. [pmid: 20556385].
Riou B, Rothmann C, Lecoules N, et al. Incidence and risk factors for venous thromboembolism in patients with nonsurgical isolated lower limb injuries. Am J Emerg Med. 2007;25(5):502-8. [pmid: 17543652].
Robinson S, Zincuk A, Toft P. Enoxaparin: Effective dosage for ICU patients. Acta Anaesthesiol. Scand. Suppl. 2009;53(119):72-3.
Rocha AT, Araujo DM, Cardoso DNR, Pereira A, Messeder O. Improving evaluation of risk factors for venous thromboembolism and use of prophylaxis in medical intensive care patients. Chest. 2009;136(4).
Rocha E, Gomez-Outes A, Martinez Gonzalez J, Kakkar VV. Effect of unfractionated heparin and long-term treatment with low-molecular-weight heparin, bemiparin, on potassium levels. Thromb Haemost. 2005;94(5):1109-10. [pmid: 16363259].
Roehm Jr JOF, Johnsrude IS, Barth MH, Gianturco C. Radiology. The bird's nest inferior vena cava filter: Progress report. 1988;168:745-9. [pmid: 3043548].
Rosner MK, Kuklo TR, Tawk R, Moquin R, Ondra SL. Prophylactic placement of an inferior vena cava filter in high-risk patients undergoing spinal reconstruction. Neurosurg Focus. 2004;17(4):E6. [pmid: 15633992].
Rothberg MB, Lahti M, Pekow PS, Lindenauer PK. Venous thromboembolism prophylaxis among medical patients at US hospitals. J Gen Intern Med. 2010;25(6):489-94. [pmid: 20352366].
Sabry A, Taha M, Nada M, Al Fawzan F, Alsaran K. Anticoagulation therapy during haemodialysis: a comparative study between two heparin regimens. Blood Coagul Fibrinolysis. 2009;20(1):57-62. [pmid: 20523166].
Saggau W, Encke A, Schmidt U. Prevention of thromboembolism using subcutaneous heparin. Chirurg. 1974;45(9):407-9. [pmid: 4425325].
Salem M, Elrefai S, Shrit MA, Warkentin TE. Fondaparinux thromboprophylaxis-associated heparin-induced thrombocytopenia syndrome complicated by arterial thrombotic stroke. Thromb Haemost. 2010;104(5):1071-2. [pmid: 20806120].
Saltissi D, Morgan C, Westhuyzen J, Healy H. Nephrology Dialysis Transplantation. Comparison of low-molecular-weight heparin (enoxaparin sodium) and standard unfractionated heparin for haemodialysis anticoagulation. 1999;14:2698-703.
Sanchez-Ballester J, Smith M, Hassan K, Kershaw S, Elsworth CS, Jacobs L. Wound infection in the management of hip fractures: a comparison between low-molecular weight heparin and mechanical prophylaxis. Acta Orthop Belg. 2005;71(1):55-9. [pmid: 15792208].
Sandor T, Laszlo E, Magyary F, et al. Prophylaxis of postoperative thromboembolism with heparin-dihydroergotamine combination. Phlebology. 1986;1:57-64.
Sarich TC, Teng R, Peters GR, et al. No influence of obesity on the pharmacokinetics and pharmacodynamics of melagatran, the active form of the oral direct thrombin inhibitor ximelagatran. Clin Pharmacokinet. 2003;42(5):485-92. [pmid: 12739986].
Sato DT, Robinson KD, Gregory RT, et al. Duplex directed caval filter insertion in multi-trauma and critically ill patients. 1999;13:365-71.
Saturno PJ, Gama ZA, Fonseca YA. Prevention of venous thromboembolism and safe use of heparin in Spanish hospitals. Int J Qual Health Care. 2011;23(2):117-25. [pmid: 21242163].
Sauvageon M, Lecoeur A, Levy R, Lebas-Certain M, Le Mercier F. Dabigatran etexilate: First step in its use in an orthopaedic surgery department. Int. J. Clin. Pharm. 2011;33(2):440.
Scannapieco G, Ageno W, Airoldi A, et al. Incidence and predictors of venous thromboembolism in post-acute care patients. A prospective cohort study. Thromb Haemost. 2010;104(4):734-40. [pmid: 20664897].
Schadenbock R, Schlag G. Anticoagulant prophylaxis of thromboembolism in fractures of the pelvic area. Hefte Unfallheilkd. 1968;97:60-3. [pmid: 5712849].
Schanzer H, Schanzer A. Guidewire entrapment during deployment of the over-the-guidewire stainless steel Greenfield filter: a device design-related complication. J Vasc Surg. 2000;31(3):607-10. [pmid: 10709077].
Scharpff E, Seitz R. Extended thrombo-embolic prophylaxis with anticoagulants in internal medicine. Medizinische. 1955:27-8. 976. 9.
Schleich JM, Laurent M, Le Helloco A, Langella B, Ramee A, Almange C. American Journal of Roentgenology. Short-term follow-up of inferior vena caval filters: Comparison of imaging techniques. 1993;161:799-803. [pmid: 8372763].
Schmidt WJ. Not Available. Ned Tijdschr Geneeskd. 1956;100(28):1968-76. [pmid: 13369606].
Schneider PA, Geissbuhler P, Piguet JC, Bounameaux H. Follow-up after partial interruption of the vena cava with the Gunther filter. Cardiovasc Intervent Radiol. 1990;13(6):378-80. [pmid: 2126997].
Scholz PM, Jones RH, Sabiston DC Jr. Prophylaxis of thromboembolism. Adv Surg. 1979;13:115-43. [pmid: 391002].
Schondorf TH. Thrombosis prevention with heparin and acetylsalicylic acid in elective hip joint surgery. Med Welt. 1979;30(5):170-3. [pmid: 759806].
Schreiber B, Dvorak V, Novotny A. Use Of A Point System In The Prevention Of Thromboembolic Disease. Cas Lek Cesk. 1963;102:951-5. [pmid: 14051526].
Schuerer DJ, Whinney RR, Freeman BD, et al. Evaluation of the applicability, efficacy, and safety of a thromboembolic event prophylaxis guideline designed for quality improvement of the traumatically injured patient. J Trauma. 2005;58(4):731-9. [pmid: 15824649].
Schwartsmann CR, Cavalieri Costa R, Drumond SN, et al. Randomized, comparative, open study to assess the efficacy and safety of enoxaparin compared with unfractionated heparin in the prophylaxis of venous thromboembolism in patients undergoing total hip arthroplasty: Estudo aberto, randomizado, comparativo, para avaliar a eficacia e seguranca da enoxaparina comparada a heparina nao fracionada na profilaxia do trombembolismo venoso em pacientes submetidos a artroplastia total do quadril. REV. BRAS. ORTOP. 1996;31(10):797-808.
Scott JR, Klein MB, Gernsheimer T, Honari S, Gibbons J, Gibran NS. Arterial and venous complications of heparin-induced thrombocytopenia in burn patients. J Burn Care Res. 2007;28(1):71-5. [pmid: 17211203].
Scurr JH, Robbe IJ, Ellis H, Goldsmith HS. Simple mechanical method for decreasing the incidence of thromboembolism. Am J Surg. 1981;141(5):582-5. [pmid: 7223954].
Segesser D, Gruber UF. Efficacy of sodium heparin as compared to calcium heparin for preventing thromboembolic complications. Arzneimittelforschung. 1977;27(11):2157-63. [pmid: 580021].
Sellier E, Labarere J, Bosson JL, et al. Effectiveness of a guideline for venous thromboembolism prophylaxis in elderly post-acute care patients: a multicenter study with systematic ultrasonographic examination. Arch Intern Med. 2006;166(19):2065-71. [pmid: 17060535].
Sevitt S, Gallagher N. Venous thrombosis and pulmonary embolism. A clinico-pathological study in injured and burned patients. 1961;48:475-89.
Sharnoff JG, De Blasio G, Breen SR, Tucci P. Pulmonary thromboembolism; prevention of fatal postoperative. Med Trial Tech Q. 1970;16(4):63-9. [pmid: 5425125].
Sharnoff Jg, Kass Hh, Mistica Ba. A plan of heparinization of the surgical patient to prevent postoperative thromboembolism. Surg Gynecol Obstet. 1962;115:75-9. [pmid: 13911387].
Sharnoff Jg. A Plan Of Heparinization Of The Surgical Patient For The Successful Prevention Of Thromboembolism. R I Med J. 1963;46:651. [pmid: 14086306].
Sharnoff JG. Prevention of venous thrombosis. Lancet. 1970;1(7647):617. [pmid: 4190568].
Sharpe RP, Gupta R, Gracias VH, et al. Journal of Trauma - Injury, Infection and Critical Care. Incidence and natural history of below-knee deep venous thrombosis in high-risk trauma patients. 2002;53:1048-52.
Shelley OP, Weiler-Mithoff E. DIEP flap perforators and prophylaxis--X marks the spot. J Plast Reconstr Aesthet Surg. 2006;59(8):891. [pmid: 16876097].
Sher MH. Complications in the application of the inferior vena cava umbrella technique. Arch Surg. 1971;103(6):688-90. [pmid: 5120193].
Siemens HJ. Perioperative prophylaxis of thrombosis [2]: Perioperative thromboseprophylaxe. Gynakologe. 2002;35(2):195-6.
Siguret V, Pautas E, Gouin I. Low molecular weight heparin treatment in elderly subjects with or without renal insufficiency: New insights between June 2002 and March 2004. 2004;10:366-70.
Silbernagel G, Brechtel K, Strolin A, Balletshofer B. Infrarenal implantation of vena cava filters: two case reports. Dtsch Med Wochenschr. 2010;135(50):2539. [pmid: 21154194].
Silver JR, Morris WR, Otfinowski JS. Associated injuries in patients with spinal injury. Injury. 1980;12(3):219-24. [pmid: 7228385].
Simon M, Athanasoulis CA, Kim D, et al. Radiology. Simon nitinol inferior vena cava filter: Initial clinical experience. Work in progress. 1989;172:99-103. [pmid: 2662259].
Simpson HK, Baird J, Allison M, et al. Long-term use of the low molecular weight heparin tinzaparin in haemodialysis. Haemostasis. 1996;26(2):90-7. [pmid: 9119288].
Smith JA, Atkinson NR, Walters NA, Thomson KR. Medical Journal of Australia. Early experience with the bird's nest inferior vena-caval filter. 1989;150:164-5. [pmid: 2716589].
Spencer FA, Gore JM, Lessard D, et al. Thrombosis and Haemostasis. Venous thromboembolism in the elderly a community-based perspective. 2008;100:780-8. [pmid: 18989521].
Spieler U, Preter B, Brunner U. Prevention of thromboses in lower leg fractures. Helv Chir Acta. 1972;39(5):679-83. [pmid: 4652328].
Spiro TE, Colwell CW, Bona RD, et al. A clinical trial comparing the efficacy and safety of enoxaparin a low molecular weight heparin and unfractionated heparin for the prevention of deep venous thrombosis after elective knee replacement surgery. Blood. 1993;82(10 Suppl 1):410a.
Spiro TE. A randomized, trial of enoxaparin administered post operatively for the prevention of deep vein thrombosis following elective hip replacement surgery. Thrombosis and Haemostasis. 1991;65(6):927.
Spivack S, Kalker E, Samuels D, Orron DE. Filter placement in duplicated inferior vena cava. Isr Med Assoc J. 2001;3(6):459-60. [pmid: 11433647].
Staffen A, Schurer-Waldheim H. 3 years of general embolism prophylaxis in nailed femoral neck fractures by anticoagulants. Wien Klin Wochenschr. 1970;82(44):793-4. [pmid: 5476162].
Stamatakis JD, Kakkar VV, Lawrence D, Bentley PG, Nairn D, et al. Failure of aspirin to prevent postoperative deep vein thrombosis in patients undergoing total hip replacement: Failure of aspirin to prevent postoperative deep vein thrombosis in patients undergoing total hip replacement. British Medical Journal (England). 1978;1:1031.
Stannard JP, Singhania AK, Lopez-Ben RR, et al. Deep-vein thrombosis in high-energy skeletal trauma despite thromboprophylaxis. J Bone Joint Surg Br. 2005;87(7):965-8. [pmid: 15972912].
Stedry V, Slavik M, Ort J, Janotova H, Kapounek B. Prevention of thromboembolic disease in patients after total endoprosthesis hip joint surgery using small doses of heparin. Acta Chir Orthop Traumatol Cech. 1982;49(5):406-12. [pmid: 7158196].
Stehlik J, Karpas K, Urban K. Comparison of thromboembolic prophylaxis with heparin and fraxiparine after total endoprostheses of the hip joint. Acta Chir Orthop Traumatol Cech. 1995;62(1):36-9. [pmid: 20470484].
Stephens PH, Healy MT, Smith M, Jewkes DA. British Journal of Neurosurgery. Prophylaxis against thromboembolism in neurosurgical patients: A survey of current practice in the United Kingdom. 1995;9:159-63. [pmid: 7632361].
Stern SH, Wixson RL, O'Connor D. Evaluation of the safety and efficacy of enoxaparin and warfarin for prevention of deep vein thrombosis after total knee arthroplasty. J Arthroplasty. 2000;15(2):153-8. [pmid: 10708078].
Stewart JR, Peyton JWR, Crute SL, Greenfield LJ. Surgery. Clinical results of suprarenal placement of the Greenfield vena cava filter. 1982;92:1-4. [pmid: 7089859].
Sturm V, Gruber UF. Prevention of postoperative thromboembolic complications. Hippokrates. 1977;48(1):52-61. [pmid: 845041].
Stutz P, Gruber UF. Relationship between various forms of prevention of thromboembolic complications and location of deep vein thrombi (author's transl). Schweiz Rundsch Med Prax. 1978;67(37):1355-8. [pmid: 693462].
Sue LP, Davis JW, Parks SN. Iliofemoral venous injuries: an indication for prophylactic caval filter placement. J Trauma. 1995;39(4):693-5. [pmid: 7473957].
Taberner DA, Poller L, Thomson JM. Adjusted versus fixed dose subcutaneous heparin in preventing deep vein thrombosis in hip surgery. British Journal of Haematology. 1988;69:115.
Taks AC, Duchateau AM, Janelli FI, Merkus FW. Letter: Postoperative thrombosis prevention with low doses of heparin administered subcutaneously. Ned Tijdschr Geneeskd. 1976;120(12):530-1. [pmid: 1250441].
Tapson VF, Decousus H, Pini M, et al. Venous thromboembolism prophylaxis in acutely ill hospitalized medical patients: findings from the International Medical Prevention Registry on Venous Thromboembolism. Chest. 2007;132(3):936-45. [pmid: 17573514].
Teitelbaum GP, Jones DL, Van Breda A, et al. Radiology. Vena caval filter splaying: Potential complication of use of the titanium Greenfield filter. 1989;173:809-14. [pmid: 2813790].
Textor HJ, Strunk H, Schild HH. Temporary vena cave filter: critical comments. Rofo. 1996;165(4):371-4. [pmid: 8963050].
The German Hip Arthroplasty Trial (GHAT) Group. Prevention of deep vein thrombosis with low molecular-weight heparin in patients undergoing total hip replacement. Archives of Orthopaedic and Trauma Surgery. 1992;111(2):110-20. [pmid: 1314065].
Thies HA. Thromboembolism in the framework of post-traumatic intensive care. Klin Med Osterr Z Wiss Prakt Med. 1967;22(8):342-5. [pmid: 5632403].
Thomas Iii WO, Ferrara JJ, Rodning CB. A retrospective analysis of inferior vena caval filtration for prevention of pulmonary embolization. 1988;54:726-30.
Thomas JH, Cornell KM, Siegel EL, Sparks C, Rosenthal SJ. American Journal of Surgery. Vena caval occlusion after bird's nest filter placement. 1998;176:598-600. [pmid: 9926797].
Thromboprophylaxis in hip fracture surgery: a pilot study comparing danaparoid, enoxaparin and dalteparin. The TIFDED Study Group. Haemostasis. 1999;29(6):310-7. [pmid: 10844404].
Tilsner V, Eifrig B, Schontag H, Reuter H. Intraoperative coagulation activity--a defined group of trauma surgery patients. Folia Haematol Int Mag Klin Morphol Blutforsch. 1989;116(6):915-25. [pmid: 2483711].
Tinmouth A, Morrow B, Cruickshank M, Moore P, Kovacs M. Dalteparin as periprocedure anticoagulation for patients on warfarin and at high risk of thrombosis. Annals of Pharmacotherapy. 2001;35(6):669-74. [pmid: 11408982].
Tobin KD, Pais SO, Austin CB. Investigative Radiology. Femoral vein thrombosis following percutaneous placement of the Greenfield filter. 1989;24:442-5. [pmid: 2521124].
Toll A, Gallardo F, Abella ME, Fontcuberta J, Barranco C, Pujol RM. Low-molecular-weight heparin-induced skin necrosis: a potential association with pre-existent hypercoagulable states. Int J Dermatol. 2005;44(11):964-6. [pmid: 16336536].
Touzard RC. Prevention of thrombo-embolic complications (100 patients with hip surgery). Sem Hop. 1969;45(40):2481-3. [pmid: 4310897].
Trigilio-Black CM, Ringley CD, McBride CL, et al. Inferior vena cava filter placement for pulmonary embolism risk reduction in super morbidly obese undergoing bariatric surgery. Surg Obes Relat Dis. 2007;3(4):461-4. [pmid: 17544921].
Tubiana R, Duparc J. Frequency and prevention of thromboembolic complications in orthopedic surgery. Acta Orthop Belg. 1962;28:605-11. [pmid: 13994658].
Tukallo K, Wilczek W, Lukomski J. Use of small doses of heparin for prevention of thrombophlebitis. Chir Narzadow Ruchu Ortop Pol. 1980;45(1):77-80. [pmid: 7379626].
Turpie AG, Gallus AS, Hoek JA. A synthetic pentasaccharide for the prevention of deep-vein thrombosis after total hip replacement. N Engl J Med. 2001;344(9):619-25. [pmid: 11228275].
Ulehlova J, Slavik L, Krcova V, Prochazkova J, Hlusi A, Cech L. Laboratory monitoring of dabigatran during orthopedic surgery. J. Thromb. Haemost. 2009;7(S2):674.
Upchurch GR Jr, Demling RH, Davies J, Gates JD, Knox JB. Efficacy of subcutaneous heparin in prevention of venous thromboembolic events in trauma patients. Am Surg. 1995;61(9):749-55. [pmid: 7661468].
Vallano A, Arnau JM, Miralda GP, Perez-Bartoli J. Use of venous thromboprophylaxis and adherence to guideline recommendations: a cross-sectional study. Thromb J. 2004;2(1):3. [pmid: 15059286].
van Vroonhoven TJ. Low doses subcutaneously administered heparin as thrombosis prevention in surgery. Ned Tijdschr Geneeskd. 1976;120(4):159-63. [pmid: 1107860].
Vaziri K, Bhanot P, Hungness ES, Morasch MD, Prystowsky JB, Nagle AP. Retrievable inferior vena cava filters in high-risk patients undergoing bariatric surgery. Surg Endosc. 2009;23(10):2203-7. [pmid: 19184212].
Verardi S, Cortese F, Baroni B, Boffo V, Palazzini E, et al. Deep vein thrombosis prevention in surgical patients: effectiveness and safety of a new low-molecular-weight heparin: Deep vein thrombosis prevention in surgical patients: effectiveness and safety of a new low-molecular-weight heparin. Current Therapeutic Research (USA). 1989;46:366-72.
Verne Jm, De Montrichard C, Chevillard L, Ranson M. Mixed prophylaxis of postoperative thrombo-embolic disease in general surgery. Prevention by anticoagulant and vasomotor phlebotropic therapy. Pharmacodynamic and clinical study of Ruscus aculeatus extract. Ann Chir. 1960;14:1221-51. [pmid: 13780954].
Verstraete M. Critical evaluation of the usefulness of drugs inhibiting platelet function in the prevention of postoperative deep venous thrombosis and in ischemic cardiopathy. Recenti Prog Med. 1980;68(4):361-81. [pmid: 6992244].
Vignon P, Dequin P-F, Benzekri-Lefevre D, et al. Intermittent pneumatic compression to prevent venousthrom-boembolism in patients hospitalized in intensive care units with high risk of bleeding: A randomized trial. Intensive Care Med. 2011;37:S230.
Vimlati L, Rozsa I, Sas G. Low-dose prophylactic heparin in the prevention of postoperative pulmonary complications. Orv Hetil. 1980;121(49):2997-9. [pmid: 7220016].
von Huben R, Roth H. Comparative study on the prevention of postoperative thromboembolism. Schweiz Med Wochenschr. 1970;100(8):380-2. [pmid: 5524938].
Vorwerk D, Hollmann J, Gunther R. Long-term follow-up of vena cava filters: real-time sonography and the native x-ray image. Rofo. 1987;146(5):558-62. [pmid: 3035643].
Vukovich T, Proidl S, Teufelsbauer H, et al. Laboratory monitoring of thromboprophylaxis with low molecular weight and standard heparin. Thromb Res. 1992;66(6):735-43. [pmid: 1519232].
Walsh PN, Rogers PH, Marder VJ, Gagnatelli G, Escovitz ES, Sherry S. Platelet coagulant activities and venous thrombosis after hip surgery. Trans Assoc Am Physicians. 1974;87:140-52. [pmid: 4617363].
Wang CJ, Wang JW, Weng LH, Hsu CC, Huang CC, Yu PC. Prevention of deep-vein thrombosis after total knee arthroplasty in Asian patients. Comparison of low-molecular-weight heparin and indomethacin. J Bone Joint Surg Am. 2004;86-A(1):136-40. [pmid: 14711956].
Wardrop M, Lube M, Du Coin C. Platelet counts in trauma patients admitted to the intensive care unit that receive enoxaparin (Lovenox) for venous thrombo-embolism prophylaxis. Crit. Care Med. 2010;38:A57.
Warkentin TE, Roberts RS, Hirsh J, Kelton JG. Heparin-induced skin lesions and other unusual sequelae of the heparin-induced thrombocytopenia syndrome: a nested cohort study. Chest. 2005;127(5):1857-61. [pmid: 15888871].
Warwick D, Bannister GC, Glew D, et al. Perioperative low-molecular-weight heparin. Is it effective and safe. J Bone Joint Surg Br. 1995;77(5):715-9. [pmid: 7559695].
Weber U, Koppenhagen K, Malzer H, Matthes M. Different effectiveness of two preparations of low molecular weight heparin in patients with elective hip joint replacement. Langenbecks Arch Chir. 1991;376(3):147-51. [pmid: 1651434].
Westrich GH, Salvati EA, Sharrock N, Potter HG, Sanchez PM, Sculco TP. The effect of intraoperative heparin administered during total hip arthroplasty on the incidence of proximal deep vein thrombosis assessed by magnetic resonance venography. J Arthroplasty. 2005;20(1):42-50. [pmid: 15660059].
Wickramasinghe LS, Basu SK, Bansal SK. Long-term oral anticoagulant therapy in elderly patients. Age Ageing. 1988;17(6):388-96. [pmid: 3149144].
Wicky J, Couson F, Ambrosetti P, Didier D, Rohner A, Bounameaux H. Thrombosis and Haemostasis. Postoperative deep venous thrombosis (DVT) and low-molecular weight heparin (LMWH) type and dosage [2]. 1993;69:402-3. [pmid: 8388582].
Wieberdink J. Preventive anticoagulation in surgery. Ned Tijdschr Geneeskd. 1965;109(47):2221-3. [pmid: 5848402].
Wilhelm K, Brader JJ, Beer HP, Lauterjung KL, Messmer K. Thrombosis prophylaxis with low doses of dextran 60 (author's transl). MMW Munch Med Wochenschr. 1978;120(7):223-6. [pmid: 304984].
Wille E. Effectivity of anticoagulation and extension of long-term anticoagulant therapy. Z Allgemeinmed. 1974;50(33):1521-5. [pmid: 4218413].
Williams RW, Schenk WG Jr. A removable intracaval filter for prevention of pulmonary embolism: early experience with the use of the Eichelter catheter in patients. Surgery. 1970;68(6):999-1008. [pmid: 5483252].
Wilson B, Hawkins ML, Mansberger AR Jr. Posttraumatic phlegmasia cerulea dolens: an indication for the Greenfield filter. South Med J. 1989;82(6):780-2. [pmid: 2734642].
Winchell RJ, Hoyt DB, Walsh JC, et al. Risk factors associated with pulmonary embolism despite routine prophylaxis: Implications for improved protection. 1994;37:600-6.
Winchell RJ, Hoyt DB, Walsh JC, Simons RK, Eastman AB. Risk factors associated with pulmonary embolism despite routine prophylaxis: implications for improved protection. J Trauma. 1994;37(4):600-6. [pmid: 7932891].
Windisch C, Kolb W, Kolb K, Grutzner P, Venbrocks R, Anders J. Pneumatic compression with foot pumps facilitates early postoperative mobilisation in total knee arthroplasty. Int Orthop. 2011;35(7):995-1000. [pmid: 20652250].
Wirth T, Misselwitz F, Schneider B, et al. Low molecular weight heparin (reviparin) for the prevention of venous thromboembolism after knee arthroscopy. Results of a randomized controlled trial. Annals of Hematology. 2001;80:A72.
Wolf F, Thurnher S, Lammer J. Simon Nitinol-vena-cava-Filter: Wirksamkeit und Komplikationen: Simon Nitinol vena cava filters: Effectiveness and complications. 2001;173:924-30.
Wyss PA, Gruber UF. Does bandaging of legs or elastic stockings prevent postoperative deep venous thrombosis. Vasa. 1977;6(4):376-80. [pmid: 930296].
Yelnik A, Denys P, Schouman-Claeys E, Frija G, Held JP. Prevention of venous thrombosis in paraplegic patients. An open study of fraxiparin. Ann Med Interne (Paris). 1989;140(7):647. [pmid: 2692496].
Yelnik A, Dizien O, Bussel B, et al. Systematic lower limb phlebography in acute spinal cord injury in 147 patients. Paraplegia. 1991;29(4):253-60. [pmid: 1870890].
Yogaratnam D, Smith BS, Angood PB, Gandhi PJ. Antifactor Xa levels in four patients with burn injuries who received enoxaparin to prevent venous thromboembolism. Pharmacotherapy. 2004;24(12):1793-9. [pmid: 15585445].
Yoshida WB, Rollo HA, Giannini M, Sobreira ML, Moura R. Preliminary experience with a new vena cava filter: Results of 15 implantations. 2008;7(3):282-8.
Younas F, Janjua M, Chughtai H, et al. Outcome with inferior vena cava filters. Vasc. Med. 2010;15(2):156-7.
Zaczek T, Palczak R. Attempted analysis of the preventive action of anticoagulants according to surgical material of a provincial hospital. Przegl Lek. 1966;22(6):445-6. [pmid: 5916716].
Zenahlikova Z, Kvasnicka J, Kudrnova Z, et al. FXa inhibition and coagulation changes during DVT prophylaxis by enoxaparin over the course of a 15-day follow-up in septic patients. Clin Appl Thromb Hemost. 2010;16(5):584-90. [pmid: 19850587].
Ziemski JM, Kostrzewska E, Marchlewski S, et al. Efficacy of small doses of heparin given during 2 to 6 days in the prevention of postoperative deep vein thrombosis. Pol Tyg Lek. 1979;34(5):161-4. [pmid: 432128].
Zwaan M, Kagel Ch, Marienhoff N, et al. First Results With Temporary Vena Cava Filters: Erste Erfahrungen Mit Temporaren Vena-Cava-Filtern. Rofo Fortschr. Geb. Rontgenstr. Neuen Bildgebenden Verfahren. 1995;163(2):171-6.

## Treatment

Ahmad I, Yeddula K, Wicky S, Kalva SP. Clinical sequelae of thrombus in an inferior vena cava filter. Cardiovasc Intervent Radiol. 2010;33(2):285-9. [pmid: 19688372].
Aidinian G, Fox CJ, White PW, Cox MW, Adams ED, Gillespie DL. Intravascular ultrasound--guided inferior vena cava filter placement in the military multitrauma patients: a single-center experience. Vasc Endovascular Surg. 2009;43(5):497-501. [pmid: 19640915].
Al-Yaseen E, Wells PS, Anderson J, Martin J, Kovacs MJ. The safety of dosing dalteparin based on actual body weight for the treatment of acute venous thromboembolism in obese patients. 2005;3:100-2.
Alt W. Clinical Experiences With Essaven In The Prevention And Therapy Of Thrombosis Of The Lower Extremities. Ther Ggw. 1964;103:1147-54. [pmid: 14337915].
Amendolara M, Perri S, Capellari F, Ciccia B, Battocchio F, Gelmi G. Surgical prophylaxis of pulmonary embolism using caval filters. Preliminary study: Profilassi chirurgica dell'embolia polmonare con l'impiego dei filtri cavali. Studio preliminare. 1997;10(3):236-40.
Amitrano L, Guardascione MA, Menchise A, et al. Safety and efficacy of anticoagulation therapy with low molecular weight heparin for portal vein thrombosis in patients with liver cirrhosis. 2010;44:448-51.
Ansell J. Long-term follow-up of patients with vena cava filters for the prevention of pulmonary embolism. Curr Hematol Rep. 2005;4(5):375-7. [pmid: 16131438].
Arcelus JI, Caprini JA, Monreal M, Suarez C, Gonzalez-Fajardo J. The management and outcome of acute venous thromboembolism: a prospective registry including 4011 patients. J Vasc Surg. 2003;38(5):916-22. [pmid: 14603194].
Ascher E, Hingorani A, Tsemekhin B, Yorkovich W, Gunduz Y. Lessons learned from a 6-year clinical experience with superior vena cava Greenfield filters. J Vasc Surg. 2000;32(5):881-7. [pmid: 11054219].
Aswad MA, Sandager GP, Pais SO, et al. Early duplex scan evaluation of four vena caval interruption devices. J Vasc Surg. 1996;24(5):809-18. [pmid: 8918328].
Barba R, Marco J, Mart+-ín-Alvarez H, et al. The influence of extreme body weight on clinical outcome of patients with venous thromboembolism: Findings from a prospective registry (RIETE). 2005;3:856-62.
Baskara A, Ahmed R, Domingo O, Ahmadinejad A, Raezer D. Surgical management of inferior vena cava strut penetration causing hydronephrosis: case report. Vasc Endovascular Surg. 2010;44(6):491-3. [pmid: 20843969].
Becker CD, Hoogewoud HM, Felder P, Gal I, Ruijs PA, Triller J. Long-term follow-up of the Gunther basket inferior vena cava filter: does mechanical instability cause complications?. Cardiovasc Intervent Radiol. 1994;17(5):247-51. [pmid: 7820832].
Belenotti P, Sarlon-Bartoli G, Bartoli MA, et al. Vena cava filter migration: an unappreciated complication. About four cases and review of the literature. Ann Vasc Surg. 2011;25(8):1141.e9-14. [pmid: 22023951].
Beller BM, Talley RC, Lawrence JL. Nonsurgical inferior vena cava obstruction for prevention of pulmonary emboli. JAMA. 1972;220(7):973-9. [pmid: 5067453].
Bianchini AU, Mehta SN, Mulder DS, Barkun AN, Mayrand S. American Journal of Gastroenterology. Duodenal perforation by a Greenfield filter: Endoscopic diagnosis. 1997;92:686-7. [pmid: 9128325].
Bolton JW, Aldea GS. Perforation of the heart by an inferior vena cava filter. Mil Med. 1994;159(4):360-2. [pmid: 20058439].
Bret P, Lecuire J, Lapras C, Deruty R, Desgeorges M, Prudhon JL. Subdural hematoma and anticoagulant therapy. Neurochirurgie. 1976;22(6):603-20. [pmid: 67569].
Brodsky SV, Satoskar A, Chen J, et al. Acute kidney injury during warfarin therapy associated with obstructive tubular red blood cell casts: a report of 9 cases. Am J Kidney Dis. 2009;54(6):1121-6. [pmid: 19577348].
Campbell JJ, Calcagno D. Aortic pseudoaneurysm from aortic penetration with a bird's nest vena cava filter. J Vasc Surg. 2003;38(3):596-9. [pmid: 12947283].
Charles HW, Black M, Kovacs S, et al. G2 inferior vena cava filter: retrievability and safety. J Vasc Interv Radiol. 2009;20(8):1046-51. [pmid: 19560938].
Cimochowski GE, Evans RH, Zarins CK. Journal of Thoracic and Cardiovascular Surgery. Greenfield filter versus Mobin-Uddin umbrella: The continuing quest for the ideal method of vena cava interruption. 1980;79:358-65. [pmid: 6986511].
Cosh DG, Moritz CK, Ashman KJ, Dally RJ, Gallus AS. Prospective evaluation of a flexible protocol for starting treatment with warfarin and predicting its maintenance dose. Aust N Z J Med. 1989;19(3):191-7. [pmid: 2775039].
Cousins GR, DeAnda A Jr. Images in cardiothoracic surgery. Superior vena cava filter erosion into the ascending aorta. Ann Thorac Surg. 2006;81(5):1907. [pmid: 16631708].
Crochet D, Petitier H, Ricco JB, et al. Journal de Radiologie. Efficacy of the new caval filter (LEM) in the prevention of pulmonary embolism. Preliminary results of a French multicenter study. 1988;69:431-6. [pmid: 3047374].
Crochet DP, Stora O, Ferry D, et al. Vena Tech-LGM filter: long-term results of a prospective study. Radiology. 1993;188(3):857-60. [pmid: 8351362].
Davis WC, McManus WF, Freeman DE, LeVeen RF. Evaluation of inferior vena caval occlusion to prevent pulmonary emboli. Am Surg. 1972;38(5):268-73. [pmid: 5026669].
De Gregorio MA, Gamboa P, Bonilla DL, et al. Retrieval of G++nther Tulip optional vena cava filters 30 days after implantation: A prospective clinical study. 2006;17:1781-9.
de Gregorio MA, Gamboa P, Gimeno MJ, et al. The Gunther Tulip retrievable filter: prolonged temporary filtration by repositioning within the inferior vena cava. J Vasc Interv Radiol. 2003;14(10):1259-65. [pmid: 14551272].
De Waele JJ, De Pauw M, Van Belleghem Y, Van Nooten G. Diagnosis of myocardial perforation by a Greenfield filter made by transesophageal echocardiography. J Am Soc Echocardiogr. 2002;15(4):374-5. [pmid: 11944017].
DeWeese MS, Kraft RO, Nichols WK, Six HH, Thompson NW. Fifteen-year clinical experience with the vena cava filter. Ann Surg. 1973;178(3):247-57. [pmid: 4580969].
Donaldson MC, Wirthlin LS, Donaldson GA. Thirty-year experience with surgical interruption of the inferior vena cava for prevention of pulmonary embolism. Ann Surg. 1980;191(3):367-72. [pmid: 7362302].
Epstein DH, Darcy MD, Hunter DW, et al. Experience with the Amplatz retrievable vena cava filter. Radiology. 1989;172(1):105-10. [pmid: 2662247].
Fecher AM, O'Mara MS, Goldfarb IW, et al. Analysis of deep vein thrombosis in burn patients. Burns. 2004;30(6):591-3. [pmid: 15302428].
Ferrell A, Byrne TK, Robison G. Placement of inferior vena cava filters in bariatric surgical patients - Possible indications and technical considerations. 2004;14:738-43.
Ferris EJ, McCowan TC, Carver DK, McFarland DR. Percutaneous inferior vena caval filters: follow-up of seven designs in 320 patients. Radiology. 1993;188(3):851-6. [pmid: 8351361].
Foley PJ, Nathan DP, Wang GJ, et al. A “fall-back” technique for difficult inferior vena cava filter retrieval. J Vasc Surg. 2012.
Gaston EA. Incorrect placement of intracaval prosthesis for pulmonary embolism. JAMA. 1970;214(13):2338. [pmid: 5536897].
Gjores JE. Value of anticoagulant therapy in the prevention of the postthrombotic syndrome. Sven Lakartidn. 1956;53(46):3006-10. [pmid: 13391632].
Goldman KA, Adelman MA. Cardiovascular Surgery. Retroperitoneal caval filter as a source of abdominal pain. 1994;2:85-7. [pmid: 8049932].
Graves DJ, Wenger NK, Clark WS. Lack of excessive bleeding risk in elderly patients receiving long-term oral anticoagulation. 1995;3(4):273-80.
Greenfield LJ, Cho KJ, Proctor MC, Sobel M, Shah S, Wingo J. Late results of suprarenal Greenfield vena cava filter placement. Arch Surg. 1992;127(8):969-73. [pmid: 1642540].
Greenfield LJ, Cho KJ, Tauscher JR. Limitations of percutaneous insertion of Greenfield filters. J Cardiovasc Surg (Torino). 1990;31(3):344-50.
Greenfield LJ, Michna BA. Twelve-year clinical experience with the Greenfield vena caval filter. Surgery. 1988;104(4):706-12. [pmid: 3175867].
Greenfield LJ, Proctor MC, Cho KJ, et al. Journal of Vascular Surgery. Extended evaluation of the titanium Greenfield vena caval filter. 1994;20:458-65. [pmid: 8084040].
Greenfield LJ, Proctor MC, Fischer DF Jr. Journal of Vascular Surgery. Suprarenal filter placement. 1998;28:432-8. [pmid: 9737452].
Guimbretiere J, Lebeaupin R, Pannier M. Heparin therapy and burns. Anesth Analg (Paris). 1977;34(6):1339-44. [pmid: 613885].
Hagedorn JC, Morton JM. Pulmonary embolus after retrieval of a temporary inferior vena caval filter in a Jehovah's Witness undergoing gastric bypass surgery. Obes Surg. 2006;16(8):1096-100. [pmid: 16901367].
Hajduk B, Tomkowski W, Fijalkowska A, et al. LGM inferior vena cava filters--observation of 79 patients. Pol Arch Med Wewn. 2000;104(5):753-60. [pmid: 11434087].
Harries SR, Wells IP, Roobottom CA. Clinical Radiology. Long-term follow-up of the Antheor inferior vena cava filter. 1998;53:350-2. [pmid: 9630273].
Hawkins SP, Al-Kutoubi A. Clinical Radiology. The Simon nitinol inferior vena cava filter: Preliminary experience in the UK. 1992;46:378-80. [pmid: 1493649].
Helling TS, Kaswan S, Miller SL, Tretter JF. Practice patterns in the use of retrievable inferior vena cava filters in a trauma population: a single-center experience. J Trauma. 2009;67(6):1293-6. [pmid: 20009680].
Hlavaty TS, McCowan TC, Ferris EJ, Carver DK, Harris DL, Barnes RW. The Journal of the Arkansas Medical Society. Experience with the Kimray-Greenfield inferior vena caval filter. 1991;88:215-7. [pmid: 1804837].
Hoff J, Labadie F, Berranger C, Guillemot L, Grinand M. Shock occurring shortly after inferior vena cava interruption using an endovascular device: think of filter thrombosis. Ann Fr Anesth Reanim. 2003;22(9):815-7. [pmid: 14612169].
Janjua M, Younas F, Moinuddin I, et al. Outcomes with retrievable inferior vena cava filters. J Invasive Cardiol. 2010;22(5):235-9. [pmid: 20440042].
Janjua M, Younas F, Moinuddin I, et al. Outcome with retrievable inferior vena cava filters. Chest. 2009;136(4).
Janvier AL, Hamdan H, Malas M. Bilateral renal vein thrombosis and subsequent acute renal failure due to IVC filter migration and thrombosis. Clin Nephrol. 2010;73(5):408-12. [pmid: 20420804].
Jarrell BE, Posuniak E, Roberts J, Osterholm J, Cotler J, Ditunno J. A new method of management using the Kim-Ray Greenfield filter for deep venous thrombosis and pulmonary embolism in spinal cord injury. Surg Gynecol Obstet. 1983;157(4):316-20. [pmid: 6623320].
Johnson Iii ON, Gillespie DL, Aidinian G, White PW, Adams E, Fox CJ. The use of retrievable inferior vena cava filters in severely injured military trauma patients. 2009;49:410-6.
Johnson SP, Raiken DP, Grebe PJ, Diffin DC, Leyendecker JR. Journal of Vascular and Interventional Radiology. Single institution prospective evaluation of the over-the-wire greenfield vena caval filter. 1998;9:766-73. [pmid: 9756064].
Kalavakunta JK, Thomas CS, Gupta V. A needle through the heart: rare complication of inferior vena caval filters. J Invasive Cardiol. 2009;21(11):E221-3. [pmid: 19901424].
Kalva SP, Athanasoulis CA, Fan CM, et al. “RecoveryG+ñ+¦” vena cava filter: Experience in 96 patients. 2006;29:559-64.
Kalva SP, Athanasoulis CA, Fan CM, et al. “Recovery” vena cava filter: experience in 96 patients. Cardiovasc Intervent Radiol. 2006;29(4):559-64. [pmid: 16565794].
Kalva SP, Chlapoutaki C, Wicky S, Greenfield AJ, Waltman AC, Athanasoulis CA. Suprarenal inferior vena cava filters: a 20-year single-center experience. J Vasc Interv Radiol. 2008;19(7):1041-7. [pmid: 18589318].
Kaskarelis IS, Koukoulaki M, Chlapoutaki CE, et al. Clinical experience with Gunther temporary inferior vena cava filters. Clin Imaging. 2006;30(2):108-13. [pmid: 16500541].
Kazmers A, Ramnauth S, Williams M. American Surgeon. Intraoperative insertion of Greenfield filters: Lessons learned in a personal series of 152 cases. 2002;68:877-82. [pmid: 12412714].
Keeling WB, Haines K, Stone PA, Armstrong PA, Murr MM, Shames ML. Current indications for preoperative inferior vena cava filter insertion in patients undergoing surgery for morbid obesity. Obes Surg. 2005;15(7):1009-12. [pmid: 16105398].
Kim D, Edelman RR, Margolin CJ, et al. Angiology. The Simon nitinol filter: Evaluation by MR and ultrasound. 1992;43:541-8. [pmid: 1626731].
Kostler H. Therapy and prophylaxis of thrombosis with a new anticoagulant of the heparin group. Med Klin (Munich). 1956;51(15):646-9. [pmid: 13347888].
Kumar BC, Chakraverty S, Zealley I. Failed retrieval of potentially retrievable IVC filters: a report of two cases. Cardiovasc Intervent Radiol. 2006;29(1):126-7. [pmid: 16252080].
Lazo-Langner A, Kovacs MJ. Standard-intensity vs low-dose anticoagulation for long-term management of patients with venous thromboembolism. Clin Adv Hematol Oncol. 2005;3(11):877-9. [pmid: 16491633].
Levine MN, Raskob G, Landefeld S, Kearon C. Chest. Hemorrhagic complications of anticoagulant treatment. 1998;114:511S-23S. [pmid: 9822060].
Looby S, Given MF, Geoghegan T, McErlean A, Lee MJ. Gunther Tulip retrievable inferior vena caval filters: Indications, efficacy, retrieval, and complications. 2007;30:59-65.
Lorch H, Welger D, Wagner V, et al. Current practice of temporary vena cava filter insertion: a multicenter registry. J Vasc Interv Radiol. 2000;11(1):83-8. [pmid: 10693718].
Marmor DB, Merli GJ, Whellan DJ, et al. Relationship of inferior vena cava filter usage in post-surgical patients by various surgical and medical subspecialists. Am J Cardiol. 2008;102(2):226-30. [pmid: 18602527].
Marx R. Heparin therapy in thromboses of the deep veins of the leg and pelvis (author's transl). Munch Med Wochenschr. 1973;115(48):2195-9. [pmid: 4801300].
McKenzie S, Gibbs H, Leggett D, et al. An Australian experience of retrievable inferior vena cava filters in patients with increased risk of thromboembolic disease. Int Angiol. 2010;29(1):53-7. [pmid: 20224533].
Melon E, Keravel Y, Gaston A, Huet Y, Combes S. Anesthesiology. Deep venous thrombosis prophylaxis by low molecular weight heparin in neurosurgical patients. 75.
Millward SF, Marsh JI, Peterson RA, et al. Journal of vascular and interventional radiology : JVIR. LGM (Vena Tech) vena cava filter: clinical experience in 64 patients. 1991;2:429-33. [pmid: 1797207].
Millward SF, Oliva VL, Bell SD, et al. Gunther Tulip Retrievable Vena Cava Filter: results from the Registry of the Canadian Interventional Radiology Association. J Vasc Interv Radiol. 2001;12(9):1053-8. [pmid: 11535767].
Mourelo R, Kaidar-Person O, Fajnwaks P, et al. Hemorrhagic and thromboembolic complications after bariatric surgery in patients receiving chronic anticoagulation therapy. 2008;18:167-70.
Murphy TP, Dorfman GS, Yedlicka JW, et al. LGM vena cava filter: objective evaluation of early results. J Vasc Interv Radiol. 1991;2(1):107-15. [pmid: 1799739].
Murphy TP, Dorfman GS, Yedlicka JW, et al. Journal of vascular and interventional radiology : JVIR. LGM vena cava filter: objective evaluation of early results. 1991;2:107-15. [pmid: 1799739].
Nazzal M, Abbas J, Shattu J, Nazzal M. Complications secondary to the Bard retrievable filter: a case report. Ann Vasc Surg. 2008;22(5):684-7. [pmid: 18504101].
Neuerburg JM, Gunther RW, Vorwerk D, et al. Results of a multicenter study of the retrievable Tulip Vena Cava Filter: early clinical experience. Cardiovasc Intervent Radiol. 1997;20(1):10-6. [pmid: 8994718].
Nicholson AA, Ettles DF, Paddon AJ, Dyet JF. Long-term follow-up of the Bird's Nest IVC Filter. 1999;54:759-64.
O'Malley KF, Ross SE. Journal of Trauma. Pulmonary embolism in major trauma patients. 1990;30:748-50. [pmid: 2352304].
Orsini RA, Jarrell BE. Suprarenal placement of vena caval filters: indications, techniques, and results. J Vasc Surg. 1984;1(1):124-35. [pmid: 6481860].
Parkin E, Serracino-Inglott F, Chalmers N, Smyth V. Symptomatic perforation of a retrievable inferior vena cava filter after a dwell time of 5 years. J Vasc Surg. 2009;50(2):417-9. [pmid: 19631878].
Pernod G, Sevestre M, Labarere J, et al. D-dimer and duration of anticoagulation…. New England Journal of Medicine. 2007;356(4):421-3. [pmid: 17251543]. Palareti G, Cosmi B, Legnani C, et al. D-Dimer testing to determine the duration of anticoagulation therapy. N Engl J Med. 2006;355:1780-9. [pmid: 17065639].
Perrin M. Skin necrosis as a complication of compression in the treatment of venous disease and in prevention of venous thromboembolism. Phlebolymphology. 2008;15(1):27-30.
Piazza G, Goldhaber SZ. Acute pulmonary embolism: part II: treatment and prophylaxis. Circulation. 2006;114(3):e42-7. [pmid: 16847156].
Piazza G, Seddighzadeh A, Goldhaber SZ. Double trouble for 2,609 hospitalized medical patients who developed deep vein thrombosis: prophylaxis omitted more often and pulmonary embolism more frequent. Chest. 2007;132(2):554-61. [pmid: 17573518].
Piecuch J, Wiewiora M, Nowowiejska-Wiewiora A, Szkodzinski J, Polonski L. Perforation of inferior vena cava during filter placement. Vasa. 2011;40(2):157-62. [pmid: 21500182].
Pisco JM, Santiago MJ, Basto I. Percutaneous placement of inferior vena cava filters. Acta Med Port. 1992;5(10):527-32. [pmid: 1492602].
Pomper SR, Lutchman G. Angiology. The role of intracaval filters in patients with COPD and DVT. 1991;42:85-9. [pmid: 2006765].
Porcellini M, Stassano P, Musumeci A, Bracale G. Intracardiac migration of nitinol TrapEase vena cava filter and paradoxical embolism. Eur J Cardiothorac Surg. 2002;22(3):460-1. [pmid: 12204746].
Rao G. Long-term experience with the Mobin-Uddin umbrella. Int Surg. 1980;65(3):223-30. [pmid: 7014494].
Ricco JB, Crochet D, Sebilotte P, et al. Annals of Vascular Surgery. Percutaneous transvenous caval interruption with the “LGM” filter: early results of a multicenter trial. 1988;2:242-7. [pmid: 3056484].
Ricco JB, Dubreuil F, Reynaud P, et al. The LGM Vena-Tech caval filter: results of a multicenter study. Ann Vasc Surg. 1995;9(Suppl):S89-100. [pmid: 8688316].
Rodger MA, Ramsay T, Mackinnon M, et al. Tinzaparin Versus Dalteparin for Periprocedure Prophylaxis of Thromboembolic Events in Hemodialysis Patients: A Randomized Trial. Am J Kidney Dis. 2012.
Rousseau H, Perreault P, Otal P, et al. The 6-F nitinol TrapEase inferior vena cava filter: results of a prospective multicenter trial. J Vasc Interv Radiol. 2001;12(3):299-304. [pmid: 11287505].
Salzman EW, Deykin D, Shapiro RM, Rosenberg R. Management of heparin therapy: Controlled prospective trial. N Engl J Med. 1975;292(20):1046-50. [pmid: 1091856].
Saour J, Al Harthi A, El Sherif M, Bakhsh E, Mammo L. Inferior vena caval filters: 5 years of experience in a tertiary care center. Annals of Saudi Medicine. 2009;29(6):446-9. [pmid: 19847081].
Savin MA, Panicker HK, Sadiq S, Albeer YA, Olson RE. Placement of vena cava filters: factors affecting technical success and immediate complications. AJR Am J Roentgenol. 2002;179(3):597-602. [pmid: 12185026].
Schleich JM, Laurent M, Le Helloco A, Langella B, Ramee A, Almange C. American Journal of Roentgenology. Short-term follow-up of inferior vena caval filters: Comparison of imaging techniques. 1993;161:799-803. [pmid: 8372763].
Schleich JM, Morla O, Laurent M, Langella B, Chaperon J, Almange C. Long-term follow-up of percutaneous vena cava filters: a prospective study in 100 consecutive patients. Eur J Vasc Endovasc Surg. 2001;21(5):450-7. [pmid: 11352522].
Schlosser V, Spillner G, Kaiser W. Prevention of pulmonary embolism by inferior vena cava filters: results in 62 cases. World J Surg. 1977;1(1):113-6. [pmid: 868049].
Schneider PA, Geissbuhler P, Piguet JC, Bounameaux H. Follow-up after partial interruption of the vena cava with the Gunther filter. Cardiovasc Intervent Radiol. 1990;13(6):378-80. [pmid: 2126997].
Shepherd MF, Rosborough TK, Schwartz ML. Unfractionated heparin infusion for thromboprophylaxis in highest risk gastric bypass surgery. 2004;14:601-5.
Shprecher AR, Cheng-Lai A, Madsen EM, et al. Peak antifactor Xa activity produced by dalteparin treatment in patients with renal impairment compared with controls. 2005;25:817-22.
Siddiqui RA, Hans S. Double inferior vena cava filter implantation in a patient with a duplicate inferior vena cava. J Invasive Cardiol. 2008;20(2):91-2. [pmid: 18252974].
Siguret V, Gouin I, Debray M, et al. Initiation of warfarin therapy in elderly medical inpatients: a safe and accurate regimen. Am J Med. 2005;118(2):137-42. [pmid: 15694897].
Simon M, Athanasoulis CA, Kim D, et al. Radiology. Simon nitinol inferior vena cava filter: Initial clinical experience. Work in progress. 1989;172:99-103. [pmid: 2662259].
Singh S, Verma M, Bahekar A, et al. Enoxaparin-induced skin necrosis: a fatal outcome. Am J Ther. 2007;14(4):408-10. [pmid: 17667218].
Smith JA, Atkinson NR, Walters NA, Thomson KR. Medical Journal of Australia. Early experience with the bird's nest inferior vena-caval filter. 1989;150:164-5. [pmid: 2716589].
Sparrow P. Double whammy: inferior vena cava filter-related perforation and thrombosis of the inferior vena cava and aorta. Circulation. 2011;123(7):e245-6. [pmid: 21343589].
Spivack S, Kalker E, Samuels D, Orron DE. Filter placement in duplicated inferior vena cava. Isr Med Assoc J. 2001;3(6):459-60. [pmid: 11433647].
Starok MS, Common AA. Follow-up after insertion of Bird's Nest inferior vena caval filters. Can Assoc Radiol J. 1996;47(3):189-94. [pmid: 8640416].
Stewart JR, Peyton JWR, Crute SL, Greenfield LJ. Surgery. Clinical results of suprarenal placement of the Greenfield vena cava filter. 1982;92:1-4. [pmid: 7089859].
Tardy B, Mismetti P, Page Y, et al. Symptomatic inferior vena cava filter thrombosis: Clinical study of 30 consecutive cases. 1996;9:2012-6.
Teitelbaum GP, Jones DL, Van Breda A, et al. Radiology. Vena caval filter splaying: Potential complication of use of the titanium Greenfield filter. 1989;173:809-14. [pmid: 2813790].
Thomas Iii WO, Ferrara JJ, Rodning CB. A retrospective analysis of inferior vena caval filtration for prevention of pulmonary embolization. 1988;54:726-30.
Tobin KD, Pais SO, Austin CB. Investigative Radiology. Femoral vein thrombosis following percutaneous placement of the Greenfield filter. 1989;24:442-5. [pmid: 2521124].
Todd GJ, Sanderson J, Nowygrod R, Benvenisty A, Reemtsma K. Recent clinical experience with the vena cava filter. Am J Surg. 1988;156(5):353-8. [pmid: 3189705].
Welch TJ, Stanson AW, Sheedy PF 2nd, Johnson CM, Miller WE, Johnson CD. Percutaneous placement of the Greenfield vena caval filter. Mayo Clin Proc. 1988;63(4):343-7. [pmid: 3352317].
Wellons ED, Matsuura JH, Shuler FW, Franklin JS, Rosenthal D, Naslund TC. Bedside intravascular ultrasound-guided vena cava filter placement. 2003;38:455-8.
Wicky J, Couson F, Ambrosetti P, Didier D, Rohner A, Bounameaux H. Thrombosis and Haemostasis. Postoperative deep venous thrombosis (DVT) and low-molecular weight heparin (LMWH) type and dosage [2]. 1993;69:402-3. [pmid: 8388582].
Williams RW, Schenk WG Jr. A removable intracaval filter for prevention of pulmonary embolism: early experience with the use of the Eichelter catheter in patients. Surgery. 1970;68(6):999-1008. [pmid: 5483252].
Wilson SJ, Wilbur K, Burton E, Anderson DR. Effect of patient weight on the anticoagulant response to adjusted therapeutic dosage of low-molecular- weight heparin for the treatment of venous thromboembolism. Haemostasis. 2001;31(1):42-8. [pmid: 11408748].
Wittenberg G, Kueppers V, Tschammler A, Scheppach W, Kenn W, Hahn D. Long-term results of vena cava filters: experiences with the LGM and the Titanium Greenfield devices. Cardiovasc Intervent Radiol. 1998;21(3):225-9. [pmid: 9626439].
Woolson ST, Harris WH. Greenfield vena caval filter for management of selected cases of venous thromboembolic disease following hip surgery. A report of five cases. Clin Orthop Relat Res. 1986;204:201-6. [pmid: 3956011].
Xu K, Zhou YB, Wang AL, Xiao L. Clinical study of domestic ZQL-type retrievable vena cava filter. Chin Med J (Engl). 2009;122(2):140-4. [pmid: 19187635].
Yale SH, Mazza JJ, Glurich I, Peters T, Mukesh BN. Recurrent venous thromboembolism in patients with and without anticoagulation after inferior vena caval filter placement. 2006;25:60-6.
Yoshida WB, Rollo HA, Giannini M, Sobreira ML, Moura R. Preliminary experience with a new vena cava filter: Results of 15 implantations. 2008;7(3):282-8.

## Other

LMWH and UFH in direct comparison. Consent: CERTIFY. MMW Fortschr Med. 2007;149(20):53.
AbuRahma AF, Robinson PA, Boland JP, et al. Therapeutic and prophylactic vena caval interruption for pulmonary embolism: caval and venous insertion site patency. Ann Vasc Surg. 1993;7(6):561-8. [pmid: 8123459].
Adamus R, Bolte R, Loose R. Clinical results with a detachable temporary vena cava filter. Rofo. 2007;179(6):601-4. [pmid: 17534770].
Albino P. Inferior vena cava interruption: a 17-years experience (1989-2006). Rev Port Cir Cardiotorac Vasc. 2006;13(3):165-71. [pmid: 17057821].
Altintas F, Gurbuz H, Erdemli B, et al. Venous thromboembolism prophylaxis in major orthopaedic surgery: A multicenter, prospective, observational study. Acta Orthop Traumatol Turc. 2008;42(5):322-7. [pmid: 19158452].
Arcangeli A, Rocca B, Salvatori G, Ciancia M, De Cristofaro R, Antonelli M. Heparin versus prostacyclin in continuous hemodiafiltration for acute renal failure: Effects on platelet function in the systemic circulation and across the filter. Thromb. Res. 2010;126(1):24-31. [pmid: 20185164].
Arimune M, Morita H. Safety of low dose unfractionated heparin (LDUH) in patients undergoing hip fracture operation. Masui. 2008;57(10):1223-6. [pmid: 18975536].
Arriagada I, Mertens R, Valdes F, et al. Percutaneous inferior vena cava filters: indications and results in 287 patients. Rev Med Chil. 2007;135(3):351-8. [pmid: 17505581].
Bajardi G, Ricevuto G, Mastrandrea G, et al. Post-operative venous thromboembolism in bariatric surgery: Le Tromboembolie Venose Post-Chirurgiche In Chirurgia Bariatrica. 1993;48:539-42.
Bargues L, Foissaud V, Jault P, Samson T, Carsin H. Heparin-induced thrombocytopenia: report of four cases in severely burned patients. Ann Fr Anesth Reanim. 2006;25(11-12):1135-9. [pmid: 17034986].
Barsotti J, Benhamou AC, Guerois C, Gratteau B, Guilmot JL, Jolidon C. White clot syndrome. Arterial and venous thromboses during heparin therapy with thrombopenia after bone surgery. J Mal Vasc. 1983;8(2):139-42. [pmid: 6875393].
Barsotti J, Gruel Y, Rosset P, et al. Comparative double-blind study of two dosage regimens of low-molecular weight heparin in elderly patients with a fracture of the neck of the femur. J Orthop Trauma. 1990;4(4):371-5. [pmid: 2176235].
Bartolo M, Antignani PL, Gozzer G. Physical and pharmacologic measures in the prophylaxis of deep venous thrombosis. Clin Ter. 1986;119(3):227-34. [pmid: 3542347].
Baschera D, Sebunya J, Walter C, Zellweger R. Vena cava filters in trauma patients. Unfallchirurg. 2010;113(9):764-9. [pmid: 20740267].
Bi C, Wen J, Jiang K, et al. Chinese drugs for supplementing Qi and activating blood circulation in preventing deep venous thrombosis after big operations in orthopaedics and traumatology. Zhongguo Zhong Yao Za Zhi. 2009;34(5):625-7. [pmid: 19526798].
Borobia AM, Fernandez Capitan C, Iniesta Arandia N, et al. Risk of thromboembolic events and evaluation of the use of venous thromboembolism prophylaxis in hospitalized medical patients and after discharge. Rev Clin Esp. 2009;209(1):15-20. [pmid: 19268092].
Bounameaux Y. Pharmacodynamic prevention of thrombosis. Rev Med Liege. 1971;26(19):637-46. [pmid: 5125111].
Braekkan S, Grimsgaard S, Hansen JB. Thromboembolic prophylaxis in hospitalized medical patients. Tidsskr Nor Laegeforen. 2007;127(9):1177-80. [pmid: 17479133].
Brakenridge SC, Toomay SM, Sheng JL, Gentilello LM, Shafi S. Predictors of early versus late timing of pulmonary embolus after traumatic injury. Am J Surg. 2011;201(2):209-15. [pmid: 20385370].
Brophy DF, Martin EJ, Best AM, Gehr TWB, Carr ME. Journal of Thrombosis and Haemostasis. Antifactor Xa activity correlates to thrombin generation time, platelet contractile force and clot elastic modulus following ex vivo enoxaparin exposure in patients with and without renal dysfunction. 2004;2:1299-304. [pmid: 15304034].
Brunner U. Prevention of venous thrombosis in surgery of the lower limbs. Various phases of an experience in a general traumatology service. Phlebologie. 1984;37(1):41-7. [pmid: 6718503].
Cadroy Y, Pourrat J, Baladre MF, et al. Delayed elimination of enoxaparine in patients with chronic renal insufficiency. 1991;63:385-90.
Carmody BJ, Sugerman HJ, Kellum JM, et al. Pulmonary embolism complicating bariatric surgery: detailed analysis of a single institution's 24-year experience. J Am Coll Surg. 2006;203(6):831-7. [pmid: 17116551].
Chevrel JP, Cupa M, Lapendry C. Prevention of postoperative thromboses. Med Chir Dig. 1974;3(3):209-14. [pmid: 4431268].
Citterio LE, Mannucci PM. Low-dose heparin for prevention of deep-vein thrombosis in patients undergoing hip-arthroplasty. Thrombosis Et Diathesis Haemorrhagica. 1975;34(3):926.
Cohen AT, Davidson BL, Gallus AS, et al. Fondaparinux for the prevention of VTE (venous thromboembolism) in acutely ill medical patients. Blood. 2003;102(11( Pt 1)):15a.
Cohen AT, Spiro TE, Buller HR, et al. Rivaroxaban versus enoxaparin for the prevention of venous thromboembolism in acutely ill medical patients: Analysis of factors contributing to benefit and risk in MAGELLAN. J. Thromb. Haemost. 2011;9:961.
Colwell CW, Berkowitz SD, Comp PC, et al. Randomized, double-blind comparison of ximelagatran, an oral direct thrombin inhibitor, and warfarin to prevent venous thromboembolism (VTE) after total knee replacement (TKR): EXULT B [Abstract]. Blood. 2003;102(11 Part 1):14a.
Colwell CW, Spiro TE, Trowbridge AA. A randomized trial comparing the safety and efficacy of enoxaparin and heparin for the prevention of deep vein thrombosis following hip replacement surgery [Abstract]. Orthopaedic Transactions. 1992;16(3):713.
Cotter SA, Cantrell W, Fisher B, Shopnick R. Efficacy of venous thromboembolism prophylaxis in morbidly obese patients undergoing gastric bypass surgery. Obes Surg. 2005;15(9):1316-20. [pmid: 16259895].
Crochet D, Petitier H, Ricco JB, et al. The new LEM caval filter in the prevention of pulmonary embolism. Preliminary results of a French multicenter study. J Radiol. 1988;69(6-7):431-6. [pmid: 3047374].
Dahl OE, Kurth AA, Rosencher N, et al. Oral prevention of venous thromboembolism after total knee or hip replacement surgery in the elderly and those with moderate renal impairment: Efficacy and safety profile of dabigatran etexilate. Haematologica. 2009;94:179.
David W, Gross WS, Colaiuta E, Gonda R, Osher D, Lanuti S. Pulmonary embolus after vena cava filter placement. Am Surg. 1999;65(4):341-6. [pmid: 10190360].
Deitelzweig SB, Lin J, Lin G. Preventing venous thromboembolism following orthopedic surgery in the United States: Impact of special populations on clinical outcomes. Clin. Appl. Thromb. Hemost. 2011;17(6):640-50. [pmid: 21593017].
Delavenne X, Zufferey P, Nguyen P, et al. Pharmacokinetics of fondaparinux 1.5 mg once daily in a real-world cohort of patients with renal impairment undergoing major orthopaedic surgery. Eur J Clin Pharmacol. 2012.
Eisele R, Greger W, Weikert E, Kinzl L. Ambulatory prevention of thrombosis in traumatology. Unfallchirurg. 2001;104(3):240-5. [pmid: 11284355].
Elakkary E, Kusti M, Olgers F, Groves L, Bellotte T, Moynihan D. Standardized protocol for deep venous thrombosis and pulmonary embolism prophylaxis A simple pathway to minimize the risk of thromboembolism after bariatric surgery. Obes. Surg. 2010;20(8):1064.
Emter M, Alexander K. Prevention of thrombosis with anti-thrombosis stockings and intermittent compression. Vasa Suppl. 1991;33:220. [pmid: 1788681].
Eriksson BI, Eriksson E, Wadenvik H, Tengborn L, Risberg B. Comparison of low molecular weight heparin and unfractionated heparin in prophylaxis of deep vein thrombosis and pulmonary embolism in total hip replacement. Thrombosis and Haemostasis. 1989;62(1):470. Abstract no: 1471.
Fernandez I, Sanz E, Mendoza M, Larramona G, Hernandez M, et al. Assessing the use of low molecular weight heparins for venous thromboembolism prophylaxis in internal medicine patients: Assessing the use of low molecular weight heparins for venous thromboembolism prophylaxis in internal medicine patients. Farmacia Hospitalaria (Spain). 2004;28. NIL.
Ferree BA, Stern PJ, Jolson RS, Roberts JM 5th, Kahn A 3rd. Deep venous thrombosis after spinal surgery. Spine (Phila Pa 1976). 1993;18(3):315-9. [pmid: 8475429].
Folwaczny EK, Sturmer KM. Heparin-induced thrombocytopenia and thrombosis. Thrombosis as an early cardinal symptom of heparin allergy. Chirurg. 2002;73(12):1197-203. [pmid: 12491049].
Fordyce MJF, Ling RSM. The prevention of deep vein thrombosis following total hip replacement by use of the A-V impulse system: Artificial stimulation of the physiological venous foot pump [Abstract]. Journal of Bone and Joint Surgery - British Volume. Suppl 2. 1992;74:156-7.
Friedman RJ, Caprini JA, Comp PC, et al. Dabigatran etexilate versus enoxaparin in preventing venous thromboembolism following total knee arthroplasty [abstract no:O-W-051]. Journal of Thrombosis & Haemostasis. 2007;5(Suppl 1).
Frikha N, Ouerghi S, Mnif MA, Mebazaa MS, Ben Ammar MS. The prophylaxis of the thromboembolic disease in the head trauma. Tunis Med. 2010;88(8):545-50. [pmid: 20711959].
Fuji T, Fujita S, Tachibana S, et al. Efficacy and safety of edoxaban versus enoxaparin for the prevention of venous thromboembolism following total hip arthroplasty: Stars J-V trial [Abstract No. 3320]. Blood. 2010;116(21).
Fuji T, Fujita S, Tachibana S, Kawai Y. Randomized, double-blind, multi-dose efficacy, safety and biomarker study of the oral factor xa inhibitor DU-176b compared with placebo for prevention of venous thromboembolism in patients after total knee arthroplasty. Blood. 2008;112(11). Abstract no:34.
Gadzhiev MG. Hemostatic indices in combined injuries of the head and thorax. Vestn Khir Im I I Grek. 1984;132(2):54-6. [pmid: 6719722].
Garcia-Godoy F, Collins T, Sacks D, Vasas S, Sarani B. Retrieval of inferior vena cava filters after prolonged indwelling time. Arch Intern Med. 2011;171(21):1953-5. [pmid: 22123810].
Gassanov N, Caglayan E, Erdmann E, Er F. Prophylaxis of thrombembolic diseases with rivaroxaban. Dtsch Med Wochenschr. 2010;135(44):2189-92. [pmid: 20979005].
Gatterer R, Wruhs O, Havelec L, Polterauer P, Marosi L. Prevention of thromboembolism in accident surgery--angiospastic complications with DHE-heparin. A multicenter study. Unfallchirurgie. 1987;13(5):263-70. [pmid: 3321657].
Gehrmann G. Neurologic complications in anticoagulant therapy. Med Welt. 1971;9:327-9. [pmid: 4101784].
Gerkens S, Beguin C, Crott R, Closon MC, Horsmans Y. Assessing the quality of pharmacological treatments from administrative databases: the case of low-molecular-weight heparin after major orthopaedic surgery. J Eval Clin Pract. 2008;14(4):585-94. [pmid: 18462276].
Glushkov NI, Openchenko SV. Intermittent pneumatic compression of the lower extremity muscles in complex prophylactics of postoperative venous thromboses in elderly and senile patients. Vestn Khir Im I I Grek. 2009;168(2):47-9. [pmid: 19514391].
Gordon-Smith IC, Grundy DJ, Le Quesne LP, Newcombe JF, Bramble FJ. Controlled trial of two regimens of subcutaneous heparin in prevention of postoperative deep vein thrombosis: Controlled trial of two regimens of subcutaneous heparin in prevention of postoperative deep vein thrombosis. Lancet (England). 1972;1:1133-5.
Goss TP, Stinchfield FE, Cosgriff SW. The efficacy of low-dose heparin--warfarin anticoagulation prophylaxis after total hip replacement arthroplasty. Clin Orthop Relat Res. 1979;141:134-7. [pmid: 477094].
Greenfield LJ, Proctor MC, Rodriguez JL, Luchette FA, Cipolle MD, Cho J. Posttrauma thromboembolism prophylaxis. J Trauma. 1997;42(1):100-3. [pmid: 9003265].
Grouille D, Rigaud G, Orsel I, Colin D. A comparative study of 3 preventive anticoagulation protocols used successively in orthopedics at the CHU of Limoges. A retrospective study of 953 total hip prostheses (single or repeat). Cah Anesthesiol. 1991;39(5):355-6. [pmid: 1742640].
Gruber UF, Allemann U, Wettler H. 1st direct comparison of allergic side effects of dextran with and without hapten. Schweiz Med Wochenschr. 1982;112(17):605-12. [pmid: 6178151].
Gruber UF, Bon G. Intermittent pneumatic compression for the prevention of thrombosis. Dtsch Med Wochenschr. 1983;108(46):1767-71. [pmid: 6196170].
Grubnik VV, Golliak VP, Grubnik AV. Prophylaxis of thromboembolic complications in patients, operated on for alimentary-constitutional obesity. Klin Khir. 2006;9:35-9. [pmid: 17269389].
Haas S, Fareed J, Breyer HG, et al. Prevention of severe venous thromboembolism after hip and knee replacement surgery - A randomized comparison of low-molecular-weight heparin with unfractionated heparin [abstract no: 2957]. Blood. 2001;98(11).
Halmi D, Kolesnikov E. Preoperative placement of retreivable inferior vena cava filters in bariatric surgery. Surg Obes Relat Dis. 2007;3(6):602-5. [pmid: 17544920].
Hansen M, Mayer A, Peetz D, Hafner G, Prellwitz W, Rommens PM. Improved postoperative prevention of thrombosis in trauma surgery by dose adjusted low molecular weight heparin based on TAT and D-dimer values. Langenbecks Arch Chir Suppl Kongressbd. 1998;115:1213-7. [pmid: 9931839].
Harrington DT, Mozingo DW, Cancio L, Bird P, Jordan B, Goodwin CW. Thermally injured patients are at significant risk for thromboembolic complications. 2001;50:495-9.
Heidecke V, Rainov NG, Heidecke K, Burkert W. Thromboembolic complications in neurosurgical patients. Zentralbl Chir. 1997;122(5):367-73. [pmid: 9334098].
Heit J. Efficacy and safety of RD heparin (a LMWH) versus warfarin for prevention deep vein thrombosis after hip or knee replacement. Blood. 1991;(Suppl 78):1878a. Abstract no: 739.
Heizmann M, Baerlocher GM, Steinmann F, Horber FF, Wuillemin WA. Anti-Xa activity in obese patients after double standard dose of nadroparin for prophylaxis. 2002;106:179-81.
Hitos K, Chu P, Fletcher JP. Epidemiology of venous thromboembolism in trauma patients with lower extremity injuries. J. Thromb. Haemost. 2011;9:159.
Hitos K, Rogers J, Soo G, et al. A prospective study on venous thromboembolism following spinal surgery: Use of thromboprophylaxis and associated bleeding complications. J. Thromb. Haemost. 2011;9:399-400.
Hoff J, Labadie F, Berranger C, Guillemot L, Grinand M. Shock occurring shortly after inferior vena cava interruption using an endovascular device: think of filter thrombosis. Ann Fr Anesth Reanim. 2003;22(9):815-7. [pmid: 14612169].
Hoffmann R, Largiader F, Roethlin M. Peroperative thromboembolism prophylaxis: low-dose heparin or low molecular weight heparin-DHE, the advantages and disadvantages. A prospective randomized study. Helv Chir Acta. 1987;54(4):521-5. [pmid: 2833477].
Holmqvist B, Johansson H, Nordlund S. Subcutaneous heparin as a thrombosis preventive. Nord Med. 1959;62:1810. [pmid: 14402814].
Janni W, Bergauer F, Rjosk D, Lohscheidt K, Hagena FW. Prospective randomized study comparing the effectiveness and tolerance of various low-molecular-weight heparins in high risk patients. Zentralbl Chir. 2001;126(1):32-8. [pmid: 11227291].
Janni W, Bergauer F, Rjosk D, Lohscheidt K, Hagena F-W. A randomized controlled study evaluating the safety and efficacy of different low molecular weight heparins for high risk patients: Prospektiv randomisierte studie zum vergleich der wirksamkeit und der vertraglichkeit verschiedener niedermolekularer heparine bei hochrisikopatienten. Zentralbl. Chir. 2001;126(1):32-8. [pmid: 11227291].
Jaras Hernandez, Agudo de Blas P, Gonzalez Polo J, et al. Low Molecular Weight Heparin use in Internal Medicine hospitalized patients. An Med Interna. 2006;23(7):347-54. [pmid: 17067238].
Jorgensen PS, Knudsen JB, Broeng L, et al. The thromboprophylactic effect of low molecular weight heparin (Fragmin) in hip fracture surgery. A placebo controlled trial. Ugeskr Laeger. 1993;155(10):706-8. [pmid: 8384388].
Juhan-Vague I, Aillaud MF, Serradimigni A. Natural inhibitors of fibrinolysis. Haemostasis. Suppl 4. 1986;16:16-20.
Junghans E, Schmidt HD. Experiences with anticoagulants in general prophylaxis of postoperative thromboembolism. Z Geburtshilfe Gynakol. 1960;154:293-308. [pmid: 14408207].
Kakkar VV, Field ES, Nicolaides AN. Prevention of postoperative deep-vein thrombosis using heparin. Br J Surg. 1971;58(11):872-3. [pmid: 5124909].
Kakkar VV. A dose ranging study designed to assess the safety and efficacy of a low molecular weight heparin fragment (fragmin) as prophylaxis against deep vein thrombosis. Thrombosis Research. 1987;(Suppl VII):18. Abstract no: 14.
Kalodiki E, Nicolaides AN, Al-Kutoubi A, et al. LMWH and LMWH plus graduated elastic compression for DVT prophylaxis in total hip replacement. Thrombosis and Haemostasis. 1993;69(6):619. Abstract no: 270.
Kaplan J, Marciniak C, Chen D. Retrospective study comparing the safety and efficacy of enoxaparin vs tinzaparin in the prevention of venous thromboembolic disorders during rehabilitation following acute SCI. J. Spinal Cord Med. 2009;32(4):466.
Kearon C. Duration of venous thromboembolism prophylaxis after surgery. Chest. 2003;124(6 Suppl):386S-92S. [pmid: 14668422].
Keller F, Flosbach CW, THE PRIME - Study Group. A randomised multicentre double blind study investigating the efficacy and safety of the low molecular weight heparin enoxaparin versus unfractionated heparin in the prevention of thromboembolism in immobilised medical patients. Thrombosis and Haemostasis. 1995;73(6):1106. Abstract no: 788.
Kettunen K, Poikolainen E, Karjalainen P, et al. Prevention of postoperative deep vein thrombosis with small doses of heparin. Duodecim. 1974;90(11):834-8. [pmid: 4426267].
Kistler U, Kramers-de Quervain I, Munzinger U, Kucher N. Bleeding complications after systematic switch of routine thromboprophylaxis for major orthopaedic surgery. Thromb Haemost. 2008;99(6):1049-52. [pmid: 18521507].
Klimenko SM. Prevention of thromboembolic complications in postoperative period. Pediatr Akus Ginekol. 1970;4:58-60. [pmid: 5504832].
Kroger K. Prophylaxis of deep vein thrombosis with enoxaparin 40 mg in outpatients compared to hospitalized medically ill patients. Med Klin (Munich). 2009;104(8):608-13. [pmid: 19701731].
Kuklina AS, Leibzon ND, Monakova EA, Naumenko VG, Shcherbakova EA. Pulmonary artery thromboembolism and the state of the blood coagulation system in severe cranio-cerebral trauma. Vopr Neirokhir. 1972;36(4):25-8. [pmid: 5085148].
Lacherade JC, Cook D, Heyland D, Chrusch C, Brochard L, Brun-Buisson C. Prevention of venous thromboembolism in critically ill medical patients: a Franco-Canadian cross-sectional study. J Crit Care. 2003;18(4):228-37. [pmid: 14691896].
Lachish T, Rudensky B, Slotki I, Zevin S. Enoxaparin dosage adjustment in patients with severe renal failure: Antifactor Xa concentrations and safety. 2007;27:1347-52.
Lacut K, Delluc A, Vignon P, et al. Intermittent pneumatic compression to prevent venous thromboembolism in patients hospitalized in intensive medical care units with high risk of bleeding: A randomized trial. J. Thromb. Haemost. 2011;9:302-3. [pmid: 21781266].
Lai S, Barbano B, Cianci R, et al. The risk of bleeding associated with low molecular weight heparin in patients with renal failure. G Ital Nefrol. 2010;27(6):649-54. [pmid: 21132647].
Lavrik AS, Tyvonchuk AS, Bubalo AF, Zgonnik AIu. Prophylaxis of thromboembolic complications in bariatric surgery. Klin Khir. 2007;(8):39-42. [pmid: 18318070].
Le Quesne LP, Bramble J, Gordon-Smith IC, Grundy D, Newcombe J. A trial of two different regimes of subcutaneous heparin in the prophylaxis of deep-vein thrombosis. Br J Surg. 1972;59(4):300. [pmid: 4553588].
Lechler E, Schramm W, Flosbach CW. A randomized, multicentre double blind study investigating the efficacy and saftey of the low molecular weight heparin enoxaparin versus unfractionated heparin in the prevention of thromboembolism in immobilised patients. Annals of Hematology. 1994;68(Suppl 1):A55.
Leizorovicz A, Cohen A, Turpie AGG, Olsson CG, Vaitkus PT, Goldhaber SZ. A randomized placebo controlled trial of dalteparin for the prevention of venous thromboembolism in 3706 acutely ill medical patients: the PREVENT medical thromboprophylaxis study. Journal of Thrombosis & Haemostasis. 2003;1(Suppl 1 July). Abstract no: OC 396.
Leizorovicz A, Cohen AT, Turpie AGG, Olsson C-G, Vaitkus PT, Goldhaber SZ. Randomized, placebo-controlled trial of dalteparin for the prevention of venous thromboembolism in acutely ill medical patients. Circulation. 2004;110(7):874-9. [pmid: 15289368].
Levy JH, Bergese SD, Jaffer A, Minkowitz HS, Kurz MA, Sane DC. Multi-center trial of desirudin for the prophylaxis of thrombosis: An alternative to heparin-based anticoagulation - Results from the DESIRABLE trial. J. Thromb. Haemost. 2011;9:960.
Levy JH, Key NS, Shorr AF, Kurz MA, Marder VJ. VTE prophylaxis with desirudin in patients with thrombocytopenia: Insights from the DESIRABLE trial. Blood. 2011;118(21).
Lewandowski RJ, Ryu RK, Riaz A, et al. A prospective study of 467 IVC filter placements: Is there a difference between optional and permanent filters?. J Vasc. Intervent. Radiol. 2012;23(3):S25.
Leypold J, Privara M, Stepankova S. Prevention of postoperative thromboembolic accidents using small doses of heparin. Rozhl Chir. 1984;63(8-9):611-5. [pmid: 6505875].
Liavag I, Fotland K. Prevention of postoperative thrombo-embolism by elastic compression bandage of the legs. Tidsskr Nor Laegeforen. 1972;92(4):239-41. [pmid: 5016483].
Loew D, Boehme K, Artik N. A model for studying the antithrombotic effect of acetylsalicylic acid in the prevention of postoperative thrombo-embolism (author's transl). Dtsch Med Wochenschr. 1974;99(12):558 p. [pmid: 4835525].
Lohmann U, Glaser E, Braun BE, Botel U. Prevention of thromboembolism in spinal fractures with spinal cord injuries. Standard heparin versus low-molecular-weight heparin in acute paraplegia. Zentralbl Chir. 2001;126(5):385-90. [pmid: 11396248].
Luders K, Konold P, Otten G, Koslowski L. Prevention of postoperative thromboembolism. Randomized, prospective study of the comparison of thromboembolism prevention using anticoagulants (Heparin-Marcumar) and dextran 60 (Macrodex). Chirurg. 1973;44(12):563-9. [pmid: 4594859].
Ludwig KP, Simons HJ, Mone M, Barton RG, Kimball EJ. Implementation of an enoxaparin protocol for venous thromboembolism prophylaxis in obese surgical intensive care unit patients. Ann Pharmacother. 2011;45(11):1356-62. [pmid: 22009998].
Magee CJ, Barry J, Javed S, MacAdam R, Kerrigan D. Extended thromboprophylaxis reduces incidence of postoperative venous thromboembolism in laparoscopic bariatric surgery. Surg. Obes. Relat. Dis. 2010;6(3):322-5. [pmid: 20510295].
Mahmud M, Friedman H, Zekarias F, Vargas FMS. Prophylaxis against dvt with low molecular weight heparin and risk of bleeding in patients with and without CKD. J. Gen. Intern. Med. 2010;25:S369.
Malavaud A, Bichain N, Nicolas D, Sethian M. Prophylaxis of postoperative thromboembolic disease: heparinate or heparinoid? 1000 cases. Anesth Analg (Paris). 1970;27(2):225-35. [pmid: 4192784].
Marine L, Mertens R, Kramer Sch A, et al. Suprarenal inferior vena cava filters. Retrospective review of 30 cases. Rev Med Chil. 2008;136(12):1535-41. [pmid: 19350170].
Martinez Ramos C, Lopez Pastor A, Nunez Pena JR, et al. Laboratory evaluation of the effect of prophylaxis for thromboembolism with fractionated heparin in patients undergoing laparoscopic cholecystectomy. Rev Esp Enferm Dig. 2000;92(1):27-35. [pmid: 10749595].
Marx R. Heparin therapy in thromboses of the deep veins of the leg and pelvis (author's transl). Munch Med Wochenschr. 1973;115(48):2195-9. [pmid: 4801300].
Matviichuk BO, Matviichuk OB, Fedchyshyn NP. Prophylaxis of thromboembolism in general surgery: problems and perspectives. Klin Khir. 2007;8:36-8. [pmid: 18318069].
McCowan TC, Ferris EJ, Carver DK, Molpus WM. Complications of the nitinol vena caval filter. J Vasc Interv Radiol. 1992;3(2):401-8. [pmid: 1627893].
Miller MT, Rovito PF. An approach to venous thromboembolism prophylaxis in laparoscopic Roux-en-Y gastric bypass surgery. Obes Surg. 2004;14(6):731-7. [pmid: 15318974].
Mismetti P, Samama CM, Rosencher N, et al. Venous thromboembolism prevention with fondaparinux 1.5 mg in renally impaired patients undergoing major orthopaedic surgery. A real-world, prospective, multicentre, cohort study. Thromb Haemost. 2012;107(6):1151-60. [pmid: 22476471].
Mitchell M, Williams K, Umscheid CA. Low molecular weight heparins for prevention of venous thromboembolism in total knee arthroplasty patients (Structured abstract). Philadelphia. Center for Evidence-Based Practice (CEP). 2009.
Mouret P. The oral direct thrombin inhibitor Ximelagatran Prophylaxis of venous thromboembolism in hip and knee replacement. Hamostaseologie. 2002;22(3):21-4. [pmid: 12215757].
Muhe E. New method of preventing thrombosis: Intermittent sequential high-pressure leg compression (author's transl). Dtsch Med Wochenschr. 1982;107(28):1092-5. [pmid: 7084076].
Myhre HO, Holen A. Thrombosis prophylaxis. Dextran or warfarin-sodium? A controlled clinical study. Nordisk Medicin. 1969;82(49):1534-8. [pmid: 5372427].
Napolitano LM, Garlapati VS, Heard SO, et al. Asymptomatic deep venous thrombosis in the trauma patient: is an aggressive screening protocol justified?. J Trauma. 1995;39(4):651-7. discussion 657-9. [pmid: 7473949].
National Institute for Health and Clinical Excellence. Rivaroxaban for the prevention of venous thromboembolism after total hip or total knee replacement in adults (Structured abstract). London. National Institute for Health and Clinical Excellence (NICE). 2009.
Neeman Z, Auerbach A, Wood BJ. Metastatic involvement of a retrieved inferior vena cava filter. J Vasc Interv Radiol. 2003;14(12):1585. [pmid: 14654498].
Ohashi S. Prevention of postoperative venous thrombosis. Kokyu To Junkan. 1983;31(4):391-5. [pmid: 6867492].
Ooy Av, Hamulyak K. The ‘froac trial’ - low molecular heparin (LMWH) versus oral anticoagulants (OAC) for prevention of deep venous thrombosis (DVT) in elective hip and knee prosthesis implantations [Abstract]. Acta Orthopaedica Scandinavica. 1995;66(Suppl 265):65.
Otero-Fernandez R, Gomez-Outes A, Martinez-Gonzalez J, Rocha E, Fontcuberta J. Evaluation of the effectiveness and safety of bemiparin in a large population of orthopedic patients in a normal clinical practice. Clin Appl Thromb Hemost. 2008;14(1):75-83. [pmid: 17895506].
Paiement GD, Wessinger SJ, Hughes R, Harris WH. Routine use of adjusted low-dose warfarin to prevent venous thromboembolism after total hip replacement. J Bone Joint Surg Am. 1993;75(6):893-8. [pmid: 8314829].
Paige JT, Gouda BP, Gaitor-Stampley V, et al. No correlation between anti-factor Xa levels, low-molecular-weight heparin, and bleeding after gastric bypass. Surg Obes Relat Dis. 2007;3(4):469-75. [pmid: 17567541].
Patil S, Gandhi J, Curzon I, Hui AC. Incidence of deep-vein thrombosis in patients with fractures of the ankle treated in a plaster cast. J Bone Joint Surg Br. 2007;89(10):1340-3. [pmid: 17957074].
Peterson EA, Yenson PR, Liu D, Lee AWJ, Lee AY. Reasons for failure to remove inferior vena cava filters: Retrospective study in a tertiary care and trauma centre. Blood. 2011;118(21).
Pieri S, Agresti P, Morucci M, de' Medici L. Optional vena cava filters: preliminary experience with a new vena cava filter. Radiol Med. 2003;105(1-2):56-62. [pmid: 12700546].
Piotrowski JJ, Alexander JJ, Brandt CP, McHenry CR, Yuhas JP, Jacobs D. American Journal of Surgery. Is deep vein thrombosis surveillance warranted in high-risk trauma patients?. 1996;172:210-3. [pmid: 8795534].
Planes A, Vochelle N, Mazas F, et al. Double-blind randomized comparative study of enoxaparin and standard heparin in the prevention of thromboembolic disease during insertion of total hip replacement. Rev Med Interne. 1988;9(3):327-33. [pmid: 2841742].
Pomper SR, Lutchman G. Angiology. The role of intracaval filters in patients with COPD and DVT. 1991;42:85-9. [pmid: 2006765].
Poniewierski M, Barthels M, Poliwoda H. The safety and efficacy of a low molecular weight heparin (fragmin) in the prevention of deep vein thrombosis in medical patients: a randomized double-blind trial. Thrombosis and Haemostasis. 1987;58(1):119. Abstract no:. 425.
Potron G, Seys A, Lardennois B. Mini-dose heparin therapy. Protocol for a preoperative prophylaxis of thrombophlebitis. Cah Med. 1973;14(3):219-23. [pmid: 4730893].
Prystowsky JB, Morasch MD, Eskandari MK, Hungness ES, Nagle AP. Prospective analysis of the incidence of deep venous thrombosis in bariatric surgery patients. Surgery. 2005;138(4):759-63. discussion 763-5. [pmid: 16269306].
Purdue GF, Hunt JL. Pulmonary emboli in burned patients. J Trauma. 1988;28(2):218-20. [pmid: 3346921].
Quebbemann B, Akhondzadeh M, Dallal R. Continuous intravenous heparin infusion prevents peri-operative thromboembolic events in bariatric surgery patients. Obes Surg. 2005;15(9):1221-4. [pmid: 16273676].
Rader CP, Kramer C, Konig A, Hendrich C, Eulert J. Low-molecular-weight heparin and partial thromboplastin time-adjusted unfractionated heparin in thromboprophylaxis after total knee and total hip arthroplasty. J Arthroplasty. 1998;13(2):180-5. [pmid: 9526211].
Radmilovic A, Boric Z, Naumovic T, Stamenkovic M, Musikic P. Shunt thrombosis prevention in hemodialysis patients--a double-blind, randomized study: pentoxifylline vs placebo. Angiology. 1987;38(7):499-506. [pmid: 3304027].
Radziejewicz P, Gregosiewicz A, Bednarek A, Siczek M. The attempt of identification of the essentials risk factors of venous thromboembolism after hip arthroplasty despite of pharmacological prophylaxis. Chir Narzadow Ruchu Ortop Pol. 2010;75(4):242-7. [pmid: 21375033].
Renney JT, O'Sullivan EF, Burke PF. Prevention of postoperative deep vein thrombosis with dipyridamole and aspirin. Br Med J. 1976;1(6016):992-4. [pmid: 773495].
Reshetnikov EA, Gorodnichenko AI, Boriskin AA. Deep veins thrombosis prophylaxis in patients with fractures of long bones of the lower limbs. Khirurgiia (Mosk). 2009;8:15-20. [pmid: 19738556].
Riha GM, Van PY, Differding JA, Schreiber MA. Incidence of deep vein thrombosis is increased with 30 mg twice daily dosing of enoxaparin compared with 40 mg daily. Am J Surg. 2012;203(5):598-602. [pmid: 22521049].
Rimaud D, Boissier C, Calmels P. Evaluation of the effects of compression stockings using venous plethysmography in persons with spinal cord injury. J Spinal Cord Med. 2008;31(2):202-7. [pmid: 18581669].
Rocha ATC, Braga P, Ritt G, Lopes AA. Inadequacy of thromboprophylaxis in hospitalized medical patients: Inadequacao de tromboprofilaxia venosa em pacientes clinicos hospitalizados. Rev. Assoc. Med. Bras. 2006;52(6):441-6. [pmid: 17242783].
Roos J. Prevention of thrombosis in surgical patients. Ned Tijdschr Geneeskd. 1970;114(44):1828-33. [pmid: 4919447].
Rudowski W, Kostrzewska E, Sawicki F, Klawe Z. Anticoagulant action of dextran. Pol Tyg Lek. 1973;28(43):1669-73. [pmid: 4764094].
Sakamaki F. Prevention of acute pulmonary embolism. Respir. Circ. 2005;53(7):711-7.
Schellong SM, Hull RD, Tapson VF, et al. Extended-Duration Enoxaparin for Venous Thromboembolism Prophylaxis in Acutely Ill Medical Patients: An Evaluation of the EXCLAIM Study Based on a Recently Recommended Composite Efficacy Endpoint [Abstract]. Blood. 2007;110(11):554a.
Schiff RL, Kahn SR, Shrier I, et al. Identifying orthopedic patients at high risk for venous thromboembolism despite thromboprophylaxis. Chest. 2005;128(5):3364-71. [pmid: 16304285].
Schlag G, Gaudernak T, Pelinka H, Redl H, Kuderna H, Poigenfurst J. Thrombosis prevention with heparin/dihydroergotamine versus heparin/Sintrom in Ender nailing of pertrochanteric fractures. Unfallchirurgie. 1988;14(1):12-21. [pmid: 3284133].
Serin K, Yanar H, Ozdenkaya Y, Tugrul S, Kurtoglu M. Venous thromboembolism prophylaxis methods in trauma and emergency surgery intensive care unit patients: low molecular weight heparin versus elastic stockings + intermittent pneumatic compression. Ulus Travma Acil Cerrahi Derg. 2010;16(2):130-4. [pmid: 20517766].
Sevitt S, Gallagher N. Venous thrombosis and pulmonary embolism. A clinico-pathological study in injured and burned patients. 1961;48:475-89.
Sharpe RP, Gupta R, Gracias VH, et al. Journal of Trauma - Injury, Infection and Critical Care. Incidence and natural history of below-knee deep venous thrombosis in high-risk trauma patients. 2002;53:1048-52.
Shen YX, Zhu B, Wang Q. Application of intermittent air compression in prevention of embolism from venous thrombosis in intensive care unit. Zhongguo Wei Zhong Bing Ji Jiu Yi Xue. 2007;19(9):574-6. [pmid: 17767844].
Shepherd MF, Rosborough TK, Schwartz ML. Unfractionated heparin infusion for thromboprophylaxis in highest risk gastric bypass surgery. 2004;14:601-5.
Silbernagel G, Brechtel K, Strolin A, Balletshofer B. Infrarenal implantation of vena cava filters: two case reports. Dtsch Med Wochenschr. 2010;135(50):2539. [pmid: 21154194].
Simonneau G, Leizorovicz A. Comparison of various methods of prevention of venous thrombosis in orthopedics. Ann Fr Anesth Reanim. 1992;11(3):354-62. [pmid: 1380220].
Siragusa S, Vicentini L, Carbone S, Barone M, Beltrametti C, Piovella F. Intermittent pneumatic leg compression (IPLC) and unfractionated heparin (UFH) in the prevention of post-operative deep vein thrombosis in hip surgery. Blood. 1994;84(Suppl 1):70a.
Sjalander A, Jansson JH, Bergqvist D, Eriksson H, Svensson P. Evidence for thrombosis prophylaxis to high-risk patients. Lakartidningen. 2007;104(20-21):1585-7. [pmid: 17564265].
Sowier J, Skrobisz J. Subcutaneous heparin in the prevention of postoperative thrombosis. Wiad Lek. 1984;37(11):836-40. [pmid: 6506705].
Spieler U, Preter B, Brunner U. Prevention of thromboses in lower leg fractures. Helv Chir Acta. 1972;39(5):679-83. [pmid: 4652328].
Staffen A, Schurer-Waldheim H. 3 years of general embolism prophylaxis in nailed femoral neck fractures by anticoagulants. Wien Klin Wochenschr. 1970;82(44):793-4. [pmid: 5476162].
Stangier J, Rathgen K, Sthle H, Mazur D. Influence of renal impairment on the pharmacokinetics and pharmacodynamics of oral dabigatran etexilate: An open-label, parallel-group, single-centre study. Clin. Pharmacokinet. 2010;49(4):259-68. [pmid: 20214409].
Stannard JP, Singhania AK, Lopez-Ben RR, et al. Deep-vein thrombosis in high-energy skeletal trauma despite thromboprophylaxis. J Bone Joint Surg Br. 2005;87(7):965-8. [pmid: 15972912].
Stormorken H. Prophylaxis of postoperative thrombosis with small doses of heparin. Tidsskr Nor Laegeforen. 1972;92(18):1265-6. [pmid: 5048572].
Stroh C, Birk D, Flade-Kuthe R, et al. Evidence of thromboembolism prophylaxis in bariatric surgery-results of a quality assurance trial in bariatric surgery in Germany from 2005 to 2007 and review of the literature. Obes Surg. 2009;19(7):928-36. [pmid: 19415404].
Sudo Y, Takahara Y, Murayama H, et al. Clinical experience of the Greenfield filter--especially about tilting and distal migration of the filters. Kokyu To Junkan. 1991;39(12):1221-5. [pmid: 1784848].
Sue LP, Davis JW, Parks SN. Iliofemoral venous injuries: an indication for prophylactic caval filter placement. J Trauma. 1995;39(4):693-5. [pmid: 7473957].
Thies HA. Ambulant use of anticoagulants. Munch Med Wochenschr. 1958;100(52):2038-9. [pmid: 13622566].
Tian H, Song F, Zhang K, Liu Y. Efficacy and safety of aspirin in prevention of venous thromboembolism after total joint arthroplasty. Zhonghua Yi Xue Za Zhi. 2007;87(47):3349-52. [pmid: 18478950].
Tran MH, Cortese-Hassett A, Raftopoulos I. Use of the endogenous thrombin production test in studying the pharmacokinetics of fondaparinux effect in the morbidly obese. Haemophilia. 2009;15(2):629.
Trca S, Krska Z, Sedlar M, Kudrnova Z, Dohnalova A. Comparison of various types of pharmacological prevention of lower extremities deep vein thrombosis in patients with proximal femoral fractures. Rozhl Chir. 2007;86(5):241-8. [pmid: 17634013].
Trigilio-Black CM, Ringley CD, McBride CL, et al. Inferior vena cava filter placement for pulmonary embolism risk reduction in super morbidly obese undergoing bariatric surgery. Surg Obes Relat Dis. 2007;3(4):461-4. [pmid: 17544921].
Tsukanov IuT, Noskov VK, Dziuba GG, Epanchintsev PM. Outcomes of prolonged anticoagulant prevention of thrombosis of deep veins of the crus in closed comminuted fractures of tibial bones. Angiol Sosud Khir. 2009;15(1):79-82. [pmid: 19791578].
Unstable angina: diagnosis and management. United States Department of Health and Human Services Public Health Service. 1994. Clinical practice guideline; number 10.
Valles JA, Vallano A, Torres F, Arnau JM, Laporte JR. Multicentre hospital drug utilization study on the prophylaxis of venous thromboembolism. The Venous Thromboembolism Study Group of the Spanish Society of Clinical Pharmacology. Br J Clin Pharmacol. 1994;37(3):255-9. [pmid: 8198934].
Vicentini L, Siragusa S, Barone M, Carbone S, Beltrametti C, Piovella F. Intermittent pneumatic leg compression and unfractionated heparin in the prevention of post-operative deep vein thrombosis in hip surgery: A randomized clinical trial. Haemostasis. 1994;24(Suppl 1):236. Abstract no: 237. [pmid: 7527368].
Vignon P, Dequin P-F, Benzekri-Lefevre D, et al. Intermittent pneumatic compression to prevent venousthrom-boembolism in patients hospitalized in intensive care units with high risk of bleeding: A randomized trial. Intensive Care Med. 2011;37:S230.
Villar Fernandez I, Urbieta Sanz E, Arenere Mendoza M, Lopez Larramona G, Rabanaque Hernandez M, et al. Evaluation of the use of heparins of low molecular weight as a prophylaxis in venous thromboembolism in patients of internal medicine: Evaluation of the use of heparins of low molecular weight as a prophylaxis in venous thromboembolism in patients of internal medicine. Farmacia Hospitalaria (Spain). 2004;28:402-9.
von Bary S, Kuhn J, Krieger S, Sobala KH. Vena cava filter--prevention of pulmonary embolism. Report of clinical experiences. Zentralbl Chir. 1999;124(1):27-31. [pmid: 10091294].
von Huben R, Roth H. Comparative study on the prevention of postoperative thromboembolism. Schweiz Med Wochenschr. 1970;100(8):380-2. [pmid: 5524938].
Warwick D, Mitchelmore A, et al. Is a short peri-operative course of low molecular weight heparin effective in preventing deep venous thrombosis after total hip replacement? [Abstract]. Journal of Bone and Joint Surgery - British Volume. Suppl II, III. 1994;76-B:151.
Warwick DJ, Harrison J, Whitehouse SL, Glew D, Mitchelmore AE. Pneumatic plantar compression versus low molecular weight heparin for the prevention of deep vein thrombosis after total knee replacement [Abstract]. Journal of Bone and Joint Surgery - British Volume. Suppl 2. 1999;81:210.
Watson N. Anti-coagulant therapy in the prevention of venous thrombosis and pulmonary embolism in the spinal cord injury. Paraplegia. 1978;16(3):265-9. [pmid: 733308].
Wells PS, Borah BJ, Sengupta N, Supina D, McDonald HP, Kwong LM. Analysis of venous thromboprophylaxis duration and outcomes in orthopedic patients. Am J Manag Care. 2010;16(11):857-63. [pmid: 21348557].
Wenzl ME, Hasse W, Seide K, Wolter D. Prevention of thromboembolism with low-molecular-weight heparin in orthopedic surgery: a 5-year experience. Clin Appl Thromb Hemost. 2004;10(1):1-4. [pmid: 14979398].
White RH, Sadeghi B, Strater A, et al. Comparative effectiveness of low molecular weight heparin (LMWH) prophylaxis in morbidly obese and less obese patients undergoing total knee arthroplasty (TKA). J. Thromb. Haemost. 2011;9:412. [pmid: 21073652].
Widmer BJ, Bassora R, Warrender WJ, Abboud JA. Thromboembolic Events Are Uncommon After Open Treatment of Proximal Humerus Fractures Using Aspirin and Compression Devices. Clin Orthop Relat Res. 2011.
Winkler WB, Stollberger C, Karnik R, Urban M, Slany J, Hruby W. Vena cava filter for the prevention of pulmonary embolism: experiences with percutaneous implantation and long-term follow-up. Vasa Suppl. 1990;30:210-3. [pmid: 2150131].
Wolf F, Thurnher S, Lammer J. Simon nitinol vena cava filters: effectiveness and complications. Rofo. 2001;173(10):924-30. [pmid: 11588681].
Worley S, Short C, Pike J, Anderson D, Douglas JA, Thompson K. Dalteparin vs low-dose unfractionated heparin for prophylaxis against clinically evident venous thromboembolism in acute traumatic spinal cord injury: a retrospective cohort study. J Spinal Cord Med. 2008;31(4):379-87. [pmid: 18959355].
Wu QH. Application of anticoagulating medicine after surgery of cavity of pelvis and abdomen. Zhonghua Wai Ke Za Zhi. 2006;44(19):1297-9. [pmid: 17217810].
Yang Z, Liu X, Dai S, et al. Effectiveness of low molecular weight heparin for prevention of deep vein thrombosis after total hip arthroplasty. Zhongguo Xiu Fu Chong Jian Wai Ke Za Zhi. 2010;24(9):1058-61. [pmid: 20939473].
Younas F, Janjua M, Chughtai H, et al. Outcome with inferior vena cava filters. Vasc. Med. 2010;15(2):156-7.
Zhang YZ, Gao HW, Zhang GB, Liu MR. Prevention and treatment of deep vein thrombosis after pelvic fractures. Zhongguo Gu Shang. 2010;23(3):215-6. [pmid: 20415083].