# Results

## Introduction

We organized the results by Key Question (KQ) (see Introduction for a complete list of KQs). For example, if a study was primarily based in a school but had some home components, we reported the results under KQ 1 (school-based interventions). Each setting is subdivided by intervention (diet-only, physical activity-only, or combination of diet and physical activity).

## Results of the Literature Search

The literature search identified 34,544 unique citations. During the title screening, we excluded 28,344 citations. During the abstract screening, we excluded 5,600 citations that met at least one of the exclusion criteria (see Chapter 2 for details). During article screening, we excluded an additional 470 articles that did not meet one or more of the inclusion criteria (see Appendix D). In total, we included 131 articles, which reported on 124 studies (i.e., some studies were described in multiple articles), in the review (Figure 2). The majority (104 out of the 124 studies) were school-based studies, which might have included intervention components conducted in other settings such as at home.

Figure 2 Results of the literature search

* Sum of excluded abstracts exceeds 5,600 because reviewers were not required to agree on reasons for exclusion.

† Sum of excluded abstracts exceeds 470 because reviewers were not required to agree on reasons for exclusion.

This figure illustrates the flow of studies through the systematic review process: 40356 articles retrieves, 34546 unique titles screened, 6201 abstracts screened, 601 articles screened, and 131 articles included for data abstraction.

We conducted a grey literature search of ClinicalTrials.gov (see Appendix B) and identified 3,186 potentially relevant titles. A title screen excluded 2,826 of the trials. Of the 342 potentially relevant trials none that apply to this systematic review were completed, or data was not available.

## Description of Types of Studies Retrieved

One hundred and four studies described in 110 articles addressed KQ 1 (school-based interventions); six studies addressed KQ 2 (home-based interventions); one study addressed KQ 3 (primary care–based interventions); four studies described in five articles addressed KQ 4 (child-care center–based interventions); nine studies addressed KQ 5 (community-based interventions); and no studies directly addressed KQ 6 (consumer health informatics–based interventions). We addressed KQ 7 (combination settings) under the above KQs.

Eighty-three studies were randomized controlled trials (RCTs). Of those, 69 addressed KQ 1, six addressed KQ 2, none addressed KQ 3, three addressed KQ 4, and five addressed KQ 5. Eighty-three studies stated that their goal was obesity prevention: 66 of these addressed KQ 1, six addressed KQ 2, one addressed KQ 3, two addressed KQ 4, and eight addressed KQ 5. Of the studies stating that their goal was obesity prevention, 54 were RCTs. Of those, 43 addressed KQ 1, five addressed KQ 2, none addressed KQ 3, two addressed KQ 4, and four addressed KQ 5.

## Key Question 1 What is the comparative effectiveness of school-based interventions for the prevention of obesity or overweight in children?

### Key Points

#### School-Only–Based Studies

The strength of evidence is moderate that diet or physical activity interventions are more effective at preventing obesity and insufficient that a combination of diet and physical activity is more effective at preventing obesity or overweight than the control.

Heterogeneity of outcomes graded to determine strength of evidence in combination diet and physical activity settings prevented us from conducting a true meta-analysis for this intervention. We analyzed studies with sufficient data to determine impact on BMI and BMI z-score and found that these specific outcomes were positively impacted.

#### School-Home–Based Studies

Only one study investigated the effectiveness of a diet intervention on obesity prevention. This RCT, with 1,321 students, demonstrated a significant decrease in the prevalence of overweight and obese children as a result of the intervention. However, since there is only one study, and the risk of bias is moderate, the strength of the evidence is insufficient that diet interventions are more effective in preventing obesity or overweight than the control.

Of the three physical activity intervention studies that measured change in BMI, all showed a statistically significant reduction in the intervention group relative to the control group. The strength of the evidence is high that physical activity interventions are more effective in preventing obesity or overweight than the control intervention.

Twenty-seven studies conducted in both the school and home settings implemented interventions of both diet and physical activity. Among these 27 studies, 21 demonstrated a favorable effect of the intervention on weight outcomes compared to the control. However, only 10 of the studies had statistically significant results. The strength of the evidence is moderate that diet and physical activity-combined interventions are more effective in preventing obesity and overweight than the control.

#### School-Home-Community–Based Studies

Out of nine studies, two studies in this setting showed a significant desirable effect on obesity prevention, both of which intervened on a combination of diet and physical activity.

The strength of evidence is insufficient that physical activity interventions are more effective at preventing obesity or overweight than the control, based on one non-RCT study.

The strength of evidence is high that combined diet and physical activity interventions are more effective at preventing obesity or overweight than the control, based on four RCTs and four non-RCTs. Among those reported, around half found desirable and significant changes in BMI, BMI z-score, prevalence of overweight or obesity, percentage of body fat, and waist circumference.

#### School-Community–Based Studies

Out of six studies in this setting, two showed a significant desirable effect: one intervened on diet, and the other intervened on a combination of diet and physical activity.

The strength of evidence is insufficient that a diet intervention is more effective at preventing obesity or overweight than the control, based on one RCT. The single study did show significant lower incidence rate for overweight in the intervention as compared to the control (p=0.018).

The strength of the evidence is moderate that combined diet and physical activity interventions is more effective at preventing obesity or overweight than the control, based on one RCT and three non-RCTs. The two studies with moderate risk of bias showed a favorable effect and there was no other low risk of bias studies in the opposite direction.

The strength of the evidence is insufficient that a physical activity and self-management intervention is more effective at preventing obesity or overweight than the control, based on one RCT. This study shows no difference between the intervention and control groups.

#### School-Consumer Health Informatics–Based Studies

Four studies took place in this setting. The evidence is insufficient that school with consumer health informatics physical activity or combined diet and physical activity interventions prevent obesity or overweight in children.

#### School-Home-Consumer Health Informatics–Based Studies

One study took place in this setting. The evidence is insufficient that school, home, consumer health informatics combination diet and physical activity interventions prevent obesity or overweight in children.

### School-Only–Based Studies

#### Study Characteristics

Fifty-four studies, described in 58 articles reported on school-only-based interventions. Thirty-six of these studies were RCTs. Twenty-three of the RCTs had a stated goal of obesity prevention in children.45-63 Thirteen RCTs took place in the U.S.45,46,48,50,56,57,64-70The remaining RCTs took place in Australia, Belgium, Canada, the Northern Marianas, France, Germany, Greece, Iceland, Italy, New Zealand, Poland, Portugal, Spain, Switzerland, and the United Kingdom (Table 3; Appendix E, Evidence Table 1).

Table 3 Study and participant characteristics of studies based only in schools

Author, Year | RCT | Goal: Obesity Prevention | Country | Sex^*^ | Age Range, Years^*^ | Grade^*^ | Other^*^ | Total N | Followup in Weeks^†^ | % Girls^†^ | Mean Age [Range] Years^†^ | Grade^†^ | Race^†^
Amaro, 2006^72^ | Y | N | Italy | NR | NR | NR | NR | 241 | 26 | 44.8 | 11-14 | Middle school | WNH 100
Barbeau, 2007^68^ | Y | N | U.S. | NR | 8-12 | 3,4,5 | BNH, <300 lbs., no meds, regular physical activity | 201 | 43 | 100 | 9.5 | Elementary school | BNH 100
Bronikowski, 2011^105^ | Y | N | Poland | NR | NR | NR | NR | 137 | 130 | NR | 13.2 | NR | NR
Burguera, 2011^91^ | N | Y | Spain | NR | NR | 7-9 | Could not be part of any federated sport team or organized after-school sports. | 90 | 26 | 59.7 | 13.9 | NR | NR
Bush, 1989^70^ | Y | N | U.S. | NR | NR | 4-6 | NR | 1,041 | 104 | 54 | 10.5 | NR | NR
Chiodera, 2008^106^ | N | N | Italy | NR | NR | NR | BMI<30, no major pathologies, no outside physical activity | 4,500 | 34 | 50.1 | 6-10 | Primary school | NR
Coleman, 2011^64^ | Y | N | U.S. | NR | NR | 2, 3, 6 | NR | NR | 104 | 57 | 8.9 | NR | Mixed
Damon, 2005^94^ | N | Y | Austria | NR | NR | NR | NR | 481 | 43 | NR | 10-12 | 1 | NR
DeBar, 2011^65^ | Y | N | U.S. | NR | NR | 6 | Schools were at least 50% of students were eligible for welfare, black, or Hispanic. | 4603 | 104 | Arm1: 46.5 Arm2: 58.6 Arm3: 49.3 | 11.2-11.3 | NR | Mixed
Donnelly, 2009^45^ | Y | Y | U.S. | NR | NR | 2&3 | NR | 1,527 | 156 | 51.7 | NR | NR | Mixed (all)
Foster, 2012^46^ | Y | Y | U.S. | NR | NR | 6 | 50% of children in the school needed to be eligible for federally subsidized lunches; 50% of the students had to be black or Hispanic | 4,603 | 156 | 52.7 | 11.3 | 6 | Hispanic: 54.2 Black: 18.0 White: 19.3 Other: 8.5
Fung, 2012^90^ | N | Y | Canada | NR | NR | 5 | NR | NR | 104 | Arm1: 50.7 Arm2: 48.5 | NR | 5 | NR
Gortmaker, 1999^56^ | Y | Y | U.S. | NR | NR | NR | NR | 1,295 | 104 | 48 | 11.7 | NR | Mixed (all)
Graf, 2008^47^ | Y | Y | Germany | NR | NR | Primary school | NR | 615 | 208 | 48.9 | 6.8 | Primary school | NR
Gutin, 2008^48^ | Y | Y | U.S. | NR | NR | 3 | NR | 210 | 138 | 53 | 8.5 | 3 | BNH >50
Haerens, 2006^71^ | Y | N | Belgium | NR | NR | NR | NR | 2,840 | 95 | 36.6 | 13.06 | 7-8 | NR
Heelan, 2009^95^ | Y | N | U.S. | NR | NR | NR | NR | 324 | 78 | 55 | 8.3 | 1-5 | NR
Howe, 2011^57^ | Y | Y | U.S. | Boys | 8-12 | 3-5 | Weigh <300lbs Not taking medication No physical impairment to regular PA | 106 | 40 | NR | 9.7-9.9 | 3-5 | BNH 100
Jago, 2011^81^ | Y | N | U.S. | NR | NR | 6 | NR | 6,413 | NR | 52.4 | 11.3 | NR | Mixed (all)
James, 2004^49^ | Y | Y | U.K. | NR | 7-11 | NR | Parental consent | 644 | 52 | 50 | 8.7 | NR | NR
James, 2007^54^ | Y | Y | U.K. | NR | 7-11 | Jr. high school | NR | 644 | 39 | 50 | NR | NR | NR
Kafatos, 2005^78^ | Y | N | Greece | NR | NR | 1 | NR | 541 | 312 | NR | NR | NR | NR
Kain, 2009^84^ | N | Y | Chile | NR | NR | 1-8 | NR | 2,430 | 314 | 38 | 10 | NR | NR
Klish, 2012^74^ | N | N | U.S. | NR | NR | 3-5 | NR | 1,289 | 36 | Arm1: 49.4 Arm2: 46.3 | 7.86-7.95 | NR | Latin/Hispanic >92
Lazaar, 2007^79^ | Y | N | France | NR | NR | 1,2 | No know disease, no other studies | 425 | 26 | 50 | 7.4 | NR | NR
Llargues, 2012^58^ | Y | Y | Spain | NR | 5-6 | 1 | No special diet, no physical activity incapacities | 509 | 208 | Arm1: 45.6 Arm2: 46.3 | 6-8 | NR | NR
Lubans, 2012^59^ | Y | Y | Australia | Boys | NR | 9 | Speak English | 100 | 24 | NR | 14.3 | 9 | NR
Lubans, 2012^60^ | Y | Y | Australia | Girls | NR | 8 | Low SES | 357 | 52 | 100 | 13.8 | 8 | Australian 85.4 Asian 1.1 European 10.1
Madsen, 1993^67^ | Y | N | U.S. | NR | NR | 5, 6 | No high BP, no CVD, no high cholesterol | 314 | 104 | NR | 12 | 5-6 | NR
Magnusson, 2012^61^ | Y | Y | Iceland | NR | NR | NR | Born in 1999 | 266 | NR | Arm1: 60 Arm2: 51 | 7.3-7.4 | NR | WNH 100
Manios, 1999^103^ | N | N | Greece | NR | NR | 1 | NR | 1,046 | 156 | NR | NR | NR | NR
Manios, 2002^104^ | N | N | Greece | NR | NR | 1 | NR | 1,046 | 312 | 47 | NR | NR | NR
Manios, 2006^100^ | N | N | Greece | NR | NR | NR | NR | 441 | 312 | NR | NR | 1-5 | NR
Metcalf, 2012^77^ | Y | Y | Switzerland | NR | NR | Pre-school | NR | 652 | 47 | 50 | 5.2 | NR | NR
Muckelbauer, 2009^55^ | Y | Y | Germany | NR | NR | NR | School level randomization | 3,190 | NR | 49.7 | 8.3 | 2-3 | NR
Neumark-Sztainer, 2010^50^ | Y | Y | U.S. | Girls | NR | NR | No high-level physical activity, no eating disorder | 356 | 36-52 | 100 | 15.8 | NR | Mixed (all)
Newton, 2010^85^ | N | Y | U.S. | NR | NR | NR | NR | 77 | 78 | 50 | 9.26 | 2-6 | BNH 100
Reed, 2008^82^ | Y | N | Canada | NR | NR | 4-5 | No health condition limiting physical activity | 268 | NR | NR | NR | NR | NR
Resaland, 2011^87^ | N | N | Norway | NR | NR | 4 | NR | 256 | 104 | Arm1: 57 Arm2: 56 | 9.2 | NR | NR
Rosario, 2012^62^ | Y | Y | Portugal | NR | NR | NR | Attend public elementary schools | 464 | 24 | 51.5 | 8.3 | NR | NR
Rush, E, 2012^63^ | Y | Y | New Zealand | NR | 5-10 | NR | NR | NR | 104 | 50.2 | NR | NR | European 67.3; Maori 25.7; Others 7
Sahota, 2001^51^ | Y | Y | U.K. | NR | NR | NR | NR | 636 | NR | NR | 8.3 | 4-5 | NR
Sallis, 1993^86^ | Y | Y | U.S. | NR | NR | 4 | NR | 549 | NR | 44 | 9.25 | 4 | WNH >80
Sallis, 2003^75^ | Y | N | US | NR | >5 | NR | NR | 1,858 | 156 | 48.2 | 7.7 | NR | Mixed (All)
Salmon, 2008^80^ | Y | Y | Australia | NR | NR | 5 | Low SES | 306 | 39 | 51 | NR | NR | NR
Scheffler 2007^102^ | N | N | Germany | NR | NR | Pre-school | NR | 264 | 104 | NR | NR | NR | NR
Skybo, 2002^96^ | N | N | U.S. | NR | NR | NR | English speakers | 58 | 39 | 48 | NR | 3 | Mixed (all)
Smolak, 2001^89^ | N | N | U.S. | NR | 9-11 | NR | NR | 509 | 104 | 49.5 | NR | 6 | NR
Sollerhed, 2008^98^ | Y | Y | Sweden | NR | NR | NR | NR | 132 | 156 | 44.6 | 6-9 | NR | NR
Stenevi-Lundgren, 2009^92^ | N | N | Sweden | Girls | NR | 1-2 | Healthy girls, no meds | 103 | 52-104 (Control group was followed for 104) | 100 | 7.9 | 1-2 | WNH 100
Stock, 2007^88^ | N | Y | Canada | NR | NR | NR | School-level randomization | 360 | 43 | 55.2 | NR | 7-8 | NR
Taylor, 2007^99^ | N | Y | New Zealand | NR | NR | NR | NR | 730 | 104 | 49.8 | 7.7 | NR | WNH >80
Thivel, 2011^76^ | Y | N | France | NR | 6-10 | 1 or 2 | No more than 3 hours physical activity per day, no known disease, no other studies | 457 | 26 | 52 | 6-10 | 1-2 | NR
Treveno, 2005^69^ | Y | N | U.S. | NR | NR | 4 | Low income | 387 | 34 | 52 | 9.7 | NR | NR
Tucker, 2011^97^ | N | N | U.S. | NR | NR | NR | NR | 99 | 34 | 100 | 9.6 | 4-5 | NR
Valdimarsson, 2006^101^ | N | N | Sweden | Girls | NR | 1-2 | NR | 103 | 52–104^†^ | 100 | 7.8 | NR | NR
Vandongen, 1995^83^ | Y | N | Australia | NR | NR | 8 | NR | 1,147 | 39 | 42.2 | 10-12 | 6 | NR
Vizcaino, 2008^73^ | Y | Y | Spain | NR | NR | NR | NR | 1,044 | 36-72 | 54 | 9.4 | NR | NR
Walter, 1985^66^ | Y | N | U.S. | NR | NR | 4 | NR | 1,563 | 52 | 48.6 | 9.1 | 4 | Mixed (all)
Walther, 2009^52^ | Y | N | Germany | NR | NR | 6 | NR | 211 | 52 | 45 | 11.1 | 6 | NR
Warren, 2003^53^ | Y | Y | U.S. | NR | 5-7 | Primary school | NR | 218 | 61-69 | 49 | 6.1 | 1-2 | NR

AIAN = American Indian/Alaska Native; API = Asian Pacific Islander; BMI = Body Mass Index (in kg/m^2)^; BNH = Black Non-Hispanic; BP = Blood Pressure; CVD = Cardio Vascular Disease; Maint = Maintenance; Meds = Medications; N = No; NR = Not Reported; physical activity = Physical Activity; RCT = Randomized Controlled Trials; WNH = White Non-Hispanic; Y=Yes

* Inclusion/exclusion criteria.

† Participant characteristics.

Seven RCTs (19.4 percent) did not specify inclusion or exclusion criteria.51,56,65,71-74 Three RCT's included girls only,50,60,68 two RCT's included boys only,57,59 and the remainder did not use sex as an exclusion criteria. Of the eight RCTs that used age range as an inclusion criteria, one included only children under 5 years old,75 two included children ages 5 to 7 years,53,58 two included children ages 6 to 10 years,63,76 one included children ages 7 to 11 years,49,54 and two included children ages 8 to 12 years.57,68 Many RCTs used grade level as an inclusion criteria; one included “pre-school” children,77 eight included children in grades 1, 2, or 3;^45,48,53,58,64,76,78,79^ two included children in grades 3 to 5;^57^ 68 ten included children in grades 4, 5, or 6;^46,52,66,67,69,70,80-83^ one included “primary school” children;47 two included children in grades 7, 8, or 9;^59,60^ and one included “junior high school” children.54 We list additional inclusion criteria in Table 3 and Appendix E, Evidence Table 1.

Eighteen of the school-based studies were non-RCTs: 16 were clinical trials (non-randomized), one was pre-post design, one was a natural experiment, one was a pilot study and two were quasi-experimental. Ten of the non-RCTs had a stated goal of weight maintenance or obesity prevention in children.84-94 Seven took place in the U.S.,74,85,86,89,95-97and the remainder took place in Canada, Germany, Chile, Croatia, Greece, Italy, New Zealand, Norway, Spain and Sweden (Table 3; Appendix E, Evidence Table 1).

Seven of these non-RCTs (39 percent) did not specify inclusion criteria.85,94,95,97-100 Three included girls only,92,93,101 and the remainder did not specify any sex for enrollment. Two studies restricted study participation by age, enrolling 9 to 11 year olds,89and 16 to 18 year olds.93 The remainder of the non-RCTs did not limit participation by age. Eleven non-RCTs restricted participation by grade. One limited participation to preschoolers;102 one to first-graders;103,104 two to children in grades 1 or 2;^92,101^ four to children in grades 3, 4, or 5;^86,90,93,96^ one to children in grades 7 thru 9;^91^ and one to children in grades 1 to 8.^84^ The remaining studies did not limit participation by grade level. Other inclusion criteria are in Table 3 and Appendix E, Evidence Table 1.

#### Population Characteristics

The number of participants across all RCTs was 31,126; each individual RCT included between 100 and 6,413 participants. Three RCTs included only girls.50,60,68 The remainder of the RCTs had between 36 and 60 percent girls enrolled or did not report on this characteristic. Seventeen RCTs had participants in elementary grades (ages 6.1 to 9.7 years) (Table 3; Appendix E, Evidence Table 2).47-49,51,53,55,57,58,61,62,64,66,68,69,73,76,77,79 Thirteen RCTs had participants in middle-school (ages 10 to 15.8 years),46,50,52,56,59,60,67,70-72,81,83,105 and eight did not report on the age of their participants.45,54,63,65,74,78,80,82

There were 18 non-RCTs that included from 77 to 4,500 participants, with 12,405 participants across studies. Of the non-RCTs reporting on sex, three enrolled only girls,92,93,101 and the others had between 38 and 59.7 percent girls enrolled. Of the non-RCTs reporting on age, all children were between 6 and 15 years old (Table 3; Appendix E, Evidence Table 2).64,84-87,91,92,95,97-99,101,106

Fourteen non-RCTs reported on grade range. Twelve included participants in elementary school,64,85-87,92,94,95,97-99,101,106 four included participants in middle school,84,88,89,91 and one included participants in grades 2 through 6.^85^ The majority of studies did not report on participant race. One non-RCTs had only black non-Hispanic participants,85 one study had up 94.2 percent Latin/Hispanic participants,74 three studies had at least 80 percent white non-Hispanic participants,92,99,106 and one study had a population of mixed races (Table 3; Appendix E, Evidence Table 2).96

#### Interventions

Thirty-six of the 54 studies were RCTs. four RCTs described in four articles had arms that included diet interventions.49,54,55,64,83 These RCT's were directed at dietary changes and utilized educational interventions.49,54,55,64,83 Ten RCTs had arms that included physical activity interventions.45,52,57,73,76,79,80,82,83,105 Of these, one RCT had arms that included education-only interventions,105 five had arms that included environment-only interventions,52,57,73,76,79 and four had arms that included both educational and environmental physical activity interventions.45,80,82,83 Twenty-four RCTs had arms that included both diet and physical activity interventions.46-48,50,51,53,56,58-63,65-72,74,78,84 Nine RCTs had arms that included a combination of diet, physical activity, and self-management interventions.46,47,50,55,56,67,70,72,78 One RCT had intervention arms that were dietary interventions only, physical activity interventions only, and a combined diet and physical activity intervention arm.83 As such, we counted the study in all three categories listed above. Other combinations of interventions are on Table 4 and Appendix E, Evidence Table 3.

Table 4 Interventions of studies based only in schools

Author, Year | Control Arm | Description of Intervention | Diet (Phys/Env) | Diet (Psych) | Physical Activity (Phys/Env) | Physical Activity (Psych)
Amaro, 2006^72^ | Usual care | Kaledo: Educational board-game on Mediterranean diet with one play session per week and one PA session per week, also includes BMI screening. | | X | X
Barbeau, 2007^68^ | Usual care | Subjects given healthy snacks during homework time, and a PA component including skills development, MVPA, and heart rate monitors. | X | | X
Bronikowski, 2011^105^ | Usual care | PE teachers provided social support and reinforcement for student's self-programmed out-of-school physical activity plan. Those pupils who fulfilled the PA obligations in PA plan received a reward. | | | X
Burguera, 2011^91^ | Despite informed consent, did not participate in the intervention | ACTYBOSS: Subjects offered two nutrition and behavioral modification workshops. Special emphasis on healthy lifestyle and self-responsibility. Opportunities to participate in PA sessions, not stated if required. | | X | X | X
Bush, 1989^70^ | Parents only received results of screening | Subjects received nutrition, exercise, anti-smoking lessons, health screening and a “Health Passport”. Health newsletters were mailed to parents throughout intervention | X | X
Chiodera, 2008^106^ | No control | Aimed to professionally qualify PE in schools without changing hours dedicated per week | | | X
Coleman, 2011^64^ | Usual care | Healthy ONES: Subjects brought unhealthy snacks from home. Subjects discouraged from unhealthy snacks by teachers and staff, including promoting healthy eating in class. More nutritious snacks and food offered at school, especially for events. | X | X
Damon, 2005^94^ | Usual care | Education on diet and physical activity and increase in physical activity | X | | X | X
DeBar, 2011^65^ | Usual care | 1 hour initial training outlined the required tasks, skills, and procedures, including 30-minute trainings specific to each intervention activity. Communications intervention strategies, including public commitment opportunities for students, were intended to strengthen the impact of all HEALTHY intervention components. Themes included healthier diet, decrease sugar drinks and increase PA. | | X | X | X
Donnelly, 2009^45^ | Usual care | A target goal of 90min/week of MVPA per child was given along with WSB to increase frequency of walking to school. Teacher training was implemented for the intervention | | | X | X
Foster, 2010^46^ | Usual care | Quantity and nutritional quality of food served in the school environment was changed. The amount of time students spent in moderate to vigorous physical activity was increased. Behavioral knowledge and skill were taught in classrooms using the FLASH program | X | | X
Fung, 2012^90^ | Usual care | APPLE: School health facilitators promote community gardens and healthier breakfast/lunch options. Facilitated professional development for teachers and school staff, and parent information nights. After school PA sessions promoted along with walk to school days. Weekend events, celebrations and newsletters used to promote healthy living. | X | | X
Gortmaker, 1999^56^ | Usual care | Planet Health: Class sessions focused on behavioral changes to promote healthy eating, MVPA, and reduce TV time. | | X | X
Graf, 2008^47^ | Usual care | Extra health education on nutrition, biology, self-management. PA breaks were provided in mornings. | | X | X | X
Gutin, 2008^48^ | Regular health screening and diet/PA information included | Youths were provided healthy snacks during after-school PA sessions along with academic enrichment homework and assistance. | X | | X
Haerens, 2006^71^ | Usual care | Subjects received additional information on healthy living along with providing healthy snack options. For PA, a computer tailored intervention was implemented about the child's activity levels and feedback. Schools were encouraged to offer more PA opportunities. Newsletters were sent out to community and parents regarding the intervention. | X | X | X | X
Heelan, 2009^95^ | Usual care | Walking School Bus program. Children walk in groups along set route to school, with adult as “driver” (chaperone). | | | X
Howe, 2011^57^ | Usual care | After school program for two hours that included; skills development, VPA, toning and stretching | | | X
James, 2004^49^ James, 2007^54^ | Usual care | Discourage drinking of fizzy drinks (sweetened and unsweetened) among school-age children. | | X
Kafatos, 2005^78^ | Usual care | Cretan Health/Nutrition Program: Classroom modules designed to develop behavioral capability, expectations, and self-efficacy for healthy eating. Theoretical component of PA was given by PE instructor along with PA sessions. Children also kept food diary. | | X | X | X
Kain, 2009^84^ | Usual care | Intervention included diet/nutrition lessons and additional PE sessions along with novel card game to promote healthy living. | | X | X
Klish, 2012^74^ | Usual care | Obese children with parents were invited to after-school behavior modification program that offered dietary instruction and behavioral therapy. Chef-in-school program: professional chef comes to the school to teach how to prepare healthy meals. New exercise equipment brought in to promote active recess time. | | X | X
Lazaar, 2007^79^ | Usual care | After school PA program with double objective; playful physical practice and dynamic exercise within 1 hour. | | | X
Llargues, 2012^58^ | Usual care | IVAC method: Promoting healthy dietary habits and increasing PA through pedagogy Investigation, Vision, Action and Change intervention (IVAC) | | X
Lubans, 2012^59^ | Usual care | PALs: Nutritional handbooks and seminars, sport sessions, lunchtime activities and leadership sessions. | | X | X | X
Lubans, 2012^60^ | Usual care | Nutritional handbooks and seminars, sport sessions, lunchtime activities and leadership sessions. | | X | X | X
Madsen, 1993^67^ | No control | SCORES: Children in program pay soccer three days a week, community service and/or creative writing. Training in self-monitoring in regard to diet and sodium content along with self-monitoring for PA. | | X | X | X
Magnusson, 2012^61^ | Usual care | Interventions were designed to increase dietary knowledge and self-efficacy. Teachers integrated PA into curriculum. | | X | X
Manios, 1999^103^ Manios, 2002^104^ Manios, 2006^100^ | Usual care for children, and parents received mailed envelopes with all medical screening results with brief comments | Educational sessions offered for health and nutritional components. PA component included educational sessions and increased PA with stretching, fitness stations and aerobic games. | | X | X | X
Muckelbauer, 2009^55^ | Usual care | Intervention targeted behavioral change and education regarding diet, nutrition, and goal setting. | X | X
Neumark-Sztainer, 2010^50^ | Usual care | New Moves: intervention targets increasing fruit, vegetable intake, and limiting sugar-sweetened beverages. Subjects were served healthy foods during lunch and offered more PA opportunities | X | X | X
Newton, 2010^85^ | No control | School Cafeteria were modified with more healthy choices up to the state standards. Teachers were encouraged to model daily PA tips for short bouts of PA and an additional increased PE session indoors. | X | X | X | X
Reed, 2008^82^ | Usual care | Goal to deliver 15 min of MVPA daily for 75 extra min of PA per week in schools. Principals and teachers met with facilitators to design program. Teachers also provide classroom activities such as skipping, dancing and resistance training. | | | X | X
Resaland, 2011^87^ | Usual care | 60 min of PA conducted by specialist PE teacher for 104 weeks | | | X
Rosario, 2012^62^ | Usual care | Teachers addressed nutrition topics via classroom activities, including food, nutrition, diet guidelines, along with PA/lifestyle topics. | | X | | X
Rush, 2012^63^ | Usual care | Energizer educated through information regarding replacing sugary drinks with water and importance of eating breakfast. Canteen makeovers were conducted to remove pastries and pies, and to add healthier options. Promotion of PA sessions with games and activities. | X | X | X | X
Sahota, 2001^51^ | Usual care | Increase knowledge and attitudes towards healthy living, modification of school meals and PE sessions. | X | X | X
Sallis, 1993^86^ | Usual care | Self-management program to promote PA outside school for children. Lessons taught skills to maintain activity habits post-intervention. Additional PE classes were provided. A brief nutrition intervention of seminars for teachers were also conducted | | | X | X
Salmon, 2008^80^ | Usual care | BM/FMS: Focused on teaching object control and locomotors skills. Reduce TV and video game time at home and involvement of parents in process. | | | X | X
Skybo, 2002^96^ | Usual care | American Heart Association Heart Power! Emphasize nutrition in class discussions as well as importance of PA. Children then engaged in PA such as jumping jacks or running in place. | | X | X | X
Smolak, 2001^89^ | No curriculum different schools | ESEM: Encouraged parents to modify diet and PA habits at home. | | | X | X
Sollerhed, 2008^98^ | Usual care | I-school: Increased PE time in intervention school, time was expanded from one/two lessons per week to 4 lessons | | | X
Stenevi-Lundgren, 2009^92^ | Usual care | Increase school PE time per week. | | | X
Stock, 2007^88^ | Usual care | Themes targeted exposure to nutritional information on foods and beverages. Themes also included structured PA/aerobic fitness and lessons on healthy body image and self-esteem. | | X | X | X
Taylor, 2007^99^ | Usual care | APPLE: Encourage healthy eating with science lessons highlighting adverse health effects of sugary drinks and fatty foods. Cooled water filters installed in schools to promote drinking water. Initiatives were set to promote more PA activity as well as sports equipment were provided for free time. | X | X | X | X
Thivel, 2011^76^ | Usual care | PA program of additional 2hrs of PA in addition to 2hrs of regular PE class. Objective to increase PA and minimize inactivity | | | X
Trevino, 2005^69^ | Usual care | Beinestar Health Program: Decrease dietary fats and increase fiber intake through parent fun activities. PA promotion was also included in the activities along with a after school program with activities such as games, dancing, singing, crafts, etc. | | X | X | X
Tucker, 2011^97^ | Let's Go 5-2-1-0 Program curriculum ONLY, without student nurse coaching, parent evening offerings, and reinforcement incentives | Let's Go: Coaching sessions designed to promote healthy eating and exercise conducted by nursing staff and parents. | | X | | X
Valdimarsson, 2006^101^ | Usual care | POP: Increase PA in schools from 60min/week to 200min/week. | | | X
Vandongen, 1995^83^ | Usual care | Increase fruit and vegetable consumption and whole grains while also reducing consumption of fatty foods and sugar sweetened beverages with educational lessons | | X
Vandongen, 1995^83^ | Usual care | Classroom sessions providing rational basis for activity programs. Fitness program included relays, skipping and health hustles. | | | X | X
Vandongen, 1995^83^ | Usual care | Classroom sessions to provide rational basis for activity programs. Activity programs include; relays, skipping and health hustles. Heart rates of 150-170 beats/min were to be achieved in first 15 min. Nutrition education was provided focusing on increase fruits, vegetables, whole grains, and decrease intake of fatty foods and sugars. Homework assignments and comics were given to children to help improve healthy eating. | | X | X | X
Vizcaino, 2008^73^ | Usual care | Activity program with sports using alternative equipment (pogo sticks, Frisbees, parachutes, etc.). Primary care providers encouraged to focus on behavioral targets for patients | | | X
Walter, 1985^66^ | Usual care | Incorporates social learning strategies to encourage behavioral change regarding diet and PA (improvement of cardiovascular fitness) | | X | | X
Walther, 2009^52^ | Mandatory 2 units (45 mins.) of PE classes/week plus healthy lifestyle lessons/month | 45 min of PA with 15 min endurance training per school day. Non-randomized sport students received 12 units (45min) of high-level endurance exercise per week. | | | X
Warren, 2003^53^ | Be smart; educational program about food in non-nutrition sense. | Eat Smart Educational Intervention: emphasizing food contributing to health and healthy food. Lessons were given in PA education and television viewing. | | X | | X

Phys/Env=Physical/environmental intervention; Psych = psychosocial intervention

No non-RCTs addressed diet interventions. Nine of the 18 non-RCTs tested physical activity interventions.86,87,92,93,95,96,98,101,106 One arm included educational intervention only,95 six had arms that included environmental interventions only,87,92,93,98,101,106 and the remainder included both educational and environmental interventions.86,96 Ten non-RCTs had arms that included diet and physical activity (Table 4; Appendix E, Evidence Table 3).74,84,85,88,90,91,94,97,99,100,103,104

#### Outcomes

##### Diet Interventions

We identified two RCTs, described in three articles.49,54,83

###### Weight-Related Outcomes

###### BMI z-Score

One study reported on BMI z-score showing a significant decrease of it at final followup at 158 weeks (mean difference=0.24; 95% CI: 0.02 to .46; p=0.03)49,54(Appendix E, Evidence Table 4a).

###### BMI

Both of the diet intervention studies reported on BMI as an outcome. One study looked at the entire population and showed significant changes in BMI in favor of the intervention group at 158 weeks (mean difference =0.68; 95% CI: 0.06 to 1.30; p=0.03).49,54 One study reported on a subgroup analyses by sex. The results showed a nonsignificant change in favor of the control for boys, and nonsignificant change in favor of the intervention for girls (Appendix E, Evidence Table 4a,b).83

###### Prevalence of Overweight and Obesity

One study reported on prevalence of obesity and overweight, but found no statistical significance intervention effect.49,54 The study reported prevalence of overweight and obesity in subgroups of boys and girls and found no intervention effect (Appendix E, Evidence Table 4a,b).49,54

###### Percent Body Fat

One study reported percent body fat change in subgroups of boys and girls. In both subgroups the there was no intervention effect (Appendix E, Evidence Table 4b).83

###### Waist Circumference

One study reported on waist circumference.54 This study showed a change in waist circumference in favor of the intervention, but it was not significant (Appendix E, Evidence Table 4a).

###### Skinfold Thickness

One study reported on skinfold thickness in subgroups by sex. The changes in triceps skinfold thickness in boys favored the control and for girls, favored the intervention. Neither difference was significant.83 The change in subscapular skinfold thickness favored the control for both the boys and girls. Neither difference was significant (Appendix E, Evidence Table 4b).83

###### Clinical Outcomes

One study reported on systolic and diastolic blood pressure in boys and girls subgroups. Both controls and interventions decreased for these two outcomes, the differences between the interventions and controls was not significant except in the case of diastolic blood pressure in girls where the difference in decrease was significantly in favor of the intervention (numbers not reported).83 This study also reported on total cholesterol in boys and girls and found that total cholesterol was significantly higher in the intervention groups of both the boys and the girls (numbers not reported) (Appendix E, Evidence Table 4c).83

###### Adverse Events

The research did not report any.

###### Intermediate Outcomes

###### Dietary Intake

One study examined the change in energy intake using a number of parameters.83 The percent of energy from sugar decreased significantly in boys, but did not in girls. The percent of energy from total fat increased in the intervention groups relative to the control groups, but was not significant for either boys or girls. For percent of energy intake as saturated fat, the intervention had no effect on boys, but there was a nonsignificant decrease in the intervention girls. Overall energy intake (MJ/d) did not differ between the intervention and control groups for both the boys and girls (Appendix E, Evidence Table 4d).

One study recorded change in carbonated beverage consumption but the differences between groups were not significant (Appendix E, Evidence Table 4d).49

###### Interpretation

The results from an outcome measure from each of the two studies reporting on dietary interventions support our conclusions. One reported on BMI z-score.54 This study showed a significant decrease in BMI z-score at 3 years. The other study reported on BMI, and showed a nonsignificant change in favor of the intervention in boy and girl subgroups at nine months.83 Based on this evidence we conclude that dietary interventions positively impact BMI z-score and BMI outcomes. One of these dietary intervention studies has a goal of obesity prevention.49,54 Both studies focused on education that promoted a healthy diet, and reduced the consumption of carbonated drinks.

##### Physical Activity Interventions

Fifteen studies reported on the effects of physical activity interventions on weight-related outcomes.45,52,73,76,79,80,82,83,86,87,89,92,95,101,106

###### Weight-Related Outcomes

###### BMI z-Score

Two studies reported on BMI z-score and found a difference in BMI in the intervention group compared with control groups.79,95 One study reported a reduction in BMI z-score in favor of the intervention that was not significant.95 The other study reported reductions in BMI z-score in both boys and girls stratified by obese and non-obese, but these reductions were not significant (Appendix E, Evidence Table 5a,b).79.

###### BMI

Six studies reported on BMI in the whole population.45,52,82,87,92,95 None of these studies found a statistically significant intervention effect. One study showed a nonsignificant reduction in BMI in favor of the intervention group,52and two studies showed no difference in BMI between the control and intervention (Appendix E, Evidence Table 5a,b).45,87

Nine studies reported on BMI by subgroup. Seven of these studies reported boy and girl subgroups. Six studies reported nonsignificant BMI change in favor of the intervention in boys,79,83,86,87,89,106 and five studies reported nonsignificant BMI change in favor of the intervention in girls.79,83,87,106,107 One study reported on BMI change in favor of the control group in boys,108and another study reported the same in girls.86 One study reported a null affect in girls.108 Another study showed significant changes in BMI in favor of the intervention girls (-0.15; 95%CI: -0.31 to -0.0; p<0.05).80

One study reported BMI outcomes by obese and normal weight subgroups, the change was in favor of the intervention, but was not significant in both groups.76 One study reported on BMI by grade and reported a nonsignificant BMI change in favor of the intervention in most grades (Appendix E, Evidence Table 5a,b).106

###### BMI Percentile

One study reported on BMI percentiles.95 This study showed a nonsignificant reduction in BMI percentile in favor of the intervention. (Appendix E, Evidence Table 5a).

###### Prevalence of Overweight and Obesity

Two studies reported on the prevalence of overweight. One study showed a large decrease in obesity prevalence over time, but the significance was not reported in the paper.52One study reported on a subgroups of boys and girls, stratified into obese and non-obese groups, with a nonsignificant reduction in the prevalence of overweight among girls and boys in favor of the intervention (Appendix E, Evidence Table 5a,b).79

###### Percent Body Fat

Three studies reported on percent body fat as an outcome in the whole population.95,101,106One study showed an increase in body fat in both the intervention and control, but the change was in favor of the control group and was not significant.92 A second study suggested that the change in percent body fat favors the intervention group, but was not significant.95The third study included reported a significant increase in body fat in the intervention group (mean difference =0.9+/- 1.5; p> 0.001).101 One study reported on percent body fat in boy and girl subgroups. Both subgroups reported changes in favor of the intervention, but they were not significant (Appendix E, Evidence Table 5a,b).73,83

###### Waist Circumference

Two studies reported on waist circumference. One study evaluated the entire population and found a smaller increase in the intervention groups when compared to the control groups.87 These differences were not significant. A third study evaluated the effect of physical activity on subgroups of boys and girls.79This study reported a decrease in two of the intervention groups in boys, but the differences were not significantly different than those seen in the control group. This study did show a significant decrease in waist circumference in the subgroup of obese girls in favor of the intervention (mean difference in difference=0.43 cm; p<0.001). (Appendix E, Evidence Table 5a).79

###### Skinfold Thickness

Two studies measured triceps skinfold thickness. One found a significant difference in triceps skinfold thickness in a subgroup analyses by BMI between the 25^th^ and 75^th^ percentile in favor of the intervention group, (mean difference in differences=-1.25; 95% CI: -1.82 to -0.67; p<0.001) at 52 weeks, but no significant change at 104 weeks.73 Another found a change in favor of the control for boys and a change in favor of the intervention for girls. Neither of these differences was significant.83This same study also reported on subscapular skinfold thickness in the two subgroups and found changes in favor of the intervention, The changes were not significant for either subgroup (Appendix E, Evidence Table 5a,b).83

###### Weight

Three studies reported on weight change. Two studies reported on the entire population and both measured an increase in weight in favor of the control group; increases were not significant in either study.87,92 Two studies reported on boy and girl subgroups. One study reported no significant change in weight in girls after 104 weeks, however the girls in the intervention group did gain more at the final time point.108 In the other study reporting on boy and girl subgroups, boys in the intervention group gained less weight at 104 weeks, and girls in the intervention group gained more.87 The differences were not significant in either subgroup. One study reported on overweight and normal weight subgroups.76 The normal weight intervention group gained less weight at 26 weeks, and the overweight intervention group gained slightly more at 26 weeks; these changes were not significant (Appendix E, Evidence Table 5a,b).

###### Clinical Outcomes

Three studies reported on clinical outcomes in the whole population. Two studies reported on systolic and diastolic blood pressure.82,87. One study found a significant difference in the systolic blood pressures of children in the intervention group compared with control group (p<0.05 at 39 weeks) but only an nonsignificant decrease in diastolic blood pressure.82 The other study reported decreases in both systolic and diastolic blood pressure in favor of the intervention that were nonsignificant.87 One study reported on High-density lipoprotein (HDL) and Low-density lipoprotein (LDL) and reported decreases in both in favor of the intervention that were nonsignificant.52 Another study reported on LDL, and reported a decrease in favor of the intervention that was not significant.82 This study also reported on the ration of HLD to LDL and reported a decrease in favor of the intervention that was not significant. Three studies reported total cholesterol. Two studies reported a decrease in favor of the intervention,82,87 and the third reported a slight decrease in favor of the control which was not significant.52 Two studies reported changes in triglycerides and reported slight decreases in favor of the intervention, but the decreases were not significant.52,87 One study reported on clinical outcomes in boy and girl subgroups.83 The study measured systolic and diastolic blood pressure and total cholesterol. For all of these outcomes, the change in the boys favored the control and were not statistically significant. For the blood pressure outcomes in girls, both favored the intervention and the change in diastolic blood pressure was significantly in favor of the intervention (the paper did not report the p value). Differences in total cholesterol in girls favored the control but differences were nonsignificant (Appendix E, Evidence Table 5c).83

###### Adverse Events

The research did not report any.

###### Intermediate Outcomes

###### Physical Activity and Sedentary Behavior

Three studies reported on change in physical activity or sedentary activity. One study reported on reduction of sedentary activity (TV viewing time).80 This study reported significantly less TV viewing in the intervention group when compared to the control (p<0.05). The three studies measured the change in physical activity in a variety of ways. One study measured daily physical activity using an accelerometer and found a significant increase (p>0.05) in the intervention group when compared to the control.45 Another study measured change in physical activity in hours per week and found that the intervention group spent significantly more time per week (p>0.05) involved in physical activity than did the control group.92 This same study looked at participation in organized sports and found that the intervention group spent significantly more time engaged in organized sports (p<0.05) than the control group.92 One study measured the amount of time spent engaged in moderate activity, and amount of time engaged in vigorous activity.80 Moderate physical activity increased significantly (p<0.01) in boys engaged in behavior modification and in girls (p<0.05) engaged in movement skills training.80 Vigorous activity increased significantly in both boys and girls in the intervention groups when compared to no intervention.80 This same study found that the intervention groups spent significantly less time (p<0.05) watching TV than the control group (Appendix E, Evidence Table 5d).

###### Interpretation

The results from an outcome measure from each of the 15 studies reporting on physical activity interventions support our conclusions. Two studies reported on BMI z-score.79,95 Both reported changes in BMI z-score in favor of the intervention. One study did not report on significance,95 and the other reported an nonsignificant change.79 Eleven studies reported on BMI.45,52,76,80,82,83,86,87,89,92,106 Eight of these reported a change in BMI in favor of the intervention. One of these were significant,80and the remaining had either nonsignificant changes, or did not report on significance.52,76,82,87,92,109 A single study reported on change in percent body fat and reported a significant change in favor of the control (no intervention).101 A single study reported on skinfold thickness fat and reported a significant change in favor of the control (no intervention).73 Based on this evidence we conclude that physical activity interventions positively impact BMI z-score and BMI. Based on this evidence we cannot conclude that physical activity interventions positively impact skinfold thickness and percent body fat.

One study that showed a significant effect on percent body fat101 enrolled pre-pubertal girls and focused on daily physical educational classes led by school teachers. A major strength of this study101 is that we could regard the intervention group as a population-based cohort, since the study invited all girls in grades 1 and 2 in one school enrolled 90 percent.

One study reported on the influence of gender on the magnitude of the changes in anthropometric variables79 and found a significant reduction in waist circumference of girls but no effect in boys. Plausible explanations for this sex-difference may be that girls are basically less physically active compared to boys; adding daily physical activity into girls' daily routine might have produced a substantial effect on their energy expenditure. Additionally, the postexercise eating behavior may have been different according to gender.

Some of the physical activity interventions also had impact on clinical outcomes (e.g., systolic blood pressure),82 and intermediate outcomes (e.g., increasing physical activity and reducing sedentary activities). These studies targeted cardiovascular disease risk profiles82 and promoted daily physical activity in elementary-school children45,80,92. All of these factors may have contributed to the significant effects of the interventions on weight and other outcomes.

There were no clear differences between the studies that were effective at preventing obesity and those that were not.

##### Diet and Physical Activity Intervention

Thirty-seven studies in 39 articles assessed the effect of a combined diet and physical activity intervention on weight-related outcomes.47,48,50,51,53,55-72,74,78,83-85,88,90,91,94,96-98,100,103-105

###### Weight-Related Outcomes

###### BMI z-Score

Eleven studies reported on BMI z-score. Seven of these studies reported on BMI z-score in the entire population. Five of these studies reported no significant difference between the intervention and control. Four of these reported increases in BMI z-score in both the intervention and the control but the change favored the intervention.55,62,72,99 A single study reported no statistics but stated that the difference between the control and intervention was not significant.51 Another was a pre-post study that reported no statistical change between groups.85 Two combined diet and physical activity intervention studies that evaluated BMI z-score as an outcome reported a statistically significant change in BMI z-score in favor of the intervention group compared to the control group: mean difference in differences 0.04, p=0.04^46^;.mean difference in differences -0.08 (95% CI: -0.02 to 0.04).60 Four studies that reported on entire populations and BMI z-score were RCTs and included sufficient data and homogeneity for a meta-analysis.46,55,60,62,72 This analysis showed an overall difference in BMI z-score of -0.08 (95% CI -0.14, -0.02, p=0.009), in favor of the intervention (Figure 3; Appendix E. Evidence Table 6a).

Figure 3 Meta-analysis of change in BMI z-score between the control and combined diet and physical activity intervention groups in three school-only settings

WMD = weighted mean difference

This figure is an analysis of 5 studies that take place in a school only setting using a combined diet and physical activity intervention to measure BMI z-score change. The intervention had a significant effect in favor of the intervention on BMI z-score in these three studies.

Two studies reporting on BMI z-score also reported data by sex subgroups.71,84 Both studies reported changes in BMI z-score in favor of the intervention. In one study the changes were significant in favor of the intervention for both subgroups; p<0.05 for both girls and boys84 The other study found only significant changes in favor of the intervention in girls, p<0.05.^71^ (Appendix E. Evidence Table 6b).

###### BMI

Twenty-one studies, described in 22 articles, reported on BMI. Sixteen of them reported on BMI in the entire population. Seven studies reported no significant intervention effect.50,57,65,67,91,94,99 Four showed change in BMI in the direction in favor of the intervention, 57,61,65,67,91,99 and one showed no effect in overweight children only.94 Eight of these studies, described in 11 articles, reported a statistically significant desirable effect on BMI; reported in article with no statistics48; adjusted change =-0.45 (95% CI: -0.79 to -0.12); p=0.008; 68; mean difference in difference at 10 years =0.62; p=0.014^100,103,104^; mean difference in differences =-2; p=0^98^; 0.7 kg/m2 (s.e. 0.28) difference in differences between groups at 4 years; p=0.019^78^; adjusted difference in change = -0.019 (95% CI: -0.70 to 0.33)60; mean difference in difference = 0.8; p<0.001^58^ However, One study reported a statistically significant change in BMI in favor of the control mean adjusted difference =0.7; p<0.001.^47^

Seven of the studies showing a statistically significant effect were RCTs and included sufficient data for further analysis.50,57,58,60,61,68,110 These studies showed an overall mean difference of -0.32 kg/m^2^ (95% CI: -0.49, -0.16, p<0.001) in favor of intervention (Figure 4; Appendix E. Evidence Table 6a).

Figure 4 Meta-analysis of change in BMI between the control and combined diet and physical activity intervention groups in four school-only settings

WMD = weighted mean difference

This figure is an analysis of 6 studies that take place in a school only setting using a combined diet and physical activity intervention to measure BMI change. The intervention had a nonsignificant effect in favor of the intervention on BMI in these studies.

Nine studies reporting on BMI also reported data by subgroups. Six by sex,69,71,78,83,84,105 two by weight status,47,94 and one by grade.88 In six of the seven studies, all of the subgroup analyses by sex showed change in BMI in favor of the intervention. One study105 reported an nonsignificant change in favor of the control, and the other71 reported an nonsignificant change in BMI in favor of the intervention in girls and a significant change in favor of the intervention in boys (p-value not specified). The studies reporting on weight status subgroups (obese, overweight, underweight, and normal weight) did not report on significance in differences across groups. One found changes in favor of the control in obese, overweight, and normal weight groups, and changes in BMI in favor of the intervention in the underweight group.47 A study describing grade subgroups reported changes in favor of the intervention, for grades k-3, and a significant difference for grades 4–7; mean difference in differences 0.3, p_0.008 (Appendix E. Evidence Table 6b).88

###### Prevalence of Overweight and Obesity

Eleven studies reported on the prevalence of overweight and obesity. They reported prevalence in one of three ways: prevalence of overweight and obesity, prevalence of obesity, or prevalence of overweight. Four studies reported overweight and obesity prevalence in total populations. Two reported a nonsignificant change in favor of the intervention,46,58and another reported a nonsignificant difference in favor of the control.64 The fourth reported a significant difference in prevalence of overweight/obesity in favor of the intervention; mean difference in differences = 0.31, p=0.04.^55^ Five studies reported on the prevalence of obesity in the entire population. All showed a nonsignificant change in obesity prevalence in favor of the intervention.46,53,62,74,90Three studies reported on the prevalence of overweight in total populations. One study reported a nonsignificant change in favor of the control,64 A pre-post study reported no difference,53 On study, after controlling for confounders, the predicted odds of incidence was 75% lower for the intervention group (odds ratio [OR]: 0.25; 95% CI: 0.07–0.92; p < 0.05) (Appendix E. Evidence Table 6a).62

Four studies reported outcomes by sex subgroups. One study reported on prevalence of overweight/obese and found a nonsignificant change in prevalence in favor of the intervention in both boys and girls.58 Two studies reported on the prevalence of obesity. One study reported a nonsignificant change in prevalence in favor of the intervention for boys, and a significant change in favor of the control for girls; OR, 0.47; 95% CI, 0.24-0.93; p= .03.^56^ The other found a significant change in prevalence in favor of the intervention for boys (17.0% to 11.4% vs. 21.6% to 19.7 %, p<0.05) and a nonsignificant change in prevalence in favor of the intervention for girls.84 One study reported on the prevalence of overweight and showed a nonsignificant change in favor of the intervention for girls and a nonsignificant change in favor of the control for boys (Appendix E, Evidence Table 6b).78

###### Percent Body Fat

Nine studies reported on percentage body fat. They recorded in three ways: percent body fat, percent lean mass, and percent muscle. Six studies reported on percent body fat in the entire population. Three of these studies reported nonsignificant change in body fat in favor of the intervention,50,61,85 and one showed no significant difference between the intervention and control groups.96 Two studies reported significant changes in favor of the intervention; adjusted change = _2.01; 95% CI: 2.98 to 1.04; p=0.0001,^68^ and p<0.05.^48^ One study measured lean mass and reported a nonsignificant change in favor of the control.61 (Appendix E. Evidence Table 6a).

Four studies presented subgroup results. One study only included girls, and found a nonsignificant change in percent body fat in favor of the intervention.60 Another reported on percent body fat by age subgroups and found nonsignificant changes in percent body fat in favor of the control group for both 5 to 7 year olds and 10 to 12 year olds.63Attendance had a nonsignificant influence on percent body fat in favor of the intervention in one study.48 One study measured lean muscle mass in boys and girls and there was a significant change in favor of the intervention for boys (p<0.05) and nonsignificant change in favor of the control for girls (Appendix E. Evidence Table 6b).105

###### Waist Circumference

Six studies reported on waist circumference change in the entire population. Five studies reported nonsignificant changes in waist circumference in favor of the intervention.57,61,68,98,99 One study reported a significant reduction in waist circumference > the 90^th^ percentile (p=0.03) and the same study reported a nonsignificant change in waist circumference in favor of the intervention (Appendix E. Evidence Table 6a).46

One study reported on waist circumference based on attendance and found a nonsignificant change in favor of the control.48 Another study reported on sex subgroups and found significant changes in waist circumference in favor of the intervention group for both boys (p<0.05) and girls (p<0.05) (Appendix E. Evidence Table 6b).84

###### Skinfold Thickness

Studies reported skinfold thickness in two ways: triceps skinfold thickness, and the sum of four skinfold thickness measures. One study reported triceps skinfold thickness for the entire population and showed nonsignificant changes in favor of the intervention.70 One study reported the sum of four skin fold measures for the entire population and showed a nonsignificant change in favor of the control group (Appendix E. Evidence Table 6a).61

Two studies reported on skinfold outcomes in sex subgroups. One study reported on triceps skinfold thickness and showed significant changes in favor of the control in both boys (p<0.05) and girls (p<0.05).84 Another study reported on the sum of four skinfold measures and found a nonsignificant change in favor of the control in boys and a nonsignificant change in favor of the intervention for girls (Appendix E. Evidence Table 6b).105

###### Weight

Three studies reported on weight change in the entire population. These studies showed changes in weight in favor of the control. These changes were not significant in two studies,99,103 and the changes were significant in the other (p<0.05) (Appendix E. Evidence Table 6a).96

Three studies reported on weight change in subgroups, two by sex subgroups and one by grade. One study reported nonsignificant changes in weight in favor of the intervention for both boys and girls,105 and the other showed nonsignificant changes in favor of the intervention for boys and nonsignificant changes in favor of the control for girls.71 The third study reporting on grade subgroups reported nonsignificant changes in favor of the intervention in grades K-3 and nonsignificant changes in favor of the control for grades 4-7 (Appendix E. Evidence Table 6b).102

###### Clinical Outcomes

Seven studies reported on clinical outcomes. Five studies reported on change in systolic and diastolic blood pressure. One study reported a statistically significant change in both blood pressure measures in favor of the control (p<0.001 for both). Three of the remaining four studies reported nonsignificant changes in both blood pressure measures in favor of the intervention.48,67,96 A single study reported a change in systolic blood pressure in favor of the intervention and a change in diastolic blood pressure in favor of the control.91 An additional study reported on systolic and diastolic blood pressure SDS in 5 to 7 year olds, and 10 to 12 year olds. The study reported no significant difference in either measure in both groups.63

Six studies reported on metabolic measures. Three studies reported on HDL. One reported nonsignificant change in favor of the control.48 Two studies reported significant changes in favor of the control, p>0.001^70^, and p=0.014^100^ Two studies reported on LDL changes. Both reported changes in favor of the intervention, one nonsignificant,67 and the other significant (p<0.001)100 Five studies reported total cholesterol. Three of these reported nonsignificant changes in favor of the control.67,70,96 Two reported nonsignificant changes in favor of the intervention.48,104 One reported significant changes in favor of the intervention (p<0.001).100 A single study reported on triglycerides and showed nonsignificant changes (Appendix E. Evidence Table 6c).100

###### Adverse Events

One study110 reported on musculoskeletal injury and used a combined intervention of diet and physical activity in a school-based setting. In year 1, there were 24 adverse events. Overall, there were 0.0006 adverse events per program hour (or incident rate 0.06 per student). Another study reported that at least one adverse event was reported by 2.4 percent of students at baseline, and 1.7 percent of students at the end of the study with no significant difference between the intervention and control groups.(Appendix E. Evidence Table 6d).46

###### Intermediate Outcomes

###### Physical Activity and Sedentary Behavior

Three studies measured changes in hours spent weekly in physical activity. Two studies showed no significant intervention effect.51,72 Another study measured differences in the amount of physical activity based on where the physical activity took place.101 In this study there was a significant difference in the weekly hours spent doing physical activity in favor of the intervention (p<0.001) inside of school, a significant difference in the weekly hours spent doing physical activity in favor of the intervention (p<0.05) outside of school, and a significant difference in the weekly hours spent doing physical activity in favor of the intervention (p<0.001) both in and outside of school.101

One study measured physical activity in 30 minute blocks per day and found the overall change in the amount of physical activity was not significantly different in favor of the control for groups engaged in moderate to physical activity.50

Seven studies, described in eight articles, measured changes in moderate to vigorous physical activity in hours per day.56,57,60,68,75,81,100,104 Two of these showed significant increases in physical activity favoring the intervention, p=0.006,^68^ p=0.04.^57^ Another study reported significant change in physical activity in favor of the control at 6 years, p<0.05^104^ and 10 years, p=0.038.^100^ Three studies measured the change in vigorous physical activity and found no intervention effect.60,68,81 A single study measured a physical activity index measured as sedentary activity, low activity, moderate activity, and vigorous activity.62 All of these measures changed in favor of the intervention, but the changes were not significant.

One study measured the percentage of participants who ran in the morning or afternoon and found no difference between groups.53 This study also found no difference in playground activity between groups. One study reported the prevalence of active commuting over time and found a significant increase in favor of the intervention.95

A study measured daily physical activity via accelerometer and found significant increases in the intervention group over time (p<0.050).95 Another study measured leisure time physical activity and found a significant increase in the intervention group (p=0.0005).103

Two studies measured sedentary activity, neither found a significant difference between the intervention and control groups, but did show change in favor of the intervention.50,62 We did not conduct meta-analyses on intermediate outcomes (Appendix E, Evidence Table 6e).

###### Dietary Intake

Five studies reported on the change in energy intake (e.g., caloric intake, J/day), and four reported a change in the total population in favor of the intervention, but it was not significant.56,60,62,90 One study, reporting on the whole population, showed a significant change in energy intake in favor of the intervention (p<0.05).104 One study, reporting on sex subgroups, showed a change in energy intake in favor of the intervention in boys (p<0.05), but not in girls (p>0.05).56

Seven articles described five studies measured change in the consumption of food high in fat. Four of these studies reported data on the total population and three of these studies showed no difference in consumption between the intervention and control,51,97 one reported a nonsignificant change in favor of the intervention,70 one reported a nonsignificant change in favor of the control70 A single study did show a significant difference in favor of the intervention at 6 years, p<0.05.^104^ One study reported on sex subgroups and found nonsignificant changes in favor of the intervention.56 One of these studies also measured the recall of fatty food intake but found no differences between groups.51 One paper measured energy from saturated fat and found no difference between the intervention and control (Appendix E, Evidence Table 6e).70

Eight studies reported on changes in fruit and vegetable intake. Two studies reported on change in vegetable intake. One did not find significant differences between intervention and control,72 and the second showed a nonsignificant change in favor of the control.53 A single study measured fruit intake only and found a significant increase in intake in boys (<0.05).53 Five studies measured fruit and vegetable intake. Four of these looked at fruit and vegetable intake in the whole population. Two studies reported a nonsignificant change in intake in favor of the intervention,50,65 one reported a nonsignificant change in favor of the control.90 Two studies reported significant changes, both in favor of the intervention (p=0.003),56 and (p<0.05).53 One study found a significant increase among girls in the intervention group (p=0.003),56 but not in boys.

Six studies reported on sugar-sweetened beverage consumption. None showed a statistically significant change in consumption, but two studies showed a change in the direction in favor of the intervention.50,95

A single study58 reported multiple measures of change in dietary intake. None of these changed significantly in this study. One study reported on change in consumption of unfavorable foods.94 The intervention group showed a significant change in favor of the intervention (p=0.002) (Appendix E, Evidence Table 6e).

###### Interpretation

The results from an outcome measure from each of the 37 studies reporting on combination diet and physical activity interventions support our conclusions. Ten studies reported on BMI z-scores.51,55,59,62,71,72,84,85,99 Seven of these reported changes in BMI z-score in favor of the intervention,55,59,62,71,72,84,99 with four of these reporting statistically significant changes.62,71,84,99 Seventeen studies (described in 19 articles) reported on BMI.47,48,50,57,58,61,65,67-69,83,88,91,98,100,103-105,111 Eleven of these studies reported a change in BMI in favor of the intervention,48,50,57,58,65,68,88,98,100,103,104,111 with five of these reporting statistical significance.68,88,98,100,103,104,111 Five studies reported on change in the prevalence in obesity or overweight.53,56,64,74,90 Only one of these studies showed a change in prevalence over time in favor of the intervention, and the change was not significant.90 Two studies reported on percentage body fat.63,96 Neither of these studies reported a change in percentage body fat in favor of the intervention. Two studies reported on skinfold thickness.66,70 Neither of these studies reported a change in skinfold thickness in favor of the intervention. Based on this evidence we conclude that combined diet and physical activity interventions positively impact BMI z-score and BMI. In addition to this evidence, two meta-analyses of smaller sets of studies showed significant changes in favor of the intervention for both BMI and BMI a-score (p<0.001 for both outcomes). Based on this evidence we cannot conclude that combined diet and physical activity interventions positively impact prevalence of overweight and obesity, percentage body fat, and skinfold thickness.

Some diet and physical activity combined interventions appear to be effective at reducing BMI, BMI z-score, prevalence of obesity and overweight, percent body fat, waist circumference, and skinfold thickness. Often these studies specifically targeted obesity prevention and included intensive classroom physical activity lessons led by trained teachers, moderate to vigorous physical activity sessions, nutritional education materials, and healthy diet promotion and provision. The intervention studies that had significant impact took place over a duration of 52 to 156 weeks. All of these factors may have contributed to the significant effect of the intervention on weight outcomes because a more intensive implementation of the program could have a more positive influence on the anthropometric data.

The results from these studies also suggest that schools have the opportunity to raise the physical performance of children through a higher number of physical education lessons per week.57,68,95,100,103,104 Children who followed long-term intervention program57,68,95,100,103,104 showed significant positive changes in physical performance, whereas children in studies of shorter intervention duration had nonsignificant results. Similarly, there were significant effects of the interventions on energy intake,56,104, reduced consumption of sweetened beverages,95,112 and increased fruit and vegetable intake53,56. Overall these results indicate intervention components and intervention dose are critical to the impact of interventions on all outcomes. Long-term intervention duration and long-term followup are vital. Future studies of this type should be of sufficient duration to enable changes in anthropometry and other secondary outcomes.

Combination diet and physical activity interventions that included psychosocial aspects to the interventions had a significant impact on obesity-prevention outcomes.62,113 Otherwise the studies included here were very heterogeneous, and no distinct difference between effective and non-effective studies can be seen.

#### Strength of the Evidence

##### Weight-Related Outcomes

The strength of evidence is moderate that school-only based dietary or physical activity interventions prevent obesity or overweight in children. For both interventions the majority of studies had a moderate risk of bias and consistent direction of effect in favor of the intervention. The strength of evidence is insufficient that school-only based combination diet and physical activity interventions prevent obesity or overweight in children. We identified two low risk of bias studies and used them to evaluate the strength of evidence. These studies were inconsistent; one showed a positive effect in favor of the intervention and the other showed no effect. Additionally, the studies were imprecise (Table 5; Appendix F, Strength of Evidence Table 1).

Table 5 Summary of the strength of evidence for weight-related outcomes in studies taking place in a school setting

Setting | Intervention, n | Years of Publication | Enrolled Participants | Studies With Low/Moderate/High Risk of Bias(n) | % With Favorable (Statistically Sig) Outcome | % With Favorable Outcome (Does Not Need to be Stat Sig) | Risk of Bias | Consistency | Precision | Directness | Strength of the Evidence
School | D, 2 | 1995-2012 | 1,782 | 0/2/0 | 50 | 100 | Moderate | Consistent | Imprecise | Direct | Moderate
School | PA, 15 | 1993-2011 | 10,086 | 0/13/2 | 26 | 73 | Moderate | Consistent | Imprecise | Direct | Moderate
School | C, 37 | 1985-2012 | 41,875 | 2/27/8 | 45 | 54 | Low | Inconsistent | Imprecise | Direct | Insufficient

D = diet intervention; PA = physical activity intervention; C = combination of diet and physical activity interventions

* Total = 54-one study reported on diet, physical activity, and combination interventions, therefore was counted more than once.

##### Intermediate Outcomes

We graded multiple intermediate outcomes. The strength of evidence that diet interventions impacted energy intake (measured as change in kcal, mJ, or J per day) was insufficient. One moderate risk of bias study demonstrated no intervention effect. There was insufficient evidence that physical activity impacted energy intake since no studies reported on this outcome. The strength of evidence that combination interventions impacted change in energy intake was low. Sixty percent of the studies had a moderate risk of bias and 40 percent had a low risk of bias. While all showed a favorable impact of the intervention on the outcome, the poor risk of bias scores and low precision reduced the strength of evidence.

One diet intervention study measured change in fatty food intake. This study had a moderate risk of bias, and reported only on subgroups. A nonsignificant positive impact of the intervention in favor of the intervention was seen in girls and a significant difference was shown in favor of the boys. The lack of precision and consistency between the groups led to an insufficient grade. There was insufficient evidence that physical activity impacted fatty food intake since no studies reported on this outcome. There was a moderate strength of evidence that combination interventions positively impact this outcome in favor of the intervention; 80 percent of the studies were of a moderate risk of bias and all demonstrated an effect in favor of the intervention.

There was insufficient evidence that either diet or physical activity interventions changed fruit and vegetable intake since no studies reported on this outcome. There was moderate strength of evidence that combination outcomes positively impact fruit and vegetable intake. Most of the studies had a moderate risk of bias, and over 70 percent showed an impact in favor of the intervention.

There was insufficient evidence that either diet-only or physical activity-only interventions impacted change in sugar-sweetened intake since no studies reported on this outcome. There was moderate strength of evidence that combination outcomes positively impact sugar-sweetened beverage intake. Most of the studies had a moderate risk of bias, and all of them showed an impact in favor of the intervention.

There was insufficient evidence that diet-only interventions impacted change in physical activity since no studies reported on this outcome. Physical activity interventions have a moderate strength of evidence that the intervention positively impacts the outcome. All of these studies had a moderate risk of bias, all showed an impact in favor of the intervention, and they were precise. Combination interventions have a moderate strength of evidence that the intervention positively impacted the intervention. All of the studies had a moderate risk of bias and over 70 percent showed an impact in favor of the intervention.

There was insufficient evidence that diet or physical activity interventions impacted change in sedentary activity since no studies reported on this outcome. The single physical activity study had a moderate risk of bias with a significant change in favor of the intervention, but the study was too small (n-233) to make a conclusion. The strength of the evidence that combination interventions impact this outcome is low. All studies had a moderate risk of bias, but the direction of effect was inconsistent and there was low precision (Appendix F, Strength of Evidence Tables 2–7).

### School-Home–Based Studies

#### Study Characteristics

Thirty studies reported on interventions delivered in the school and home settings. Of these, 21 (70 percent) were RCTs,114-134 and 9 (30 percent) were non-RCTs.135-143 Six of the non-RCTs consisted of a non-randomized control group design,135-138,140,142, one was a pre-test/post-test, matched control group, quasi-experimental design143, one was a pretest/posttest study design, 141 and one used a serial cross-sectional design.139 Twenty-four studies (80 percent) measured obesity prevention in children.115-117,119-123,125-133,136-139,141-143The remaining studies measured other outcomes but contained data on weight maintenance.114,124,134,135,140(Table 6; Appendix E, Evidence Table 7).

Table 6 Study and participant characteristics of studies based in schools with a home component

Author, Year | RCT | Goal: Weight Maint | Country | Sex^*^ | Age Range, Years^*^ | Grade^*^ | Other^*^ | Total N | Followup in Weeks | % Girls^†^ | Mean Age [Range] Years^†^ | Grade^†^ | Race^†^
Brandstetter, 2012^127^ | Y | Y | Germany | NR | NR | 2 | NR | 1119 | 52 | 46.3% | 7.57 | 2 | NR
Burke, 1998^118^ | Y | N | Australia | NR | NR | NR | NR | 800 | 26 | 49% | 11 | NR | NR
Caballero, 2003^115^ | Y | Y | U.S | NR | NR | 3 | NR | 1,704 | 156 | NR | 7.6 | 3 | ≥ 90% American Indian
Coleman, 2005^143^ | N | Y | U.S | NR | NR | NR | NR | 896 | 104 | 47.2% | NR | 3 | 93% Hispanic
Danielzik, 2007^120^ | Y | Y | Germany | NR | NR | NR | NR | 1,764 | 208 | 50.5% | 6.3 | 1 | NR
Dzewaltowski, 2010^119^ | Y | Y | U.S | NR | NR | NR | NR | 273 | 104 | 50% | 9.3 | 3,4 | 62.7% WNH, 18.8% BNH, 8.9% American Indian, 6.6% Hispanic, 3% Other
Foster, 2008^133^ | Y | Y | U.S | NR | NR | NR | NR | 1,349 | 104 | 53.7% | 11.2 | 4, 5, 6 | 45.6% BNH, 22.4% Asian, 14.1% Hispanic, 12.4% WNH, 5.5% Other
Hatzis, 2010^124^ | Y | N | Greece | NR | NR | NR | NR | 634 | 520 | 52.4% | NR | 1 | NR
Hendy, 2011^116^ | Y | Y | U.S | NR | NR | NR | NR | 382 | 52 | 44.8% | NR | 1,2,3,4 | NR
Hoelscher, 2010^139^ | N | Y | U.S | NR | NR | NR | NR | 1,107 | 52 | 53% | 9.9 | 4 | 66% Hispanic, 20% WNH, 14% BNH
Hollar, 2010^138^ | N | Y | U.S | NR | NR | NR | NR | 1,197 | 68 | 51% | 7.8 | NR | 68% Hispanic, 15% WNH, 9% BNH, 8% Other
Hopper, 2005^134^ | Y | N | U.S | NR | NR | NR | NR | 238 | 86 | 49% | 7.6 | 3 | 83% WNH, 5% Hispanic, 5% Asian, 5% American Indian, 2% BNH
Kriemler, 2010^121^ | Y | Y | Switzerland | NR | NR | NR | NR | 502 | 47 | 51% | 6.9, 11.1 | 1,5 | NR
Llargues, 2011^128^ | Y | Y | Spain | NR | NR | 1st year primary school | NR | 509 | 76 | 45.9% | 6.03 | 1 | NR
Lloyd, 2012^129^ | Y | Y | England | NR | 9-10 years old | Year 5 class | NR | 202 | 72-96 weeks | 50.0% | 9.69 | 5 | NR
Lionis, 1991^140^ | N | N | Greece | NR | 13-14 | NR | NR | 171 | 39 | 51% | 13-14 | NR | NR
Manios, 1998^135^ | N | N | Greece | NR | NR | NR | NR | 962 | 156 | 47% | NR | 1 | NR
Marcus, 2009^125^ | Y | Y | Sweden | NR | NR | NR | NR | 3,152 | 208 | 49% | 7.5 | 1,2,3,4 | NR
Mihas, 2010^123^ | Y | Y | Greece | NR | 12-13 | 7 | NR | 191 | 52 | 49% | 13.2 | 7 | NR
Nader, 1999^122^ | Y | Y | U.S | NR | NR | NR | NR | 3,714 | 156 | 48% | NR | 3 | 69% WNH, 14% Hispanic, 13% BNH, 4% Other
Robinson, 1999^117^ | Y | Y | U.S | NR | NR | 3, 4 | NR | 198 | 26 | 46.6% | 8.9 | 3, 4 | NR
Schetzina, 2009^141^ | N | Y | U.S | NR | NR | NR | NR | 114 | 78 | 53% | 9 | 3, 4 | 94% WNH, 3% BNH, 3% Other
Shofan, 2011^136^ | N | Y | Israel | NR | NR | NR | NR | 118 | 104 | 46.6% | 9-11 | 4,5,6 | NR
Siegrist, 2011^131^ | Y | N/NR | Germany | NR | NR | 2 and 3 | NR | 724 | 52 | 48.3% | 8.4 | 2,3 | NR
Simon, 2008^132^ | Y | Y | France | NR | NR | NR | NR | 954 | 208 | 50.0% | 11.6 | 6 | NR
Simonetti D'Arca, 1986^137^ | N | Y | Italy | NR | NR | NR | NR | 1,321 | 52 | NR | 3-9 | NR | NR
Speroni, 2007^142^ | N | Y | U.S | NR | NR | NR | NR | 185 | 104 | 50.3% | 9.3 | 2, 4 | 78.3% WNH, 21.7% Hispanic
Story, 2012^126^ | Y | Y | U.S. | NR | NR | Kindergarten | NR | 454 | 80 | 48.9% | 5.81 | Kindergarten | 100% American Indian
Trevino, 2004^114^ | Y | N | U.S | NR | <12 | 4 | NR | 1,419 | 34 | 49.5% | 9.8 | 4 | 80% Mexican American
Williamson, 2012^130^ | Y | Y | U.S. | NR | NR | 4 to 6; rural communities | NR | 2060 | 121 | 58.5% | 10.5 | 4,5,6 | 31.6% WNH; 68.4% Black

AIAN = American Indian/Alaska Native; API = Asian Pacific Islander; BMI = Body Mass Index (in kg/m^2^); BNH = Black Non-Hispanic; BP = Blood Pressure; CVD = Cardio Vascular Disease.; Maint = Maintenance; Meds = Medications; N = No; NR = Not Reported; physical activity = Physical Activity; RCT = Randomized Controlled Trials; WNH = White Non-Hispanic; Y=Yes

* Inclusion/exclusion criteria.

† Participant characteristics.

Fifteen studies (48 percent) took place in the U.S.,114-117,119,122,126,130,133,134,138,139,141-143 and the remainder were conducted in England,129Greece,123,124,135,140 Australia,118 France,132 Germany,120,127,131 Israel,136 Italy,137 Spain,128 Sweden,125 and Switzerland (Table 6; Appendix E, Evidence Table 7).121

#### Population Characteristics

The total number of participants in the 30 studies combined was 28,413.^114-143^ The number of participants in each individual study ranged from 114^141^ to 3,714 (Table 6; Appendix E, Evidence Table 8).122

The length of follow-up ranged from 26 weeks (6 months) to 520 weeks (10 years). Eleven studies had a follow-up period of 1 year or less.114,116-118,121,123,127,131,137,139,140Twelve studies had a follow-up period of between 1 and 2 years,119,126,128-130,133,134,136,138,141-143six studies had a follow-up period of 3 or 4 years,115,120,122,125,132,135 and one study had a follow-up period of 10 years (Table 6; Appendix E, Evidence Table 8).124

All studies contained both girls and boys, and all but three studies reported the percentage of girls in the study.114,116,117,119-136,138-143 Most studies had roughly half girls and half boys, with the percentage of girls ranging from a low of 44.8 percent116 to a high of 58.5 percent (Table 6; Appendix E, Evidence Table 8).130,133

Twenty-three studies (77 percent) reported the mean age of participants,114,115,117-121,123,125-134,138-142which ranged from 5.8 years126 to 13.2 years.123 The oldest participant was 14 years old (Table 6; Appendix E, Evidence Table 8).140

One study included kindergarten children126; twenty-four studies (80 percent) included children in grades one through six.114-117,119-122,124,125,127-136,139,141-143one study included children in grade seven.123The remaining four studies did not report the specific grade of their participants.118,137,138,140 There were no high school students in any of the school-home studies (Table 6; Appendix E, Evidence Table 8).

Thirteen of 30 studies (43 percent) reported the race or ethnicity of study participants.114,115,119,122,126,130,133,134,138,139,141-143 In five of the studies, the majority of participants were white (63 percent,119 69 percent,122 78 percent,142 83 percent,134 and 94 percent).141 In three of the studies, the majority of participants were Hispanic (66 percent,139 68 percent,138 and 93 per).143 In two of the studies, the participants were primarily Black (68 percent130 and 46 percent)133; in another two studies, participants were primarily American Indian (100 percent126 and ≥ 90 percent115); and in the last study, participants were primarily Mexican American (80 percent).114 Among the studies that did not report race, only two were U.S. studies.116,117 (Table 6; Appendix E, Evidence Table 8).

#### Interventions

Twenty-six of the 30 studies (87 percent) included combined diet and physical activity interventions.114-116,118-120,122-131,133-136,138-143(Table 7; Appendix E, Evidence Table 9). One study included an intervention that focused exclusively on diet modification.137 (Table 7; Appendix E, Evidence Table 9). Two studies focused exclusively on physical activity interventions,121,132 and a third study focused on the reduction of sedentary behavior associated with television, videotape, and videogame use (Table 7; Appendix E, Evidence Table 9).117 There were no studies that reported on self-management alone (Table 7; Appendix E, Evidence Table 9).

Table 7 Interventions of studies based in schools with a home component

Author, Year | Control Arm | Description of Intervention | Diet (Phys/Env) | Diet (Psych) | Physical Activity (Phys/Env) | Physical Activity (Psych)
Brandstetter, 2012^127^ | Usual care | URMEL-ICE: School health promoting behavior change Family homework lessons, training and information of parents. | X | | X | X
Burke, 1998^118^ | Usual care | WASPAN^a^: Classroom lessons on physical activity and nutrition. Home-based nutritional program for children and their families. | X | | | X
| Usual care | WASPAN^b^ : Classroom nutrition and physical activity lessons with physical education enrichment activities. Home-based nutritional program for children and family. | X | | | X
Caballero, 2003^115^ | Usual care | Classroom curriculum Family involvement. | X | X | X | X
Coleman, 2005^143^ | Usual care | Classroom and school wide physical education and nutrition changes in the cafeteria Home reduction of sedentary activity | X | X | X | X
Danielzik, 2007^120^ | Usual care | Behavioral and educational messages using nutrition fairy tales about eating fruit and vegetables every day and reduce intake of high-fat foods. Behavioral and educational messages to keep active and decrease television consumption Preparing a healthy breakfast at home | X | | X
Dzewaltowski, 2010^119^ | Usual care | HOP'N after school: a weekly social-cognitive-theory based curriculum (eat fruits and vegetables and increase physical activity). Home—no more than 2 hours a day sedentary activity; remove TV from the bedroom. | X | X | X | X
Foster, 2008^133^ | Usual care | School Nutrition Policy Initiative: classroom-based nutrition education, foods sold met a specified nutritional standard; physical activity linked to personal behavior. Reduced sedentary activity at home. | X | X | X
Gorely, 2009^144^ | Usual care | GreatFun2Run: increase children's activities through physical activity on running. Raise awareness at home | X | | X | X
Hatzis, 2010^124^ | Usual care | "Know Your Body" education material with major modifications to the Mediterranean diet of Crete and the orthodox Christian church fasting rituals. | X | | X
Hendy, 2011^116^ | Usual care | KCP group (LIONS)-received stars for 3 good health behaviors. | X | | X
Hoelscher, 2010^139^ | Usual care | CATCH BP c Classroom curricula and a physical education program, a child nutrition services component Family involvement | X | X | X | X
Hoelscher, 2010^139^ | Usual care | CATCH BPC d Classroom curricula and a physical education program, a child nutrition services component Family involvement Community action team | X | X | X | X
Hollar, 2010^138^ | Usual care | HOPS intervention: School provided diet, classroom curricula, and physical activity during school day. | X | X | X | X
Hopper, 2005^134^ | Usual care | School classroom lessons on nutrition and exercise. Home activities for parents and children to complete. | X | | X | X
Kriemler, 2010^121^ | Usual care | KISS: School based stringent physical activity program Home daily physical activity homework of about 10 minutes. | | | | X
Lionis, 1991^140^ | Usual care | School health education curriculum. | X | | X
Llargues, 2011^128^ | Usual care | Education about food habits and physical activity: developing posters, food tables, games, crafts, cooking workshops and promotion of games in the playground. | X | | X
Lloyd, 2012^129^ | Usual care | School newsletters, plays, homework, assembly Home: multiple activities involving home and parents | X | | X
Manios, 1998^135^ | Usual care | School health education plus physical activity components. Provide parents screening results and lessons on the importance of children's dietary and exercise habits. | X | | X | X
Marcus, 2009^125^ | Usual care | Diet and physical activity awareness: Change the school environment, including school lunches, afternoon snacks, after school care activities and sports days. Parents were asked not to provide unhealthy snacks for birthdays etc. | | X | | X
Mihas, 2010^123^ | Usual care | Health and nutrition education | X | | X
Nader, 1999^122^ | Usual care | CATCH intervention: targeted consuming foods low in fat, saturated fat and sodium via a multicomponent program that included school environmental changes, and a family component. | X | X | X | X
Robinson, 1999^117^ | Usual care | Classroom curriculum to reduce television, videotape, and video game use. | | | X | X
Schetzina, 2009^141^ | Usual care | Winning with Wellness Pilot program: classroom instruction, school health services, and removing soda from vending machines and physical education and activity | X | | X | X
Shofan, 2011^136^ | Usual care | Focused on increased physical education and activity together with nutritional advice to the children and their families. | X | | | X
Siegrist, 2011^131^ | Usual care | JuvenTUM: educate students, parents and teachers; alter school environments for diet and physical activity | X | X | X | X
Simon, 2008^132^ | Usual care | School education on physical activity and sedentary behaviors, opportunities for physical activity were offered. Parents were asked to support the child's physical activity. | | | X | X
Simonetti D'Arca, 1986^137^ | Usual care | Written Action School: Focused on educating staff, students and parents using printed material only. | X
Simonetti D'Arca, 1986^137^ | Usual care | Multi-media Action School: Focused on educating staff, students and parents using media. | X
Speroni, 2007^142^ | Usual care | After-school exercise and diet education program | X | | | X
Story, 2012^126^ | Usual care | Bright Start: School physical activity sessions, nutritional lessons Goal to increase health awareness and better eating habits at home through motivational interventions | | X | | X
Trevino, 2004^114^ | Usual care | School health behavior messages in classroom, school cafeteria, and after-school care. Reinforced at home and after school care. | X | | X | X
Williamson, 2012^130^ | Usual care | School change in food from school cafeterias and vending machines, physical activity in class, during recess and PE classes Newsletters sent home providing campaign-specific information | | X | | X

Phys/Env = Physical/environmental intervention; Psych = psychosocial intervention

a Western Australian Schools Physical Activity and Nutrition.

b Western Australian Schools Physical Activity and Nutrition plus physical activity enrichment for children with high cardiovascular risk.

c Coordinated Approach To Child Health BasicPlus (CATCH BP).

d Coordinated Approach To Child Health BasicPlus (CATCH BP) plus Community.

#### Outcomes

##### Diet Interventions

There was one diet-only intervention, which employed an educational approach to diet and nutrition (Appendix E, Evidence Table 10a,b).137

###### Weight-Related Outcomes

###### Prevalence of Overweight and Obesity

This RCT with 1,321 participants 137 measured the change of prevalence in overweight and obesity after 1 year. It compared two different interventions to one control group. In the control school, students received usual care. The study called one intervention the written action (WA) intervention, and the other the multi-media action (MA) intervention. The results of this study demonstrated an increase in the prevalence of overweight students (+0.8 percent) and obese students (+5.9 percent) in the control group. The WA intervention arm led to a 2.3 percent decrease in overweight students, but a 5.3 percent increase in obese students. However, the MA intervention led to 12.1 percent reduction in the prevalence of overweight students and a 12.2 percent reduction in the prevalence of obese students at the end of the study.(Appendix E, Evidence Table 10a,b).

Among boys, there was a 2.0 percent reduction in overweight in the control group versus the MA group, and a 1.6 percent increase in the control group versus the WA group. Among girls, there was a 5.4 percent reduction in overweight in the control group versus the MA group, and a 3.7 percent reduction in the control group versus the WA group (Appendix E, Evidence Table 10a). Among boys, there was a 2.6 percent reduction in obese children in the control group versus the MA group, and a 1.1 percent increase in the control group versus the WA group. Among girls, there was a 2.2 percent reduction in obese children in the control group versus the MA group, and a 1.0 percent increase in the control group versus the WA group (Appendix E, Evidence Table 10a).

###### Clinical Outcomes

The research did not report any.

###### Adverse Events

The research did not report any.

###### Intermediate Outcomes

The research did not report any.

###### Interpretation

The results from an outcome measure from this study support our conclusions. In this study, the less intensive intervention, which relied exclusively on the dissemination of printed material, was less effective in reducing the prevalence of overweight and obesity compared to the intervention, which employed qualified staff to interact directly with students, teachers, and parents through meetings, discussions, and other interactive activities.

##### Physical Activity Interventions

Two studies focused exclusively on physical activity interventions. These studies were multi-component physical activity programs that included both an educational and environmental approach to physical activity.121,132 A third study focused on the reduction of sedentary behavior associated with television, videotape, and videogame use (Appendix E, Evidence Table 11a,b).117

###### Weight-Related Outcomes

###### BMI

Of the three studies reported above that measured change in BMI,121,132,117 all three showed a statistically significant reduction in the intervention group relative to the control group: -0.12 (p<.003); -0.26 at 2 years, -0.25 at 3 years, and -0.25 at 4 years, (p=0.01), and -0.45 (p=.002), respectively (Appendix E, Evidence Table 11a,b).

###### Prevalence of Overweight and Obesity

One physical activity study found a reduction in the prevalence of overweight in the intervention group relative to the control: at 4 years; 4.2 percent of the initially non-overweight students were overweight in the intervention schools, compared to 9.8 percent in the control schools (odds ratio [OR], 95% confidence interval [CI]=0.41 [0.22; 0.75]) (Appendix E, Evidence Table 11a,b).132

###### Percent Body Fat

One study stratified the analysis according to “initially non-overweight” and “initially overweight” participants, the results showed an improvement in percent body fat in the “initially non-overweight” group (-0.55 percent, p=0.19) in the intervention group, but a worsening in the “initially overweight” group (1.33 percent, p=0.18) (Appendix E, Evidence Table 11a,b).132

###### Waist Circumference

Of the two studies that measured change in waist circumference (cm),121,117 both showed a reduction in waist circumference in the intervention group relative to the control group, -0.08 (p=0.25) and -2.30 (p<0.001), respectively (Appendix E, Evidence Table 11a,b).

###### Skinfold Thickness

The study that measured triceps skinfold thickness showed a decrease of 1.47 (p=0.002) in the intervention group relative to the control group (Appendix E, Evidence Table 11 a,b).117

The study that measured change in the sum of four skinfolds showed an decrease of 0.12 (p=0.009) in the intervention group relative to the control group (Appendix E, Evidence Table 11a,b).121

###### Clinical Outcomes

One study computed a cardiovascular risk score that included all components of the metabolic syndrome, including average z-score of waist circumference, mean blood pressure, blood glucose, inverted HDL cholesterol, and triglycerides. The results showed that the intervention resulted in an improvement in the cardiovascular risk score, corresponding to 0.18 (−0.29 to −0.06) z-score units (p=0.003).121 Two studies found a reduction of -0.08 mm Hg (p=0.88)121 and -0.42 mm Hg (p=0.66)132 in systolic blood pressure in favor of the intervention, but neither result was statistically significant. Two studies121 132 found a reduction of 0.12 (p=0.02) and 0.46 (p=0.60), respectively in diastolic blood pressure, mostly in favor of the intervention relative to the control group. One study found an increase in total cholesterol of 2.71 (p=0.15) in the intervention group relative to the control group.132 Two studies showed an increase in HDL. One showed an increase in HDL of 3.43 (p<0.0001),132 and one showed a decrease of -0.78 which was not significant.140 Two studies121 132 found a reduction in triglycerides in favor of the intervention (-0.10, p<0.02) and (-2.60, p=0.34), respectively. One study132 found no difference in glucose between the intervention and control group (0.0, p=0.81). One study found a slight increase in the intervention group relative to the control group (0.03 (95% CI -0.98; 1.04) p=0.96), and a slight increase in HOMA in the intervention group relative to the control group (0.01 (95% CI -0.23; 0.24) p=0.95) (Appendix E, Evidence Table 11c).132

###### Adverse Events

The research did not report any.

###### Intermediate Outcomes

One study reported a large number of intermediate outcomes which included a series of child and parent reported measures of television viewing, diet, and physical activity and fitness.117 The children-reported measures showed a consistent reduction (on a per-week basis) in favor of the intervention group with respect to all of the following measures: 5.53 fewer hours of television (p<0.001), 1.53 fewer hours of videotapes (p=0.11), 2.54 fewer hours of videogame usage (p=0.01), 0.54 fewer meals in front of the TV (p=0.01), 0.11 fewer snacks in front of the television (p=0.16), 0.82 fewer daily servings of high fat food (p=0.12), and 0.34 fewer other sedentary behaviors (p=0.44). The only outcomes that did not show a reduction were daily servings of high-advertised foods (increase of 0.06, p=0.71) and the 20-meter shuttle test (fewer cones by 0.87, p=0.45).117

Parent reports of their children's behavior yielded similar results: 4.29 fewer hours of TV (p<0.001), 0.25 fewer hours of videotapes (p=0.60), 0.76 fewer video game hours (p=0.13), 0.77 fewer hours of household TV use (p=0.10), 1.1 fewer meals in front of the TV (p=0.02), 1.9 percentage decline in TV viewing while snacking (p=0.59), 4.88 fewer other sedentary behaviors (p=0.16), and 2.0 more hours/week of physical activity, (p=0.13) (Appendix E, Evidence Table 11d).117

In another study, there was an improvement in the Shuttle Run of 0.17 cones in the intervention group relative to the control group (p=0.04); an increase in in-school physical activity (counts/min) by 0.92 (p=0.003); and an increase in in-school total moderate to vigorous physical activity (min/day) by 1.19, p<0.001.^121^ In a second study, intervention students had an increase in supervised physical activity (p=0.0001) and a reduction in TV/video viewing (p=0.01) relative to the control group (Appendix E, Evidence Table 11d).132

###### Interpretation

The results from an outcome measure from these two studies support our conclusions. Even though two of the three studies focused on increasing physical activity and the other focused on decreasing sedentary behavior, they all demonstrated some improvements in BMI, waist circumference, and skinfold thickness due to the intervention. This suggests that interventions aimed at either increasing physical activity or reducing sedentary behavior can be effective at preventing obesity.

##### Diet and Physical Activity Interventions

Twenty-six of 30 studies conducted in both the school and home setting implemented combined diet and physical activity interventions. Of the 27, 18 were RCTs (Appendix E, Evidence Table 12a,b).

###### Weight-Related Outcomes

Twenty-three out of 30 studies included a measure of BMI, BMI z-score, or BMI percentile. Of these, six were statistically significant in favor of the intervention, 14 were nonsignificant, two did not report p-values, and one had inconsistent results.

###### BMI z-Score

Among the eight studies that measured BMI z-score, one showed significant reductions in favor of the intervention (-0.34)138,144 and the rest did not.120,126,129-131,133,141

###### BMI

Among the 17 studies that measured BMI, 14 showed a reduction in BMI in the intervention group relative to the control group, with the magnitude of difference ranging from -0.4 to -1.20 kg/m^2^. However, only four of these changes were statistically significant. 124,128,135,140

There were seven studies118,119,126,131(but a total of eight active intervention arms) that we included in a meta-analysis for the BMI (kg/m^2^) outcome measure. The results of the meta-analysis yielded an overall weighted mean difference of 95 percent -0.17 kg/m^2^ (95% CI: -0.57, 0.23, p=0.407), which favored the control over the intervention, but was not statistically significant. Studies were excluded from the meta-analysis for the following reasons: a) if they were not an RCT, b) if there was considerable heterogeneity when included in the analysis, c) if there was insufficient outcome reporting, or d) if there was an insufficient numbers of studies with a similar intervention. (Figure 5) (Appendix E, Evidence Table 12 a, b).

Figure 5 Meta-analysis of change in BMI between the control group and combined diet and physical activity-only interventions in a school setting with a home component

WMD = weighted mean difference

This figure is an analysis of 8 studies that take place in a school/home setting using a combined diet and physical activity intervention to measure BMI change.

One study compared one control arm with two intervention arms.118 One intervention arm was the Western Australian Schools Physical Activity and Nutrition project, and the second intervention arm was Western Australian Schools Physical Activity and Nutrition project plus a physical education enrichment program targeting only children with higher levels of cardiovascular risk (Appendix E, Evidence Table 12a). There was no improvement in BMI in either boys or girls due to either intervention arm.

###### BMI Percentile

Two studies reported BMI percentile. One showed a clear reduction in due to the intervention,142 (-3.8 percent, p<0.01). The other study examined change in BMI percentile in two strata of participants: average weight participants (n=200) and overweight participants (n=112).116 At the 3-month followup period, the results showed a nonsignificant reduction in average weight participants by 2.40 percent (p=0.32) relative to the control group, but a significant reduction in overweight participants by 2.60 percent (p=0.001). However, this reduction was not maintained when reexamined 6 months later. The third study showed no effect of the intervention on the BMI percentile.94 (Appendix E, Evidence Table 12a,b).

###### Prevalence of Overweight and Obesity

Only one study examined the change in the incidence of overweight and obesity due to the intervention.133 After controlling for gender, race/ethnicity, and age, this study found that the odds of becoming overweight in the intervention group were 33 percent lower for the intervention group compared to the control group (adjusted OR, 0.67 [95% CI 0.47–0.96], p<0.03). However, there were no differences in the incidence of obesity between the intervention and controls schools (adjusted OR, 1.00 [95% CI 0.66–1.52], p=0.99) (Appendix E, Evidence Table 12a,b).

After 2 years, the unadjusted prevalence of overweight had decreased by 10.3 percent in intervention schools and had increased by 25.9 percent in control schools. After controlling for gender, race/ethnicity, age, and baseline prevalence, the predicted odds of overweight prevalence were 35 percent lower for the intervention group (adjusted OR 0.65 (95% CI 0.54–0.79), p<0.0001). Similar to the results for incidence of obesity, there was no apparent reduction in the prevalence of obesity as a result of the intervention (adjusted OR 1.09 (95% CI 0.85–1.40), p=0.48) (Appendix E, Evidence Table 12a,b).

A study with similar results126showed a 10 percent reduction in the prevalence of overweight (between 85 and 95 percentile) in favor of the intervention group (p=0.019), but no corresponding change in the prevalence of obesity (BMI ≥ 95^th^ percentile).

Another study125 found a significant reduction in the prevalence of overweight (-3.70 percent, p<0.05), obesity (-2.30 percent, p<0.05), and the two together (-6.00 percent, p<0.05) due to the intervention (Appendix E, Evidence Table 12a,b).

One study compared two different intervention arms: the Combined Approach to Child Health (CATCH) curriculum Basic Plus (BP) and the CATCH Basic Plus Community (BPC).139 There was no control group in this study. The CATCH BP led to a reduction of 3.1 percent (p=0.33) prevalence of overweight and obesity from baseline to followup, and the CATCH BPC led to a reduction of 8.30 percent (p<0.005), indicating that the enhance CATCH BPC had a greater effect on weight control than the CATCH BP intervention (Appendix E, Evidence Table 12a,b).

In one study, the prevalence of overweight and obesity had decreased by -7.6 percent in the intervention group by 18 months, and by -9.7 percent by 24 months.129

In another study, the prevalence of overweight increased by 8.0 percent in the control group but only by 5.3 percent in the intervention group, and the prevalence of obesity increased by 0.5 percent in the control group, but decreased by 3.6 percent in the intervention group. Prevalence of excess weight (overweight and obesity) increased by 8.5 percent in the control group and by 1.8 percent in the intervention group.128

One study that compared the risk of overweight or overweight in girls and boys found that the rate of increase in percent overweight was 2.0 percent for girls in the intervention schools compared to 13.0 percent for girls in the control schools; and 1.0 percent in boys in the intervention schools compared to 9.0 percent in the control schools (Appendix E, Evidence Table 12b).143

###### Percent Body Fat

Among the four studies that investigated change in percent body fat, only one showed a reduction in percent body fat in the intervention group relative to the control group by -0.83 at 18 months and -1.28 at 24 months.129; the other four demonstrated a trend in favor of the control group,114,115,124,126 although the results were not statistically significant (Appendix E, Evidence Table 12a,b). A final study found no differences between groups in percent body fat for either girls or boys.130

###### Waist Circumference

Among the six studies that reported waist circumference, five showed a reduction due to the intervention120,124,127,129,131(-0.80, -0.70, -0.61, -2.01, and -1,70 cm, respectively), and one study showed an increase, but the change was not significant118 (Appendix E, Evidence Table 12a,b).

###### Skinfold Thickness

Among the six studies that measured change in triceps skinfold thickness, three showed an improvement in the intervention group, relative to the control group122,127,135, and the remaining three studies revealed an increase in the intervention group, although none of these differences were statistically significant115,122,126,140(Appendix E, Evidence Table 12a,b). Four studies measured change in subscapular skinfolds. None showed a significant difference between groups (Appendix E, Evidence Table 12a, b).115,122,126,135

###### Clinical Outcomes

One study found a small reduction in systolic blood pressure and a reduction of -2.47 mm Hg and -2.09 mm Hg, respectively in diastolic blood pressure (fourth and fifth phase) in favor of the intervention group. (Appendix E, Evidence Table 12c)140 This study also demonstrated significant improvements in cholesterol levels in the intervention group, including a decrease in total cholesterol of -17.21 (p<0.001); a reduction in LDL of 17.6 (mg/l) (p<0.0001), and improvements in the ratio of LDL/HDL and the ratio of total cholesterol to HDL of 0.31 (p<0.001) and 0.31 (p<0.001), respectively.140 (Appendix E, Evidence Table 12c).

###### Adverse Events

The research did not report any.

###### Intermediate Outcomes

###### Physical Activity and Sedentary Behavior

Fifteen of the 16 studies that measured change in physical activity showed some improvement in physical activity in the intervention group relative to the control group.

Among the studies that measured number of steps, one study demonstrated that the intervention group increased the number of steps it took by 11,971 steps per month, compared to 758 steps in the control group (p=0.011) (Appendix E, Evidence Table 12d).116 In a study with a pre-test/post-test design, participants took an average of 886 more steps after the intervention compared to before (p<0.001).141

Among studies that measured total physical activity, one study showed a slight increase in total physical activity of 0.30 hours/wk (95 percent CI- 0.40 to 1.0 hr/wk, p=0.40) and a corresponding reduction in total inactivity in the intervention group relative to the control (p<0.001) (Appendix E, Evidence Table 12).133 Another study demonstrated a 10.8 percent increase in the proportion of students who exercised greater than or equal to 7 times per week, but no increase in the actual exercise intensity (-0.30). One study showed that participants in the intervention group increased the amount of time they spent playing outside (by 2 percent), participating in sports clubs (by 5 percent) and participating in sport activity outside of sports club (by 8 percent) compared to the control group.127 Another study showed an increase of 10 percent in the intervention group in the amount of physical activity performed outside of school compared to the control group.145 Two other studies showed an increase in the number of active days per week131 and the number of minutes of physical activity per week126, but neither of these results were statistically significant. One study demonstrated an improvement in physical activity in three out of five measures, including number of days engaged in at least 30 minutes of vigorous physical activity (0.3), number of days played outdoors (0.1), and number of days played sports activity (0.2); but there was no improvement in the percent engaged in at least 30 minutes of vigorous physical activity per day (-0.6), nor in the number of days participated in some organized activity (-0.1) (Appendix E, Evidence Table 12d).139

Among studies that measured moderate to vigorous physical activity, one study showed a statistically significant improvement of 1.6 minutes (p<0.005) in the intervention group relative to the control group. (Appendix E, Evidence Table 12d).135 Another study demonstrated a 3 percent increase in the number of students engaged in vigorous physical activity (p<0.05) and a 5 percent increase in the number of students engaged in moderate to vigorous physical activity (nonsignificant) in the intervention group relative to the control group (Appendix E, Evidence Table 12d).143 A final study showed an improvement of 8.8 more minutes of vigorous physical activity in the intervention compared to the control group (p=0.001) (Appendix E, Evidence Table 12d).122

In one study, there was a nonsignificant increase in physical activity according to a motion sensor (average vector magnitude/min) of 20.43 (95% CI= -19.05, 59.92) in the intervention group relative to the control group (p=0.310) (Appendix E, Evidence Table 12).115 And another study showed an increase of 18 counts per minute of physical activity in the intervention group compared to the control group. The one study that did not show improvement measured physical activity by a self-administered activity checklist.130

Seven studies measured change in sedentary behavior. All five of the studies that measured screen time, showed a reduction in TV, video, or computer usage in the intervention group compared to the control group.118,127,129,133,139 In one study, which compared the CATCH BP Program to CATCH BPC, the BPC group showed a 4.7 percent reduction (p=0.095) among students who watched greater than 2 hours of TV per day, a -5.6 percent reduction (p=0.182) among students who spent greater than 2 hours on the computer per day, and a 1.3 percent reduction (p=0.182) among students who played greater than 2 hours of video games per day.139 In another study, according to student's diaries, there was no overall change in physical activity or TV-watching, except for the subgroup of boys in the physical activity enrichment arm of the study.118 In a third study, there was a decrease in total TV hours during the weekdays by 5 percent (p<0.0001) and on the weekends to a lesser degree (3 percent, p=0.39).133 Two other studies showed a reduction in general sedentary behavior in the intervention group compared to the control.128,130 (Appendix E, Evidence Table 12d)

###### Dietary Intake

Seven of nine studies showed a reduction in caloric intake in the intervention group relative to the control.122,123,126,130,133,134,140 Of the remaining two studies, one showed an increase in caloric intake in the intervention group,124,134,140 and one reported a reduction of -265 (kcal) (95% CI -437 to -94, p=0.003) in the intervention group using a 24-hour dietary recall method, but a minor increase in caloric intake according to school-lunch observation measure. (Appendix E, Evidence Table 12d).115

Among the seven studies that measured change in fruit and vegetable intake, four showed improvements,116,126,128,139 two showed no improvement,125,133 and one showed an improvement in fruit, but not vegetable, intake due to the intervention.123

In the first study, the intervention group increased their fruits and vegetables first behavior by 2.31 meals (of six meals), compared to 0.72 in the control group (p=0.000) and increased their healthy drinks behavior by 3.46 meals compared to 0.52 meals in the control group, (p=0.000).116 In the second study, there was a small improvement in the number of fruits and vegetables consumed in the intervention group (0.3, p=0.074).139 In the third study, there was no between-group difference in the portions of vegetables consumed per week, but there was a slight, nonsignificant increase of 1.0 portion of fruit consumed per week by the intervention group relative to the control group.123 In a fourth study, children in the intervention group reported less consumption of high-fat dairy products (p=0.001), sweetened cereals (p=0.02), and sweet products (p=0.002) than children in the control group; however, there was no between-group difference in the amount of fruits and vegetables consumed (p=0.47).125 In the fifth study, fruit and vegetable intake decreased in both groups over time133 (Appendix E, Evidence Table 12d).

There were four studies that showed modest improvements in the intervention group relative to the control group.126-128,139 (Appendix E, Evidence Table 12d).139

There were two studies that measured change in fatty food intake. One study showed a reduction in grams of fat, percentage of total fat calories, and percentage of calories from saturated fat in the intervention group compared to the control group, however there was no change in the amount of fast food per day.126 The other study showed a reduction on total fat and saturated fat, but these changes were not significant.130 An additional study measured change in fatty food intake by the Unhealthy Food Index. This study demonstrated a modest, but significant decrease of -0.6 points on the Unhealthy Food index in the intervention group relative to the control (Appendix E, Evidence Table 12d).139

###### Interpretation

Our conclusions are based on one outcome measure from each of the 26studies reporting on combined diet and physical activity interventions. Overall the findings suggest that combined diet and physical activity interventions have favorable effects on weight outcomes, as well as for increasing physical activity, reducing sedentary behavior, and promoting healthier eating.

Seventeen studies reported on BMI (kg/m^2^).115,118-120,122-124,126-129,131,133-136,140 Fourteen of these studies reported changes in favor of the intervention.115,119,120,122-124,127-129,131,133-135,140 Among the 14, four were statistically significant.124,128,135,140

Two studies reported on BMI percentile,116,142 which were statistically significant in favor of the intervention.

Three studies reported on BMI percentile,94,116,142 and two of these were statistically significant in favor of the intervention.

Three studies reported on prevalence of overweight or obesity.125,139,143 All three showed a significant effect in favor of the intervention.

One study reported on percent body fat.114 This study was not in favor of the intervention, nor was it statistically significant.

The differences between the statistically significant and non-significant studies that tested a combination physical activity and diet intervention or physical activity intervention do not appear to be related to characteristics related to study participants (sex or age), type of intervention (education or environment), or country. The factors that could contribute to more successful interventions could be related to implementation; other characteristics of the intervention such as intensity, dose, and duration; and participant engagement. These types of characteristics were sought but rarely reported in studies; we were thus unable to explore the impact of these factors on our conclusions. In addition, worth noting it is possible and even likely that the dose of the home component of many school-based interventions with a home component would be very low, rendering them similar to those school-only based interventions.

Since few studies included clinical outcomes, there is insufficient evidence about the impact of these types of interventions on markers of cardiovascular health.

However, many studies included measures of physical activity, sedentary behavior and dietary intake. Overall, 15 out of 16 studies showed some improvement in physical activity due to the intervention. All seven of the studies that aimed to reduce sedentary behavior, showed a reduction in TV, video, or computer use or other sedentary activity, due to the intervention. Dietary outcomes also showed improvements of various kinds: seven of nine studies showed a reduction in caloric intake in the intervention group relative to the control; four of seven studies showed an increase in fruit and vegetable intake; four of four studies showed a modest decrease in sugar-sweetened beverage intake, and two other studies demonstrated a decrease in fatty food intake.

#### Strength of the Evidence

##### Weight-Related Outcomes

The strength of the evidence is insufficient that diet interventions positively impact obesity prevention, because there is only one study that contained a diet intervention. In contrast, the strength of the evidence is high that physical activity interventions positively impact obesity prevention. Three out of three studies showed a positive impact in favor of the intervention, and all were statistically significant changes. The strength of evidence is moderate that combined diet and physical activity interventions prevent obesity or overweight in children (Table 8; Appendix F, Strength of Evidence Table 1). While 21 (81 percent) of these studies showed a favorable effect due to the intervention, only 10 (39 percent) were statistically significant. There were no studies addressing adverse events.

Table 8 Summary of the strength of evidence for weight-related outcomes in studies taking place in a school setting with a home component

Setting | Intervention, n | Years of Publication | Enrolled Participants | Studies With Low/Moderate/High Risk of Bias(n) | % With Favorable (Statistically Sig) Outcome | % With Favorable Outcome (Does Not Need to be Stat Sig) | Risk of Bias | Consistency | Precision | Directness | Strength of the Evidence
School-Home | D, 1 | 1986 | 1,321 | 0/1/0 | 100 | 100 | Moderate | NA | Precise | Direct | Insufficient
School-Home | PA, 3 | 1999-2010 | 1,654 | 1/2/0 | 100 | 100 | Moderate | Consistent | Precise | Direct | High
School-Home | C, 26 | 1991 -2012 | 25,438 | 2/20/4 | 39 | 81 | Moderate | Consistent | Precise | Direct | Moderate

D = diet intervention; PA = physical activity intervention; C = combination of diet and physical activity interventions

##### Intermediate Outcomes

The strength of the evidence is moderate that combined diet and physical activity interventions increase physical activity. However, the strength of the evidence is low that school/home based interventions reduce sedentary behavior, or change dietary intake (e.g., fruit and vegetable intake, energy intake, sugar-sweetened beverage intake, fatty food intake) (Appendix F, Strength of Evidence Tables 2-7).

### School-Home-Community–Based Studies

#### Study Characteristics

Out of nine studies, we identified four RCTs146-149 and five non-RCTs for this section.150-154 Those nine studies came from 10 articles, since researchers re-analyzed results from one study151 4 years later using multi-level analysis and reported the findings in the most recent reference.155 In six studies, the stated goal of the intervention was obesity prevention or weight maintenance,147,151-154,156 while the remainder did not state a goal for the interventions.146,148,150 One study took place in the U.S.,147 two in the Netherlands,148,150 two in Australia,151,152 one in Greece,146 one in Belgium,149 one in Canada,154 and the other in both Germany and Netherlands.153 Three studies did not specify inclusion criteria,146,151,153 while four set grade level as an inclusion criterion: two studies enrolled children from elementary and middle schools (grades 3 to 8).148,150 The former study required schools to have (1) a certified physical education teacher, (2) a majority of pupils with low socio-economic status, and (3) a gymnasium in the school or in the immediate vicinity.150 The latter study required participants to be able to comprehend the questionnaires and perform the fitness tests.147 One study enrolled 4 to 12 graders.154 Another study enrolled children from secondary school,152 while the last one included only children from pre-elementary school to first grade.149 Four studies also used age as an inclusion criteria, with two studies enrolling both young children and pre-adolescents (4-12 years old),148,151 one study enrolling only adolescents (12-18 years old),152 and one enrolled only young children (3-6 years old) (Table 9; Appendix E, Evidence Table 13).149

Table 9 Study and participant characteristics of studies based in schools with home and community components

Author, Year | RCT | Goal: Obesity Prevention | Country | Sex^*^ | Age Range, Years^*^ | Grade^*^ | Other^*^ | Total N | Followup in Weeks | % Girls^†^ | Mean Age [Range] Years^†^ | Grade^†^ | Race^†^
Angelopoulos, 2009^146^ | Y | N | Greece | NR | NR | NR | NR | 646 | 65-73 | 55.7 | 10.3 | 5 | NR
De Coen, 2012^149^ | Y | Y | Belgium | NR | 3-6 | Pre-primary-1 | NR | 3,241 | 104 | 50 | NR | NR | NR
de Meij, 2010^150^ | N | N | Netherlands | NR | NR | 3-8 | NR | 2,829 | 34-86 | 49.6 | 8.5 | NR | Mixed, Dutch, Moroccan, Turkish, Surinam
Greening, 2011^147^ | Y | Y | U.S. | NR | NR | NR | NR | 450 | 34 | 48 | 8.3 | NR | WNH, 40 % BNH, 60%
Jansen, 2011^148^ | Y | N | Netherlands | NR | 6-12 | 3-8 | NR | 2,622 | 39 | Grades 3-5, 50 Grades 6-8, 50 | Grades 3-5, 7.7 Grades 6-8, 10.8 | Grades 3-5, Arm 1: 52.7, Arm 2: 53; Grades 6-8, Arm 1: 47.3, Arm 2: 47 | Mixed, Dutch, Moroccan, Turkish, Surinam
Millar, 2011^152^ | N | Y | Australia | NR | 12-18 | Secondary school | NR | 2,054 | NR | 46.5 | 14.6 (1.42) | NR | NR
Naul, 2012^153^ | N | Y | Germany, Netherlands | NR | NR | NR | NR | 557 | 208 | NR | NR | NR | NR
Sanigorski, 2008^151^ | N | Y | Australia | NR | 4-12 | NR | NR | 1,807 | 104-156 | 51 | 8.3 | NR | NR
Tomlin, 2012^154^ | N | Y | Canada | NR | NR | 4-12 | NR | 148 | 28 | NR | NR | NR | NR

AIAN = American Indian/Alaska Native; API = Asian Pacific Islander; BMI = Body Mass Index (in kg/m^2^); BNH = Black Non-Hispanic; BP = Blood Pressure; CVD = Cardio Vascular Disease;, Maint = Maintenance; Meds = Medications; N = No; NR = Not Reported; physical activity = Physical Activity; RCT = Randomized Controlled Trials; WNH = White Non-Hispanic; Y = Yes

* Inclusion/exclusion criteria

† Participant characteristics

Note: Weight outcomes were reported based on Johnson, 2012^155^ for Sanigorski, 2008.^151^

#### Population Characteristics

The nine studies included 14,354 participants. The percentage of girls ranged from 48 to 55.7 percent across studies. The average age of the children was under 15 years in all studies. Seven studies did not report the grade level of children,147,149-154 one study included only children in grade 5,^146^ and the remaining study's enrollment was 53 percent elementary school (grades 3-5) and 47 percent from middle school (grades 6-8).148 Six studies did not report on race or ethnicity.146,149,151-154 Among those that reported on race or ethnicity, one U.S.-based study included roughly 40 percent non-Hispanic white and 60 percent non-Hispanic black students.147 The other two Dutch studies were also mixed-race studies, with one including roughly 15 percent Dutch; 31 percent Moroccan; and 55 percent Turkish, Surinam, and children of other races.150 The other one had a large proportion of Moroccan and Turkish participants (Table 9; Appendix E, Evidence Table 14).148

#### Interventions

All the nine studies include a home and community component like involving parents and the neighboring community in the prevention programs. No studies reported on diet interventions alone. Only one study reported on a physical activity intervention alone, and this had both an educational and physical/environmental component.150 Eight studies reported having both changes in diet and physical activity and/or other components,146-149,151-154 with two using an educational component for diet and an educational and physical/environmental component for physical activity,151,153 three studies using an educational and physical/environmental component for both diet and physical activity,146,148,152 two using an educational and physical/environmental component for diet and a physical/environmental component for physical activity147,149, and the other one using an educational component for diet and a physical/environmental component for physical activity (Table 10; Appendix E, Evidence Table 15).154

Table 10 Interventions of studies based in schools with home and community components

Author, Year | Control Arm | Description of Intervention | Diet (Phys/Env) | Diet (Psych) | Physical Activity (Phys/Env) | Physical Activity (Psych)
Angelopoulos, 2009^146^ | Usual care | A student workbook and teacher manual which covered themes related to self-esteem, body image, nutrition, physical activity, fitness and environmental issues. | X | X | X | X
De Coen, 2012^149^ | Usual care | Intervention based on the socio-ecological model in health promotion programs. Multi-topic intervention specifically based on 'Nutrition and physical Activity Health Targets' of the Flemish Community. | X | X | | X
de Meij, 2010^150^ | Usual care | Offering recurrent breaks for PA, relaxation and posture exercises, during regular lessons; structural and easily accessible school sports activities. Parental information services. | | | X | X
Greening, 2011^147^ | Usual care | Family and school-based informational events that alternated between nutrition and physical activities/contest. Health curriculum and intervention program | X | X | | X
Jansen, 2011^148^ | Usual care | Targets individual behaviors as well as school policies and curriculum. Parent Involvement. Local sports clubs were involved in providing some of the PE classes and PA activities outside of school hours. | X | | X | X
Millar, 2011^152^ | Usual care | It's Your Move Project: Use of social marketing to promote healthy eating, offering refillable water bottles at school and removing soda machines, labeled school food based on healthiness, provided recipe books . Promoted active transport to and from school, increased participation in organized sports or other recreation, and provided education sessions regarding sports. acceptance of healthy body size and shape | X | X | X | X
Naul, 2012^153^ | Usual care | Multi-component program involving physical activity, nutritional lessons, etc. Home involvement of family, parents, and home life | X | | X | X
Sanigorski, 2008^151^ | Usual care | Community capacity-building program promoting healthy eating, physical activity and healthy weight | X | X | X | X
Tomlin, 2012^154^ | baseline | Lessons on healthy eating and physical activity as well as extra physical activity sessions Promote family events | X | | | X

Psych = psychosocial intervention; Phys/Env = Physical/environmental intervention

#### Outcomes

##### Diet Interventions

None reported.

##### Physical Activity Interventions

One study used a physical activity intervention.150

###### Weight-Related Outcomes

###### BMI

The study found an nonsignificant difference between the intervention and control in BMI in favor of the control (beta=0.07 kg/m^2^, 95% CI: −0.02 to 0.16 kg/m^2^) (Appendix E, Evidence Table 16a).150

###### Waist Circumference

The study found a statistically nonsignificant difference between the intervention and control in waist circumference in favor of the control (beta=0.3 cm, 95% CI: −0.15 to 0.75 cm) (Appendix E, Evidence Table 16a).150

###### Clinical Outcomes

None reported.

###### Adverse Events

None reported.

###### Intermediate Outcomes

The study150 found a significant difference between the intervention and control in organized sports participation (OR=2.8, 95% CI 2.18 to 3.62) and positive but nonsignificant improvements for physical activity (beta=40 counts/min, 95% CI −27 to 106 counts/min) and shuttle run (beta=0.02 laps, 95% CI −0.26 to 0.29 laps) (Appendix E, Evidence Table 16b).

###### Interpretation

We can make no conclusions. One study reported a nonsignificant change in BMI in favor of the control.150 Based on the evidence, physical activity interventions did not significantly change weight outcomes over a period of 2 school years, as this study did not specifically target weight gain prevention but rather sports participation and aerobic fitness (which have improved significantly), thus it did not attempt to modify other risk factors for childhood obesity, such as energy intake.

##### Diet and Physical Activity Interventions

We identified eight studies on diet and physical activity interventions.146-149,151-154 Six of them reported on BMI and BMI z-score,148,149,151-154 among these two studies showed significant desirable effect.151,152

###### Weight-Related Outcomes

###### BMI z-Score

Five studies reported on BMI z-score.146,149,151,152,154 Two of them found a statistically significant difference between the intervention and control in BMI z-scores (p=0.04 or 0.03),151,152 while the other three found an nonsignificant difference between the intervention and control groups in favor of the intervention146,149,154 (Appendix E, Evidence Table 17a,b).

###### BMI

Six studies reported on BMI.146-148,151-153 Two studies found a significant difference between the intervention and control and were in favor of the intervention (p=0.03 or 0.06),151,152 while another one with a pre-post study design reported a significant rise in BMI in followup measures as compared to baseline (p<0.001).153 One reported by subgroups and found a positive but nonsignificant improvement in BMI for grades 3-5 (mean difference=0.10 kg/m2, 95% CI: -0.22 – 0.03 kg/m2), and almost no improvements for grades 6-8 (mean difference=0.03 kg/m2, 95% CI: -0.12-0.17 kg/m2)148 Another two studies found a positive but nonsignificant difference between the intervention and control in BMI (Appendix E, Evidence Table 17a,b).147,151

###### BMI Percentiles

One study reported on BMI percentiles and found a desirable but nonsignificant effect (Appendix E, Evidence Table 17a, b).147

###### Prevalence of Obesity or Overweight

Two studies reported on the prevalence of obesity or overweight.148,152 One study found a significant desirable difference between the intervention and control in the prevalence of overweight for grades 3-5 (OR=0.53, 95% CI: 0.36-0.78), but no improvements for grades 6-8 (OR=1.25, 95% CI: 0.79-1.99).148 The other one found an expected but nonsignificant difference between the intervention and control in the prevalence of obesity or overweight (p=0.12) (Appendix E, Evidence Table 17a,b).152

###### Percent Body Fat

Two studies reported on body fat percentage. One found a significant difference between the intervention and control in body fat percentage in favor of the intervention (p=0.02),147 and the other found a favorable but nonsignificant intervention effect (p=0.58)152 (Appendix E, Evidence Table 17a,b).

###### Waist Circumference

Three studies reported on waist circumference.147,148,151 One study reported by subgroups and found a significant difference between the intervention and control for grades 3-5 in favor of the intervention (difference in mean change=-1.29 cm, 95% CI: -2.16 – -0.42 cm), as well as an expected although nonsignificant difference between the intervention and control for grades 6-8 (difference in mean change=-0.71cm, 95% CI: -1.72 – 0.29 cm).148 One study147 found a favorable but nonsignificant difference between the intervention and control (p=0.92). The other study found a statistically significant difference between the intervention and control in favor of the intervention (p<0.05) (Appendix E, Evidence Table 17a,b).151

###### Weight

Three studies reported on body weight.151,152,157 Two studies151,152 found a significant desirable intervention effect (p=0.03 or 0.04), while the other found a favorable but nonsignificant difference between the intervention and control groups (p=0.124)146 (Appendix E, Evidence Table 17a,b).

###### Weight/Height Ratio

One study reported weight/height ratio and found a significant intervention effect (p=0.01) (Appendix E, Evidence Table 17a, b).151

###### Clinical Outcomes

Two studies reported on change in clinical outcomes,146,154 One study found a significant difference between the intervention and control in systolic and diastolic blood pressures in favor of the intervention (p=0.016 for systolic and p=0.005 for diastolic blood pressure).146 The other study with a pre-post study design found an increase in systolic blood pressure z-scores (p=0.076) and a decrease in diastolic blood pressure z-scores (p=0.267), but both were nonsignificant (Appendix E, Evidence Table 17c).154

###### Adverse Events

A single study reported on potential adverse events.151 The study examined a number of safety measures and concluded that the intervention did not increase the proportion of children participating in behaviors that would put them at increased risk of eating disorders (p-value not reported). Specifically, the intervention did not increase the prevalence of thinness/underweight (intervention: 3.1 percent at baseline to 3.6 percent at followup, comparison: 2.2–2.4 percent, not significant) (Appendix E, Evidence Table 17d).151

###### Intermediate Outcomes

###### Physical Activity and Sedentary Behavior

Seven studies reported on changes in physical activity.149-152,154 Two studies reported on a combination of diet, physical activity, and self-management and found a significant desirable effect on physical activity levels (p=0.04 or 0.041).146,147

Three studies reported on a combination of diet and physical activity and found an undesirable intervention effect; one study was statistically significant (p=0.01)152 and the other two were not (p=0.555 or not reported).149,154 Two studies reported a favorable but nonsignificant intervention effect (p-value not reported).150,151

Three studies reported on a combination of diet and physical activity reported on changes in sedentary behavior.149,151,152 One study found an unexpected but significant intervention effect (p=0.001),152 one found a desirable intervention effect with unknown significance,151 while the other one found no difference in change in sedentary behavior between the intervention and control groups (Appendix E, Evidence Table 17e).149

###### Dietary Intake

We identified nine studies that examined dietary intake. One study reported on change in calorie intake, which showed no significant desirable effect. Five studies reported on change in fruit and vegetable intake. One of these, which intervened on a combination of diet, physical activity and self-management, showed significant desirable effect. Three studies reported on change in fatty food intake. Of these, two that intervened on a combination of diet, physical activity and self-management showed significant desirable effect. Five studies reported on change in sugar-sweetened beverage intake, and one of them showed significant desirable effect, which intervened on a combination of diet, physical activity and self-management. Seven studies reported on change in physical activity levels, and two of them showed significant desirable effect, which both intervened on a combination of diet, physical activity and self-management. Three studies reported on change in sugar-sweetened beverage intake, and none showed significant desirable effect.

Only one study, examining a combination of diet and physical activity, reported on change in calorie intake and found a nonsignificant difference in calorie intake between the intervention and control in favor of the intervention (p=0.159).154

Five studies reported on change in fruit and vegetable intake.146,149,151,152,154 Four studies found a favorable intervention effect,146,149,151,154 however, in three of the studies examining a combination of diet and physical activity, the findings were either nonsignificant or the studies did not report on significance.149,151,154 Only one study, examining a combination of diet, physical activity, and self-management, showed significant desirable effect (p=0.044).146 The last study reported on a combination of diet and physical activity and found an undesirable intervention effect in fruit and vegetable intake (p=0.14).152

Three studies reported on change in fatty foods intake. Two studies reported on a combination of diet, physical activity, and self-management and found a significant desirable effect (p=0.0005 or 0.028).146,147 The other study reported on a combination of diet and physical activity and found an nonsignificant difference in fatty foods intake between the intervention and control in favor of the intervention (p=0.054).154

Five studies reported on change in sugar-sweetened beverage intake.146,149,151,152,154 One study reported on a combination of diet, physical activity, and self-management and found a significant desirable effect on sugar-sweetened beverage intake (p=0.039).146 Three studies reported on a combination of diet and physical activity and found an undesirable intervention effect,149,152,154 while the other study reported on a combination of diet and physical activity and found a favorable intervention effect in sugar-sweetened beverage intake,151 however, it did not report the p-value.

###### Interpretation

The results from an outcome measure from each of the eight studies reporting on combined diet and physical activity interventions support our conclusions. Five studies reported on BMI z-score.146,149,151,152,154 All reported changes in BMI z-score in favor of the intervention. Two studies were significant,151,152 and the remaining three reported an nonsignificant change.146,149,154 Three studies reported on BMI.147,148,153 One reported an nonsignificant change in BMI in favor of the intervention.147 One reported an nonsignificant change in BMI in favor of the intervention for grades 3-5, but almost no improvements for grades 6-8^148^. Another pre-post study found a significant rise in BMI in followup measures as compared to baseline disfavor of the intervention.153 Based on this evidence, we conclude that studies on combined diet and physical activity interventions in a school, home, and community setting generally showed positive but nonsignificant improvements in weight outcomes over a period of at least 6 months because the majority of these studies specifically targeted weight gain prevention; all included both dietary and physical activity components focusing both on education and making structural changes to promote diet and physical activity. One reason for the nonsignificant effect of some of the interventions on weight outcomes might be that that the interventions did not specifically target weight gain prevention, or the sample size was too small to detect a significant effect.

#### Strength of the Evidence

##### Weight-Related Outcomes

The strength of evidence is insufficient that school-home-community based interventions that only attempt to change physical activity can prevent obesity or overweight in children, as there was only one study with moderate risk of bias. The strength of evidence is high that interventions which use a combination of interventions (e.g., diet, physical activity, and/or self-management) can prevent obesity or overweight in children, as both a study with low risk of bias and the majority of studies with moderate risk of bias showed a favorable effect (Table 11; Appendix F, Strength of Evidence Table 1).

Table 11 Summary of the strength of evidence for weight-related outcomes in studies taking place in schools with a home and community component

Setting | Intervention, n | Years of Publication | Enrolled Participants | Studies With Low/Moderate/High Risk of Bias(n) | % With Favorable (Statistically Sig) Outcome | % With Favorable Outcome (Does Not Need to be Stat Sig) | Risk of Bias | Consistency | Precision | Directness | Strength of the Evidence
School-Home-Community | PA,1 | 2010 | 2,829 | 0/1/0 | 0 | 0 | Moderate | NA | Precise | Direct | Insufficient
School-Home-Community | C,8 | 2008-2012 | 11,525 | 1/4/3 | 12.5 | 81 | Moderate | Consistent | Imprecise | Direct | High

##### Intermediate Outcomes

There was insufficient evidence to grade calorie or fatty foods intake in interventions that included a combination of diet and physical activity approaches in a school-home-community setting, as there was only one study with moderate risk of bias. The strength of evidence is low to grade changes in sugar-sweetened beverage intake, physical activity levels, or sedentary behaviors for interventions trying to impact both diet and physical activity, as there were a few studies with low or moderate risk of bias and they showed conflicting results. The strength of evidence is moderate that diet and physical activity approaches impact fruit and vegetable intake in a school-home-community setting, as both a study with low risk of bias and another study with moderate risk of bias showed a favorable effect (and there were no low or moderate risk of bias studies going in the other direction).

The strength of evidence is insufficient that interventions which included diet, physical activity, and self-management impact fruit and vegetable intake or sugar-sweetened beverage intake in a school-home-community setting, as there was only one study with moderate risk of bias in this category. The strength of evidence is moderate that interventions which included diet, physical activity, and self-management impact fatty foods intake or physical activity levels in a school-home-community setting, as there were only two studies with a moderate risk of bias that both reported a favorable intervention effect (Appendix F, Strength of Evidence Tables 2-7).

### School-Community–Based Studies

#### Study Characteristics

We included six school/community-based studies including three RCTs158-160 and three non-RCTs (Table 12; Appendix E, Evidence Table 18).161-163 The stated goal in four studies was obesity prevention or weight maintenance.158,160,161,163 Three studies took place in the U.S.,159,160,162 one in Germany,158 one in Canada,161 and the other one in New Zealand.163 Two studies did not list any inclusion criteria.161,162 One included only English-speaking girls from one public middle school (grade 6).159 One included kindergarten to Grade 2 Latinos.160 One included only children aged 9 to 13 years.163 The other study included children (grades 2 to 3) from elementary schools in socially deprived neighborhoods of two cities in Germany (Table 12; Appendix E, Evidence Table 18).158

Table 12 Study and participant characteristics of studies based in schools with a community component

Author, Year | RCT | Goal: Obesity Prevention | Country | Sex^*^ | Age Range, Years^*^ | Grade^*^ | Other^*^ | Total N | Followup in Weeks | % Girls^†^ | Mean Age [Range] Years^†^ | Grade^†^ | Race^†^
Crespo, 2012^160^ | Y | Y | U.S. | NR | NR | K-2 | Latino | 820 | 156 | NR | NR | NR | NR
Macaulay, 1997^161^ | N | Y | Canada | NR | NR | NR | NR | 537 | 156 | NR | [6-11] | 1-6 | NR
Madsen, 2009^162^ | N | N | U.S. | NR | NR | NR | NR | 178 | 34 | 48 | 9.8 (7.9-12.2) | 3-5 | Mixed, White, Black, Latino/Hispanic, Asian/Pacific Islander, Other/unknown
Muckelbauer, 2009^158^ | Y | Y | Germany | NR | NR | 2-3 | NR | 2,950 | 47 | 49.8 | Arm 1: 8.3 Arm 2: 8.3 | 2-3 | NR
Utter,2011^163^ | N | Y | New Zealand | NR | 9-13 | NR | NR | 3,881 | 104 | 51.6 | NR | NR | Mixed, Asian/Pacific Islander, Pacific, Maori, European
Webber, 2008^159^ | Y | NR | U.S. | Girls | NR | 6 | NR | 1,721 | 156 | 100 | NR | 6 | WNH: 46.1%; BNH: 23.5%; Latino/Hispanic: 12.3%; Multi-ethnic, or missing: 18.0%

BNH = Black non-Hispanic; N = no; NR = not reported; RCT = randomized controlled trials; WNH=White non-Hispanic; Y = yes

* Inclusion/exclusion criteria.

† Participant characteristics.

#### Population Characteristics

The six studies enrolled 10,087 children. Two studies did not report the distribution of gender,160,161 one included only girls,159 and the other three studies included 48.0 to 51.6 percent girls.158,162,163 Two studies did not report age,160,163 one study did not report age but included only children from grade 6,^159^ the remaining three studies enrolled children from elementary school.158,161,162 Only one study reported on race or ethnicity, and included 46 percent white children, 24 percent black children, 12 percent Hispanic children, and 18 percent children of other races or with unknown race,159 another two studies also included a sample of mixed races/ethnicities (Table 12; Appendix E, Evidence Table 19).162,163

#### Interventions

Out of six studies, one reported on diet, one on physical activity, and the remaining four reported on a combination of diet and physical activity. One study reported on a diet intervention158 that included both educational and physical/environmental components to alter diet. Two studies reported on both diet and physical activity components and used both an educational and physical/environmental approach.161,163 One intervention attempted to modify diet from both a psychosocial and physical/environmental approach, and attempted to modify physical activity from a psychosocial approach.162 Another study included three active arms, with each arm attempting to modify both diet and physical activity: one used a psychosocial approach, another used a physical/environmental approach, and the final arm used both approaches.160 Another study included physical activity (both educational and physical/environmental) interventions and self-management (Table 13; Appendix E, Evidence Table 20).159

Table 13 Interventions of studies based in schools with a community component

Author, Year | Control Arm | Description of Intervention | Diet (Phys/Env) | Diet (Psych) | Physical Activity (Phys/Env) | Physical Activity (Psych)
Crespo, 2012^160^ | Usual care | Intervention delivered by a community health advisor through home visit focused on increasing fruit, vegetable, and water consumption, increasing active play and decreasing sugar-sweetened beverages and TV viewing | X | | X
Crespo, 2012^160^ | Usual care | Implementation and improvement of cafeteria salad bars. School playground improvement Improvement of community park Health Informatics: | | X | | X
Crespo, 2012^160^ | Usual care | Intervention delivered by a community health advisor through home visit focused on increasing fruit, vegetable, and water consumption. School playground improvement . Improvement of community park. | X | X | X | X
Macaulay, 19 97^161^ | Usual care | Storytelling, games, food tasting, experiments, puppet shows, crafts, and audiovisual presentations to promote healthy eating. Emphasizes the benefits and pleasure of daily physical activity and the different types of activity: aerobic, strength building, and flexibility | X | | X
Madsen, 2009^162^ | Usual care | Play soccer three days a week Literacy improvement: participants perform community service or undertake creative writing the remaining two days a week. | | | X
Muckelbauer, 2009^158^ | Usual care | Combined environmental and educational intervention solely promoting water consumption | X | X

Psych = psychosocial intervention; Phys/Env = Physical/environmental intervention

#### Outcomes

##### Diet Intervention

Two articles (representing one study) investigated the impact of diet interventions on childhood obesity prevention.158,164

###### Weight-Related Outcomes

###### BMI

The study significantly lowered BMI in the intervention group versus in the control group after intervention (p=0.037). There was no significant difference before intervention (Appendix E, Evidence Table 21a).158

###### Prevalence of Obesity or Overweight

A primary study found significant improvements in the intervention group versus in the control group, as the incidence rate for obesity was significantly lower in the intervention group (p=0.018). The remission rate (previously overweight or obese to normal weight) for obesity or overweight was also higher in the intervention group but did not reach statistical significance (p=0.485 or 0.251) (Appendix E, Evidence Table 21a).158

Stratified results in another study, based on immigration backgrounds,164 found significant improvements in the incidence of overweight (p=0.006) and positive but nonsignificant improvements in the remission rate (p=0.11) in the non-immigrant group immigrants; and positive but nonsignificant improvements in the incidence rate of overweight (p=0.99) and no improvements in the remission rate (p=0.23) in the immigrant group.

###### Clinical Outcomes

None reported.

###### Adverse Events

None reported.

###### Intermediate Outcomes

###### Dietary Intake

The study found significant improvements in water and soft drinks/juices consumption post intervention (p<0.001 and p=0.019) in the intervention but not in the control (p= 0.576 and p = 0.670).158

Another study reported on immigrant and non-immigrant subgroups.164 Water consumption had improved significantly in both subgroups, with positive but nonsignificant improvements in juice consumption and no improvements in soft drinks consumption in both subgroups (Appendix E, Evidence Table 21b).

###### Interpretation

The results of the outcomes measures in one study reporting the effect of diet intervention on BMI and prevalence of overweight and obesity support our conclusions. The one study reported on a statistically significant change in BMI in favor of the intervention.158 Based on the evidence, we conclude that this diet intervention showed significant improvements in BMI and prevalence of overweight and obesity over a period of 47 weeks because it specifically targeted weight gain prevention and the sample size was as big as 2,950.

##### Physical Activity Intervention

###### Weight-Related Outcomes

###### BMI

A single study reported no improvements for BMI (p-value not reported) (Appendix E, Evidence Table 22a).159

###### Percent Body Fat

One study reported no improvements for percent body fat (p-value not reported) (Appendix E, Evidence Table 22a).159

###### Skinfold Thickness

A study found positive but nonsignificant improvements for triceps skinfold thickness (p-value not reported) (Appendix E, Evidence Table 22a).159

###### Weight

This study found positive but nonsignificant improvements for body weight (p-value not reported) (Appendix E, Evidence Table 22a).159

###### Clinical Outcomes

None reported.

###### Adverse Events

None reported.

###### Intermediate Outcomes

###### Physical Activity and Sedentary Behavior

This study measured physical activity using multiple scales. Change in minutes of moderate to vigorous physical activity, and change in minutes of total physical activity were positive but nonsignificant. Change in sedentary behavior was also positive but nonsignificant (p-value not reported) (Appendix E, Evidence Table 22b).159

###### Interpretation

We can make no conclusions regarding the effect of a physical activity intervention on BSI. The one study reported no change in BMI.159 Based on the evidence, this physical activity intervention among girls showed no improvements in weight outcomes over a period of 3 years because it did not specifically target weight gain prevention, and the effect may have faded over 3 years.

##### Diet and Physical Activity Intervention

We identified four studies.160-163

###### Weight-Related Outcomes

###### BMI z-Score

Three studies measured the impact of diet and physical activity interventions on BMI z-scores.160,162,163 The intervention was effective in reducing BMI z-scores in two studies but both were nonsignificant,160,162 another pre-post study reported nonsignificant increase in followup compared to baseline (p=0.13) (Appendix E, Evidence Table 23a,b).163

###### BMI

Three studies in this setting measured the impact of diet and physical activity interventions on BMI.161-163 The intervention was effective in reducing BMI in two studies,161,162 with one reporting significant improvements (p<0.01).161 Another pre-post study reported nonsignificant increase in followup compared to baseline (p=0.18) (Appendix E, Evidence Table 23a,b).163

###### Prevalence of Overweight and Obesity

Once study reported on prevalence of obesity and found that it declined from 33 percent at baseline to 27 percent at followup (p = 0.103) (Appendix E, Evidence Table 23a,b).162

###### Percent Body Fat

Once study reported on percent body fat and found a nonsignificant difference between the intervention and control in favor of the control (p = 0.16) (Appendix E, Evidence Table 23a,b).163

###### Skinfold Thickness

One study reported on triceps skinfold thickness and sub-scapular skinfold thickness and found a significant desirable effect in favor of the intervention (p-value not reported) (Appendix E, Evidence Table 23a,b).161

###### Weight

One study reported on weight and found a nonsignificant difference between the intervention and control in favor of the control (p = 0.21) (Appendix E, Evidence Table 23a,b).163

###### Clinical Outcomes

None reported.

###### Adverse Events

None reported.

###### Intermediate Outcomes

###### Physical Activity and Sedentary Behavior

Two studies reported on changes in physical activity levels, with one reporting a desirable but nonsignificant intervention effect (p=0.61),160 and the other finding no effect (p=0.65).163 Two studies reported on sedentary behavior, both found a desirable but nonsignificant effect (p=0.58 and p=0.09) (Appendix E, Evidence Table 23c).160,163

###### Dietary Intake

One study reported on changes in fruit and vegetable intake and showed a favorable but nonsignificant intervention effect (p=0.75).160 One study reported on changes in sugar-sweetened beverage intake and found a favorable but nonsignificant effect (p=0.42) (Appendix E, Evidence Table 23c).163

###### Interpretation

The results from an outcome measure from each of the four studies support that combined diet physical activity interventions generally showed positive but nonsignificant improvements in weight outcomes over a period of at least 6 months because the sample size was usually too small (e.g. 178 participants in one study).. Three studies reported on BMI z-scores.160,162,163 Two studies reported changes in BMI z-score in favor of the intervention and both were nonsignificant.160,162 One pre-post study reported changes in BMI z-score from baseline to followup disfavor of the intervention.163 One study reported on BMI and reported a significant change in favor of the intervention.161

#### Strength of the Evidence

##### Weight-Related Outcomes

The strength of evidence is insufficient that a solely diet or physical activity approach can impact weight outcomes in a school and community setting as only one study addressed each. The strength of evidence is moderate that combined diet and physical activity approaches prevent overweight or obesity in a school and community setting, as the two studies with moderate risk of bias showed a favorable effect and there was no other low risk of bias studies in the opposite direction. Three of these four studies showed a desirable intervention effect, while only one of them was statistically significant (Table 14; Appendix F, Strength of Evidence Table 1).

Table 14 Summary of the strength of evidence for weight-related outcomes in studies taking place in schools with a community component

Setting | Intervention, n | Years of Publication | Enrolled Participants | Studies with Low/Moderate/High Risk of Bias(n) | % With Favorable (Statistically Sig) Outcome | % With Favorable Outcome (Does Not Need to be Stat Sig) | Risk of Bias | Consistency | Precision | Directness | Strength of the Evidence
School-Community | D,1 | 2009 | 2,950 | 0/1/0 | 100 | 100 | Moderate | NA | Precise | Direct | Insufficient
School-Community | PA,1 | 2008 | 1,721 | 0/0/1 | 0 | 0 | High | NA | Imprecise | Direct | Insufficient
School-Community | C,4 | 1997-2012 | 3,017 | 0/2/2 | 25 | 75 | Moderate | Consistent | Imprecise | Direct | Moderate

D = diet intervention; PA = physical activity intervention; C = combination of diet and physical activity interventions

##### Intermediate Outcomes

The strength of evidence is insufficient that diet and physical activity approaches impact fruit and vegetable intake or sugar-sweetened beverage intake in a community/school-based setting as there was only one study in this category. The strength of evidence is low that diet and physical activity approaches impact physical activity or sedentary behaviors in a community/school-based setting as there was only one study with moderate risk of bias that reported a favorable effect and the other one was a study with high risk of bias. The strength of evidence is low that interventions which included physical activity and self-management impact BMI in a community/school-based setting as there were only two studies with high risk of bias that reported a desirable effect (Appendix F, Strength of Evidence Tables 4-7).

### School-Consumer Health Informatics–Based Studies

#### Study Characteristics

We included four studies.165-168 One study used a quasi-experimental design165 and the other studies were RCTs.166-168 Two of the studies stated weight maintenance as the goal of the interventions and took place in the Netherlands.167,168 One study took place in the U.S.166 Three of the four studies listed grade level as inclusion criteria. One study included participants in grades 4 and 5,^166^ another study included participants in grades 10 and 11,^165^ and a third study included participants in the first year of secondary school (Table 15, Appendix E, Evidence Table 24).167

Table 15 Study and participant characteristics of studies based in schools with a consumer health informatics component

Author, Year | RCT | Goal: Obesity Prevention | Country | Sex^*^ | Age Range, Years^*^ | Grade^*^ | Other^*^ | Total N | Followup in Weeks | % Girls^†^ | Mean Age [Range] Years^†^ | Grade^†^ | Race^†^
Schneider, 2007^165^ | N | N | NR | NR | NR | 10-11 | | 122 | 30 | 100 | 15.04 | NR | WNH: 57% Latino/Hispanic: 20% API: 17%
Spiegel, 2006^166^ | Y | N | U.S. | NR | NR | 4-5 | | 1,013 | 34 | NR | NR | 4-5 | NR
Prins, 2012^167^ | Y | Y | Netherlands | NR | 12-13 | First year of secondary school | Attend participating school in the Rotterdam Area | 1,213 | 26 | Arm1: 46.6 Arm2: 47.2 Arm3: 49 | Arm1: 12.6(0.4) Arm2: 12.7(0.5) Arm3: 12.7(0.5) | NR | Western Overall:(82.3) Arm1:(74.8) Arm2:(77.9) Non-Western (Overall:(17.7) Arm1:(25.2) Arm2:(22.1)
Ezendam, 2012^168^ | Y | Y | Netherlands | NR | 12-13 | NR | Secondary school; Participants in 1-5 first year classes | 883 | 114 | Arm1: 50.3 Arm2: 41.1 | Arm1: 12.6(0.6) Arm2: 12.7(0.7) | NR | Western Arm1:314(78.9) Arm2:320(66.0) Non-WesternArm1:84(21.1) Arm2:165(34.0)

API = Asian Pacific Islander; N = no; NR = not reported; RCT = randomized controlled trials; WNH = White non-Hispanic; Y = yes

* Inclusion/exclusion criteria.

† Participant characteristics.

#### Population Characteristics

The number of participants in the four included studies was 3,231 children.165-168 In the four studies the total followup period reported for participants ranged between 26 to 114 weeks. Three studies reported mean age165,167,168 and it ranged between 12.6 to 15.04 years. One study included only girls165 and the percent girl participants ranged from 41.1 percent to 50.3 percent in two other studies.167,168 All children in one study were in grades 4 and 5^166^ while participants in another study were in grades 10 and 11.^165^ In one study, 57 percent of participants were white, 20 percent were Latino/Hispanic, and 17 percent were Asian/Pacific Islander. In another study167 82.3 percent of participants were classified as Western and 17.7 percent of participants as Non-Western. In a third study reporting race, 66 to 78.9 percent of participants were Western and 21.1 to 34 percent of participants were Non-Western (Table 15, Appendix E, Evidence Table 25).168

#### Interventions

Two studies reported on physical activity interventions.165,167 One study described an intervention consisting of supervised in-class activity, health education, and Internet-based self-monitoring components.165This intervention lasted 30 weeks and aimed to increase levels of physical activity. Participants received 60-minute long educational discussions once a week related to the health benefits of exercise and strategies for adopting an active lifestyle. Student input influenced activity choices, which included a variety of aerobic and strength-building activities. Participants reported physical activity via Internet-based self-monitoring. Another study167reported on a 3-week web-based intervention that promoted physical activity among participants. Individuals in both intervention arms received school-based online lessons focused on improving physical activity and goal setting. Additionally, participants randomized to the YouRaction+e arm received computer-assisted feedback on the availability of physical activity facilities in their residential neighborhoods (Table 16, Appendix E, and Evidence Table 26).165,167

Table 16 Interventions of studies based in schools with a consumer health informatics component

Author, Year | Control Arm | Description of Intervention | Diet (Phys/Env) | Diet (Psych) | Physical Activity (Phys/Env) | Physical Activity (Psych)
Ezendam, 2012^168^ | Usual care | Web-based computer lessons conducted by teacher with a health informatics computer-tailored intervention | X | | X
Prins, 2012^167^ | Usual care | School based online lessons Web-based computer tailored physical activity promotion intervention | | | X
Prins, 2012^167^ | Usual care | School based online lessons plus feedback on nearby physical activity facilities Web-based computer tailored PA promotion intervention | | | X
Schneider, 2007^165^ | Usual care | Increase students' levels of physical activity through supervised in-class activity, health education, and Internet-based self-monitoring | | | X | X

Psych = psychosocial intervention; Phys/Env = physical/environmental intervention

Two studies reported on diet and physical activity interventions.166,168 One study166 randomized participants to attend the multidisciplinary Wellness, Academics and You program for 1 school year. The intervention consisted of a five-module program intended to develop their health attitudes and behavior addressing nutrition, physical activity, and self-management. The intervention group participated in a variety of activities integrated into their core curriculum. Activity duration ranged from 20 minutes to more than 1 hour. Another study168 reported on a 10-week Web-based intervention that aimed to promote healthy diet, increase physical activity, and reduce sedentary behavior. Participants also received lessons focused on weight management, goal setting, and behavioral feedback (Table 16, Appendix E, and Evidence Table 26).166,168

#### Outcomes

##### Diet Interventions

None reported.

##### Physical Activity Intervention

Two studies evaluated the effect of a physical activity intervention on weight outcomes.165,167 One quasi-experimental study included only adolescent girls 165 and the other study167 randomized adolescents to a control or one of two intervention groups.

###### Weight-Related Outcomes

###### BMI Percentile

One study reported a small increase in BMI over time in the intervention group, compared to the control group. (Appendix E, Evidence Table 27).165

###### Prevalence of Overweight and Obesity

One study reported no statistically significant difference between either intervention group and control in percent overweight or obese (Evidence Table 27).167

###### Percent Body Fat

One study reported no difference between the intervention and control in percent body fat over time. (Appendix E, Evidence Table 27)165

###### Waist Circumference

One study reported no statistically significant difference between either intervention group and control in waist circumference (Evidence Table 27).167

###### Clinical Outcomes

One study measured peak oxygen consumption and VO2 peak (L/min).165 Peak oxygen consumption increased in the intervention group; this was a significant difference between the intervention and control (p=0.001). VO2 peak increased in the intervention group with a p-value of 0.02. (Appendix E, Evidence Table 27).

###### Adverse Events

None reported.

###### Intermediate Outcomes

###### Physical Activity and Sedentary Behavior

In one study,167 there was no statistically significant difference between either intervention group and control in minutes of moderate-to-vigorous physical activity or compliance with moderate-to-vigorous physical activity guidelines (Evidence Table 27).167

###### Interpretation

The results from an outcome measure from each of the two studies reporting on physical activity interventions support our conclusions--none of the school with consumer health informatics physical activity interventions showed a significant beneficial effect on weight outcomes. One study reported on BMI percentiles and reported a small nonsignificant change in favor of the intervention.169 The other study reported no statistically significant change in prevalence of overweight or obesity.167 Based on this evidence we cannot determine if physical activity interventions impact BMI percentiles or prevalence of overweight and obesity.

These studies may be limited by exclusion of concurrent nutrition education and short followup. Additional factors that may have limited the realization of an intervention effect in one of the studies165 include use of a non-randomized study design.

##### Diet and Physical Activity Interventions

Two studies evaluated the effect of a diet and physical activity intervention on weight outcomes.166,168 One study randomly assigned 1,013 students in grade 4 and 5 from 69 classes in four states to intervention or control groups.166 Another study randomized 883 adolescents to an intervention or control group.168

###### Weight-Related Outcomes

###### BMI

In one study,166 there was a significant difference between the intervention and control in BMI. The shift in BMI from baseline to after intervention was significant (Pearson correlation coefficient = -0.186, p =0.01 level) In a second study168, there was no intervention effect on BMI at followup (Appendix E, Evidence Table 28a,b).166,168

One study168 reported no intervention effect on BMI among subgroups of overweight or obese children (Appendix E, Evidence Table 28a,b).

###### Prevalence of Overweight and Obesity

One study166 reported a notable decrease in the intervention group in the prevalence of obesity, and the decrease was most significant for overweight participants. The study did not statistically analyze this difference in change of the prevalence. In a second study168 there was no intervention effect on the prevalence (Appendix E, Evidence Table 28a,b).166,168

One study168 reported no intervention effect on prevalence of overweight or obese among subgroups of overweight or obese children (Appendix E, Evidence Table 28a,b).

###### Waist Circumference

One study168 reported no intervention effect on waist circumference among overweight or obese children (Appendix E, Evidence Table 28a,b).168

###### Clinical Outcome

None reported.

###### Adverse Events

None reported.

###### Intermediate Outcomes

###### Physical Activity and Sedentary Activity

Two studies addressed change in physical activity. One reported a change in favor of the intervention, but the change was not significant.168 The other reported a change in favor of the control, but this change was not significant.166 A third study reported on change in sedentary behavior by measuring changes in screen time (TV, video games). This study reported a change in favor of the intervention but reported no significance values (Appendix E, Evidence Table 28c).168

###### Dietary Intake

In one study, the combined diet and physical activity intervention compared to the control group resulted in higher fruit and vegetable consumption and increased physical activity.166The study did not statistically analyze this difference in change in physical activity and fruit and vegetable intake. In another study,168 compared to the control, the intervention group had lower self-reported snack consumption, were less likely to report drinking more than 400ml of sugar-sweetened beverages per day, and reported more vegetable consumption. While these between-group differences in dietary outcomes were observed at 4-month followup, they were not sustained at the 2-year followup. In this same study there was no significant intervention effect on physical activity (Appendix E, Evidence Table 28c).166,168

###### Interpretation

The results from outcome measures from two studies reporting on combined diet and physical activity interventions support our conclusions-- we cannot determine if combined diet and physical activity interventions impact BMI . These two studies reported on BMI.166,168 One showed a significant change in favor of the intervention,166 and the other showed no intervention effect.168

#### Strength of the Evidence

##### Weight-Related Outcomes

The strength of evidence is insufficient that school with consumer health informatics physical activity interventions prevent obesity or overweight in children. We graded this body as insufficient because it lacked precision and included studies with moderate risk of bias. The strength of evidence is insufficient that combination diet and physical activity interventions prevent obesity or overweight in children. We graded this body as insufficient because it lacked precision and included studies with moderate risk of bias (Table 17, Appendix F, Strength of Evidence Table 1).

Table 17 Summary of the strength of evidence for weight-related outcomes in studies taking place in a school setting with a consumer health informatics component

Setting | Intervention, n | Years of Publication | Enrolled Participants | Studies With Low/Moderate/High Risk of Bias(n) | % With Favorable (Statistically Sig) Outcome | % With Favorable Outcome (Does Not Need to be Stat Sig) | Risk of Bias | Consistency | Precision | Directness | Strength of the Evidence
School-CHI | PA,2 | 2007-2012 | 1,335 | 0/2/0 | 0 | 0 | Moderate | Inconsistent | Imprecise | Direct | Insufficient
School-CHI | C, 2 | 2006-2012 | 1,896 | 0/2/0 | 50 | 50 | Moderate | Inconsistent | Imprecise | Direct | Insufficient

PA = physical activity intervention; C = combination of diet and physical activity interventions; CHI = consumer health informatics; sig = significant

##### Intermediate Outcomes

The strength of evidence is insufficient that school-based physical activity interventions with consumer health informatics change physical activity. The strength of evidence is insufficient that combined diet and physical activity interventions impact changes in sedentary behavior or fruit and vegetable intake. One study each reported on these intermediate outcomes and neither presented precision (Appendix F, Strength of Evidence Tables 4-6).

The strength of the evidence that diet and physical activity interventions impact change in physical activity and change in fruit and vegetable intake is insufficient. Two moderate risk of bias studies with inconsistent results reported on these outcomes and did not report precision (Appendix F).

### School-Home-Consumer Health Informatics–Based Studies

#### Study Characteristics

We included only one non-RCT.170 The goal of the intervention in this study was weight maintenance and the study took place in England. Primary schools were the only inclusion criteria (Table 18; Evidence Table 24).170

Table 18 Study and participant characteristics of studies based in schools with a home and consumer health informatics component

Author, Year | RCT | Goal: Obesity Prevention | Country | Sex^*^ | Age Range, Years^*^ | Grade^*^ | Other^*^ | Total N | Followup in Weeks | % Girls^†^ | Mean Age [Range] Years^†^ | Grade^†^ | Race^†^
Gorely, 2011^170^ | N | Y | England | NR | NR | | Primary School | 589 | 120 | NR | Arm 1: 8.86 Arm 2: 8.76 | NR | NR

N = no; NR = not reported; RCT = randomized controlled trials; Y = yes

* inclusion/exclusion criteria.

† participant characteristics.

#### Population Characteristics

One study included 589 participants followed them over a period of 120 weeks.170 The mean age for the control group was 8.86 years and for the control group 8.76 years. The study enrolled 94.8 to 96.5 percent white participants and did not report the percentage of girls or the grade level (Table 18; Evidence Table 25).170

#### Interventions

One study reported on a 40-week diet and physical activity intervention.170 This intervention promoted physical activity through the provision of physical education lessons, and target activities (1 mile run/walk). Additionally, participants received CD-rom based learning exercises on healthy eating and physical activity and along with their families were able to access an interactive website reinforcing key messages of the intervention (Table 19; Evidence Table 26).170

Table 19 Interventions of studies based in schools with a home and consumer health informatics component

Author, Year | Control Arm | Description of Intervention | Diet (Phys/Env) | Diet (Psych) | Physical Activity (Phys/Env) | Physical Activity (Psych)
Gorely, 2011^170^ | Usual care | GreatFun2Run: Classroom and physical education sessions Interactive website for parents and children Local media campaign to promote healthy nutrition and Physical activity. | X | | X | X

Psych = psychosocial intervention; Phys/Env = physical/environmental intervention

#### Outcomes

##### Diet Interventions

None reported.

##### Physical Activity Interventions

None reported.

##### Diet and Physical Activity Interventions

One study evaluated the effect of a diet and physical activity intervention on weight outcomes.170 The study non-randomly assigned 589 students to an intervention or matched control group.170

###### Weight-Related Outcomes

###### BMI

There was no significant difference in BMI between the intervention and control groups (Appendix F, Evidence Table 28a).170

###### Percent Body Fat

Among participants in the intervention group, there was a significant increase in percent body fat compared to the control (Appendix F, Evidence Table 28a,b).170

###### Waist Circumference

There was no significant difference in BMI between the intervention and control groups (Appendix F, Evidence Table 28a,b).170

###### Clinical Outcome

None reported.

###### Adverse Events

None reported.

###### Intermediate Outcome

There was no significant difference between the intervention group and control in minutes per day of moderate-to-vigorous physical activity (Appendix F, Evidence Table 28c).170

###### Interpretation

We can make no conclusions. This study showed no intervention effect of combined diet and physical activity.170 Based on this evidence we cannot determine if combined diet physical activity interventions impact BMI.

#### Strength of the Evidence

##### Weight-Related Outcomes

The strength of evidence is insufficient that school, home, consumer health informatics diet and physical activity interventions prevent obesity or overweight in children. We graded this body as insufficient because it included only a single study with high risk of bias. No studies measured adverse events (Table 20, Appendix F, Strength of Evidence Table 1).

Table 20 Summary of the strength of evidence for weight-related outcomes in studies taking place in a school setting with a home and consumer health informatics component

Setting | Intervention, n | Years of Publication | Enrolled Participants | Studies With Low/Moderate/High Risk of Bias(n) | % With Favorable (Statistically Sig) Outcome | % With Favorable Outcome (Does Not Need to be Stat Sig) | Risk of Bias | Consistency | Precision | Directness | Strength of the Evidence
School-Home-CHI | C,1 | 2011 | 589 | 0/0/1 | 0 | 0 | High | NA | Imprecise | Direct | Insufficient

C = combination of diet and physical activity interventions; CHI = consumer health informatics; sig = significant

##### Intermediate Outcomes

The strength of the evidence is insufficient that combined diet and physical activity interventions impact change in physical activity. A single high risk of bias study was not sufficient enough evidence to draw a conclusion (Appendix F, Strength of Evidence Table 6).

## Key Question 2 What is the comparative effectiveness of home-based interventions for the prevention of obesity or overweight in children?

### Key Points

Diet, physical activity and combination (diet and physical activity) interventions did not show any significant impact on weight-related outcomes and the evidence is low, at best, inconclusive that any of these interventions are more effective in preventing obesity or overweight than the control.

### Home-Based Studies

#### Study Characteristics

We included four RCTs, and all were from the U.S.171-174Three of the studies reported that preventing obesity was the goal of the intervention.171,173,174 One study included children greater than 5 years of age.173 One study included only girls,172 and two studies based inclusion criteria on a BMI less than the 85^th^ percentile (Table 21; Appendix E, Evidence Table 29).171,172

Table 21 Study and participant characteristics of studies based in the home

Author, Year | RCT | Goal: Obesity Prevention | Country | Sex^*^ | Age Range, Years^*^ | Grade^*^ | Other | Total N | Followup in Weeks | % Girls^†^ | Mean Age [Range] Years^†^ | Grade^†^ | Race^†^
Home
Epstein, 2001^171^ | Y | Y | U.S. | NR | 6-11 | NR | | 26 | 52 | 65 | 8.6-8.8 | NR | NR
Fitzgibbon, 2012^174^ | Y | Y | U.S. | NR | 3-5 | Pre-school | | 146 | 52 | 50 | 4.5 | Pre-school | BNH 2 Latino 94 Other 4
French, 2011^173^ | Y | Y | U.S. | NR | >5 | NR | | 90 households | 52 | NR | 5-17 | NR | NR
Lappe, 2004^172^ | Y | N | U.S. | Girls | 9 | NR | | 59 | 104 | 100 | 9.5 | NR | NR
Home/PC/CHI
Patrick, 2006^175^ | Y | N | U.S. | NR | 11-15 | NR | | 878 | 52 | 49.9 | 12.7 | NR | WNH: 58.4 BNH: 6.6 Hispanic 13.1 API: 3.2 AIAN: 0.7 other: 18
Home/School/Community
Gentile, 2009^176^ | Y | Y | U.S. | NR | NR | 3-5 | | 1323 | 61 | 53 | 9.6 | 3-5 | WNH: 90%

AIAN = American Indian/Alaska Native; API = Asian Pacific Islander; BMI = body mass index (in kg/m^2^); BNH = Black non-Hispanic; BP = blood pressure, CHI = consumer health informatics; CVD = cardiovascular disease; Maint = maintenance; meds = medications; N = no; NR = not reported; PC = physical activity; PC = primary care; RCT = randomized controlled trials; WNH = White non-Hispanic; Y = yes

* Inclusion/exclusion criteria.

† Participant characteristics.

#### Population Characteristics

The total number of participants in all four studies was 321. The total followup period ranged from 52^171,173^ to 104 weeks.172 In one study all of the participants were girls172 and in two other studies171,174 50-65 percent of the participants were girls. The age range of the participants in all four studies was 4 to 17 years. Only one of the four studies reported the grade level and participants were preschoolers174. One of the four studies described the race of the participants.174 In this study, 94 percent of the participants were Latin Hispanic, 2 percent Black non-Hispanic and 4 percent multiracial/other174 (Table 21; Appendix E, Evidence Table 30).

#### Interventions

One of the four studies reported on an educational diet-only intervention.172 This study evaluated the effect of a calcium-rich diet on weight gain among girls over a 104-week study period. Three of the four home-based studies examined the effect of a combined diet and physical activity intervention on weight outcomes. One of these three studies compared the effect on change in weight at 52 weeks of two educational diet and physical activity interventions, each addressing a different dietary behavior (increased fruit and vegetable intake vs. decreased intake of high fat/high sugar foods).171 The second study173 evaluated the effect of a 52-week combined diet and physical activity intervention on television viewing, snack/sweet intake, eating out, and physical activity among entire households. A third study174 assessed the effect of a combined intervention on dietary fat, fruit and vegetable intake, television viewing, and physical activity. (Table 22; Appendix E, Evidence Table 31).

Table 22 Interventions of studies based in the home

Author, Year | Control Arm | Description of Intervention | Diet (Phys/Env) | Diet (Psych) | Physical Activity (Phys/Env) | Physical Activity (Psych)
Home
Epstein, 2001^171^ | NA | Take home child workbook; active parental involvement (parent-focused intervention) to increase fruit and vegetable intake. | | X | | X
Epstein, 2001^171^ | | Take home child workbook; active parental involvement (parent-focused intervention) to decrease fat and sugar intake. | | X | | X
Fitzgibbon, 2012^174^ | Usual care | Nutrition instruction, combined with the physical activity component, was designed to target specific child behaviors. Creating a home environment to facilitate healthy choices. Interactive instruction on family exercise (and healthful eating). Classroom sessions included an aerobic activity component. | X | X | X | X
French, 2011^173^ | Usual care | Education sessions to - limit consumption of high calorie, limit sweetened drinks, eat at least 5 servings fruits and vegetables each day, eat smaller portions ("eat less"), limit eating fast foods, make healthy choices when eating out Provided guidelines on healthy choices Sessions to encourage 30 minutes of activity per day. | X | X | X | X
Lappe, 2004^172^ | Usual care | Eating calcium rich and fortified foods, no supplements | | X
Home/PC/CHI
Patrick, 2006^175^ | Usual care | Computer-based counseling and brief provider counseling with a16-section printed Teen Guide, mail, and telephone counseling to modify total intake of fat, servings per day of fruits and vegetables, physical activity, and sedentary behaviors. | | X | | X
Home/School/Community
Gentile, 2009^176^ | Usual care | The Switch program promoted healthy active lifestyles by encouraging students to 'Switch what you Do (exercise), Chew (eat), and View (sedentary activity)'. | | X | | X

CHI = consumer health informatics; PC = primary care; Psych = psychosocial intervention; Phys/Env = physical/environmental intervention

#### Outcomes

##### Diet Interventions

One out of the four home-based studies was a diet intervention that enrolled 63 girls and randomized 59 to the intervention and control groups.172

###### Weight-Related Outcomes

###### BMI

There was no reported difference in BMI at 104 weeks between the intervention and control arms (Appendix E, Evidence Table 32a).172

###### Percent Body Fat

There was no reported difference in fat mass at 104 weeks between the intervention and control arms (Appendix E, Evidence Table 32a).172

###### Weight

There was no reported difference in weight at 104 weeks between the intervention and control arms (Appendix E, Evidence Table 32a).172

###### Clinical Outcomes

None reported.

###### Adverse Events

None reported.

###### Intermediate Outcomes

###### Physical Activity and Sedentary Behaviors

There was no difference in self-reported hours of physical activity between the intervention and control arms (Appendix E, Evidence Table 32b).172

###### Dietary Intake

At 104 weeks the intervention group had a higher total energy intake compared to the control group. The study did not statistically analyze this between group difference (Appendix E, Evidence Table 32b).172

###### Interpretation

We can make no conclusions on the effectiveness of a home-based diet intervention on obesity or overweight prevention. This is based on the results from a single diet intervention study. This study evaluated the effect of the intervention on BMI percent body fat and weight and found no significant between-group difference with respect to these outcomes. This study also reported on change in physical activity and energy intake and found no significant between-group difference with respect to these outcomes. The study did not specifically target weight gain prevention but rather the effects of a high-calcium diet on weight over a 104-week period. The intervention did not include other dietary modifications or physical activity components. All of the above mentioned factors may have contributed to the attenuated effect of the intervention on weight and intermediate outcomes. Additionally, a larger sample size may be necessary to further evaluate the impact of the intervention.

##### Physical Activity Intervention

None reported.

##### Diet and Physical Activity Intervention

Three of the four home-based studies evaluated the effects of combined diet and physical activity intervention on weight outcomes.171,173,174 One study enrolled 30 families and randomized 26 children into two intervention groups.171 Another study randomized 90 participating households with children aged 5-17 to intervention or control group for 52 weeks.173 A third study consisted of 146 children randomly assigned to receive the intervention or control.174

###### Weight-Related Outcomes

###### BMI z-Score

Two home-based studies assessed the effect of a combined diet and physical activity intervention on BMI z-score. In both studies there was no significant intervention effect on BMI z-score at 52 weeks followup (p>0.05) (Appendix E, Evidence Table 33a).173,174

###### BMI

In one of these three studies, there was no significant between- group difference at the post-intervention or 1-year followup visit (p>0.05).174. (Appendix E, Evidence Table 33a).174

###### Prevalence of Overweight and Obesity

At 52 weeks, one study demonstrated a decrease in the percent of overweight children in the increased fruit and vegetable group of 1.10 percent (S.D. 5.29), and a 2.40 (S.D. 5.39) percent decrease in percent of overweight children in the decreased high fat/high sugar intervention group. This difference was not statistically different (p>0.05).171A second study reported that the prevalence of obesity among all participants decreased from 21 to 15 percent at 52 weeks. The study did not report or statistically analyze this change by intervention or control group. (Appendix E, Evidence Table 33a).

###### Weight

In one study there was no significant intervention effect on weight post-intervention or at the 52-week followup period (p value>0.05) (Appendix E, Evidence Table 33a).171

###### Clinical Outcomes

None reported.

###### Adverse Events

None reported.

###### Intermediate Outcomes

###### Physical Activity and Sedentary Behavior

In two studies there was no significant difference between the intervention and control group in minutes per day of physical activity (Appendix E, Evidence Table 33b).173,174

In two studies there was no significant difference between the intervention and control group in TV viewing or general screen time (Appendix E, Evidence Table 33b)173,174

###### Dietary Intake

All three studies171,173,174 demonstrated a favorable intervention effect on fruit and vegetable intake but only one study173 demonstrated a statistically significant intervention effect on fruit and vegetable intake among adolescents only (p=0.05) (Appendix E, Evidence Table 33b).173

In one study there was no difference in sugar-sweetened beverage intake between the intervention and control group (p=0.96)(Appendix E, Evidence Table 33b).173

In another study there was no difference between the intervention and control in energy intake (Appendix E, Evidence Table 33b).174

###### Interpretation

The strength of the evidence is low that combined diet and physical activity interventions in a home setting effectively prevent obesity or overweight. Combined interventions in this setting had a beneficial effect on fruit and vegetable intake. However, no conclusions can be made regarding their effect on other dietary, physical activity, or sedentary behaviors. These conclusions are supported by results of three studies reporting on the effect of combined diet and physical activity interventions in the home setting.171,173,174

One study reported on BMI and did not demonstrate a favorable or significant intervention effect with respect to this outcome measure.174 Another study reported on BMI z-score and did not demonstrate a statistically significant or favorable intervention effect.173 A third study reported on prevalence of overweight and demonstrated a change in favor of one intervention group.171 This change in prevalence of overweight was not statistically significant.171

Two studies reported on physical activity and sedentary behavior.173,174 Both studies demonstrated a favorable but nonsignificant intervention effect on physical activity.173,174 Neither study demonstrated a favorable or significant intervention effect on screen time.173,174

Three studies demonstrated a favorable intervention effect on fruit and vegetable intake;171,173,174 one of these was significant173 and two were not significant.171,173 One study reported on sugar-sweetened beverages and did not demonstrate a favorable or significant intervention effect.173 One study reported on energy intake and did not demonstrate a favorable or significant intervention effect.174

Use of interventions with significant parental/family involvement may have contributed to beneficial intervention effects studies demonstrated on select intermediate outcomes. However, additional studies with larger sample sizes, greater intervention intensity and longer followup may be necessary to further evaluate the impact of combined home based interventions on the prevention of obesity in children.

#### Strength of the Evidence

##### Weight-Related Outcomes

No conclusion can be made about the effectiveness of a home-based diet intervention on obesity prevention. We based this on a single study with moderate risk of bias and no measurable impact of the intervention. The strength of evidence is low that combined diet and physical activity interventions in a home setting positively impact obesity prevention. We graded the strength of evidence low because it included three moderate to high risk of bias studies, that were inconsistent (one demonstrated a positive effect, two demonstrated a negative effect) and imprecise (Table 23, Appendix F, Strength of Evidence Table 1).

Table 23 Summary of the strength of evidence for weight-related outcomes in studies taking place in a home setting

Setting | Intervention, n | Years of Publication | Enrolled Participants | Studies With Low/Mode Rate/High Risk of Bias(n) | % With Favorable (Statistically Sig) Outcome | % With Favorable Outcome (Does Not Need to be Stat Sig) | Risk of Bias | Consistency | Precision | Directness | Strength of the Evidence
Home | D, 1 | 2004 | 59 | 0/1/0 | 0 | 0 | Moderate | NA | Imprecise | Direct | Insufficient
Home | C, 3 | 2001-2012 | 262 | 0/2/1 | 0 | 33 | Moderate | Inconsistent | Imprecise | Direct | Low

D = diet intervention; PA = physical activity intervention; C = combination of diet and physical activity interventions

##### Intermediate Outcomes

No conclusion can be made about the effectiveness of combined diet and physical activity interventions in a home setting on physical activity, screen time, sugar-sweetened beverage intake or energy intake. We graded this body of evidence as insufficient because it included inconsistent studies with moderate to high risk of bias and imprecise results. The strength of the evidence is low that combined diet and physical activity interventions in a home setting positively impact fruit and vegetable intake. This is due to the moderate risk of bias, consistent effect in favor of the intervention, and lack of precision (Appendix F, Strength of Evidence Tables 2, 4-7).

### Home-Primary Care-Consumer Health Informatics–Based Studies

#### Study Characteristics

We included one RCT conducted in the U.S.175. The study's stated goal was to improve diet, physical activity and sedentary behaviors.175 The study included participants aged 11 to 15 years, and participants who did not have health conditions which could have limited their ability to comply with physical activity or diet recommendations (Table 21; Appendix E, Evidence Table 34).175

#### Population Characteristics

The study included a total of 878 participants.175 The total followup period was 52 weeks. Forty nine percent were girls and the mean age of all participants was 12.7 years (+/- 1.3 years.) The study did not report the grade level of the participants.175 In this study175 58.4 percent of participants were white, 6.6 percent African-American, 13.1 percent Hispanic, 3.2 percent Asian or Pacific Islander, 0.7 percent Native American, and 18 percent multi-ethnic or other (Table 21; Appendix E, Evidence Table 35).

#### Interventions

This study reported on a 52-week educational diet and physical activity intervention.175 The study evaluated how a multi-strategy intervention (computer-supported assessment followed by provider counseling [monthly mail and telephone counseling]) affected eating and physical activity behaviors (Table 22; Appendix E, Evidence Table 36).

#### Outcomes

##### Diet Interventions

None reported.

##### Physical Activity Interventions

None reported.

##### Diet and Physical Activity Interventions

One study evaluated the effects of a combined diet and physical activity intervention relative to a control group on BMI z-score at 52 weeks.175 The study randomized 878 participants and included 819 in the analysis.

###### Weight-Related Outcomes

###### BMI z-Score

The study reported no significant difference in overall BMI z score at 52 weeks between the intervention and control arms (p≥0.05) (Appendix E, Evidence Table 37a).175 Among participants with a BMI greater than or equal to the 95^th^ percentile, mean BMI z-score was 0.04 less in the intervention group compared to the control group at 52 weeks, which was not statistically significantly different (p=0.10)175 (Appendix E, Evidence Table 37a,b).

###### Clinical Outcomes

None reported.

###### Adverse Events

None reported

###### Intermediate Outcomes

###### Physical Activity and Sedentary Activity

The study reported no significant difference in minutes per week of moderate plus vigorous physical activity between the intervention and control group among girls (p=0.90) or boys (p=0.017)(Appendix E, Evidence Table 37c).175

The number of hours per day of sedentary behaviors decreased significantly in the intervention group compared to the control at 52 weeks among girls and boys (p=0.001) (Appendix E, Evidence Table 37c).175

###### Dietary Intake

The study reported no significant difference in percent calories from fat among girls (p=0.86) or boys (p=0.31), nor in fruit and vegetable consumption between the intervention and control groups among girls (p=0.07) or boys (p=0.49) (Appendix E, Evidence Table 37c).

###### Interpretation

We can make no conclusions regarding the effectiveness of a combined diet and physical activity intervention in a home setting with primary care and consumer health informatics components on obesity or overweight. No conclusions can be made regarding the effectiveness of a combined diet and physical activity intervention in a home setting with primary care and consumer health informatics components on diet and physical activity. Combined diet and physical activity interventions in this setting have a favorable and significant effect on sedentary behaviors. We based this on results of a single study reporting on a combined diet and physical activity intervention.175

This study evaluated the effect of an intervention on BMI z-score.175 and reported a favorable but nonstatistically significant intervention effect on BMI z-score among obese adolescents175 and a nonsignificant intervention effect on BMI z-score for the overall sample.175 We were unable to determine if there was a favorable effect of the intervention because the study did not provide BMI z-score values for the overall sample. This study demonstrated a favorable and statistically significant intervention effect on sedentary behaviors and demonstrated a favorable but nonsignificant intervention effect on physical activity among boys175 and a favorable but nonsignificant intervention effect on fruit and vegetable intake among girls.175

The integrated approach, including family engagement, computer-based behavioral assessments, and provider and telephone counseling, may have contributed to observed beneficial effects on select intermediate outcomes. However, additional studies with longer followup and greater intervention intensity may be needed to appreciate subsequent changes in weight-related outcomes.

#### Strength of the Evidence

##### Weight-Related Outcomes

We make no conclusions regarding the effectiveness of a combined diet and physical activity intervention in a home setting with primary care and consumer health informatics components on obesity or overweight. This is due to the inclusion of a single study that lacked precision with regard to the results from the overall sample. We were unable to determine the magnitude of the intervention effect on BMI z-score for the entire sample because the study did not provide actual outcome values (Table 24; Appendix F, Strength of Evidence Table 1).

Table 24 Summary of the strength of evidence for weight-related outcomes in studies taking place in a home setting with primary care and consumer health informatics components

Setting | Intervention, n | Years of Publication | Enrolled Participants | Studies With Low/Moderate/High Risk of Bias(n) | % With Favorable (Statistically Sig) Outcome | % With Favorable Outcome (Does Not Need to be Stat Sig) | Risk of Bias | Consistency | Precision | Directness | Strength of the Evidence
Home-PC-CHI | C, 1 | 2006 | 878 | 1/0/0 | 0 | Unable to determine – actual outcome values not reported only significance | Low | NA | Imprecise | Direct | Insufficient

C = combination diet and physical activity intervention; PC = primary care; CHI = consumer health informatics; NA = not applicable

##### Intermediate Outcomes

We can make no conclusions regarding the effectiveness of a combined diet and physical activity intervention in a home setting with primary care and consumer health informatics components on diet or physical activity. This was due to the inclusion of a single study that lacked precision and demonstrated favorable effect for sex-based subgroups only. The strength of evidence is low that a combined diet and physical activity intervention in a home setting with primary care and consumer health informatics components positively impacts sedentary behaviors. This is due to the low risk of bias, favorable effect on the outcome for the overall sample and high precision (Appendix F, Strength of Evidence Tables, 2,4,6, and 7).

### Home-School-Community–Based Studies

#### Study Characteristics

We included one RCT conducted in the U.S.176 The stated goal of the intervention was to prevent obesity. Participants included students attending grade 3 through 5 of two community school districts (Table 21; Appendix E, Evidence Table 38).

#### Population Characteristics

The study included a total of 1,323 participants. The total followup period (including an additional measurement period at 6 months post-intervention) was 61 weeks. Roughly half (53 percent) of the participants were girls. The mean age of the participants was 9.6 (+/- 0.9 years). All of participants were in grades 3 through 5 and 90 percent of participants were white (Table 21; Appendix E, Evidence Table 39).

#### Interventions

This study reported on an educational diet and physical activity intervention. It evaluated the effects of the intervention on three targeted behaviors (increase fruit and vegetable intake, increase physical activity, and decreased screen time) over a 61-week study period (Table 22; Appendix E, Evidence Table 40).

#### Outcomes

##### Diet Intervention

None reported.

##### Physical Activity Intervention

None reported.

##### Diet and Physical Activity Intervention Studies

One study evaluated the effects of a combined diet and physical activity intervention relative to a control group on BMI at 34 and 61 weeks.176 The study randomized 1,323 participants and included 992 in the analysis at all three data collection points (baseline, post intervention, and 6 months post intervention).

###### Weight-Related Outcomes

###### BMI

At 34 weeks, mean BMI was 19 kg/m^2^ (S.E. 0.03) for the control group, and 19 kg/m^2^ (S.E. 0.02) for the intervention group. The difference in mean BMI between the groups did not reach statistical significance (p ≥0.06) (Evidence Table 41a). At 61 weeks, the mean BMI was 19.5 kg/m^2^ (S.E. 0.1) for the control group and 19.4 kg/m^2^ (S.E. 0.1) for the intervention group. The difference in mean BMI between the groups did not reach statistical significance (p≥ 0.05) (Appendix E, Evidence Table 41a).

There was a significant effect difference in boys at 61 weeks (p<0.05), with boys in the intervention group demonstrating a 0.3 kg/m2 lower BMI than boys in the control group (Evidence Table 41b).

###### Clinical Outcomes

None reported.

###### Adverse Events

None reported.

###### Intermediate Outcomes

###### Physical Activity and Sedentary Activity

There was no statistically significant difference in physical activity (steps/day) or screen time between the intervention and control group at either followup time period (Appendix E, Evidence Table 41c).

###### Dietary Intake

Children in the intervention group reported significantly more fruit and vegetable consumption compared to the control group at 61 weeks (p<0.05). (Appendix E, Evidence Table 41c).

###### Interpretation

We can make no conclusions regarding the effectiveness of a combined diet and physical activity intervention in a home setting with school and community components on obesity or overweight. We can make no conclusions regarding the effectiveness of a combined diet and physical activity intervention in a home setting with school and community components on diet, physical activity, or sedentary behaviors. This is due to the results of a single study reporting on a combined diet and physical activity intervention.176

This study evaluated the effect of the intervention on BMI and found no favorable or statistically significant effect for the overall sample. However, it demonstrated a significant intervention effect among boys at 61 weeks.176 This study also reported on the effect of the intervention on child-reported physical activity, screen time, and fruit and vegetable intake and demonstrated a favorable effect with respect to these outcome measures at 61 weeks. However, only fruit and vegetable intake was significantly different between the intervention and control groups at 61 weeks.

A comprehensive approach with family, school, and community components, may have contributed to observed beneficial effects on behavior change. However, additional studies of greater quality with longer intervention duration and followup may be needed to appreciate subsequent changes in weight-related outcomes.

#### Strength of the Evidence

##### Weight-Related Outcomes

We can make no conclusions regarding the effectiveness of a combined diet and physical activity intervention in a home setting with school and community components on obesity or overweight. This is due to the inclusion of a single study with high risk of bias, and poor precision with respect to BMI for the overall sample (Table 25; Appendix F, Strength of Evidence Table 1).

Table 25 Summary of the strength of evidence for weight-related outcomes in studies taking place in a home setting with school and community components

Setting | Intervention, n | Years of Publication | Enrolled Participants | Studies With Low/Moderate/High Risk of Bias(n) | % With Favorable (Statistically Sig) Outcome | % With Favorable Outcome (Does Not Need to be Stat Sig) | Risk of Bias | Consistency | Precision | Directness | Strength of the Evidence
Home-School–Community | C, 1 | 2009 | 1323 | 0/0/1 | 0 | 0 | High | NA | Imprecise | Direct | Insufficient

C = combination diet and physical activity intervention; NA = not applicable

##### Intermediate Outcomes

We can make no conclusions regarding the effectiveness of a combined diet and physical activity intervention in a home setting with school and community components on diet, physical activity or sedentary behaviors. This is due to the inclusion of a single study with high risk of bias (Appendix F, Strength of Evidence Tables 4, 6, and 7).

## Key Question 3 What is the comparative effectiveness of primary care-based interventions for the prevention of obesity or overweight in children?

### Key Points

We can make no conclusions regarding the effectiveness of a combined diet and physical activity intervention in a primary care setting on obesity or overweight prevention.

### Primary Care–Based Studies

#### Study Characteristics

We included one study from the U.S. that used a quasi-experimental design.177The goal of the intervention was to prevent obesity. The study included participants aged 5 to18 years (Table 26; Appendix E, Evidence Table 42).

Table 26 Summary table for study and participant characteristics in primary-care based settings

Author, Year | RCT | Goal: Obesity Prevention | Country | Sex^*^ | Age Range, Years^*^ | Grade^*^ | Other^*^ | Total N | Followup in Weeks | % Girls^†^ | Mean Age [Range]Years^†^ | Grade^†^ | Race^†^
Polacsek, 2009^177^ | N | Y | U.S. | NR | 5-18 years | NR | NR | 600 | 78 | 47 | 5-17 years | NR | NR

N = no; NR = not reported; RCT = randomized controlled trials; Y = yes

* Inclusion/exclusion criteria.

† Participant characteristics.

#### Population Characteristics

The study included 600 subjects177. The followup period was 78 weeks,177 47 percent of participants were girls, 56 percent were 5-11 years, and 44 percent were 12-17 years. This study did not report race or grade level (Table 26; Appendix E, Evidence Table 43).178

#### Interventions

One study177 reported on a combined diet and physical activity intervention and used educational and physical environmental approaches including improving clinical decision support, counseling families and patients on “5-2-1-0” behavioral goals (consuming at least five or more servings of fruits and vegetables daily, limiting screen time to no more than 2 hours daily, engaging in at least 1 hour or more of daily physical activity, and avoiding sugar-sweetened beverages), and providing overall practice and provider management over the entire 78-week study period (Table 27; Appendix E, Evidence Table 44).

Table 27 Summary table for intervention in primary care-based settings

Author, Year | Control Arm | Description of Intervention | Diet (Phys/Env) | Diet (Psych) | Physical Activity (Phys/Env) | Physical Activity (Psych)
Polacsek, 2009^177^ | NA | Encouraging >5 servings of fruits and vegetables daily; limiting screen time to <2 hours daily and; avoiding (0) sugar-sweetened beverages and greater than 1 hour of physical activity daily. Pediatric Obesity Clinical Decision Support Chart with an algorithm and guidelines for the prevention and management of overweight. | X | X | X | X

Psych = psychosocial intervention; Phys/Env = physical/environmental intervention; NA = not applicable

#### Outcomes

##### Diet Interventions

None reported

##### Physical Activity Interventions

None reported.

##### Diet and Physical Activity Interventions

One non-RCT study included 600 participants in the analysis.177

###### Prevalence of Overweight and Obesity

The prevalence of overweight in the intervention group increased from 36.8 to 38.9 percent during the study. The study did not statistically analyze this change (Appendix E, Evidence Table 45a).177 The prevalence of obesity in the intervention group increased from 19.8 to 20.3 percent during the study. The study did not statistically analyze this change (Appendix E, Evidence Table 45a).177

###### Clinical Outcomes

None reported.

###### Adverse Events

None reported.

###### Intermediate Outcomes

###### Physical Activity and Sedentary Activity

Fifteen percent of parents reported making physical activity changes for themselves and their children (Appendix E, Evidence Table 45b).177 The study did not measure parent-reported behavioral changes at baseline.

Twelve percent of parents reported making TV/screen changes for themselves and their children (Appendix E, Evidence Table 45b).177 The study did not measure parent-reported behavioral changes at baseline.

###### Dietary Intake

In the study, 26 percent of parents reported making nutrition changes and 17 percent of parents reported making changes in sugar-sweetened beverages consumption for themselves and their children (Appendix E, Evidence Table 45b).177 The study did not measure parent-reported behavioral changes at baseline.

###### Interpretation

We can make no conclusions regarding the effectiveness of a combined diet and physical activity intervention in a primary care setting on obesity or overweight. We can make no conclusions regarding the effectiveness of a combined diet and physical activity intervention in a primary care setting on diet, physical activity or sedentary behaviors. This is due to the results of a single arm study reporting on a combined diet and physical activity intervention.177 This study evaluated the effect of an intervention on prevalence of overweight and obesity, both of which increased during the intervention. The study did not statistically analyze this change in prevalence of overweight and obesity. The study reported on percent of parents reporting diet, physical activity and screen time changes, based on surveys conducted during the intervention. However, it did not report any baseline values for these outcomes, hence we could not fully assess the intervention effect. Although the study's overall goal was to reduce the risk of childhood obesity, the intervention primarily aimed to achieve this goal through direct improvement of clinical decision support and family management of risk behaviors. Hence the intervention effect on weight outcomes may have been attenuated. Additional factors that may have limited intervention effectiveness include the lack of randomization, absent comparison group, and failure to reassess weight outcomes following the completion of the intervention. Parental reports of behavior changes did not appear to impact their children's outcomes.

#### Strength of the Evidence

##### Weight-Related Outcomes

We can make no conclusions regarding the effectiveness of a combined diet and physical activity intervention in a primary care setting on obesity or overweight prevention. This is due to the inclusion of a single imprecise study with a moderate risk of bias (Table 28, Appendix F, Strength of Evidence Table 1).

Table 28 Summary of the strength of evidence for weight-related outcomes in studies taking place in a primary care setting

Setting | Intervention, n | Years of Publication | Enrolled Participants | Studies With Low/Moderate/High Risk of Bias(n) | % With Favorable (Statistically Sig) Outcome | % With Favorable Outcome (Does Not Need to be Stat Sig) | Risk of Bias | Consistency | Precision | Directness | Strength of the Evidence
Primary Care | C, 1 | 2009 | 600 | 0/1/0 | 0 | 0 | Moderate | NA | Imprecise | Direct | Insufficient

C = combination diet and physical activity intervention; NA = not applicable

##### Intermediate Outcomes

We can make no conclusions regarding the effectiveness of a combined diet and physical activity intervention in a primary care setting on diet, physical activity or sedentary behaviors. This is due to the inclusion of a single imprecise study with a moderate risk of bias and no testable intervention effect (Appendix F, Strength of Evidence Tables 6 and 7).

## Key Question 4 What is the comparative effectiveness of child-care-based interventions for the prevention of obesity or overweight in children?

### Key Points

One non-RCT study tested an educational physical activity intervention and found significant differences in weight outcomes between the intervention and control groups. The strength of evidence is insufficient that diet alone or physical activity alone prevent obesity or overweight in child-care setting.

Two out of three studies showed no statistical difference in weight outcomes between the intervention and control groups. Combined diet and physical activity interventions implemented in child-care setting showed no beneficial effect at preventing obesity, with a low strength of evidence.

### Childcare–Based Studies

#### Study Characteristics

Five articles reported on four studies.77,102,179,180 Two articles77,181 reported on one study and count as one study. Three were RCTs77,179,180 and one was a non-randomized102 prospective study. Two77,180 out of the four studies conducted in child-care settings stated the goal of the study was obesity prevention and weight maintenance in children. Only one study180 took place in the U.S., while two102,179 took place in Germany and one in Switzerland77 (Table 29; Appendix E, Evidence Table 46).

Table 29 Study and participant characteristics of studies based in childcare settings

Author, Year | RCT | Goal: Obesity Prevention | Country | Sex^*^ | Age Range, Years^*^ | Grade^*^ | Other^*^ | Total N | Followup in Weeks | % Girls^†^ | Mean Age [Range] Years^†^ | Grade^†^ | Race^†^
Bayer, 2009^179^ | Y | N | Germany | NR | NR | NR | NR | 1,340 | 78 | 47.6 | 6.12 | Kindergarten | NR
Fitzgibbon, 2006^180^ | Y | Y | U.S. | NR | NR | NR | NR | 401 | 104 | 49.4 | 4.3 | Pre-school | Latino 81.4% Black 11.5% Other 7.5%
Metcalf, 2012^77^ Burgi, 2012^181^ | Y | Y | Switzerland | NR | NR | Pre School | NR | 652 | 52 | 50 | 5.2 | Pre-school | NR
Scheffler, 2007^102^ | N | N | Germany | NR | NR | Pre School | NR | 264 | 104 | NR | NR | NR | NR

N = no; NR = not reported; RCT = randomized controlled trials; Y = yes

* Inclusion/exclusion criteria.

† Participant characteristics.

#### Population Characteristics

The number of participants in four included studies was 2,657. The followup period for one was 52 weeks,77 for another was 78 weeks179 and for two others was 104 weeks.102,180 Across all studies 47.6 to 50 percent of the participants were girls. The age range of the participants in all four studies was 3 to 6.1 years. Two out of the four studies reported the grade level and participants in both studies were preschoolers.77,102 Only one study described race and the race distribution was as follows: 81.4 percent Hispanic, 11.5 percent Black, and 7.5 percent others/multiracial180 (Table 29; Appendix E, Evidence Table 47).

#### Interventions

One study reported on a physical activity intervention comprising of a playful-athletic exercise program lasting 1 hour, 3 times a week.102 The exercises were easy to do and included running with a newspaper in front of the breast without letting the paper fall down, jumping from a chalk circle into another and balancing on a line. This non-RCT evaluated the effect of 104 weeks of physical activity training on BMI, percent body fat, and skinfold thickness in pre-school children in 17 nursery schools in Berlin.

Three studies77,179,180 evaluated the effect of combined diet and physical activity interventions. One of them included an educational component and alterations in food served and physical activity recommended during an aftercare program for kindergarteners.179 It aimed to achieve this through educating care providers and communication with families. The study analyzed two samples, control and intervention, containing different children, at time intervals of 5.7 and 17.6 months after the start of the intervention.179

Another study randomized 12 Latino Head Start centers to a culturally tailored combined diet and physical activity intervention or control group.180 The intervention consisted of a variety of diet and physical activity modification curriculum delivered by trained early childhood educators for 14 weeks. This included 20 minutes of nutritional activity based on hand puppets reflecting the food pyramid and 20 minutes of aerobic activity. Behaviors for the intervention included increased fruit and vegetable consumption, decreased fat intake, decreased sedentary behaviors, and increased physical activity.

The third study had a multidimensional culturally tailored intervention which included a physical activity program, lessons on nutrition, media use, and sleep for pre-school children in a high migrant population.77 (Table 30; Appendix E, Evidence Table 48).

Table 30 Interventions of studies based in child-care settings

Author, Year | Control Arm | Description of Intervention | Diet (Phys/Env) | Diet (Psych) | Physical Activity (Phys/Env) | Physical Activity (Psych)
Bayer, 2009^179^ | Usual care | Tiger Kids “low cost behavioral intervention.” An Internet platform with supporting information for Kindergarten teachers and families: modifying habits of food and drink consumption, and regular consumption of water and other nonsugared drinks. Offer fruits and vegetables throughout the day. Information materials and modules with songs for use in the day care Enhancing physical activity. | X | X | X | X
Fitzgibbon, 2006^180^ | Usual care | Nutrition activity based on hand puppets that reflected the food pyramid. Curriculum to increase physical activity and aerobic activity. | X | | X
Metcalf, 2012^77^ Burgi, 2012^181^ | Usual care | Information sessions for children focusing on healthy nutrition. Information sessions that included promoting physical activity. Extra physical activity sessions, additional exercise equipment was provided. | X | X | X | X
Scheffler, 2007^102^ | Usual care | Playful athletic exercise programs were designed. The exercises targeted improving the pleasure of movement and train the motor basics like endurance, power, speed and skillfulness. | | | | X

Psych = psychosocial intervention; Phys/Env = physical/environmental intervention

#### Outcomes

##### Diet Interventions

No study reported.

##### Physical Activity Interventions

One study out of the four child-care center-based studies was a physical activity intervention that enrolled 264 children from 17 nursery schools and followed them for 104 weeks.102

###### Weight-Related Outcomes

###### BMI

The study reported an increase in the BMI of intervention children compared with children of the control group in both sexes (16.56 kg/m^2^ vs. 16.41 kg/m^2^ in boys and 16.10 kg/m^2^ vs. 15.86 kg/m^2^ in girls, no p value reported).102 However with the additional analysis of body composition (e.g., skeleton, body fat) the data indicates that the comparative high BMI in the physical activity intervention group is a result of higher percentage of muscle and not body fat102 (Appendix E, Evidence Table 49a).

###### Percent Body Fat

Similarly this study reported a significant lower percentage of body fat in the intervention group compared to the control group (16.34 vs. 17.26 percent in boys and 19.33 vs. 19.75 percent in girls, no p value reported)102 (Appendix E, Evidence Table 49a).

###### Skinfold Thickness

This study also reported a significant decrease in triceps skinfold thickness in the intervention group compared to the control group (8.05 mm vs. 8.64 mm in boys and 9.10 vs. 9.26 in girls, no p value reported)102 (Appendix E, Evidence Table 49a).

###### Clinical Outcomes

The physical activity-only intervention resulted in significant lower diastolic blood pressure at 104 weeks after the start of the intervention (Intervention group 62.0 SD 11.2 mm Hg vs. 68.8 SD 11.1 mm Hg, p<0.001) (Appendix E, Evidence Table 49b).

###### Adverse Events

None reported.

###### Intermediate Outcomes

None reported.

###### Interpretation

The results from an outcome measure from the one study reporting on physical activity interventions in a child-care setting support our conclusions. In this study, there was no significant beneficial physical activity intervention effect on BMI but there were significant positive intervention effect with respect to percent body fat, skinfold thickness, and diastolic blood pressure in a child-care setting. We need more well-designed studies to further evaluate the impact of the intervention in this setting.

##### Diet and Physical Activity Intervention

Three RCTs out of the four child-care center-based studies assessed the effects of combined diet and physical activity diet on weight outcomes. One study randomly assigned 64 kindergartens as intervention or control with samples of 1,318 and 1,340 included in analyses179. Another study randomized 420 children attending 12 head start centers and followed them for 104 weeks. The third study randomized 652 children in a high migrant population.

###### Weight-Related Outcomes

###### BMI z-Score

One study reported on BMI z-score and found no significant difference between the intervention and control group at 52 weeks (0.00 vs. 0.07, p=0.56) and 104 weeks (-0.13 vs. 0.00, p=0.34) post intervention180 (Appendix E, Evidence Table 50a,b).

###### BMI

Two studies reported on BMI and found no significant difference in BMI of intervention group compared with the control group. In one study the mean increase in BMI was 0.33 kg/m^2^ versus 0.48 kg/m^2^ (p =0.46) at 52 weeks and 0.46 kg/m^2^ vs. 0.70 kg/m^2^ (p =0.34) at 104 weeks followup.180 The second study reported that compared with the control children in the intervention group had no significant difference in BMI (-0.07 kg/m^2^, -0.19 to 0.06, p=0.31)77(Appendix E, Evidence Table 50a,b).

###### Prevalence of Overweight and Obesity

Two studies reported on the prevalence of overweight and found no difference in the prevalence of overweight.77,179 One study at 78 weeks followup found no difference between the intervention and the control groups.179 The odds ratio for overweight was 0.73 (95% CI 0.51-1.04), p=0.054 in the first sample and 0.89 (95% CI 0.66-1.22), p=0.59 in the second sample.179 Similarly, this study did not report any difference in the prevalence of obesity at 78 weeks between the intervention and the control groups. The odds ratio for obesity was 0.58 (95% CI 0.31-1.10), p=0.074 in the first sample and 0.79 (95% CI 0.35-1.77), p=0.63 in the second sample.179 The second study found no difference between intervention (10.5 to 11.0 percent) and control group (13.0 to 14.9 percent) at 52 weeks post intervention (p=0.23)77 (Appendix E, Evidence Table 50a,b).

###### Percent Body Fat

One study reported significant intervention effect on percent body fat. The percent body fat decreased from a baseline of 23.7 to 23.2 percent, 52 weeks post intervention in the intervention group and increased from 23.6 to 24.1 percent in the control group with a between group difference of -1.1, 95% CI-2.02 to -0.20 (p= 0.02)77 (Appendix E, Evidence Table 50a,b).

###### Waist Circumference

The same study reported on and also found significant intervention effect on waist circumference. The waist circumference increased from a baseline of 52.8cm to 53.3cm, 52 weeks post intervention in the intervention group and increased from 52.8cm to 54.3cm in the control group with a between-group difference of -1.0, 95% CI-1.6 to -0.42 (p= 0.001)77 (Appendix E, Evidence Table 50a,b).

###### Clinical Outcomes

None reported.

###### Adverse Events

None reported.

###### Intermediate Outcomes

###### Physical Activity and Sedentary Activity

Two combined diet and physical activity intervention studies reported on physical activity and neither found significant intervention effect77,180 (Appendix E, Evidence Table 50c).

###### Dietary Intake

One combined diet and physical activity intervention resulted in higher fruit and vegetable consumption in the two different samples at 78 weeks after the start of the intervention compared to the control group. The odds ratio for high fruit consumption was 1.64 (95% CI 1.26-2.12), p<0.001 in the first sample and 1.59 (95% CI 1.26-2.01), p<0.001 in the second sample.179 Another combined diet and physical intervention study found no significant intervention effect on total fat intake or fiber intake180 (Appendix E, Evidence Table 50c).

###### Interpretation

The results from an outcome measure from three studies reporting on combined diet and physical activity interventions in a child-care setting support our conclusions. Across all three combined diet and physical activity intervention studies in the child-care center-based settings, there were no significant between-group differences with respect to BMI z-score,180 BMI,77 and prevalence of obesity and overweight.179 One out of the three combined diet and physical activity intervention studies found significant increase in fruit and vegetable intake. However, none of these studies found significant intervention effect on physical activity, total fat intake, or fiber intake. The small sample size and poor quality of these studies may have contributed to the attenuated effect of the intervention on weight outcomes. We need high quality studies with a larger sample size to further evaluate the impact of the intervention.

#### Strength of the Evidence

##### Weight-Related Outcomes

The strength of evidence is insufficient that a physical activity intervention reduces BMI, percent body fat, and skinfold thickness in a child-care center-based (only) setting because only one study with high risk of bias and direct and imprecise results evaluated this intervention on the prevention of obesity. There is no evidence of benefit for combined diet and physical activity interventions delivered in a child-care setting for prevention of child overweight and obesity. The strength of evidence is low because studies that addressed these outcomes had moderate risk of bias with direct, consistent, and imprecise results (Table 31, Appendix F, Strength of Evidence Table 1).

Table 31 Summary of the strength of evidence for weight-related outcomes in studies taking place in childcare

Setting | Intervention, n | Years of Publication | Enrolled Participants | Studies With Low/Moderate/High Risk of Bias(n) | % With favorable (Statistically Sig) Outcome | % With Favorable Outcome (Does Not Need to be Stat Sig) | Risk of Bias | Consistency | Precision | Directness | Strength of the Evidence
Childcare | P, 1 | 2007 | 268 | 0/0/1 | 100 | 100 | High | NA | Precise | Direct | Insufficient
Childcare | C, 3 | 2009-2012 | 2393 | 1/2/0 | 33 | 33 | Moderate | Inconsistent | Imprecise | Direct | Low

P = physical activity interventions; C = combination diet and physical activity interventions; NA = not applicable

##### Intermediate Outcomes

There is no evidence of benefit for combined diet and physical activity intervention based in a child-care setting on increasing physical activity among children. The confidence in this conclusion is low because studies evaluating these outcomes had moderate risk of bias with direct and consistent results. We could not make a conclusion about the effectiveness of combined diet and physical activity interventions on increasing dietary intake of fruits and vegetables, total fat intake or fiber intake in a child-care setting. The strength of evidence is insufficient that a combined diet and physical activity intervention increases the intake of fruits and vegetables, total fat intake, or fiber intake in a child-care center-based (only) setting because only one study with moderate risk of bias and precise result addressed these outcomes (Appendix F, Strength of Evidence Tables 2-4).

## Key Question 5 What is the comparative effectiveness of community-based or environment-level interventions for the prevention of obesity or overweight in children?

### Key Points

#### Community and Community Plus–Based Studies

The strength of evidence is insufficient that a physical activity-only intervention is more effective at preventing obesity or overweight than the control based on one RCT study. We found positive but nonsignificant changes in percent body fat in this intervention.

The strength of evidence is moderate that a diet and physical activity intervention combined with other approaches is more effective at preventing obesity or overweight than the control based on six RCTs and two non-RCTs. We found desirable changes in BMI or BMI z-score in five of the nine studies.

### Community-Only–Based Studies

#### Study Characteristics

One RCT took place in Switzerland. The stated goal of this study was not weight maintenance. This study included only boys participating in sports (Table 32; Appendix E, Evidence Table 51).182

Table 32 Study and participant characteristics of studies based in the community

Author, Year | RCT | Goal: Obesity Prevention | Country | Sex^*^ | Age Range, Years^*^ | Grade^*^ | Other^*^ | Total N | Followup in Weeks | % Girls^†^ | Mean Age [Range] Years^†^ | Grade^†^ | Race^†^
Community Only
Eiholzer, 2010^182^ | Y | N | Switzerland | Boys | NR | NR | NR | 46 | 52 | 0 | 13.3 | NR | NR
Com-munity/School
Sallis, 2003^75^ | Y | Y | U.S. | NR | NR | NR | NR | 24 schools (mean enrollment 1,109) | 104 | 49 | NR | NR | WNH: 39.5
Singh, 2009^183^ | Y | Y | Nether-lands | NR | NR | NR | NR | 1,108 | 32-80 | 53.3 | 12.7 | NR | NR
Chomitz, 2010^184^ | N | Y | U.S. | NR | >5 | NR | NR | 1,858 | 156 | 48.2 | 7.7 | NR | WNH: 37.1 BNH: 37.3 Latino/Hispanic: 14.0 API: 10.2 Other: 1.7
Community/School/Home
Economos, 2007^185^ | N | Y | U.S. | NR | NR | NR | NR | 1,178 | 43 | NR | 7.34 – 7.9 | 1st grade 32.2% - :47.4% 2nd grade 23.7% - 29.6% 3rd grade 28.9%-38.2% | WNH:37.8 – 51.7 BNH : 6.9 – 25.1 Latino/Hispanic: 11.8 – 22.8 API : 2.3 – 9.1 Other: 11-23
Community/Home
Robinson, 2010^186^ | Y | Y | U.S. | Girls | 8-10 | NR | NR | 261 | 104 | 100 | 9.4 | NR | BNH: 100%
Klesges, 2012^187^ | Y | Y | U.S. | Girls | 8-10 | NR | BMI >= the 25^th^ pctl, or < BMI – 35 or at least 1 parent with a BMI >r than 25 | 303 | 104 | 100 | 9.3 | NR | African-American: 100
Community/Home/PC/CC
de Silva-Sanigorski, 2010^188^ | N | Y | Australia | NR | 0-5 | NR | NR | 43,811 | 208 | NR | [2-4] | NR | NR
Community/School/PC/CC
Chang, 2010^189^ | N | Y | US | NR | NR | NR | NR | NR | 208 | NR | NR | NR | WNH, Arm1:35.9) Arm2:(35.4) Arm3:(22.9) Arm4:(38) Arm5:(37.3)

API = Asian Pacific Islander; BMI = body mass index (in kg/m^2^); BNH = Black non-Hispanic, N = no; NR = not reported; RCT = randomized controlled trials; WNH = White non-Hispanic; Y = yes

* Inclusion/exclusion criteria.

† Participant characteristics.

#### Population Characteristics

The study included 46 participants and followed them for 52 weeks. All participants were middle school-aged. It did to report race (Table 32; Appendix E, Evidence Table 52).182

#### Interventions

The study included a combined diet and physical activity intervention (Table 33; Appendix E, Evidence Table 53).

Table 33 Interventions of studies based in the community

Author, Year | Control Arm | Description of Intervention | Diet (Phys/Env) | Diet (Psych) | Physical Activity (Phys/Env) | Physical Activity (Psych)
Community Only
Eiholzer, 2010^182^ | Usual care | The resistance exercise program consisted of supervised 1-hour exercise sessions twice weekly. | | | X | X
Community/School
Sallis, 2003^75^ | Usual care | School activities/components including physical education classes, school food sources. Statewide regulatory changes to reduce sedentary behavior and promote healthy lifestyle; childcare technical assistance; training around healthy habits. | X | | X | X
Singh, 2009^183^ | Usual care | Classroom based educational program that covered 11 lessons for the subjects of biology and physical education. Aimed at raising awareness and information processing with regard to energy balance–related behaviors; Aimed at facilitation of choice to improve 1 of the risk behaviors. | X | X | X | X
Chomitz, 2010^184^ | Usual care | Healthy eating and active living through a poster campaign, newsletters, mini-grants. Innovative food service projects such as new recipe and menu development and cafeteria taste-tests were developed. Raise community awareness of resources available in the city to promote active living through a poster campaign. Physical education programs were implemented at all 12 K-8 schools similarly to improve access to physical activity opportunities. | X | X | X | X
Community/School/Home
Economos, 2007^185^ | Usual care | Breakfast program; walk to school campaign; professional development for staff; school food service; classroom curriculum; Enhanced recess; school wellness policy development; after school SUS curriculum; walk from school campaign. Parent outreach and educational information; family events; nutrition forums; Child's health report card. Community or environment-level: SUS Community Advisory Council; Ethnic-minority collaborations; walking trainings; Farmers Market; City Employee Wellness Campaign; SUS approved restaurants; SUS 5K & Fitness fair; media placement; collaboration on health events. | X | X | X | X
Community/Home
Klesges, 2012^187^ | Both groups received the same intervention for 1 year. After first year program included social awareness and community responsibility | Practical experience with nutrition and physical activity by way of interactive learning. The girls developed behavioral goals to eat a nutritional diet, increase physical activity, and reduce sedentary activity. | | X | | X
Robinson, 2010^186^ | Usual care | Daily 1-hour homework period and small snack followed by 45 to 60 minutes of learning and practicing dance routines. Home-based screen time reduction intervention designed to incorporate African or African American history and culture. | X | | | X
Community/Home/PC/CC
de Silva-Sanigorski, 2010^188^ | Usual care | Increase awareness of key messages in homes, primary care, and childcare settings. Promote healthy eating, distribute water bottles, active play. | X | X | X | X
Community/School/PC/CC
Chang, 2010^189^ | Usual care | Wellness programs; assessment of student fitness; promote healthy eating/physical education/activity, training of childcare providers about healthy behaviors Implementation of Expert Committee recommendations on assessment, prevention and treatment of child and adolescent overweight Implementation of policy and practice changes with organizations such as YMCA Childcare | X | X | X | X

CC = childcare; PC = primary care; Psych = psychosocial intervention; Phys/Env = physical/environmental intervention

#### Outcomes

##### Diet Interventions

None reported.

##### Physical Activity Interventions

###### Weight-Related Outcomes

###### Percent Body Fat

There was no difference in percent body fat between the intervention and control groups at baseline and followup (Appendix E, Evidence Table 54a).182

###### Clinical Outcomes

None reported.

###### Adverse Events

None reported.

###### Intermediate Outcomes

This study reported a significant increase in physical activity (p=0.01) as indicated by in the spontaneous activity energy expenditure (SpAEE), kcal/min (Appendix E, Evidence Table 54b).182

###### Interpretation

The results from an outcome measure from one community only-based study reporting on a physical activity intervention support our conclusion. The study reported on percent body fat and showed no significant change over 1 year. However, it did show a significant increase in physical activity. The study enrolled a small sample of boys only and aimed to increase spontaneous activity. It did not include dietary components. We need more physical activity interventions among larger, more diverse populations to further evaluate the impact of these interventions.

##### Diet and Physical Activity Interventions

None reported.

#### Strength of the Evidence

##### Weight-Related Outcomes

The strength of evidence is insufficient that community-only based physical activity interventions prevent obesity or overweight in children (Table 34; Appendix F, Strength of Evidence Table 1).

Table 34 Summary of the strength of evidence for weight-related outcomes in studies taking place in community-only settings

Setting | Intervention, n | Years of Publication | Enrolled Participants | Studies With Low/Moderate/High Risk of Bias(n) | % With Favorable (Statistically Sig) Outcome | % With Favorable Outcome (Does Not Need to be Stat Sig) | Risk of Bias | Consistency | Precision | Directness | Strength of the Evidence
Community-only | PA, 1 | 2010 | 46 | 0/1/0 | 0 | 0 | Moderate | NA | Imprecise | Direct | Insufficient

PA = physical activity intervention; NA = not applicable

##### Intermediate Outcomes

There was insufficient evidence to grade intermediate outcomes of physical activity interventions.

### Community-School–Based Studies

#### Study Characteristics

There were three studies, including two RCTs,75,183 and one non-RCT.184 Their stated goal was obesity prevention or weight maintenance. Two studies took place in the U.S.,75,184 and the other in the Netherlands.183 Two studies did not report inclusion criteria,75,183the other only included children under 5 years old (Table 32; Appendix E, Evidence Table 55).184

#### Population Characteristics

Two studies included a total of 2,966 participants and one study included 24 schools with a mean enrollment of 1,109 at each school. One study had a followup of 156 weeks,184, one study had a followup of between 32-80 weeks183, and one study had a followup of 104 weeks75 The proportion of females ranged from 48.2^184^ to 53.3^183^ percent in these studies. Two studies did not report on age.183 Mean age ranged from 7.7 years184 to 12.7 years.183 None of the studies reported on the grade of the participants. Two studies reported on race (Table 32; Appendix E, Evidence Table 56).75,184

#### Interventions

All three studies reported on combined diet and physical activity interventions (Table 33; Appendix E, Evidence Table 57).183

#### Outcomes

##### Diet Interventions

None Reported.

##### Physical Activity Interventions

None Reported.

##### Diet and Physical Activity Interventions

###### Weight-Related Outcomes

###### BMI z-Score

One study reported on change in BMI z score and showed a decrease (0.67 vs. 0.63, p < 0.001) (Appendix E, Evidence Table 58a,b).184

###### BMI

Two studies reported on BMI. One did not observe any differences in BMI between the intervention and control groups183 and one observed differences among males but not females75 (Appendix E, Evidence Table 58a,b).

###### Prevalence of Overweight and Obesity

One study reported on the prevalence of obesity and showed a decrease (20.2 percent vs. 18.0 percent, p < 0.05) (Appendix E, Evidence Table 58a,b).184

This study also reported on subgroups; the sum of skinfold thickness was lower in girls in intervention schools at both a 32-week followup (-2.3mm; 95% CI: -4.3, -0.03mm) and 240-week followup (-2.0mm; 95% CI: -3.9, -0.1mm) (Appendix E, Evidence Table 58).183 Additionally, Black and Hispanic children were more likely to be obese at baseline (27 percent and 28.5 percent, respectively) compared to white (12.6 percent) and Asian children (14.3 percent). But obesity along all race/ethnicity groups declined during the study (Appendix E, Evidence Table 58a,b).

###### Waist Circumference

One study reported on waist circumference change. For males, waist circumference was lower in the intervention group at a 32-week followup (-0.6cm; 95% CI: -1.1 to -0.1cm), but at a 20-month followup waist circumference was significantly lower in the control group (Appendix E, Evidence Table 58a,b).183

###### Skinfold Thickness

One study reported on skinfold thickness change. At the 240 week followup, bicep skinfold thickness among females was lower (-0.7mm; 95% CI: -1.3, -0.04mm) (Appendix E, Evidence Table 58a,b).183

###### Clinical Outcomes

None reported.

###### Adverse Events

None reported.

###### Intermediate Outcomes

###### Physical Activity and Sedentary Behavior

One study measured the impact of this intervention on endurance and fitness.184 The percent that passed the endurance cardiovascular test significantly increased from 52.6 to 66.6 percent (14.0 percent increase, p<0.001) in the intervention group. One study183 measured active commuting (walking) to school and found no significant difference between groups. This study also reported on consumption of sugar-sweetened beverages and found no difference between the control and interventions. One study measured moderate to vigorous physical activity, sedentary hours, and fatty foods and found no significant differences between groups (Appendix E, Evidence Table 58c).

###### Interpretation

The results from outcome measures from two community/school-based studies reporting on combined interventions support our conclusions. One study reported on BMI z-score and showed a significant decrease. Two studies reported on BMI and one showed a significant decrease. These interventions focused on education and environmental changes promoting a healthy diet and physical activity. We may need more interventions combining diet and physical activity to further evaluate the impact of these interventions.

#### Strength of the Evidence

##### Weight-Related Outcomes

The strength of evidence is moderate that community/school based diet and physical activity interventions prevent obesity or overweight in children (Table 35, Appendix F, Strength of Evidence Table 1). No studies measured adverse events.

Table 35 Summary of the strength of evidence for weight-related outcomes in studies taking place in community settings with a school component

Setting | Intervention, n | Years of Publication | Enrolled Participants | Studies With Low/Moderate /High Risk of Bias(n) | % With Favorable (Statistically Sig) utcome | % With Favorable Outcome (Does Not Need to be Stat Sig) | Risk of Bias | Consistency | Precision | Directness | Strength of the Evidence
Community-School | C, 3 | 1997-2010 | 2966 and 24 schools (mean enrollment 1,109) | 0/3/0 | 66 | 66 | Moderate | Consistent | Imprecise | Direct | Moderate

C = combination of diet and physical activity interventions

##### Intermediate Outcomes

There was insufficient evidence to grade intermediate outcomes of combination interventions.

### Community-School-Home–Based Studies

#### Study Characteristics

One non-RCT study took place in this setting and the goal of this study was not weight maintenance. This study took place in the U.S. (Table 32; Appendix E, Evidence Table 59).185

#### Population Characteristics

This study included 1,178 participants whose mean age was between 7.3 and 7.9 years old. Participants were in grades 1-3, and were of mixed ethnicity (Table 32; Appendix E, Evidence Table 60).185

#### Interventions

This study reported on a combination of diet and physical activity intervention (Table 33; Appendix E, Evidence Table 61).185

#### Outcomes

##### Diet Interventions

None reported.

##### Physical Activity Interventions

None reported.

##### Diet and Physical Activity Interventions

One non-RCT reported on a diet, physical activity and change in sedentary behavior intervention.185 The study randomized 1,178 participants and analyzed 1,178 at 43 weeks.

###### Weight-Related Outcomes

###### BMI z-Score

In the intervention community, BMI z-score decreased by -0.1005 (p = 0.001) compared with children in the control communities (Appendix E, Evidence Table 62a,b).185

###### Clinical Outcomes

None reported.

###### Adverse Events

None reported.

###### Intermediate Outcomes

None reported.

###### Interpretations

The results from outcome measures from one community/school/home-based study reporting on a combination intervention support our conclusions. This study showed a significant decrease in BMI z-score over 1 year. The study was conducted in a community in Massachusetts with components in the school and the home. We need more diet and physical activity intervention studies among diverse populations.

#### Strength of the Evidence

##### Weight-Related Outcomes

The strength of evidence is insufficient that community/school/home based interventions which target a combination of diet and physical activity prevent obesity or overweight in children. No studies measured adverse events. No studies measured intermediate outcomes (Table 36, Appendix F, Strength of Evidence Table 1).

Table 36 Summary of the strength of evidence for weight-related outcomes in studies taking place in community settings with a school and home component

Setting | Intervention, n | Years of Publication | Enrolled Participants | Studies With Low/Moderate/High Risk of Bias(n) | % With Favorable (Statistically Sig) Outcome | % With Favorable Outcome (Does Not Need to be Stat Sig) | Risk of Bias | Consistency | Precision | Directness | Strength of the Evidence
Community-School-Home | C, 1 | 2007-2008 | 1326 | 0/1/0 | 100 | 100 | Moderate | NA | Imprecise | Direct | Insufficient

C = combination of diet and physical activity interventions

### Community-Home–Based Studies

#### Study Characteristics

Two RCTs were included in this setting.186,187 Both studies included only girls in elementary school who were African-American girls aged 8 to 10 years old.186,187 One study included only participants with a BMI at or higher than the 25^th^ percentile or had a parent with a BMI of 25 or higher187 (Table 32; Appendix E, Evidence Table 63).

#### Population Characteristics

The two studies include 924 participants. Length of followup was 104 weeks for both studies. Participants were on average 9.3 to 9.4 years old and were all African-American (Table 32; Appendix E, Evidence Table 64).186

#### Interventions

Both studies tested a combined diet and physical activity intervention (Table 33; Appendix E, Evidence Table 65).186,187

#### Outcomes

##### Diet Interventions

None reported.

##### Physical Activity Interventions

None reported.

##### Diet and Physical Activity Interventions

###### Weight-Related Outcomes

###### BMI z-Score

Changes in BMI z-score did not differ between the two intervention groups (Appendix E, Evidence Table 66a).186

###### BMI

Changes in BMI did not differ between the intervention group and the control for either study (Appendix E, Evidence Table 66a).186,187

###### Prevalence of Overweight and Obesity

Changes in BMI ≥ 95^th^ percentile did not differ between the two intervention groups. (Appendix E, Evidence Table 66a).186

###### Waist Circumference

Changes in waist circumference did not differ between the intervention group and the control for either study (Appendix E, Evidence Table 66a).186,187

###### Skinfold Thickness

Changes in triceps skinfold did not differ between intervention group and the control for either study (Appendix E, Evidence Table 66a).186,187

###### Clinical Outcomes

Changes in systolic blood pressure did not differ between the two intervention groups. Changes in diastolic blood pressure did not differ between the two intervention groups (Appendix E, Evidence Table 66b).186

###### Adverse Events

None reported.

###### Intermediate Outcomes

###### Physical Activity and Sedentary Behavior

Group difference in changes in the intermediate outcomes including weekday, weekend and after-school moderate-to-vigorous physical activity, weekday/weekend screen time, total daily energy intake as well as average percentage of energy from fat were all in the expected direction, but did not reach statistical significance (Appendix E, Evidence Table 66c).186,187

###### Physical Activity and Sedentary Behavior

One study reported on change in dietary intake. This study reported on sugar sweetened beverage intake, and found a nonsignificant decrease in favor of the intervention. This study reported a significant increase in water consumption in the intervention group (p=0.02). Fruit and vegetable intake also increased in the intervention group but was not significant (p=0.07) (Appendix E, Evidence Table 66c).187

###### Interpretation

We can make limited conclusions regarding community- and home-based studies reporting diet and physical activity interventions. The studies reported on BMI z-score, BMI, waist circumference, and skinfold thickness over two years but did not show significant differences between the two groups. The studies took place among small samples of African-American girls. The health education and physical activity interventions took place in different study groups; therefore the participants did not receive both the diet and physical activity intervention. We need more diet and physical activity intervention studies among larger, more diverse populations to further evaluate the impact of this intervention.

#### Strength of the Evidence

##### Weight-Related Outcomes

The strength of evidence is insufficient that community/home-based interventions using a combined diet and physical activity intervention prevent obesity or overweight in children (Table 37, Appendix F, Strength of Evidence Table 1).

Table 37 Summary of the strength of evidence for weight-related outcomes in studies taking place in community settings with a home component

Setting | Intervention, n | Years of Publication | Enrolled Participants | Studies With Low/Moderate/High Risk of Bias(n) | % With Favorable (Statistically Sig) Outcome | % With Favorable Outcome (Does Not Need to be Stat Sig) | Risk of Bias | Consistency | Precision | Directness | Strength of the Evidence
Community-Home | C, 2 | 2010 | 564 | 0/1/1 | 0 | 0 | Moderate | Consistent | Imprecise | Direct | Insufficient

C = combination diet and physical activity interventions; NA = not applicable

##### Intermediate Outcomes

There was insufficient evidence to grade intermediate outcomes of combined diet and physical activity interventions (Appendix F, Strength of Evidence Tables 2 and 7).

### Community-Home-Primary Care and Childcare–Based Studies

#### Study Characteristics

We included one quasi-experimental Australian study that took place in this setting and had a stated goal of obesity prevention. The study reported on a diet, physical activity, and change in sedentary behavior188. The study randomized 2,202 participants and analyzed 2,393 at 103 weeks. This study included children between the ages of 0 and 5 years old. The study did not report any other inclusion criteria (Table 32; Appendix E, Evidence Table 67).188

#### Population Characteristics

This study included a total of 43,811 participants whose mean age was between 2 and 4 years old. The study did not report any other participant characteristics (Table 32; Appendix E, Evidence Table 68).188

#### Interventions

This study investigated the combination intervention of diet and physical activity (Table 33; Appendix E, Evidence Table 69).188

#### Outcomes

##### Diet Interventions

None reported.

##### Physical Activity Interventions

None reported.

##### Diet and Physical Activity Interventions

###### Weight-Related Outcomes

###### BMI z-Score

In the intervention group, there was a significantly lower BMI z-score in the 3.5-year-old subsample (0.67 vs. 0.54, p < 0.05) (Appendix E, Evidence Table 70a,b).188

###### BMI

In the intervention group, there was a significantly lower BMI in the 3.5-year-old subsample (16.35 kg/m^2^ vs. 16.17 kg/m^2^, p < 0.05) (Appendix E, Evidence Table 70a,b).188

###### Weight

In the intervention group, there was a significantly lower weight in the 3.5-year-old subsample (17.05 kg vs. 16.76 kg, p < 0.05) (Appendix E, Evidence Table 70a,b).188

###### Prevalence of Overweight and Obesity

In the intervention group, there was a significantly lower prevalence of overweight/obesity in the 2 and 3.5-year-old subsample (by 2.5 and 3.4 percentage points, respectively) than there was in the comparison sample (a difference of 0.7 percentage points, p < 0.05) (Appendix E, Evidence Table 70a,b).188

###### Clinical Outcomes

None reported.

###### Adverse Events

None reported.

###### Intermediate Outcomes

None reported.

###### Interpretation

We can make no conclusions regarding community, home, primary care, and childcare-based studies reporting on a combined intervention. The single study showed a significant decrease in BMI, BMI z-score, and weight among young children (3.5 years) over 4 years. The study took place in a community in Australia with components in the school, primary care, and child-care settings. We need more diet and physical activity interventions among diverse populations to further evaluate the impact of this intervention.

#### Strength of the Evidence

The strength of evidence is insufficient that community-home-primary care-child-care -based diet and physical activity interventions prevent obesity or overweight in children (Table 38, Appendix F, Strength of Evidence Table 1).

Table 38 Summary of the strength of evidence for weight-related outcomes in studies taking place in community settings with home, primary care, and child-care components

Setting | Intervention, n | Years of Publication | Enrolled Participants | Studies With Low/Moderate/High Risk of Bias(n) | % With Favorable (Statistically Sig) Outcome | % With Favorable Outcome (Does Not Need to be Stat Sig) | Risk of Bias | Consistency | Precision | Directness | Strength of the Evidence
Community-Home-PC-CC | C, 1 | 2010 | 43,811 | 0/1/0 | 100 | 100 | Moderate | NA | Imprecise | Direct | Insufficient

C = combination diet and physical activity interventions; NA = not applicable; PC=primary care; CC = childcare

### Community-School-Primary Care-Childcare–Based Studies

#### Study Characteristics

We included one quasi-experimental study conducted in the U.S. in this setting with the stated goal of obesity prevention. The study reported on a combined diet and physical activity intervention, which randomized 2,202 participants189. It did not define any inclusion criteria (Table 32; Appendix E, Evidence Table 71).189

#### Population Characteristics

This study included a total of 2,202 participants. It did not report any other participant characteristics (Table 32; Appendix E, Evidence Table 72).189

#### Interventions

This study investigated a diet intervention (Table 33; Appendix E, Evidence Table 73).189

#### Outcomes

##### Diet Interventions

None reported

##### Physical Activity Interventions

None reported.

##### Diet and Physical Activity Interventions

###### Weight-Related Outcomes

###### Prevalence of Overweight and Obesity

In the intervention group, there was no significant change in the prevalence of obesity (20.6 vs. 24.2 percent) or prevalence of overweight (17 vs. 17 percent) (Appendix E, Evidence Table 74a).189

###### Clinical Outcomes

None reported.

###### Adverse Events

None reported.

###### Intermediate Outcomes

None reported.

###### Interpretation

We can make no conclusions regarding community, school, primary care, and child-care center-based studies reporting on a combined intervention. The single diet and physical activity study showed no significant change in the prevalence of obesity over three years. The study took place in a community in Delaware with components in the school, primary care and child-care settings. We need more diet and physical activity interventions among diverse populations to further evaluate the impact of these interventions.

#### Strength of the Evidence

##### Weight-Related Outcomes

The strength of evidence is insufficient that community/home/primary care/child-care center-based combined diet and physical activity interventions prevent obesity or overweight in children (Table 39, Appendix F, Strength of Evidence Table 1). No studies measured adverse events.

Table 39 Summary of the strength of evidence for weight-related outcomes in studies taking place in community settings with school, primary care, and child-care components

Setting | Intervention, n | Years of Publication | Enrolled Participants | Studies With Low/Moderate/High Risk of Bias(n) | % With favorable (Statistically Sig) Outcome | % With Favorable Outcome (Does Not Need to be Stat Sig) | Risk of Bias | Consistency | Precision | Directness | Strength of the Evidence
Community-School-PC-CC | C, 1 | 2010 | NR | 0/0/1 | 100 | 100 | High | Inconsistent | Imprecise | Direct | Insufficient

C = combination diet and physical activity intervention; NA = not applicable; PC = primary care; CC = childcare

## Key Question 6 What is the comparative effectiveness of consumer health informatics applications for the prevention of obesity or overweight in children?

We identified six studies that met our inclusion criteria that evaluated the effects of consumer health informatics (CHI) interventions, but they took place primarily in other settings, and thus we reported them under other KQs.

KQ 1 included five studies with a consumer health informatics component: four on school-based setting with a CHI component to the intervention,165-168 and one on school-based setting with a home and CHI component.170 Two of the school-CHI studies reported on physical activity interventions and showed no significant intervention effect on weight outcomes,165,167 and two reported on combined diet and physical activity interventions,166,168 and one showed a significant intervention effect on BMI (p<0.001),166 while the other failed to show an intervention effect. The study reporting on the school-home-CHI intervention used a combined diet and physical activity intervention and demonstrated no intervention effect on weight outcomes.170

KQ 2 included one study with a CHI component: the study took place in a home-based setting with primary care and CHI components.175 This study used a combination diet and physical activity intervention and showed no difference in BMI z-score between the intervention and control during followup after adjusting for baseline BMI z-score, age, and ethnicity, and significant improvements in sedentary behaviors for both genders and active days per week among boys. Subgroup analysis for participants with BMI at or above 95th percentile showed a desirable but insignificant intervention effect: BMI z-score was 2.08±0.02 for intervention and 2.12±0.02 for the control during followup (P=.10).The intervention did not demonstrate an overall effect on BMI z scores.

The six CHI intervention studies identified only took place in concert with other interventions, primarily school-based, and also home-based physical activity and dietary interventions. CHI interventions contributed to improvements in intermediate outcomes, particularly physical activity, but only one166 of these six studies, which used a school-based diet and physical activity intervention, in concert with a CHI component, demonstrated a change in weight outcomes.