# References

1 Centers for Disease Control (CDC). Childhood Overweight and Obesity. Updated March 31, 2010. www.cdc.gov/obesity/childhood/index.html.
2 Wang Y, Lim H. The global childhood obesity epidemic and the association between socio-economic status and childhood obesity. Int Rev Psychiatry. June. 2012;24(3):176-88. [pmid: 22724639].
3 Wang Y, Beydoun MA. The obesity epidemic in the United States--gender, age, socioeconomic, racial/ethnic, and geographic characteristics: a systematic review and meta-regression analysis. Epidemiol Rev. 2007;29:6-28. [pmid: 17510091].
4 Wang Y, Lobstein T. Worldwide trends in childhood overweight and obesity. Int J Pediatr Obes. 2006;1(1):11-25. [pmid: 17902211].
5 Wang Y, Mi J, Shan XY, et al. Is China facing an obesity epidemic and the consequences? The trends in obesity and chronic disease in China. Int J Obes (Lond). Jan. 2007;31(1):177-88. [pmid: 16652128].
6 Ogden C, Carroll M, Kit B, et al. Prevalence of obesity and trends in body mass index among US children and adolescents, 1999-2010. JAMA: Journal of the American Medical Association. 2012;307(5):483-90. [pmid: 22253364].
7 Ogden CL, Carroll MD, Flegal KM. High body mass index for age among US children and adolescents, 2003-2006. JAMA. 2008;299(20):2401-5. [pmid: 18505949].
8 Birch LL, Anzman-Frasca S. Promoting children's healthy eating in obesogenic environments: Lessons learned from the rat. Physiol Behav. 2011. [pmid: 21620880].
9 Centers for Disease Control (CDC). 2010. Overweight & Obesity: Obesity Prevalence Among Low-Income, Preschool-Aged Children 1998-2008. Updated March 16, 2010. www.cdc.gov/obesity/childhood/lowincome.html.
10 Centers for Disease Control (CDC). 2010. Overweight & Obesity: Obesity Prevalence Among Low-Income, Preschool-Aged Children 1998-2008. Updated March 16, 2010. www.cdc.gov/obesity/childhood/lowincome.html.
11 Ozden MG, Tekin NS, Gurer MA, et al. Environmental risk factors in pediatric psoriasis: a multicenter case-control study. Pediatr Dermatol. 2011;28(3):306-12. [pmid: 21615473].
12 Wang Y, Zhang Q. Are American children and adolescents of low socioeconomic status at increased risk of obesity? Changes in the association between overweight and family income between 1971 and 2002. Am J Clin Nutr. 2006;84(4):707-16. [pmid: 17023695].
13 Sallis JF, Owen N. Ecological Models. Health Behavior adn Health Education (Theory, Research, and Practice). Glanz K, Lewis FM, Nad Rimer K, editors. 2nd Ed. Jossey-Bass. San Francisco. 1997:403-424.
14 World Health Organization. Global Strategy on Diet, Physical Activity, and Health. www.who.int/dietphysicalactivity/childhood_what_can_be_done/en/index.html.
15 Institute of Medicine. Preventing Childhood Obesity: Health in the Balance. 2005. www.nap.edu/catalog.php?record_id=11015.
16 Koplan JP, Liverman CT, Kraak VI. Preventing childhood obesity: health in the balance: executive summary. J Am Diet Assoc. 2005;105(1):131-8. [pmid: 15635359].
17 Shiwaku K, Anuurad E, Enkhmaa B, Kitajima K, Yamane Y. Appropriate BMI for Asian populations. Lancet. 2004;363(9414):1077. [pmid: 15051297].
18 Wang Y, Moreno LA, Caballero B, Cole TJ. Limitations of the current world health organization growth references for children and adolescents. Food Nutr Bull. 2006;27(4 Suppl Growth Standard):S175-88. [pmid: 17361655].
19 Wang Y. Epidemiology of childhood obesity - Methodological aspects and guidelines: What is new?. Int J Obes. 2004;28(SUPPL. 3):S21-S28. [pmid: 15543215].
20 Wang Y, Moreno LA, Caballero B, Cole TJ. Limitations of the current world health organization growth references for children and adolescents. Food Nutr Bull. 2006;27(4 Suppl Growth Standard):S175-88. [pmid: 17361655].
21 Wejdmark AK, Bonnett B, Hedhammar A, Fall T. Lifestyle risk factors for progesterone-related diabetes mellitus in elkhounds - a case-control study. J Small Anim Pract. 2011;52(5):240-5. [pmid: 21539568].
22 Must A, Dallal GE, Dietz WH. Reference data for obesity: 85th and 95th percentiles of body mass index (wt/ht2) and triceps skinfold thickness. Am J Clin Nutr. 1991;53(4):839-46. [pmid: 2008861].
23 Kuczmarski RJ, Ogden CL, Grummer-Strawn LM, et al. CDC growth charts: United States. Adv Data. 2000;(314):1-27. [pmid: 11183293].
24 Must A, Dallal GE, Dietz WH. Reference data for obesity: 85th and 95th percentiles of body mass index (wt/ht2) and triceps skinfold thickness. Am J Clin Nutr. 1991;53(4):839-46. [pmid: 2008861].
25 Curatola G, Bolignano D, Rastelli S, et al. Ultrafiltration intensification in hemodialysis patients improves hypertension but increases AV fistula complications and cardiovascular events. J Nephrol. 2011;24(4):465-73. [pmid: 21534239].
26 Mei Z, Grummer-Strawn LM, Pietrobelli A, et al. Validity of body mass index compared with other body-composition screening indexes for the assessment of body fatness in children and adolescents. Am. J. Clin. Nutr. 2002;75(6):978-85. [pmid: 12036802].
27 Pietrobelli A, Faith MS, Allison DB, Gallagher D, Chiumello G, Heymsfield SB. Body mass index as a measure of adiposity among children and adolescents: a validation study. J Pediatr. 1998;132(2):204-10. [pmid: 9506629].
28 Serdula MK, Ivery D, Coates RJ, Freedman DS, Williamson DF, Byers T. Do obese children become obese adults? A review of the literature. Prev Med. 1993;22(2):167-77. [pmid: 8483856].
29 Whitaker RC, Wright JA, Pepe MS, Seidel KD, Dietz WH. Predicting obesity in young adulthood from childhood and parental obesity. N Engl J Med. 1997;337(13):869-73. [pmid: 9302300].
30 Freedman DS, Khan LK, Serdula MK, Dietz WH, Srinivasan SR, Berenson GS. The relation of childhood BMI to adult adiposity: The Bogalusa heart study. Pediatrics. 2005;115(1):22-7. [pmid: 15629977].
31 Freedman DS, Mei Z, Srinivasan SR, Berenson GS, Dietz WH. Cardiovascular risk factors and excess adiposity among overweight children and adolescents: the Bogalusa Heart Study. J Pediatr. 2007;150(1):12-7.e2. [pmid: 17188605].
32 Goldhaber-Fiebert JD, Rubinfeld RE, Bhattacharya J, Robinson TN, Wise PH. The Utility of Childhood and Adolescent Obesity Assessment in Relation to Adult Health. Med Decis Making. 2012. [pmid: 22647830].
33 Reilly JJ, Kelly J. Long-term impact of overweight and obesity in childhood and adolescence on morbidity and premature mortality in adulthood: systematic review. Int J Obes (Lond). 2010. [pmid: 20975725].
34 Li L, Pinot de Moira A, Power C. Predicting cardiovascular disease risk factors in midadulthood from childhood body mass index: utility of different cutoffs for childhood BMI. Am J Clin Nutr. 2011. [pmid: 21430113].
35 Wang Y, Beydoun MA, Liang L, Caballero B, Kumanyika SK. Will all Americans become overweight or obese? estimating the progression and cost of the US obesity epidemic. Obesity (Silver Spring). 2008;16(10):2323-30. [pmid: 18719634].
36 Thomson Medstat Research Brief: Childhood Obesity: Costs, Treatment Patterns, Disparities in Care and Prevalent Medical Conditions. 2006. found at: http://www.medstat.com/pdfs/childhood_obesity.pdf.
37 Hampl SE, Carroll CA, Simon SD, et al. Resource utilization and expenditures for overweight and obese children. Arch. Pediatr. Adolesc. Med. 2007;161(1):11-4. [pmid: 17199061].
38 Hampl SE, Summar MJ. 'Weighing in' on childhood obesity. Pediatr Ann. March. 2009;38(3):143-8. [pmid: 19353903].
39 Bray JA, James WPT, Bouchard C. Handbook Of Obesity. Second Edition. New York. Marcel Dekker, INC. 1998.
40 Whitlock EP, O'Connor EA, Williams SB, Beil TL, Lutz KW. Effectiveness of weight management interventions in children: a targeted systematic review for the USPSTF. Pediatrics. 2010;125(2):e396-418. [pmid: 20083531].
41 Moher D, Liberati A, Tetzlaff J, Altman DG. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. BMJ. 2009;339:b2535. [pmid: 19622551].
42 Human Development Reports. Human Development Index. http://hdr.undp.org/en/statistics/hdi/. 21 May 2012.
43 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52(6):377-84. [pmid: 9764259].
44 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sept. 1986;7(3):177-88. [pmid: 3802833].
45 Donnelly JE, Greene JL, Gibson CA, et al. Physical Activity Across the Curriculum (PAAC): a randomized controlled trial to promote physical activity and diminish overweight and obesity in elementary school children. Prev Med. 2009;49(4):336-41. [pmid: 19665037].
46 Foster GD, Linder B, Baranowski T, et al. A school-based intervention for diabetes risk reduction. N Engl J Med. July. 29. 2010;363(5):443-53. [pmid: 20581420].
47 Graf C, Koch B, Falkowski G, et al. School-based prevention: effects on obesity and physical performance after 4 years. J Sports Sci. 2008;26(10):987-94. [pmid: 18608843].
48 Gutin B, Yin Z, Johnson M, Barbeau P. Preliminary findings of the effect of a 3-year after-school physical activity intervention on fitness and body fat: the Medical College of Georgia Fitkid Project. Int J Pediatr Obes. Suppl 1. 2008;3:3-9. [pmid: 18278626].
49 James J, Thomas P, Cavan D, Kerr D. Preventing childhood obesity by reducing consumption of carbonated drinks: Cluster randomised controlled trial. Br. Med. J. 2004;328(7450):1237-9. [pmid: 15107313].
50 Neumark-Sztainer DR, Friend SE, Flattum CF, et al. New moves-preventing weight-related problems in adolescent girls a group-randomized study. Am J Prev Med. 2010;39(5):421-32. [pmid: 20965379].
51 Sahota P, Rudolf MC, Dixey R, Hill AJ, Barth JH, Cade J. Randomised controlled trial of primary school based intervention to reduce risk factors for obesity. BMJ. 2001;323(7320):1029-32. [pmid: 11691759].
52 Walther C, Gaede L, Adams V, et al. Effect of increased exercise in school children on physical fitness and endothelial progenitor cells: a prospective randomized trial. Circulation. 2009;120(22):2251-9. [pmid: 19920000].
53 Warren JM, Henry CJ, Lightowler HJ, Bradshaw SM, Perwaiz S. Evaluation of a pilot school programme aimed at the prevention of obesity in children. Health Promot Int. 2003;18(4):287-96. [pmid: 14695360].
54 James J, Thomas P, Kerr D. Preventing childhood obesity: Two year follow-up results from the Christchurch obesity prevention programme in schools (CHOPPS). BMJ: British Medical Journal. 2007;335(7623):1-6. [pmid: 17615183].
55 Muckelbauer R, Libuda L, Clausen K, Toschke AM, Reinehr T, Kersting M. Promotion and provision of drinking water in schools for overweight prevention: randomized, controlled cluster trial. Pediatrics. 2009;123(4):e661-7. [pmid: 19336356].
56 Gortmaker SL, Peterson K, Wiecha J, et al. Reducing obesity via a school-based interdisciplinary intervention among youth: Planet Health. Arch Pediatr Adolesc Med. 1999;153(4):409-18. [pmid: 10201726].
57 Howe C, Harris R, Gutin B. A 10-month physical activity intervention improves body composition in young black boys. Journal of Obesity. 2011:8p. [pmid: 20981151].
58 Llargues E, Recasens A, Franco R, et al. Medium-term evaluation of an educational intervention on dietary and physical exercise habits in schoolchildren: The Avall 2 study: Evaluacion a medio plazo de una intervencion educativa en habitos alimentarios y de actividad fisica en escolares: Estudio Avall 2. Endocrinol Nutr. 2012;59(5):288-95. [pmid: 22521298].
59 Lubans DR, Morgan PJ, Callister R. Potential moderators and mediators of intervention effects in an obesity prevention program for adolescent boys from disadvantaged schools. J Sci Med Sport. 2012. [pmid: 22575499].
60 Lubans DR, Morgan PJ, Okely AD, et al. Preventing Obesity Among Adolescent Girls: One-Year Outcomes of the Nutrition and Enjoyable Activity for Teen Girls (NEAT Girls) Cluster Randomized Controlled Trial. Arch Pediatr Adolesc Med. 2012. [pmid: 22566517].
61 Magnusson KT, Hrafnkelsson H, Sigurgeirsson I, Johannsson E, Sveinsson T. Limited effects of a 2-year school-based physical activity intervention on body composition and cardiorespiratory fitness in 7-year-old children. Health Education Research. 2012;27(3):484-94. [pmid: 22456632].
62 Rosario R, Oliveira B, Araujo A, et al. The impact of an intervention taught by trained teachers on childhood overweight. Int. J. Environ. Res. Public Health. 2012;9(4):1355-67. [pmid: 22690198].
63 Rush E, Reed P, McLennan S, et al. A school-based obesity control programme: Project Energize. Two-year outcomes. British Journal of Nutrition. 2012;107(4):581-7. [pmid: 21733268].
64 Coleman KJ, Shordon M, Caparosa SL, et al. Changing nutrition policies and environments in low-income schools using implementation models: The healthy options for nutrition environments in schools (ONES) intervention. Obesity. 2011;19:S124. http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L70680833.
65 DeBar LL, Schneider M, Drews KL, et al. Student public commitment in a school-based diabetes prevention project: impact on physical health and health behavior. BMC Public Health. 2011;11:711. [pmid: 21933431].
66 Walter HJ, Hofman A, Connelly PA, Barrett LT, Kost KL. Primary prevention of chronic disease in childhood: changes in risk factors after one year of intervention. Am J Epidemiol. 1985;122(5):772-81. [pmid: 4050769].
67 Madsen J, Sallis JF, Rupp JW, et al. Relationship between self-monitoring of diet and exercise change and subsequent risk factor changes in children and adults. Patient Educ Couns. 1993;21(1-2):61-9. [pmid: 8337206].
68 Barbeau P, Johnson MH, Howe CA, et al. Ten months of exercise improves general and visceral adiposity, bone, and fitness in black girls. Obesity (Silver Spring). 2007;15(8):2077-85. [pmid: 17712126].
69 Trevi±o RP, Hernandez AE, Yin Z, Garcia OA, Hernandez I. Effect of the Bienestar Health Program on Physical Fitness in Low-Income Mexican American Children. Hispanic Journal of Behavioral Sciences. 2005;27(1):120-32. http://search.ebscohost.com/login.aspx?direct=true&db=psyh&AN=2005-01342-007&site=ehost-live.
70 Bush PJ, Zuckerman AE, Theiss PK, et al. Cardiovascular risk factor prevention in black schoolchildren: two-year results of the "Know Your Body" program. Am J Epidemiol. 1989;129(3):466-82. [pmid: 2916540].
71 Haerens L, Deforche B, Maes L, Stevens V, Cardon G, De Bourdeaudhuij I. Body mass effects of a physical activity and healthy food intervention in middle schools. Obesity (Silver Spring). 2006;14(5):847-54. [pmid: 16855194].
72 Amaro S, Di Costanzo A, Madeo I, et al. Kaledo, a new educational board-game, gives nutritional rudiments and encourages healthy eating in children: A pilot cluster randomized trial. European Journal of Pediatrics. 2006;165(9):630-5. [pmid: 16733670].
73 Martínez Vizcaíno V, Salcedo Aguilar F, Franquelo Gutiérrez R, et al. Assessment of an after-school physical activity program to prevent obesity among 9- to 10-year-old children: a cluster randomized trial. International Journal of Obesity (2005). 2008;32(1):12-22. [pmid: 17895883].
74 Klish WJ, Karavias KE, White KS, et al. Multicomponent school-initiated obesity intervention in a high-risk, Hispanic elementary school. J. Pediatr Gastroenterol Nutr. 2012;54(1):113-6. [pmid: 21857252].
75 Sallis JF, McKenzie TL, Conway TL, et al. Environmental interventions for eating and physical activity: a randomized controlled trial in middle schools. Am J Prev Med. 2003;24(3):209-17. [pmid: 12657338].
76 Thivel D, Isacco L, Lazaar N, et al. Effect of a 6-month school-based physical activity program on body composition and physical fitness in lean and obese schoolchildren. Eur J Pediatr. 2011:1-9. [pmid: 21475968].
77 Metcalf B, Wilkin T, Puder J, et al. Lifestyle intervention has little effect on obesity. Comment on Puder JJ, Marques-Vidal P, Schindler C, , et al. Effect of multidimensional lifestyle intervention on fitness and adiposity in predominantly migrant preschool children (Ballabeina): cluster randomised controlled trial. BMJ 2011;343:d6195. (13 October.). BMJ: British Medical Journal (Overseas & Retired Doctors Edition). 2012;344(7842):32-3. [pmid: 22293374].
78 Kafatos A, Manios Y, Moschandreas J, et al. Health and nutrition education in primary schools of Crete: Follow-up changes in body mass index and overweight status. Eur. J. Clin. Nutr. 2005;59(9):1090-2. [pmid: 16015265].
79 Lazaar N, Aucouturier J, Ratel S, Rance M, Meyer M, Duche P. Effect of physical activity intervention on body composition in young children: Influence of body mass index status and gender. Acta Paediatr. Int. J. Paediatr. 2007;96(9):1315-20. [pmid: 17718785].
80 Salmon J, Ball K, Hume C, Booth M, Crawford D. Outcomes of a group-randomized trial to prevent excess weight gain, reduce screen behaviours and promote physical activity in 10-year-old children: switch-play. Int J Obes (Lond). 2008;32(4):601-12. [pmid: 18253162].
81 Jago R, McMurray RG, Drews KL, et al. HEALTHY Intervention: Fitness, Physical Activity and Metabolic Syndrome Results. Med Sci Sports Exerc. 2011. [pmid: 21233778].
82 Reed KE, Warburton DE, Macdonald HM, et al. Action Schools! BC: a school-based physical activity intervention designed to decrease cardiovascular disease risk factors in children. Preventive Medicine. 2008;46(6):525-31. [pmid: 18377970].
83 Vandongen R, Jenner DA, Thompson C, et al. A controlled evaluation of a fitness and nutrition intervention program on cardiovascular health in 10- to 12-year-old children. Prev Med. 1995;24(1):9-22. [pmid: 7740021].
84 Kain J, Leyton B, Cerda R, et al. Two-year controlled effectiveness trial of a school-based intervention to prevent obesity in Chilean children. Public Health Nutr. 2009;12(9):1451-61. [pmid: 19102808].
85 Newton RL Jr, Han H, Anton SD, et al. An environmental intervention to prevent excess weight gain in African-American students: a pilot study. Am J Health Promot. 2010;24(5):340-3. [pmid: 20465148].
86 Sallis JF, McKenzie TL, Alcaraz JE, et al., Project SPARK. Effects of physical education on adiposity in children. Ann New York Acad Sci. 1993;699:127-36. [pmid: 8267303].
87 Resaland GK, Anderssen SA, Holme IM, Mamen A, Andersen LB. Effects of a 2-year school-based daily physical activity intervention on cardiovascular disease risk factors: the Sogndal school-intervention study. Scandinavian Journal of Medicine & Science in Sports. 2011;21(6):e122-31. [pmid: 22126720].
88 Stock S, Miranda C, Evans S, et al. Healthy buddies: A novel, peer-led health promotion program for the prevention of obesity and eating disorders in children in elementary school. Pediatrics. 2007;120(4):e1059-e1068. [pmid: 17908726].
89 Smolak L, Levine MP. A two-year follow-up of a primary prevention program for negative body image and unhealthy weight regulation. Eating Disord. 2001;9(4):313-25. [pmid: 16864392].
90 Fung C, Kuhle S, Lu C, et al. From “best practice” to “next practice”: The effectiveness of school-based health promotion in improving healthy eating and physical activity and preventing childhood obesity. 2012:27. [pmid: 22413778].
91 Burguera B, Colom A, Pinero E, et al. ACTYBOSS: Activity, behavioral therapy in young subjects - After-school intervention pilot project on obesity prevention. Obes Facts. 2011;4(5):400-6. [pmid: 22166761].
92 Stenevi-Lundgren S, Daly RM, Linden C, Gardsell P, Karlsson MK. Effects of a daily school based physical activity intervention program on muscle development in prepubertal girls. Eur J Appl Physiol. 2009;105(4):533-41. [pmid: 19018558].
93 Viskic-Stalec N, Stalec J, Katic R, Podvorac D, Katovic D. The impact of dance-aerobics training on the morpho-motor status in female high-schoolers. Coll Antropol. 2007;31(1):259-66. [pmid: 17598411].
94 Damon S, Dietrich S, Widhalm K. PRESTO - Prevention Study of Obesity: A project to prevent obesity during childhood and adolescence. Acta Paediatr Int J Paediatr. 2005;94(SUPP. 448):47-8. [pmid: 16175809].
95 Heelan KA, Abbey BM, Donnelly JE, Mayo MS, Welk GJ. Evaluation of a walking school bus for promoting physical activity in youth. J Phys Act Health. 2009;6(5):560-7. [pmid: 19953832].
96 Skybo TA, Ryan-Wenger N. A school-based intervention to teach third grade children about the prevention of heart disease. Pediatr Nurs. 2002;28(3):223-9. 235. [pmid: 12087641].
97 Tucker S, Lanningham-Foster L, Murphy J, et al. A school based community partnership for promoting healthy habits for life. J Community Health. 2011;36(3):414-22. [pmid: 20976532].
98 Sollerhed A-C, Ejlertsson G. Physical benefits of expanded physical education in primary school: Findings from a 3-year intervention study in Sweden. Scandinavian Journal of Medicine & Science in Sports. 2008;18(1):102-7. [pmid: 17490464].
99 Taylor RW, McAuley KA, Barbezat W, Strong A, Williams SM, Mann JI. APPLE Project: 2-y findings of a community-based obesity prevention program in primary school age children. Am J Clin Nutr. 2007;86(3):735-42. [pmid: 17823440].
100 Manios Y, Kafatos A. Health and nutrition education in primary schools in Crete: 10 years follow-up of serum lipids, physical activity and macronutrient intake. Br J Nutr. 2006;95(3):568-75. [pmid: 16578934].
101 Valdimarsson O, Linden C, Johnell O, Gardsell P, Karlsson MK. Daily physical education in the school curriculum in prepubertal girls during 1 year is followed by an increase in bone mineral accrual and bone width--data from the prospective controlled Malmö pediatric osteoporosis prevention study. Calcified Tissue International. 2006;78(2):65-71. [pmid: 16467972].
102 Scheffler C, Ketelhut K, Mohasseb I. Does physical education modify the body composition?--results of a longitudinal study of pre-school children. Anthropol Anz. 2007;65(2):193-201. [pmid: 17711151].
103 Manios Y, Moschandreas J, Hatzis C, Kafatos A. Evaluation of a health and nutrition education program in primary school children of Crete over a three-year period. Prev Med. 1999;28(2):149-59. [pmid: 10048106].
104 Manios Y, Moschandreas J, Hatzis C, et al. Health and nutrition education in primary schools of Crete: Changes in chronic disease risk factors following a 6-year intervention programme. British Journal of Nutrition. 2002;88(3):315-24. [pmid: 12207842].
105 Bronikowski M, Bronikowska M. Will they stay fit and healthy? A three-year follow-up evaluation of a physical activity and health intervention in Polish youth. Scandinavian Journal of Public Health. 2011;39(7):704-13. [pmid: 21948996].
106 Chiodera P, Volta E, Gobbi G, et al. Specifically designed physical exercise programs improve children's motor abilities. Scandinavian Journal of Medicine & Science in Sports. 2008;18(2):179-87. [pmid: 17490452].
107 McArthur L, Holbert D, Pena M. Obesity knowledge of adolescents from six Latin American cities: A multivariable analysis. Nutr Res. July. 2001;21(10):1323-33. http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L34024012.
108 Salcedo Aguilar F, Martínez-Vizcaíno V, Sánchez López M, et al. Impact of an after-school physical activity program on obesity in children. The Journal of Pediatrics. 2010;157(1):36-42.e3. [pmid: 20227726].
109 Brey RL, Stallworth CL, McGlasson DL, et al. Antiphospholipid antibodies and stroke in young women. Stroke. 2002;33(10):2396-400. [pmid: 12364727].
110 Yin Z, Gutin B, Johnson MH, et al. An environmental approach to obesity prevention in children: Medical College of Georgia FitKid Project year 1 results. Obes Res. 2005;13(12):2153-61. [pmid: 16421350].
111 Slykerman RF, Thompson JMD, Pryor JE, et al. Maternal stress, social support and preschool children's intelligence. Early Hum. Dev. 2005;81(10):815-21. [pmid: 16019165].
112 Will JC, Massoudi B, Mokdad A, et al. Reducing risk for cardiovascular disease in uninsured women: combined results from two WISEWOMAN projects. Journal of the American Medical Women's Association (1972). 2001;56(4):161-5. [pmid: 11759784].
113 Worthmann H, Schwartz A, Heidenreich F, et al. Educational campaign on stroke in an urban population in Northern Germany: influence on public stroke awareness and knowledge. Int J Stroke. 2012. [pmid: 22568388].
114 Trevino RP, Yin Z, Hernandez A, Hale DE, Garcia OA, Mobley C. Impact of the Bienestar school-based diabetes mellitus prevention program on fasting capillary glucose levels: a randomized controlled trial. Arch Pediatr Adolesc Med. 2004;158(9):911-7. [pmid: 15351759].
115 Caballero B, Clay T, Davis SM, et al. Pathways: a school-based, randomized controlled trial for the prevention of obesity in American Indian schoolchildren. Am J Clin Nutr. 2003;78(5):1030-8. [pmid: 14594792].
116 Hendy HM, Williams KE, Camise TS. Kid's Choice Program improves weight management behaviors and weight status in school children. Appetite. 2011;56(2):484-94. [pmid: 21277924].
117 Robinson TN. Reducing children's television viewing to prevent obesity: a randomized controlled trial. JAMA. 1999;282(16):1561-7. [pmid: 10546696].
118 Burke V, Milligan RA, Thompson C, et al. A controlled trial of health promotion programs in 11-year-olds using physical activity “enrichment” for higher risk children. J Pediatr. 1998;132(5):840-8. [pmid: 9602197].
119 Dzewaltowski DA, Rosenkranz RR, Geller KS, et al. HOP'N after-school project: an obesity prevention randomized controlled trial. Int J Behav Nutr Phys Act. 2010;7:90. [pmid: 21144055].
120 Danielzik S, Pust S, Muller MJ. School-based interventions to prevent overweight and obesity in prepubertal children: Process and 4-years outcome evaluation of the Kiel Obesity Prevention Study (KOPS). Acta Paediatr. Int. J. Paediatr. 2007;96(SUPPL. 454):19-25. [pmid: 17313410].
121 Kriemler S, Zahner L, Schindler C, et al. Effect of school based physical activity programme (KISS) on fitness and adiposity in primary schoolchildren: cluster randomised controlled trial. BMJ. 2010;340:c785. [pmid: 20179126].
122 Nader PR, Stone EJ, Lytle LA, et al. Three-year maintenance of improved diet and physical activity: The CATCH cohort. Archives of Pediatrics & Adolescent Medicine. 1999;153(7):695-704. [pmid: 10401802].
123 Mihas C, Mariolis A, Manios Y, et al. Evaluation of a nutrition intervention in adolescents of an urban area in Greece: short- and long-term effects of the VYRONAS study. Public Health Nutr. 2010;13(5):712-9. [pmid: 19781127].
124 Hatzis CM, Papandreou C, Kafatos AG. School health education programs in Crete: Evaluation of behavioural and health indices a decade after initiation. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2010;51(3-4):262-7. [pmid: 20566355].
125 Marcus C, Nyberg G, Nordenfelt A, Karpmyr M, Kowalski J, Ekelund U. A 4-year, cluster-randomized, controlled childhood obesity prevention study: STOPP. Int J Obes (Lond). 2009;33(4):408-17. [pmid: 19290010].
126 Story M, Hannan PJ, Fulkerson JA, et al. Bright Start: Description and Main Outcomes From a Group-Randomized Obesity Prevention Trial in American Indian Children. Obesity. 2012. [pmid: 22513491].
127 Brandstetter S, Klenk J, Berg S, et al. Overweight prevention implemented by primary school teachers: A randomised controlled trial. Obes Facts. 2012;5(1):1-11. [pmid: 22433612].
128 Llargues E, Franco R, Recasens A, et al. Assessment of a school-based intervention in eating habits and physical activity in school children: the AVall study. Journal of Epidemiology & Community Health. 2011;65(10):896-901. [pmid: 21398682].
129 Lloyd JJ, Wyatt KM, Creanor S. Behavioural and weight status outcomes from an exploratory trial of the Healthy Lifestyles Programme (HeLP): a novel school-based obesity prevention programme. BMJ Open. 2012;2(3). [pmid: 22586282].
130 Williamson DA, Champagne CM, Harsha DW, et al. Effect of an Environmental School-Based Obesity Prevention Programon Changes in Body Fat and Body Weight: A Randomized Trial. Obesity (Silver Spring). 2012. [pmid: 22402733].
131 Siegrist M, Lammel C, Haller B, Christle J, Halle M. Effects of a physical education program on physical activity, fitness, and health in children: The JuvenTUM project. Scand J Med Sci Sports. 2011. [pmid: 22092492].
132 Simon C, Schweitzer B, Oujaa M, et al. Successful overweight prevention in adolescents by increasing physical activity: a 4-year randomized controlled intervention. Int J Obes (Lond). 2008;32(10):1489-98. [pmid: 18626482].
133 Foster GD, Sherman S, Borradaile KE, et al. A policy-based school intervention to prevent overweight and obesity. Pediatrics. 2008;121(4):e794-802. [pmid: 18381508].
134 Hopper CA, Munoz KD, Gruber MB, Nguyen KP. The effects of a family fitness program on the physical activity and nutrition behaviors of third-grade children. Res Q Exerc Sport. 2005;76(2):130-9. [pmid: 16128481].
135 Manios Y, Kafatos A, Mamalakis G. The effects of a health education intervention initiated at first grade over a 3 year period: physical activity and fitness indices. Health Educ Res. 1998;13(4):593-606. [pmid: 10345909].
136 Shofan Y, Kedar O, Branski D, et al. A school-based program of physical activity may prevent obesity. Eur J Clin Nutr. 2011;65(6):768-70. [pmid: 21427748].
137 Simonetti D'Arca A, Tarsitani G, Cairella M. Prevention of obesity in elementary and nursery school children. Public Health. 1986;100(3):166-73. [pmid: 3737864].
138 Hollar D, Messiah SE, Lopez-Mitnik G, Hollar TL, Almon M, Agatston AS. Effect of a two-year obesity prevention intervention on percentile changes in body mass index and academic performance in low-income elementary school children. Am J Public Health. 2010;100(4):646-53. [pmid: 20167892].
139 Hoelscher DM, Springer AE, Ranjit N, et al. Reductions in child obesity among disadvantaged school children with community involvement: the Travis County CATCH Trial. Obesity (Silver Spring). Suppl 1. 2010;18:S36-44. [pmid: 20107459].
140 Lionis C, Kafatos A, Vlachonikolis J, et al. The effects of a health education intervention program among Cretan adolescents. Preventive Medicine. 1991;20:685-99. [pmid: 1766941].
141 Schetzina KE, Dalton WT 3rd, Lowe EF, et al. A coordinated school health approach to obesity prevention among Appalachian youth: the Winning with Wellness Pilot Project. Fam Community Health. 2009;32(3):271-85. [pmid: 19525708].
142 Speroni KG, Earley C, Atherton M. Evaluating the effectiveness of the Kids Living Fit program: a comparative study. J Sch Nurs. 2007;23(6):329-36. [pmid: 18052518].
143 Coleman KJ, Tiller CL, Sanchez J, et al. Prevention of the epidemic increase in child risk of overweight in low-income schools: the El Paso coordinated approach to child health. Arch Pediatr Adolesc Med. 2005;159(3):217-24. [pmid: 15753263].
144 Gorely T, Nevill ME, Morris JG, Stensel DJ, Nevill A. Effect of a school-based intervention to promote healthy lifestyles in 7-11 year old children. Int J Behav Nutr Phys Act. 2009;6:5. [pmid: 19154622].
145 Tseng M, Olufade TO, Evers KA, et al. Adolescent lifestyle factors and adult breast density in U.S. Chinese immigrant women. Nutrition & Cancer. 2011;63(3):342-9. [pmid: 21391125].
146 Angelopoulos PD, Milionis HJ, Grammatikaki E, Moschonis G, Manios Y. Changes in BMI and blood pressure after a school based intervention: the CHILDREN study. Eur J Public Health. 2009;19(3):319-25. [pmid: 19208697].
147 Greening L, Harrell KT, Low AK, Fielder CE. Efficacy of a school-based childhood obesity intervention program in a rural southern community: TEAM Mississippi Project. Obesity (Silver Spring). 2011;19(6):1213-9. [pmid: 21233806].
148 Jansen W, Borsboom G, Meima A, et al. Effectiveness of a primary school-based intervention to reduce overweight. Int J Pediatr Obes. 2011;6(2 -2):e70-e77. [pmid: 21609245].
149 De Coen V, De Bourdeaudhuij I, Vereecken C, et al. Effects of a 2-year healthy eating and physical activity intervention for 3-6-year-olds in communities of high and low socio-economic status: the POP (Prevention of Overweight among Pre-school and school children) project. Public Health Nutr. 2012:1-9. [pmid: 23294865].
150 de Meij JS, Chinapaw MJ, van Stralen MM, van der Wal MF, van Dieren L, van Mechelen W. Effectiveness of JUMP-in, a Dutch primary school-based community intervention aimed at the promotion of physical activity. Br J Sports Med. 2010. [pmid: 21112875].
151 Sanigorski AM, Bell AC, Kremer PJ, Cuttler R, Swinburn BA. Reducing unhealthy weight gain in children through community capacity-building: results of a quasi-experimental intervention program, Be Active Eat Well. Int J Obes (Lond). 2008;32(7):1060-7. [pmid: 18542082].
152 Millar L, Kremer P, de Silva-Sanigorski A, et al. Reduction in overweight and obesity from a 3-year community-based intervention in Australia: the 'It's Your Move!' project. Obes Rev. Suppl 2. 2011;12:20-8. [pmid: 22008556].
153 Naul R, Schmelt D, Dreiskaemper D, Hoffmann D, l'Hoir M. ‘Healthy children in sound communities’ (HCSC/gkgk)--a Dutch-German community-based network project to counteract obesity and physical inactivity. Fam Pract. Suppl 1. 2012;29:i110-i116. [pmid: 22399539].
154 Tomlin D, Naylor PJ, McKay H, Zorzi A, Mitchell M, Panagiotopoulos C. The impact of Action Schools! BC on the health of Aboriginal children and youth living in rural and remote communities in British Columbia. Int J Circumpolar Health. 2012;71:17999. [pmid: 22456048].
155 Johnson BA, Kremer PJ, Swinburn BA, de Silva-Sanigorski AM. Multilevel analysis of the Be Active Eat Well intervention: environmental and behavioural influences on reductions in child obesity risk. Int J Obes. 2012. [pmid: 22531087].
156 Kazemi M, Rahman A, De Ciantis M. Weight cycling in adolescent Taekwondo athletes. Journal of the Canadian Chiropractic Association. 2011;55(4):318-24. [pmid: 22131569].
157 Swami V, Tovee MJ. Big beautiful women: the body size preferences of male fat admirers. J Sex Res. 2009;46(1):89-96. [pmid: 19116865].
158 Muckelbauer R, Libuda L, Clausen K, Reinehr T, Kersting M. A simple dietary intervention in the school setting decreased incidence of overweight in children. Obes Facts. 2009;2(5):282-5. [pmid: 20057194].
159 Webber LS, Catellier DJ, Lytle LA, et al. Promoting physical activity in middle school girls: Trial of Activity for Adolescent Girls. Am J Prev Med. 2008;34(3):173-84. [pmid: 18312804].
160 Crespo NC, Elder JP, Ayala GX, et al. Results of a multi-level intervention to prevent and control childhood obesity among Latino children: the Aventuras Para Ninos Study. Ann Behav Med. 2012;43(1):84-100. [pmid: 22215470].
161 Macaulay AC, Paradis G, Potvin L, et al. The Kahnawake Schools Diabetes Prevention Project: intervention, evaluation, and baseline results of a diabetes primary prevention program with a native community in Canada. Prev Med. 1997;26(6):779-90. [pmid: 9388789].
162 Madsen KA, Thompson HR, Wlasiuk L, et al. After-school program to reduce obesity in minority children: A pilot study. Journal of Child Health Care. 2009;13(4):333-46. [pmid: 19833672].
163 Utter J, Scragg R, Robinson E, et al. Evaluation of the Living 4 Life project: A youth-led, school-based obesity prevention study. Obes Rev. 2011;12(SUPPL. 2):51-60. [pmid: 22008559].
164 Muckelbauer R, Libuda L, Clausen K, Toschke AM, Reinehr T, Kersting M. Immigrational background affects the effectiveness of a school-based overweight prevention program promoting water consumption. Obesity (Silver Spring). 2010;18(3):528-34. [pmid: 19713953].
165 Schneider M, Dunton GF, Bassin S, Graham DJ, Eliakim A, Cooper DM. impact of a school-based physical activity intervention on fitness and bone in adolescent females. Journal of Physical Activity & Health. 2007;4(1):17-29. [pmid: 17489004].
166 Spiegel SA, Foulk D. Reducing overweight through a multidisciplinary school-based intervention. Obesity (Silver Spring, Md.). 2006;14(1):88-96. [pmid: 16493126].
167 Prins RG, Brug J, van Empelen P, Oenema A. Effectiveness of YouRAction, an intervention to promote adolescent physical activity using personal and environmental feedback: A cluster RCT. PLoS ONE. 2012;7(3). [pmid: 22403695].
168 Ezendam NPM, Brug J, Oenema A. Evaluation of the web-based computer-tailored FATaintPHAT intervention to promote energy balance among adolescents: Results from a school cluster randomized trial. Arch Pediatr Adolesc Med. 2012;166(3):248-55. [pmid: 22064878].
169 Kómár M, Nagymajté nyi L, Nyári T, et al. The determinants of self-rated health among ethnic minorities in Hungary. Ethnicity & Health. 2006;11(2):121-32. [pmid: 16595315].
170 Gorely T, Morris JG, Musson H, et al. Physical activity and body composition outcomes of the GreatFun2Run intervention at 20 month follow-up. International Journal of Behavioral Nutrition & Physical Activity. 2011;8:11. [pmid: 21324105].
171 Epstein LH, Gordy CC, Raynor HA, Beddome M, Kilanowski CK, Paluch R. Increasing fruit and vegetable intake and decreasing fat and sugar intake in families at risk for childhood obesity. Obes Res. 2001;9(3):171-8. [pmid: 11323442].
172 Lappe JM, Rafferty KA, Davies KM, Lypaczewski G. Girls on a high-calcium diet gain weight at the same rate as girls on a normal diet: a pilot study. J Am Diet Assoc. 2004;104(9):1361-7. [pmid: 15354150].
173 French SA, Gerlach AF, Mitchell NR, et al. Household obesity prevention: Take action-a group-randomized trial. Obesity. 2011;19(10):2082-8. [pmid: 21212771].
174 Fitzgibbon ML, Stolley MR, Schiffer L, et al. Family-Based Hip-Hop to Health: Outcome Results. Obesity (Silver Spring). 2012.
175 Patrick K, Calfas KJ, Norman GJ, et al. Randomized controlled trial of a primary care and home-based intervention for physical activity and nutrition behaviors: PACE+ for adolescents. Arch Pediatr Adolesc Med. 2006;160(2):128-36. [pmid: 16461867].
176 Gentile DA, Welk G, Eisenmann JC, et al. Evaluation of a multiple ecological level child obesity prevention program: Switch what you Do, View, and Chew. BMC Med. 2009;7:49. [pmid: 19765270].
177 Polacsek M, Orr J, Letourneau L, et al. Impact of a primary care intervention on physician practice and patient and family behavior: Keep ME Healthy--The Maine Youth Overweight Collaborative. Pediatrics. 2009;123(Suppl):258-66. [pmid: 19470601].
178 Tanofsky-Kraff M, Wilfley DE, Young JF, et al. A pilot study of interpersonal psychotherapy for preventing excess weight gain in adolescent girls at-risk for obesity. Int J Eating Disord. 2010;43(8):701-6. [pmid: 19882739].
179 Bayer O, von Kries R, Strauss A, et al. Short- and mid-term effects of a setting based prevention program to reduce obesity risk factors in children: a cluster-randomized trial. Clin Nutr. 2009;28(2):122-8. [pmid: 19303675].
180 Fitzgibbon ML, Stolley MR, Schiffer L, Van Horn L, KauferChristoffel K, Dyer A. Hip-Hop to Health Jr. for Latino preschool children. Obesity (Silver Spring). 2006;14(9):1616-25. [pmid: 17030973].
181 Burgi F, Niederer I, Schindler C, et al. Effect of a lifestyle intervention on adiposity and fitness in socially disadvantaged subgroups of preschoolers: A cluster-randomized trial (Ballabeina). Prev Med. 2012;54(5):335-40. [pmid: 22373886].
182 Eiholzer U, Meinhardt U, Petro R, Witassek F, Gutzwiller F, Gasser T. High-intensity training increases spontaneous physical activity in children: a randomized controlled study. J Pediatr. 2010;156(2):242-6. [pmid: 19846114].
183 Singh AS, Chin A, Paw MJ, Brug J, van Mechelen W. Dutch obesity intervention in teenagers: effectiveness of a school-based program on body composition and behavior. Arch Pediatr Adolesc Med. 2009;163(4):309-17. [pmid: 19349559].
184 Chomitz VR, McGowan RJ, Wendel JM, et al. Healthy Living Cambridge Kids: a community-based participatory effort to promote healthy weight and fitness. Obesity (Silver Spring). Suppl 1. 2010;18:S45-53. [pmid: 20107461].
185 Economos CD, Hyatt RR, Goldberg JP, et al. A community intervention reduces BMI z-score in children: Shape Up Somerville first year results. Obesity (Silver Spring). 2007;15(5):1325-36. [pmid: 17495210].
186 Robinson TN, Matheson DM, Kraemer HC, et al. A randomized controlled trial of culturally tailored dance and reducing screen time to prevent weight gain in low-income African American girls: Stanford GEMS. Arch Pediatr Adolesc Med. 2010;164(11):995-1004. [pmid: 21041592].
187 Klesges RC, Obarzanek E, Kumanyika S, et al. The Memphis Girls' health Enrichment Multi-site Studies (GEMS): an evaluation of the efficacy of a 2-year obesity prevention program in African American girls. Arch Pediatr Adolesc Med. 2010;164(11):1007-14. [pmid: 21041593].
188 de Silva-Sanigorski AM, Bell AC, Kremer P, et al. Reducing obesity in early childhood: results from Romp & Chomp, an Australian community-wide intervention program. Am J Clin Nutr. 2010;91(4):831-40. [pmid: 20147472].
189 Chang DI, Gertel-Rosenberg A, Drayton VL, Schmidt S, Angalet GB. A statewide strategy to battle child obesity in Delaware. Health Aff (Millwood). 2010;29(3):481-90. [pmid: 20194990].
190 Resnicow K. School-based obesity prevention. Population versus high-risk interventions. ANN. NEW YORK ACAD. SCI. 1993;699:154-66. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L23359976. [pmid: 8267306].
191 Waters E, de Silva-Sanigorski A, Hall BJ, et al. Interventions for preventing obesity in children. Cochrane Database Syst Rev. 2011;(12):CD001871. [pmid: 22161367].
192 Institute of Medicine. 2012. Accelerating Progress in Obesity Prevention: Solving the Weight of the Nation. Washington, DC. National Academies Press. www.iom.edu/Reports/2012/Accelerating-Progress-in-Obesity-Prevention.aspx.
193 Hill JO, Wyatt HR, Reed GW, Peters JC. Obesity and the environment: where do we go from here?. Science. 2003;299(5608):853-5. [pmid: 12574618].
194 Latner JD, Stunkard AJ. Getting worse: the stigmatization of obese children. Obes Res. Mar. 2003;11(3):452-6. [pmid: 12634444].
195 Carter FA, Bulik CM. Childhood obesity prevention programs: how do they affect eating pathology and other psychological measures?. Psychosom Med. 2008;70(3):363-71. [pmid: 18378876].
196 Berg F, Buechner J, Parham E. Guidelines for childhood obesity prevention programs: promoting healthy weight in children. J Nutr Educ Behav. 2003;35(1):1-4. [pmid: 12596730].
197 Zwiauer KF. Prevention and treatment of overweight and obesity in children and adolescents. Eur J Pediatr. Suppl 1. 2000;159:S56-68. [pmid: 11011956].
198 Kropski JA, Keckley PH, Jensen GL. School-based obesity prevention programs: an evidence-based review. Obesity (Silver Spring). 2008;16(5):1009-18. [pmid: 18356849].
199 Jaime PC, Lock K. Do school based food and nutrition policies improve diet and reduce obesity? (Structured abstract). Preventive Medicine. 2009;48(1):45-53. [pmid: 19026676].
200 Doak CM, Visscher TL, Renders CM, Seidell JC. The prevention of overweight and obesity in children and adolescents: a review of interventions and programmes. Obes Rev. 2006;7(1):111-36. [pmid: 16436107].
201 Campbell K, Waters E, O'Meara S, Kelly S, Summerbell C. Interventions for preventing obesity in children. Cochrane Database Syst Rev. 2002;(2):CD001871. [pmid: 12076426].
202 Kamath CC, Vickers KS, Ehrlich A, et al. Clinical review: behavioral interventions to prevent childhood obesity: a systematic review and metaanalyses of randomized trials. J Clin Endocrinol Metab. 2008;93(12):4606-15. [pmid: 18782880].
203 Thomas H. Obesity prevention programs for children and youth: why are their results so modest?. Health Educ Res. 2006;21(6):783-95. [pmid: 17099075].
204 Bautista-Castano I, Doreste J, Serra-Majem L. Effectiveness of interventions in the prevention of childhood obesity. Eur J Epidemiol. 2004;19(7):617-22. [pmid: 15461192].
205 Lopez-Dicastillo O, Grande G, Callery P. Parents' contrasting views on diet versus activity of children: Implications for health promotion and obesity prevention. Patient Education and Counseling. 2010;78(1):117-23. olopezde@unav.es. [pmid: 19560306].
206 Harris KC, Kuramoto LK, Schulzer M, Retallack JE. Effect of school-based physical activity interventions on body mass index in children: a meta-analysis. CMAJ. 2009;180(7):719-26. [pmid: 19332753].
207 Brennan L, Castro S, Brownson RC, Claus J, Orleans CT. Accelerating evidence reviews and broadening evidence standards to identify effective, promising, and emerging policy and environmental strategies for prevention of childhood obesity. Annu Rev Public Health. 2011;32:199-223. [pmid: 21219169].
208 Institute of Medicine. 2010. Bridging the Evidence Gap in Obesity Prevention: A Framework to Inform Decision Making. Washington, DC. National Academies Press. www.iom.edu/Reports/2010/Bridging-the-Evidence-Gap-in-Obesity-Prevention-A-Framework-to-Inform-Decision-Making.aspx.