# Introduction

## Background

### Condition

Childhood obesity is a serious public health problem in the United States (U.S.) and in many other countries worldwide.1-6 Data from the 2007-2008 U.S. National Health and Nutrition Examination Survey indicated that over 30 percent of U.S. children and adolescents (ages 2-19) years are obese or overweight.7 Obesity prevalence increased from 5 to 10.4 percent (children aged 2-5 years), 6.5 to 19.6 percent (children aged 6-11 years), and 5 to 18.1 percent (adolescents aged 12-19 years) between 1976-1980 and 2007-2008.^7,8^ Some minority groups, such as African Americans, Hispanics, and Native Americans, and low-income groups are at higher risk of obesity.3,9-11 However, the patterns are complicated, and not all low-income or minority groups are at high risk; the relationship between obesity and social-economic status has changed over time in the U.S.3,12 Asian Americans have a lower prevalence of obesity than other ethnic groups, while higher income African American girls are more likely to be overweight than their lower income counterparts. On the contrary, there is an inverse relationship between obesity and social-economic status in white girls. However, social-economic status factors only explain a very small portion of the variations in body mass index (BMI), approximately 1 or 2 percent. Obesity is difficult to treat and prevention of childhood obesity has been identified as a key to fight the growing global obesity epidemic.

### Complex Causes of Obesity

Obesity is the result of many biological, behavioral, social, environmental, and economic factors and the complex interactions between them that promote a positive energy balance. At present, how these factors contribute to the disparities in obesity prevalence between population groups in the U.S. remain poorly understood. Nevertheless, a growing body of research adds to the understanding of a socio-ecological model for childhood obesity and suggests that many factors interact, such as individual factors (e.g., genetics, nutrition knowledge and attitude, body weight image), home influences (e.g., parenting, food served at home, parental weight status), school factors (e.g., nutrition service, curriculum including physical activity, annual BMI measure), factors in the local community (e.g., food environment, crime rate), and those at the regional and national levels (e.g., built environment, economic factors such as food prices, and food assistance programs).13 They contribute to obesogenic environments and affect children's weight. A number of leading health organizations, including the World Health Organization14 and the Institute of Medicine,15 have recommended comprehensive interventions to prevent childhood obesity.16

### Measurement of Adiposity and Classification of Childhood Obesity

The public health, research and medical communities have used various measures to assess adiposity and childhood obesity, which is a challenge for researchers and other health professionals in the field as well as for researchers conduct reviews. Although studies have mostly used BMI in the classification of obesity in adults and children, it remains controversial regarding what BMI cut points are most appropriate for a specific population.17,18 Researchers have used different sex-age specific BMI percentile cut-points in the U.S. and worldwide.18-21 For example, in the U.S., researchers have used two cut points, 85th (for “overweight”) and 95th percentiles (for “obesity”), to define the conditions in children. Must et al. published one in 1991 based on NHANES I22 and the Centers for Disease Prevention and Control published the other based on the 2000 U.S. Center for Disease Control and Prevention growth charts and a series of datasets.23 In general, the values of the two sets of percentiles are similar, but researchers developed them based on different data sets and growth curve fitting techniques.22-25

Researchers in the field have even used different terms for overweight and obesity among children. Before the mid-2000s, key health organizations including the World Health Organization and the U.S. Center for Disease Control and Prevention recommended the use of the term of “at risk of overweight” for “overweight”, and “overweight” for “obesity.” Some other health organizations, such as the International Obesity Taskforce, have recommended using the terms “overweight” and “obesity” the same as they do for adults, and not using the term of “at risk of overweight.” These discrepancies have further complicated the interpretation of the literature.

Additionally, BMI is an indirect measure of adiposity, and thus has several limitations. For example, it cannot distinguish between muscle mass and fat mass.19 As a result, health care professionals have increasingly used other measures for various purposes, such as percentage of body fat measured via direct measures such as dual-emission X-ray absorptiometry, waist circumference (which measures central obesity), waist-to-height ratio, skinfold thickness, and related cut points, to assess adiposity and define obesity in adults and children. The correlations between direct and indirect measures of adiposity vary across age groups, degree of obesity, and lean muscle mass. Nevertheless, overall the correlations among them are strong.26,27

In summary, the definition of overweight and obesity has been evolving over time, and is not clear even today. This, combined with the controversy over the way we measure adiposity, makes it complicated to synthesize the existing literature. We recognize the need for studies to demonstrate both statistical significance (p value<0.05) and biologically or clinically meaningful change (i.e., effect size) when demonstrating an effect of intervention programs. However, to our knowledge, there is no consensus in the pediatric obesity field regarding what effect size might be considered a meaningful change.

### Consequences of Childhood Obesity

Childhood obesity has many intermediate- and long-term health consequences. Overweight children and adolescents are at greater risk for health problems compared to their normal weight counterparts.1 Overweight children and adolescents are more likely to become obese adults.28-30 Obese children and adolescents are more likely to have adverse health conditions, such as poor cardiovascular, metabolic, and psychosocial outcomes.31 However, the link between childhood and adulthood obesity was more prominent among older children.32 Obesity is a risk factor for many chronic conditions, including type 2 diabetes, hypertension, high cholesterol, stroke, heart disease, nonalcoholic fatty liver disease, certain cancers, and arthritis.30,31,33,34 It is estimated that excess weight causes 70 percent of diabetes in the U.S. Obesity increases mortality as well.33 The other reported health risks of childhood obesity include eating disorders and mental health issues, such as depression and low self-esteem.34 Obesity also has a lot of financial consequences. Overweight and obesity and their associated health problems have a significant economic impact on the U.S. health care system.35 Childhood obesity in the U.S. is estimated to cost $11 billion for children with private insurance and $3 billion for children on Medicaid.36 The health care costs of an overweight or obese child are roughly 3 times or $172 higher than the average normal-weight child, as obese children are 2 to 3 times more likely to be hospitalized and are far more likely to have health disorders than non-obese children.37,38 Further, once developed, obesity is difficult to treat (i.e., due to the “set point theory”).39 Therefore, it is important that children develop life-long healthy lifestyles to prevent obesity.

### Types of Interventions for Prevention of Childhood Obesity

Interventions for the prevention of childhood obesity have a primary goal of preventing children from gaining excessive body weight, including diet, physical or sedentary activity, or a combination of these interventions. Unlike weight-loss studies, these interventions do not have a goal of helping children lose weight. However, childhood obesity prevention studies often enroll a diverse population that includes obese and overweight children.

## Scope of the Review

This report focuses on the comparative effectiveness of obesity prevention programs in children conducted in high-income countries based on a variety of outcome measures of adiposity including clinical outcomes, eating and physical activity behavioral outcomes, and potential harms. We focus in this report on the comparative effectiveness of interventions; thus, outcomes need to be compared between two groups each of which received an intervention or two groups where one group received usual care or no intervention. This review mainly compares the effects of an intervention against a control. We compared obesity prevention programs to usual care, active control, and/or other obesity prevention programs. We grouped our results based on setting and intervention (e.g., school-based dietary interventions) to shed light on the effectiveness of different interventions (e.g., diet versus physical activity). However, due to the large heterogeneity across such intervention studies and the scope of our study, we could not conduct specific statistical analysis to compare them.

The review does not include treatment of overweight or obese children, which the Agency for Healthcare Research and Quality (AHRQ) recently reviewed. We reviewed studies according to the setting where the studies were conducted and our Key Questions (KQs) are as follow.

## Key Questions

Key Question 1. What is the comparative effectiveness of school-based interventions for the prevention of obesity or overweight in children?

Key Question 2. What is the comparative effectiveness of home-based interventions for the prevention of obesity or overweight in children?

Key Question 3. What is the comparative effectiveness of primary care-based interventions for the prevention of obesity or overweight in children?

Key Question 4. What is the comparative effectiveness of child-care setting–based interventions for the prevention of obesity or overweight in children?

Key Question 5. What is the comparative effectiveness of community-based or environment-level interventions for the prevention of obesity or overweight in children?

Key Question 6. What is the comparative effectiveness of consumer health informatics applications for the prevention of obesity or overweight in children?

Key Question 7. What is the comparative effectiveness of multisetting interventions for the prevention of obesity or overweight in children?

## Interventions and Controversy About the Topic

We differentiate between prevention, often called “intervention” in the childhood obesity research field, and treatment, also called “weight management.” The main goal of most childhood obesity prevention programs is to prevent non-overweight children from becoming overweight or obese, while the primary objective of obesity treatment programs is for obese patients to achieve healthy body weight (e.g., losing weight, improving height-to-weight ratio). However obesity prevention programs may also help overweight or obese children to lose weight or stabilize their weight. This review focuses on prevention. We did not review treatment of overweight or obese children, as a recent AHRQ report already reviewed this.40

Interventions to prevent obesity in children included diet (called “diet intervention” in this report), physical and/or sedentary activity (called “physical activity intervention”), or a combination of these (called “diet and physical activity intervention”). Note that a very small proportion of diet and physical activity intervention studies may also address other behaviors, such as self-weight monitoring. For clarity, and given there were a small number of such studies, we chose not to separate them from those that only diet and physical and/or sedentary activity interventions.

Some interventions included changes in individuals' knowledge, attitudes and beliefs, and some included changes in the physical environment such as food provided in the school, but all of them aimed to change the energy balance by changing diet (energy intake) or physical activity (energy expenditure) or both. A growing consensus is that we need comprehensive intervention programs that involve multiple sectors in our society or that address multiple factors affecting energy balance behaviors to fight the obesity epidemic. However, studies to date have yielded mixed results.

We identified over 20 previous systematic reviews of childhood obesity prevention. Despite the many reviews (some as recent as 2011) there were few conclusions to guide decisionmaking. The majority of them focused on school-based interventions and did not include those that took place in other relevant settings, such as home, community, and primary care. Schools are the most frequent setting for interventions as they are convenient for RCTs; it is uncertain, however, if schools are the most effective setting in which to intervene. Most only focused on BMI and obesity rates outcomes, but did not examine the other important outcomes. And some systematic reviews confined their searches to evidence from a particular geographic region, such as in China, Europe, the United Kingdom, and the U.S.; and few included any quantitative pooling, which is a one key goal of systematic reviews. Additionally, many new studies have appeared since the publication of these earlier reviews.

## Organization of This Report

Because the interventions vary substantially across the settings, we organized this report first by the primary setting where the interventions took place (e.g., school, home) and then by the interventions within that setting. This should facilitate use of the evidence report as it is expected that decision-makers are best able to implement interventions in the settings over which they have control (e.g. schools). This report describes 125 studies (described in 132 articles) classified by the setting or settings (e.g., school, home) where the interventions took place. Most of the studies we included in this report took place in multiple settings (e.g., both school and home), and therefore we eliminated KQ 7 in the reporting of our results, and put those studies under one of the six other KQs depending on their primary setting of intervention.

For each KQ, we present the results according to the study design (e.g., randomized controlled trials (RCTs) vs. non-RCTs) and then the intervention (e.g., dietary changes, physical or sedentary activity changes, or both (this may also address changes such as self-weight monitoring)).

We then describe the results ordered by outcomes, such as weight-related outcomes, clinical outcomes related to obesity (e.g., blood pressure, blood lipids), behavioral outcomes (e.g., dietary intake, physical activity), and adverse effects of interventions (Table 1 and Figure 1). The weight-related outcomes include weight or body composition outcomes (e.g., BMI, weight, BMI z-score, waist circumference, percent body fat, skinfold thickness, population prevalence of obesity or overweight).

Table 1 Characteristics of the studies according to the PICOTS framework

Population(s) | All Children Between the Ages of 2 and 18 Years, Regardless of BMI Classification
Interventions | KQ 1: Examples of diet, physical activity or combination interventions delivered in schools.; - Includes: nutrition education, Nutrition, diet, healthy eating, parenting styles,education, policy; KQ 2: Examples of diet, physical activity or combination interventions delivered or implemented in the home.; - Includes: healthy eating education, parenting styles,education; KQ 3: Examples of diet, physical activity or combination interventions delivered or recommended in a primary care setting.; - Includes: patient, parent, and family counseling; referrals to nutritionists; KQ 4: Examples of diet, physical activity or combination interventions delivered in a child-care setting.; - Includes menu changes, physical activity, policy; KQ 5: Examples of diet, physical activity or a combination interventions delivered or implemented at the community level or through environmental modification.; - Includes: physical activity, farmer's markets, community gardens, cooking lessons, policy, green space, food store accessibility, access to healthy food choices; KQ 6: Examples of diet, physical activity or a combination interventions delivered with consumer health informatics; - Includes: Web-based interventions, cell phone-based interventions; KQ 7: Examples of diet, physical activity or combination interventions delivered across a combination of settings.
Comparisons | No intervention Usual care or other interventions by settings NOTE: We will compare the intervention group vs. the control group (i.e., those who did not receive intervention or received usual care or other interventions) within each study and then across studies within the same setting (e.g., schools, child-care centers).
Outcomes | Primary outcomes; - Weight-related or body composition outcomes including in BMI or BMI distribution in the population, in adiposity or other weight measures, prevalence of obesity or overweight; Intermediate outcomes; - Dietary intake, fruit and vegetable intake, fatty food intake, sugar-sweetened beverage intake, physical activity, sedentary activity.; Adverse effects; - Correlates to eating disorders, psychosocial outcomes, impact on growth and development, injury, cost; Obesity-related clinical outcomes; - Cardiovascular outcomes, metabolic outcomes, psychosocial outcomes
Timing | Outcome assessment must be at least 6 months from the baseline assessment for KQ 1 school-based interventions. Outcome assessment must be at least 1 year from the baseline assessment for KQs 2 through 7 (if it does not include school-based interventions). Outcome assessment must be at least 6 months from the baseline assessment for KQs 2 through 7 (if the KQ includes school-based interventions).
Setting | Schools, home, primary-care clinics, child-care settings, or community organizations, environmental-level interventions, consumer health informatics, or across these settings

KQ = Key Question, CHI = Consumer Health Informatics

Figure 1 Analytic framework for comparative effectiveness of childhood obesity intervention program

KQ = Key Question

This figure illustrates the population included in this study (all children age 12-18 year), intermediate outcomes of interest, primary weight related outcomes, obesity related clinical outcomes and adverse effects of the intervention.