# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Laurie Anderson, Ph.D., M.P.H.
  Centers for Disease Control and Prevention
  Scientific Information and Dissemination Branch
  Atlanta, GA
- David Katz, M.D., M.P.H.
  Yale University
  School of Medicine
  Derby, CT
- Tim Lobstein, Ph.D.
  Director of Policy and Programmes
  IASO – The International Association for the Study of Obesity
  London, United Kingdom
- Kristine Madsen, M.D.
  University of California, San Francisco
  School of Medicine
  San Francisco, CA
- Joshua Sharfstein, M.D.
  Secretary, Maryland Department of Health and Mental Hygiene
  Baltimore, MD
- Susan Woolford, M.D., M.P.H.
  University of Michigan
  Department of Pediatrics and Communicable Diseases
  Ann Arbor, MI