# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Benjamin Caballero, M.D., Ph.D.
  Johns Hopkins University
  School of Public Health
  Baltimore, MD
- Jean-Pierre Chanione, M.D., Ph.D.
  Department of Pediatrics
  University of British Columbia
  Vancouver, BC, Canada
- Cheryl DePinto, M.D., M.P.H.
  Department of Health and Mental Hygiene
  Baltimore, MD
- William Dietz, M.D., Ph.D.
  Director of the Division of Nutrition, Physical Activity, and Obesity
  Centers for Disease Control and Prevention
  Atlanta, GA
- Allison Field, Sc.D.
  Harvard University
  Department of Pediatrics
  Boston, MA
- Stacey Passaro, M.Eng.
  Passaro Engineering
  Baltimore, MD
- Joanne Spahn, M.S., R.D.
  Nutrition Evidence Analysis Library
  U.S. Department of Agriculture
  Washington, DC