# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Allen Zhang, B.S., Melissa McPheeters, M.P.H., Ph.D., Christine Chang, M.D., M.P.H., Dorothy T. Chiu, M.S.P.H., Eric Vohr, M.A., Xiaoli Chen, M.D., Jung Won Min, Ph.D., Tuan T. Nguyen, M.D., Ph.D., and Cai Li, M.D.