# Discussion

## Key Findings

We identified 124 interventional studies (described in 131 articles) meeting our inclusion criteria, of which 54 took place in the United States and 70 were in other developed countries. Eighty-three studies were RCTs. The majority (104 studies, 84 percent) were school-based studies, although many of them also included interventions implemented in other settings such as in the home or local community. Few studies tested interventions that were primarily implemented in other settings such as at home, in communities, in primary care settings, or in childcare settings.

The evidence is strong to support some interventions. The school based studies of physical activity, which included a home component, all improved obesity outcomes. Two of the three studies targeted a reduction in sedentary activity which may have contributed to the good outcomes. Combination interventions of diet and physical activity interventions in schools, with home and community components, also effectively improved outcomes (Table 40).

Table 40 Summary of conclusions

KQ/Setting | Intervention | Conclusion | SOE
School | Diet | Benefit | Moderate
School | Physical activity | Benefit | Moderate
School | Combination | No conclusion, inconsistent results | Insufficient
School-Home | Diet | Not enough evidence to reach conclusion | Insufficient
School-Home | Physical activity | Benefit | High
School-Home | Combination | Benefit | Moderate
School-Home-Community | Physical activity | Not enough evidence to reach conclusion | Insufficient
School-Home-Community | Combination | Benefit | High
School-Community | Diet | Not enough evidence to reach conclusion | Insufficient
School-Community | Physical activity | Not enough evidence to reach conclusion | Insufficient
School-Community | Combination | Benefit | Moderate
School-CHI | Physical activity | No conclusion, inconsistent results | Insufficient
School-CHI | Combination | No conclusion, inconsistent results | Insufficient
School-Home-CHI | Combination | Not enough evidence to reach conclusion | Insufficient
Home | Diet | Not enough evidence to reach conclusion | Insufficient
Home | Combination | No benefit | Low
Home-School-Community | Combination | Not enough evidence to reach conclusion | Insufficient
Home-PC-CHI | Combination | Not enough evidence to reach conclusion | Insufficient
Primary care | Combination | Not enough evidence to reach conclusion | Insufficient
Childcare | Combination | No benefit | Low
Childcare | Physical activity | Not enough evidence to reach conclusion | Insufficient
Community | Physical activity | Not enough evidence to reach conclusion | Insufficient
Community-school | Combination | Benefit | Moderate
Community-School-Home | Combination | Not enough evidence to reach conclusion | Insufficient
Community-Home | Combination | No conclusion, high risk of bias studies | Insufficient
Community-Home-PC-CC | Combination | Not enough evidence to reach conclusion | Insufficient
Community-Home-PC-CC | Combination | Not enough evidence to reach conclusion | Insufficient

Combination = combination of a diet and physical activity intervention; CHI = consumer thelath informatics; CC = childcare; PC = primary care

Additionally, there is moderate evidence that using dietary interventions or physical activity interventions, alone, in schools prevent obesity. The dietary interventions in the school setting included education of the children which may have contributed to their success. However, the paucity of studies makes it hard to know why these particular interventions worked. The strength of the evidence is also moderate that combinations of diet and physical activity in school, with a home component, positively impacts obesity prevalence. The diet and physical activity interventions included enhanced classroom physical activity lessons, moderate to vigorous physical activity sessions, nutritional education materials, and healthful diet promotion (Table 40).

The strength of evidence is low that diet and physical activity interventions administered at home, or in child-care facilities, prevent obesity or overweight in children. Those interventions with significant parental or family involvement were able to demonstrate some impact on select intermediate outcomes. However, additional studies with larger sample sizes, greater intensity interventions and longer followup may be necessary to know the impact of diet and physical activity interventions delivered at home. The small sample size and poor quality of the child-care based studies may have contributed to the attenuated effect on weight outcomes (Table 40).

The evidence is insufficient regarding interventions in other settings. This is due primarily to the small number of studies, their moderate or high risk of bias, or conflicting results across studies. We note that there were many studies that combined diet and physical activity interventions in schools and yet the evidence remains insufficient about these combined interventions. These thirty-seven studies had results that were imprecise and largely inconsistent with each other preventing conclusions (Table 40).

Almost all of those studies that reported on intermediate outcomes, such as vegetable and fruit consumption and/or physical activity, detected some statistically significant desirable effects. Similarly, roughly half of the studies that reported clinical outcomes detected some statistically significant desirable effects, predominately lowered blood pressure.

In general, we found that studies done in schools that had large sample sizes, longer follow up, with more vigorous and higher intensity interventions, were more likely to be effective. Comprehensive interventions that promoted environmental changes (e.g., modified food and beverage items offered in school cafeteria, or structural changes in school physical activity) as well as changes in individuals' knowledge and attitude were more likely to be successful than those addressing either one alone. Educational interventions were less likely to be effective than environmental changes. Given that children are exposed to many other influences outside of school, it is heartening to see that interventions implemented in schools can have a significant impact on weight and other outcomes.

## Important Unanswered Questions

### What Is the Optimal Setting for Childhood Obesity Prevention Interventions?

This review did not aim to compare interventions across settings, and it remains an unanswered question as to where interventions are best implemented. Are physical activity interventions most effective when implemented in school or in an aftercare setting? Is diet education most effective when done in school or at home visits?

This review confirmed that most obesity prevention interventions have been tested in schools, consistent with previous findings.190,191 An Institute of Medicine report on childhood obesity recommended school as the national focal point for obesity prevention in the U.S.192 We suggest, however, that while the school is the setting most commonly studied, it may not be the optimal setting for obesity prevention programs. Many experts support that obesity is driven by a host of environmental factors which increase opportunities for energy intake and decrease opportunities for energy expenditure.193 Obesity-prevention interventions based in schools may not be effective in reducing the risks posted in other settings. When sufficient studies have been conducted, cross-setting analysis of interventions will be desirable. Head-to-head comparisons of comparable interventions delivered in disparate settings may be needed.

### What Are the Other Beneficial Effects and Unwanted Consequences of Obesity Prevention?

We hypothesized that obesity prevention programs could result in desirable clinical outcomes even when the intervention did not result in weight control. In this report, we describe select clinical outcomes that are influenced by obesity, including blood pressure and blood lipids and the effect of interventions. The question is whether interventions that affect only intermediate outcomes, like dietary choices and physical activity, also have a beneficial effect on health. Given the long interval between exposure and the outcomes, these hypotheses are difficult to test and typically require observational designs.

Obesity prevention interventions may also result in some unwanted consequences for children and their families, such as stigma,194 low self-esteem,195 injury (due to physical activity), eating disorders,196 or impaired growth.197 However, very few studies we reviewed reported on such adverse effects. Failure to report adverse effects can mask the reasons for why the interventions generally showed small effects. Low self-esteem or stigmatization as a result of the intervention may reduce fidelity to the intervention and hinder participants from adhering.

### Does the Effectiveness of Obesity Prevention Differ in Subgroups?

A few studies examined whether the effect of the intervention varied across groups defined by gender, age, or baseline weight status, but reported mixed results. Very few studies examined other characteristics, such as race/ethnicity or socio-economic status. We need future research focusing on sub-populations. In some studies, children with different socio-demographic characteristics responded differently to the same intervention. For example, a combined dietary and physical activity intervention that involved the children's schools, homes, and communities was effective in elementary school children, but not in middle-school students.148 Another intervention provided health and nutrition education to pupils in Crete and found girls to be more responsive to the intervention than boys.78 A community-based after-school program found an important decrease in BMI z-scores among Asian American children, with an unanticipated increase in African American children.162 Such differences may be explained by fidelity to the intervention, cultural responses to the intervention, or differences in growth patterns. However, evidence is still limited to explain this variation.

Our limited findings related to sub-populations are similar to previous reviews. For example, one review reported that efforts to prevent weight gain were more effective in children aged 6 to 12 than in older children.191 Another review found that girls may be more responsive to interventions built on the social learning theory, while boys may be more responsive to structural or environmental approaches.198 This suggests the need for stratified analyses of pre-specified sub-groups to assess the effects of the interventions in these subgroups.

## Findings in Relationship to What Is Already Known

In general, our main findings are consistent with previous systematic reviews. However, we are unaware of other reviews which have provided a comprehensive examination of diverse study settings like ours. Most other reviewers mainly focused on select settings such as school and on select outcomes such as BMI or prevalence of overweight and obesity. This review also provides some new findings. We found that a large majority (103, 82 percent) of the 125 studies are school-based, and few studies have tested interventions in other settings. Previous reviews190,198,199 have focused primarily on schools, while a few recent reviews examined other settings.191,200 Earlier reviews focused primarily on weight outcomes, such as BMI, while we included various weight and adiposity outcomes as well as clinical and intermediate outcomes. We also described adverse effects.

The results of previous reviews looking at the impact obesity prevention on weight outcomes in the school setting are mixed. Some did not detect significant intervention effects, while some did.191,200 Most reviews described modest or mixed effects of obesity prevention interventions in children across all settings,201-203 or within schools;190,198 and there was limited evidence in support of school policies and regulations.199 The inconsistent findings are largely due to differences in the design of the reviews, their methods, and the quality of the primary literature (e.g., small study size, lack of blinding, short followup, and varied statistical analyses.191,203,204

Overall, our findings are consistent with the Institute of Medicine's recommendations 192 about obesity prevention. The Institute of Medicine reported that a) the school is the most frequent setting to be studied and included in meta-analysis or review; b) despite small effect sizes and sometimes inconsistent evidence, there is a cumulative body of research showing that school-based interventions can prevent obesity; c) school-based interventions modifying both diet and physical activity are more effective in preventing childhood obesity than modifying either diet or physical activity alone; d) school-based interventions, with family or community involvement, are more likely to be effective; e) different stakeholders, including governments, community, health care systems, industry, and educators should work together to modify the obesogenic environment to facilitate healthful behaviors;205and f) we need more research to test interventions in settings other than schools, in particular, those that test environmental and policy changes, as well as those in clinical settings.

However, discrepancies between findings from our study and previous reviews still exist, especially in the magnitude of intervention effect. For example, while our study generally found a low to moderate intervention effect for school-based intervention programs (with a few exceptions of large intervention effect for physical activity interventions in school-home settings and combined diet and physical activity interventions in school-community settings), the most recent Cochrane review on childhood obesity preventions showed strong evidence to support the beneficial effects of school-based intervention programs for children, particularly among those aged 6 to12 years,205 while another systematic review on 18 studies did not find any significant improvements in BMI from school-based physical activity interventions.206

## Applicability

The results of this review are primarily applicable to children in high-income countries. Results are not necessarily applicable to children in middle-and low-income countries. The children enrolled in the reviewed studies were diverse across studies, with a mix of girls and boys of multiple ethnic groups. However, only a small number of studies reported outcomes by the subgroups of sex, race/ethnicity, or age. Therefore, one should apply the results cautiously to subgroups of children, particularly subgroups that only a few studies included, such as very young children and select racial/ethnic groups. Also, prevention strategies that were effective in old studies may not be as effective in current populations due to differences in the social and build environments.

We gave more weight in our evidence grading to RCTs than non-RCTs). For the most part, the RCTs included in this review took place in school settings. Thus, there may be a relative understating of the value of interventions in non-school settings.

## Implications for Clinical and Policy Decisionmaking

The findings from this review can help guide decision making by researchers, clinicians, public health practitioners, and policymakers about the most effective settings and types of interventions for preventing childhood obesity in developed countries. Based on these results and the results of previous reviews, school-based interventions are likely to remain a focal point for prevention interventions. The limited number of studies conducted outside school limits the evidence about the effectiveness of interventions in those settings.

We anticipate that the school will remain a key setting for health promotion, including for childhood obesity prevention. Several factors favor school-focused efforts: (1) it is easier to conduct continuous interventions and followup measurements in school than in less standardized settings; (2) dietary and exercise behaviors at school constitute a large proportion of children's daily diet and physical activity; (3) schools have the relevant infrastructure to deliver intervention and evaluation, including annual physical check-ups, nutrition and physical education teachers, and school nurses; (4) the majority of school-age children in high-income countries attend and spend considerable time at school; and (5) the evidence supports the effectiveness of some school-based interventions.

To date, it has been unclear whether physical activity or diet (or the combination) should be the primary focus of population-based obesity intervention programs. We found a higher strength of evidence for physical activity interventions in schools that included a home component than for diet-only interventions. However, studies testing these interventions head-to-head were rare, so our review does not definitely answer this question. Nevertheless, to maintain a desirable energy balance, it may be easier to control energy intake than to increase energy expenditure, as there are biological limitations to the effectiveness of physical activity alone in controlling body weight, as well as social and environmental challenges to fitting activity into children's daily schedule. In addition, the environmental factors that affect food consumption in schools might be easier and less costly to modify than those affecting physical activity. However, we note that there may be opportunity costs if schools are required to divert attention and resources to these activities at the expense of other learning or enrichment activities.

Policy change is difficult to effect; nevertheless, in recent years, there is strong interest in the U.S. and some other industrialized countries to push community and policy based interventions. It is likely that with the growing government and public support, such interventions could become more feasible and sustainable in the future. We note that although the evidence is insufficient to address harms, policy makers implementing intervention programs might consider potential harms, which may include self-esteem effects, a sense of failure, and time diverted from other activities. When choosing an intervention to implement, decision makers need to consider the availability of resources; the costs, potential harms and unwanted consequences of an intervention; the anticipated magnitude of the effectiveness of the program, as well as the other underlying issues contributing to the obesity problem specific to their population, such as specific risk factors and other competitive needs.

## Limitations of the Evidence Review Process

This review included only studies of normal children in high-income countries, thereby limiting the generalizability of these findings to high-risk groups and low- and middle-income countries.

Publication bias is inevitable in this review, as journals are less likely to publish intervention studies failing to achieve a desirable effect. We partially addressed this bias, as we searched for “gray literature” (e.g. unpublished working papers) to include in our review. However, none of the grey literature studies met our inclusion criteria in this search.

Within each study setting, we grouped interventions by their behavioral changes (e.g., diet, physical activity, or both) although the studies might have applied very different intervention approaches. However, due to the limited number of studies by categories, we could not conduct further stratifications and analyses to explore the comparative effectiveness of the specific intervention approaches (e.g., education intervention vs. environmental change), or specific intermediate outcomes (e.g., fruits and vegetable intake vs. total energy intake). Moreover, none of the interventions was identical to another. We synthesized the evidence at the level of the intervention – this may be interpreted as “physical activity” is beneficial or as “both diet and PA” is beneficial – even if the report cannot support what specific intervention has the strongest evidence relative to another.

For studies with multiple time points during followup assessments, we mainly included the final one, reasoning that the final followup could best demonstrate how the effect of a specific intervention sustains over time. Including multiple time points for one study would inflate the influence of the study when summarizing the evidence; this may also cause problems as the length of different interventions in one setting may vary greatly based on the final followup lengths.

For school-based studies, we reduced the requirement for length of followup to 6 months (from 1 year) considering the usual length of school years. However, 6 months may be short to observe an intervention's effect on weight outcomes. It may be desirable to conduct in depth analysis to compare the findings from small, short-term (e.g., 6 months) studies with those form large, well-designed RCTs. However, we are limited by the scope of this review, the large heterogeneity across studies and small number of comparable studies. Some studies did not report the original study goals and some studies did not target obesity, that is, they targeted cardiovascular risks. These studies were included in this review because they had diet and physical activity interventions and reported body weight-related outcomes. Since these studies might differ from those that target childhood obesity prevention, they add heterogeneity to the study pool and yet provide valuable information on childhood obesity prevention.

We attempted to identify studies reported in languages other than English, but none of those met our inclusion criteria. As a result, one should exercise caution when generalizing findings from this review to non-English speaking populations.

## Limitations of the Evidence Base

There are also limitations with the evidence base. There are many differences across studies in term of countries, settings (e.g., school vs. home), design (e.g., RCTs versus non-RCTs), sample size, sample characteristics (e.g., all white versus mixed race/ethnicity), specific intervention approaches (e.g., nutrition seminars vs. change in school café menus), primary measures that assess intervention effects (e.g., BMI vs. prevalence of obesity), length of followup, and statistical analysis approaches (e.g. F-tests vs. multi-level models). Such variability made it difficult to conduct meta-analyses for most of the various intervention studies we examined. As a result, we could only conduct meta-analysis for select outcomes (mainly BMI or BMI Z score) for KQ 1, and included only a small number of intervention studies in our pooled results.

Moreover, the preponderance of studies conducted in the school setting limits the generalizability of these results to other settings, especially for primary care and childcare.

Few studies reported standard errors or confidence intervals for the weight-related outcomes. In our analysis, we graded studies that did not report measures of variability as imprecise for the body of evidence. In some instances, the studies did not report a mean difference or point estimate and just stated that there was no significant difference in weight change between the groups. This led us to grade the strength of evidence insufficient or low and prevented us from quantitatively pooling results.

Except for the school-based interventions, the strength of evidence was generally low or insufficient for the interventions in other settings. These grades were a result of how we assessed the study quality and strength of evidence (detailed in the methods section). Common reasons for low or insufficient rates were inconsistent findings, a limited number of studies, the lack of blinding, and not accounting for losses to followup.

Since obesity interventions focus on lifestyle modifications, it is difficult to effectively blind participants from knowing whether they are in the intervention or control group. Therefore, we considered blinding to be most essential at the point of group assignment to minimize selection bias, rather than requiring blinding to sustain throughout the intervention phase. This is a reasonable modification and more applicable to this review, but it does allow for reporting bias. For example, participants in the intervention groups who failed to maintain weight and were aware of their group assignment might have refused re-examination, which would result in differential drop-out. The studies we reviewed usually did not report this. Few of the studies reported blinding of outcome assessors, which was likely difficult to implement in these studies.

The measurement of some outcomes, such as physical activity is controversial. There are no consistent standards on how to measure physical activity, especially spontaneous activity. To address this challenge, we formed an ordered list of physical activities, with input from other experts, to guide us in grading the strength of evidence. We made similar lists for weight and other diet-related outcomes.

Weight-related outcomes and statistical methods studies used to evaluate intervention effects were also heterogonous. We used BMI, or related measures such as BMI z-score, BMI percentile, and prevalence of overweight and/or obesity based on BMI cut points as the primary outcome measures. However, BMI is an indirect measure of adiposity and thus has its limitations; it is also not an ideal indicator for cardiometabolic risks. In addition, studies used different BMI cut points to define overweight and obesity. Further, some studies did not even report BMI, making cross-study comparisons difficult.

Lack of reporting some important information, such as process evaluation and program costs, program adherence/fidelity, and adaptations to the local context hinder our exploration in understanding the program effects.

## Future Research Needs

Many questions remain unanswered. We have identified a number of evidence gaps, many of which may warrant future research. Many of these are also supported by other reviews.192,207

### 1 Intervention Studies Conducted in Nonschool Settings

The literature is sparse in interventions that take place in settings other than schools. This is identified by our review as well as by others.192,207 The field needs more studies that test environment- and policy-based interventions. Although environment is a critical area for obesity prevention,192 very few studies have tested such interventions.207 In addition, there is scant evidence on the impact of regional or national policies on childhood obesity prevention, including agriculture policies and regulations on food retailing and distributions.192,207

Very few studies took place in clinical settings such as primary care. Primary health care providers could play an important role in childhood obesity prevention and treatment by providing healthful eating and exercise guidelines, and regularly monitoring body weight.

### 2 Innovative Study Design and Intervention Approaches

Innovative interventions could help better target levers for behavioral changes. For example, increasingly, young people in the U.S. and worldwide are using social media, and thus it may be effective to use these modalities to reach these children and adolescents. Using well-developed behavioral theories when designing interventions will help researchers increase study success. For example, only a few studies used social marketing to deliver messages on nutrition, physical activity, and health. Studies can integrate this approach with other intervention components to promote desirable lifestyle changes. Consumer health informatics such as internet and smart phones provide promise for health promotion programs like obesity prevention. However, only six studies used consumer health informatics and only one reported significantly reduced obesity risk.

### 3 Systems Science Guided Intervention Studies

Obesity in children is the result of a complex mix of biological, behavioral, social, economic, and environmental factors. Thus, the effective and sustainable prevention of obesity in children may have to target many factors, which calls for a systems approach in study design, implementation, and evaluation, that take into account multiple risk factors and the complex interactions and feedback loops among them.208 To fill in the gaps, researchers first need to understand the contexts and challenges associated with implementing prevention programs in different settings. For example, to conduct a childhood obesity prevention program in a community setting, researchers often need to work with the local community and its key stakeholders, which requires considerable effort and resources. Such demand may help explain the small number of intervention studies conducted in nonschool settings. Researchers should report these contextual factors to help decisionmakers get a better idea of the applicability of a specific intervention program to their own community.

### 4 Studies That Test Potential Differential Effect of Interventions

We need research that generates information about important sub-groups, such as populations stratified by gender, age, race/ethnicity, or socio-economic status, to test whether different groups may respond differently to the same intervention, and help tailor future interventions to maximize their benefits. To allow for such analysis we may need larger studies, which will be more costly. However, they are essential to provide valuable information for disseminating successful interventions. Such studies will test how different groups may respond to the same intervention differently, and can help tailor future interventions to maximize their benefits. Information about subgroups may lead to interventions that are better targeted, and could thus lead to a more efficient use of resources and better outcomes.

Most of the studies we reviewed did not report results by population subgroup. Subgroup analysis is necessary, as the effect size of a specific intervention may be small due to the heterogeneity of intervention effects among different subgroups. For example, an intervention may have worked in girls but not in boys. This may result in overall effectiveness being insignificant. Future research should include stratified analyses of sub-groups by gender, age, race/ethnicity, or socio-economic status. This will help test how different groups may respond to the same intervention, and help tailor future interventions to maximize their benefits. In addition, studies have found that obesity in older children is more predictive of obesity during adulthood than obesity in younger children.32 We need more studies to find effective prevention strategies for obesity that occurs in late childhood and adolescence.

### 5 Studies With High Statistical Power

We need more studies with large sample sizes and adequate length of followup, because most childhood obesity intervention programs are not intensive enough and only result in modest behavioral changes. This is also due to the fact that many factors can affect individuals' eating and physical activity.

### 6 Publication of Process Evaluation Results on Interventions

The publication of process evaluations should be encouraged, especially those that attempt to compare multiple interventions. Such knowledge is important for translational research and dissemination. Very few of the studies we reviewed reported process evaluation, which would provide useful insights regarding why some studies might detect a desirable effect of the intervention, while others do not.

### 7 Application of Rigorous Analytic Approaches

We need more rigorous analytic approaches to better analyze the repeated measures collected during the followup, to control for confounders remaining after randomization, and to test effect modification and heterogeneity in the treatment effect.

### 8 Obesity Prevention Research on Adolescents

Obesity in adolescents has been found to be more predictive of obesity during adulthood than obesity in younger children.32 We need more studies to find effective prevention strategies for obesity that occurs in late childhood and adolescence. This is an important stage of life when young people are exposed to various social and environmental factors that establish lifelong life habits.

## Conclusions

A large number of childhood obesity intervention studies have taken place in high-income counties over the past three decades. They predominately occurred in school settings and mostly in the U.S. Many of the school-based studies also included intervention components implemented in other settings, such as the home and community. Overall, there is moderate-to-high strength of evidence to support that diet and/or physical activity interventions that are implemented in schools help prevent excessive weight gain or reduce the prevalence of overweight and obesity. The added value of school-based interventions, including involvements at home or in the community or the implementation of policies directed at the environment to improve dietary intake or increase physical activity, is generally positive. However, the effectiveness of interventions primarily implemented at home, in primary care, and child-care settings or those using consumer health informatics approaches is largely unknown. We need more research to test interventions conducted in settings other than schools, and to test the impact of policy changes and environmental changes. We should encourage research that tests innovative interventions taking advantage of new technologies, research theories, and methodologies (including systems science). Future research also needs to examine which types of interventions may be more effective and sustainable, and whether subgroups might respond to the same intervention differently.