# Strength of the Evidence

Strength of Evidence Table 1 Weight related outcomes

Setting, N | Intv, N | Years of studies | Enrolled Participants | Studies with Low/Moderate/High Risk of Bias(N) | % with favorable (statistically sig) outcome | % with favorable outcome (does not need to be stat sig) | Risk of Bias | Consistency | Precision | Directness | Conclusion | SOE
School only | D, 2 | 1995-2012 | 1,782 | 0/2/0 | 50 | 100 | Moderate | Consistent | Imprecise | Direct | Benefit | Moderate
School only | PA, 15 | 1993-2011 | 10,086 | 0/13/2 | 26 | 73 | Moderate | Consistent | Imprecise | Direct | Benefit | Moderate
School only | C, 37 | 1985-2012 | 41,875 | 2/27/8 | 45 | 54 | Low | Inconsistent | Imprecise | Direct | No conclusion, inconsistent results | Insufficient
School-Home | D, 1 | 1986 | 1,321 | 0/1/0 | 100 | 100 | Moderate | NA | Precise | Direct | Not enough evidence to reach conclusion | Insufficient
School-Home | PA, 3 | 1999-2010 | 1,654 | 1/2/0 | 100 | 100 | Moderate | Consistent | Precise | Direct | Benefit | High
School-Home | C, 26 | 1991 -2012 | 25,438 | 2/20/4 | 39 | 81 | Moderate | Consistent | Precise | Direct | Benefit | Moderate
School-Home-Community | PA,1 | 2010 | 2,829 | 0/1/0 | 0 | 0 | Moderate | NA | Precise | Direct | Not enough evidence to reach conclusion | Insufficient
School-Home-Community | C,8 | 2008-2012 | 11,525 | 1/4/3 | 12 | 81 | Moderate | Consistent | Imprecise | Direct | Benefit | High
School-Community | D,1 | 2009 | 2,950 | 0/1/0 | 100 | 100 | Moderate | NA | Precise | Direct | Not enough evidence to reach conclusion | Insufficient
School-Community | PA,1 | 2008 | 1,721 | 0/0/1 | 0 | 0 | High | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
School-Community | C,4 | 1997-2012 | 3,017 | 0/2/2 | 25 | 75 | Moderate | Consistent | Imprecise | Direct | Benefit | Moderate
School-CHI | PA,2 | 2007-2012 | 1,335 | 0/2/0 | 0 | 0 | Moderate | Inconsistent | Imprecise | Direct | No conclusion, inconsistent results | Insufficient
| C, 2 | 2006-2012 | 1,896 | 0/2/0 | 50 | 50 | Moderate | Inconsistent | Imprecise | Direct | No conclusion, inconsistent results | Insufficient
School-Home-CHI | C,1 | 2011 | 589 | 0/0/1 | 0 | 0 | High | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Home | D, 1 | 2004 | 59 | 0/1/0 | 0 | 0 | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Home | C, 3 | 2001-2012 | 262 | 0/2/1 | 0 | 33 | Moderate | Inconsistent | Imprecise | Direct | No benefit | Low
Home-School--Community | C, 1 | 2009 | 1323 | 0/0/1 | 0 | 0 | High | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Home-PC-CHI | C, 1 | 2006 | 878 | 1/0/0 | 0 | Unable to determine – actual outcome values not reported only significance | Low | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Primary Care | C, 1 | 2009 | 600 | 0/1/0 | 0 | 0 | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Child care | P, 1 | 2007 | 268 | 0/0/1 | 100 | 100 | High | NA | Precise | Direct | No benefit | Insufficient
Child care | C, 3 | 2009-2012 | 2393 | 1/2/0 | 33 | 33 | Moderate | Inconsistent | Imprecise | Direct | Not enough evidence to reach conclusion | Low
Community only | PA, 1 | 2010 | 46 | 0/1/0 | 0 | 0 | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Community-School | C, 3 | 1997-2010 | 2966 and 24 schools (mean enrollment 1109) | 0/3/0 | 66 | 66 | Moderate | Consistent | Imprecise | Direct | Benefit | Moderat
Community-School-Home | C, 1 | 2007-2008 | 1326 | 0/1/0 | 100 | 100 | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Community-Home | C, 2 | 2010 | 564 | 0/1/1 | 0 | 0 | Moderate | Consistent | Imprecise | Direct | No conclusion, high risk of bias studies | Insufficient
Community-Home-PC-CC | C, 1 | 2010 | 43,811 | 0/1/0 | 100 | 100 | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Community-School-PC-CC | D, 1 | 2010 | NR | 0/0/1 | 100 | 100 | High | Inconsistent | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient

* One study in the school only section reported on the three interventions under review in this report and was accounted for in each grade.

C = Combination of diet and physical activity; CHI = Consumer Health Informatics; D = Diet intervention; Intv = Intervention; N = Sample Size; NA = Not Applicable; P = Physical activity intervention; PC = Primary Care; Sig = Significant; SOE = Strength of Evidence.

Strength of Evidence Table 2 Change in dietary intake^*^

Setting, N | Intv, N | Years of studies | Enrolled Participants | Studies with Low/Moderate/High Risk of Bias(N) | % with favorable (statistically sig) outcome | % with favorable outcome (does not need to be stat sig) | Risk of Bias | Consistency | Precision | Directness | Conclusion | SOE/Evidence Statement
School only | D, 1 | 1995 | 869 | 0/1/0 | 0 | 0 | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
School only | C, 5^*^ | 1999-2012 | 3197 | 0/3/2 | 20 | 100 | Moderate | Consistent | Imprecise | Direct | Benefit | Low
School-Home | C, 9 | 1991-2012 | 10,515 | 0/9/0 | 11 | 78 | Moderate | Consistent | Imprecise | Direct | Benefit | Low
School-Home-Community | C, 1 | 2012 | 148 | 0/0/1 | 0 | 100 | High | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Home | D, 1 | 2004 | 59 | 0/1/0 | 0 | 0 | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Home | C, 1 | 2012 | 146 | 0/1/0 | 0 | 100 | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Home-PC-CHI | C, 1 | 2006 | 878 | 1/0/0 | 0 | 100 (boys only) | Low | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Primary Care | C, 1 | 2009 | 600 | 0/1/0 | 0 | Unable to determine (no baseline values provided; single arm study) | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Child care | C,2 | 2006-2012 | 916 | 1/1/0 | 0 | 0 | Low | Inconsistent | Imprecise | Direct | Not enough evidenct to determine benefit | Low
Community-Home | C, 1 | 2010 | 261 | 0/0/1 | 0 | 1 | High | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Community-School | C, 1 | 1997-2010 | 2966 and 24 schools (mean enrollment 1109) | 0/1/0 | 0 | 0 | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Community-Home-Primary Care-Childcare | C, 1 | 2010 | 1789 | 0/1/0 | 1 | 1 | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient

* Not all settings and interventions reported intermediate outcomes. If no intermediate outcome was reported the setting and intervention row does not appear in this table.

C = Combination of diet and physical activity; CHI = Consumer Health Informatics; D = Diet intervention; Intv = Intervention; N = Sample Size; NA = Not Applicable; P = Physical activity intervention; PC = Primary Care; Sig = Significant; SOE = Strength of Evidence.

Strength of Evidence Table 3 Fatty food intake^*^

Setting, N | Intv, N | Years of studies | Enrolled Participants | Studies with Low/Moderate/High Risk of Bias(N) | % with favorable (statistically sig) outcome | % with favorable outcome (does not need to be stat sig) | Risk of Bias | Consistency | Precision | Directness | Conclusion | SOE/Evidence Statement
School only | D, 1 | 1995 | 869 | 0/1/0 | 50 | 50 | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient.
School only | C, 5^*^ | 1989-2011 | 2075 | 1/4/0 | 0 | 100 | Moderate | Consistent | Imprecise | Direct | Benefit | Moderate
School-Home | P, 1 | 1999 | 192 | 0/1/0 | 0 | 100 | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
School-Home | C, 2 | 2012 | 2514 | 0/2/0 | 50 | 100 | Moderate | Consistent | Imprecise | Direct | Benefit | Low
School-home-community | C, 3 | 2009-2012 | 1,244 | 0/2/1 | 67 | 100 | Moderate | Consistent | Imprecise | Direct | Benefit | Low
Child care | C, 1 | 2006 | 401 | 0/1/0 | 0 | 0 | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient

* Not all settings and interventions reported intermediate outcomes. If no intermediate outcome was reported the setting and intervention row does not appear in this table.

C = Combination of diet and physical activity; CHI = Consumer Health Informatics; D = Diet intervention; Intv = Intervention; N = Sample Size; NA = Not Applicable; P = Physical activity intervention; PC = Primary Care; Sig = Significant; SOE = Strength of Evidence.

Strength of Evidence Table 4 Change in fruit and vegetable intake^*^

Setting, N | Intv, N | Years of studies | Enrolled Participants | Studies with Low/Moderate/High Risk of Bias(N) | % with favorable (statistically sig) outcome | % with favorable outcome (does not need to be stat sig) | Risk of Bias | Consistency | Precision | Directness | Conclusion | SOE/Evidence Statement
School only | C, 11 | 1999-2012 | 7133 | 0/10/1 | 36 | 72 | Moderate | Consistent | Imprecise | Direct | Benefit | Moderate
School-Home | C, 7 | 2008-2012 | 6478 | 0/7/0 | 14 | 71 | Moderate | Consistent | Imprecise | Direct | Benefit | Low.
School-Community | C, 1 | 2012 | 800 | 0/1/0 | 0 | 100 | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
School-Home-Community | C, 5 | 2008-2012 | 7,896 | 1/2/2 | 20 | 80 | Moderate | Consistent | Imprecise | Direct | Benefit | Moderate
School-CHI | C, 2 | | 1826 | 0/2/0 | 0 | 100 | Moderate | Consistent | Imprecise | Direct | Benefit | Low
Home | C, 3 | 2001-2012 | 481 | 0/2/1 | 33 | 100 | Moderate | Consistent | Imprecise | Direct | Benefit | Low
Home-School-Community | C, 1 | 2009 | 1323 | 0/0/1 | 100 | 100 | High | NA | Precise | Direct | Not enough evidence to reach conclusion | Insufficient
Home-PC-CHI | C, 1 | 2006 | 878 | 1/0/0 | 0 | 100 (girls only) | Low | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Child care | C, 1 | 2009 | 1340 | 0/1/0 | 0 | 0 | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient

* Not all settings and interventions reported intermediate outcomes. If no intermediate outcome was reported the setting and intervention row does not appear in this table.

C = Combination of diet and physical activity; CHI = Consumer Health Informatics; D = Diet intervention; Intv = Intervention; N = Sample Size; NA = Not Applicable; P = Physical activity intervention; PC = Primary Care; Sig = Significant; SOE = Strength of Evidence.

Strength of Evidence Table 5 Change in sugar sweetened beverage intake^*^

Setting, N | Intv, N | Years of studies | Enrolled Participants | Studies with Low/Moderate/High Risk of Bias(N) | % with favorable (statistically sig) outcome | % with favorable outcome (does not need to be stat sig) | Risk of Bias | Consistency | Precision | Directness | Conclusion | SOE/Evidence Statement
School only | C, 10 | 2001-2012 | 7133 | 0/7/1 | 0 | 100 | Moderate | Consistent | Imprecise | Direct | Benefit | Moderate
School-Home | C, 4 | 2010-2012 | 2523 | 0/3/1 | 25 | 100 | Moderate | Consistent | Imprecise | Direct | Benefit | Low
School-Community | C, 1 | 2011 | 1,589 | 0/0/1 | 0 | 100 | High | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
School-Home-Community | C, 5 | 2008-2012 | 7,896 | 0/2/1 | 67 | 100 | Moderate | Consistent | Imprecise | Direct | Benefit | Low
School-CHI | C, 1 | | 813 | 0/1/0 | 0 | 0 | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Home | C, 1 | 2011 | 90 households | 0/0/1 | 0 | 0 | High | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Community-School | D and P | 2009 | 1108 | 0/1/0 | 0 | 1 | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient

* Not all settings and interventions reported intermediate outcomes. If no intermediate outcome was reported the setting and intervention row does not appear in this table.

C = Combination of diet and physical activity; CHI = Consumer Health Informatics; D = Diet intervention; Intv = Intervention; N = Sample Size; NA = Not Applicable; P = Physical activity intervention; PC = Primary Care; Sig = Significant; SOE = Strength of Evidence.

Strength of Evidence Table 6 Physical activity^*^

Setting, N | Intv, N | Years of studies | Enrolled Participants | Studies with Low/Moderate/High Risk of Bias(N) | % with favorable (statistically sig) outcome | % with favorable outcome (does not need to be stat sig) | Risk of Bias | Consistency | Precision | Directness | Conclusion | SOE/Evidence Statement
School only | P, 3 | 2008-2009 | 503 | 0/3/0 | 100 | 100 | Moderate | Consistent | Precise | Direct | Benefit | Moderate
School only | C, 13 | 1999-2011 | 5514 | 0/12/0 | 31 | 77 | Moderate | Consistent | Imprecise | Direct | Benefit | Moderate.
School-Home | P, 3 | 1999-2010 | 1648 | 1/2/0 | 67 | 67 | Moderate | Inconsistent | Imprecise | Direct | Benefit | Moderate
School-Home | C, 16 | 1998-2012 | 17,575 | 2/12/2 | 50 | 94 | Moderate | Consistent | Imprecise | Direct | Benefit | Moderate
School-Community | P, 1 | 2008 | 1,721 | 0/0/1 | 0 | 100 | High | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
School-Community | C, 2 | 2011-2012 | 2,389 | 0/1/1 | 0 | 50 | Moderate | Inconsistent | Imprecise | Direct | No benefit | Low
School-Home-Community | C, 7 | 2008-2012 | 11,265 | 1/4/2 | 29 | 57 | Moderate | Inconsistent | Imprecise | Direct | No benefit | Low
School-CHI | P, 1 | 813 | | 0/2/0 | 0 | 0 | Moderate | Inconsistent | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
School-CHI | C,2 | 1826 | | 0/2/0 | 0 | 50 | Moderate | Inconsistent | Imprecise | Direct | No Benefit | Low
School-Home/CHI | C, 1 | | 589 | 0/0/1 | 100 | 100 | High | NA | Precise | Direct | Not enough evidence to reach conclusion | Insufficient
Home | D, 1 | 2004 | 59 | 0/1/0 | 0 | 100 | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Home | C, 2 | 2011-2012 | 236 | 0/1/1 | 0 | 50 | Moderate | Inconsistent | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Home-School-Community | C, 1 | 2009 | 1323 | 0/0/1 | 0 | 100 | High | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Home-PC-CHI | C, 1 | 2006 | 878 | 1/0/0 | 0 | 100 (boys only) | Low | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Primary Care | C, 1 | 2009 | 600 | 0/1/0 | 0 | Unable to determine (no baseline values provided; single arm study) | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient

* Not all settings and interventions reported intermediate outcomes. If no intermediate outcome was reported the setting and intervention row does not appear in this table.

C = Combination of diet and physical activity; CHI = Consumer Health Informatics; D = Diet intervention; Intv = Intervention; N = Sample Size; NA = Not Applicable; P = Physical activity intervention; PC = Primary Care; Sig = Significant; SOE = Strength of Evidence.

Strength of Evidence Table 7 Change in sedentary behavior^*^

Setting, N | Intv, N | Years of studies | Enrolled Participants | Studies with Low/Moderate/High Risk of Bias(N) | % with favorable (statistically sig) outcome | % with favorable outcome (does not need to be stat sig) | Risk of Bias | Consistency | Precision | Directness | Conclusion | SOE/Evidence Statement
School only | P, 1 | 2008 | 233 | 0/1/0 | 100 | 100 | Moderate | NA | Precise | Direct | Not enough evidence to reach conclusion | Insufficient
School only | C, 8 | 1999-2011 | 3978 | 0/8/0 | 25 | 62 | Moderate | Inconsistent | Imprecise | Direct | No benefit | Low
School-Home | P, 2 | 1999-2008 | 1146 | 0/2/0 | 100 | 100 | Moderate | Consistent | Precise | Direct | Benefit | Moderate
School-Home | C, 7 | 1998-2012 | 6480 | 0/6/1 | 29 | 85 | Moderate | Consistent | Imprecise | Direct | Benefit | Low
School-Community | P, 1 | 2008 | 1,721 | 0/0/1 | 0 | 100 | High | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
School-Community | C, 2 | 2011-2012 | 2,389 | 0/1/1 | 0 | 100 | Moderate | NA | Imprecise | Direct | Benefit | Low
School-Home-Community | C, 3 | 2008-2012 | 7,102 | 1/1/1 | 0 | 33 | Moderate | Inconsistent | Imprecise | Direct | No benefit | Low.
School-CHI | C, 2 | | 813 | 0/2/0 | 0 | 100 | Moderate | Consistent | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Home | C, 2 | 2011-2012 | 236 | 0/1/1 | 0 | 0 | Moderate | Consistent | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Home-School-Community | C, 1 | 2009 | 1323 | 0/0/1 | 0 | 100 | High | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Home-PC-CHI | C, 1 | 2006 | 878 | 1/0/0 | 100 | 100 | Low | NA | Precise | Direct | Benefit | Low
Primary Care | C, 1 | 2009 | 600 | 0/1/0 | 0 | Unable to determine (no baseline values provided; single arm study) | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Community-School | C, 1 | 2009 | 1108 | 0/1/0 | 0 | 1 | Moderate | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient
Community-Home | C, 1 | 2010 | 261 | 0/0/1 | 0 | 1 | High | NA | Imprecise | Direct | Not enough evidence to reach conclusion | Insufficient

* Not all settings and interventions reported intermediate outcomes. If no intermediate outcome was reported the setting and intervention row does not appear in this table.

C = Combination of diet and physical activity; CHI = Consumer Health Informatics; D = Diet intervention; Intv = Intervention; N = Sample Size; NA = Not Applicable; P = Physical activity intervention; PC = Primary Care; Sig = Significant; SOE = Strength of Evidence.