# Evidence Tables

## Key Question 1 School-based only

Evidence Table 1 Study characteristics for studies taking place in a school only setting

Evidence Table 2 Participant characteristics for studies taking place in a school only setting

Evidence Table 3 Description of the interventions used in school only settings

Evidence Table 4a Weight related outcomes for diet intervention studies taking place in a school only setting

Evidence Table 4b Weight related outcomes for diet intervention studies taking place in a school only setting, by subgroup

Evidence Table 4c Clinical outcomes for diet intervention studies taking place in a school only setting, subgroups

Evidence Table 4d Intermediate outcomes for diet intervention studies taking place in a school only setting

EvidenceTable 5a Weight related outcomes for physical activity intervention studies taking place in a school only setting

Evidence Table 5b Weight related outcomes for physical activity intervention studies taking place in a school only setting, by subgroup

Evidence Table 5c Clinical outcomes for physical activity intervention studies taking place in a school only setting, subgroups

Evidence Table 5d Intermediate outcomes for physical activity intervention studies taking place in a school only setting

Evidence Table 6a Weight related outcomes for combined diet and physical activity intervention studies taking place in a school only setting

Evidence Table 6b Weight related outcomes for combined diet physical activity intervention studies taking place in a school only setting, by subgroup

Evidence Table 6c Clinical outcomes for combined diet and physical activity intervention studies taking place in a school only setting, subgroups

Evidence Table 6d Intermediate outcomes for combined diet and physical activity intervention studies taking place in a school only setting

### References, Key Question 1: School-only Setting

1 Amaro S, Di Costanzo A, Madeo I, et al. Kaledo, a new educational board-game, gives nutritional rudiments and encourages healthy eating in children: A pilot cluster randomized trial. European Journal of Pediatrics. 2006;165(9):630-5. PMID: SR-ENDOC. [pmid: 16733670].
2 Barbeau P, Johnson MH, Howe CA, et al. Ten months of exercise improves general and visceral adiposity, bone, and fitness in black girls. Obesity (Silver Spring). 2007;15(8):2077-85. [pmid: 17712126].
3 Bronikowski M, Bronikowska M. Will they stay fit and healthy? A three-year follow-up evaluation of a physical activity and health intervention in Polish youth. Scandinavian Journal of Public Health. 2011;39(7):704-13. PMID: http://search.ebscohost.com/login.aspx?direct=true&db=rzh&AN=2011350830&site=ehost-live. [pmid: 21948996].
4 Bruss MB, Michael TJ, Morris JR, et al. Childhood obesity prevention: an intervention targeting primary caregivers of school children. Obesity (Silver Spring). 2010;18(1):99-107. [pmid: 19424164].
5 Burguera B, Colom A, Pinero E, et al. ACTYBOSS: Activity, behavioral therapy in young subjects - After-school intervention pilot project on obesity prevention. Obes. Facts. 2011;4(5):400-6. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L363050745. [pmid: 22166761].
6 Bush PJ, Zuckerman AE, Theiss PK, et al. Cardiovascular risk factor prevention in black schoolchildren: two-year results of the “Know Your Body” program. Am J Epidemiol. 1989;129(3):466-82. [pmid: 2916540].
7 Chiodera P, Volta E, Gobbi G, et al. Specifically designed physical exercise programs improve children's motor abilities. Scandinavian Journal of Medicine & Science in Sports. 2008;18(2):179-87. PMID: http://search.ebscohost.com/login.aspx?direct=true&db=psyh&AN=2008-03780-005&site=ehost-live marco.vitale@unipr.it. [pmid: 17490452].
8 Coleman KJ, Shordon M, Caparosa SL, Pomichowski ME, Dzewaltowski DA. Changing nutrition policies and environments in low-income schools using implementation models: The healthy options for nutrition environments in schools (ONES) intervention. Obesity. 2011;19:S124. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L70680833.
9 Damon S, Dietrich S, Widhalm K. PRESTO - Prevention Study of Obesity: A project to prevent obesity during childhood and adolescence. Acta Paediatr. Int. J. Paediatr. 2005;94(SUPP. 448):47-8. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L44597508.
10 DeBar LL, Schneider M, Drews KL, et al. Student public commitment in a school-based diabetes prevention project: impact on physical health and health behavior. BMC Public Health. 2011;11:711. [pmid: 21933431].
11 Donnelly JE, Greene JL, Gibson CA, et al. Physical Activity Across the Curriculum (PAAC): a randomized controlled trial to promote physical activity and diminish overweight and obesity in elementary school children. Prev Med. 2009;49(4):336-41. [pmid: 19665037].
12 Foster GD, Linder B, Baranowski T, et al. A school-based intervention for diabetes risk reduction. (1533-4406 (Electronic). 0028-4793 (Linking)).
13 Hirst K, Baranowski T, DeBar L, et al. HEALTHY study rationale, design and methods: moderating risk of type 2 diabetes in multi-ethnic middle school students. Int J Obes (Lond). Suppl 4. 2009;33:S4-20. [pmid: 19623188].
14 Fung C, Kuhle S, Lu C, et al. From “best practice” to “next practice”: The effectiveness of school-based health promotion in improving healthy eating and physical activity and preventing childhood obesity. 2012:27. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L51911819.
15 Gortmaker SL, Peterson K, Wiecha J, et al. Reducing obesity via a school-based interdisciplinary intervention among youth: Planet Health. Arch Pediatr Adolesc Med. 1999;153(4):409-18. [pmid: 10201726].
16 Graf C, Koch B, Falkowski G, et al. School-based prevention: effects on obesity and physical performance after 4 years. J Sports Sci. 2008;26(10):987-94. [pmid: 18608843].
17 Gutin B, Yin Z, Johnson M, Barbeau P. Preliminary findings of the effect of a 3-year after-school physical activity intervention on fitness and body fat: the Medical College of Georgia Fitkid Project. Int J Pediatr Obes. Suppl 1. 2008;3:3-9. [pmid: 18278626].
18 Haerens L, Deforche B, Maes L, Stevens V, Cardon G, De Bourdeaudhuij I. Body mass effects of a physical activity and healthy food intervention in middle schools. Obesity (Silver Spring). 2006;14(5):847-54. [pmid: 16855194].
19 Heelan KA, Abbey BM, Donnelly JE, Mayo MS, Welk GJ. Evaluation of a walking school bus for promoting physical activity in youth. J Phys Act Health. 2009;6(5):560-7. [pmid: 19953832].
20 Howe C, Harris R, Gutin B. A 10-month physical activity intervention improves body composition in young black boys. Journal of Obesity. 2011:8. PMID: http://search.ebscohost.com/login.aspx?direct=true&db=rzh&AN=2010876163&site=ehost-live.
21 James J, Thomas P, Cavan D, Kerr D. Preventing childhood obesity by reducing consumption of carbonated drinks: Cluster randomised controlled trial. Br. Med. J. 2004;328(7450):1237-9. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L38686107. [pmid: 15107313].
22 James J, Thomas P, Kerr D. Preventing childhood obesity: Two year follow-up results from the Christchurch obesity prevention programme in schools (CHOPPS). BMJ: British Medical Journal. 2007;335(7623):1-6. PMID: http://search.ebscohost.com/login.aspx?direct=true&db=psyh&AN=2007-15305-001&site=ehost-live janet.james@rbch.nhs.uk. [pmid: 17615183].
23 Kafatos A, Manios Y, Moschandreas J, et al. Health and nutrition education in primary schools of Crete: Follow-up changes in body mass index and overweight status. Eur. J. Clin. Nutr. 2005;59(9):1090-2. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L43118171. [pmid: 16015265].
24 Kain J, Leyton B, Cerda R, Vio F, Uauy R. Two-year controlled effectiveness trial of a school-based intervention to prevent obesity in Chilean children. Public Health Nutr. 2009;12(9):1451-61. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L355201446. [pmid: 19102808].
25 Klish WJ, Karavias KE, White KS, et al. Multicomponent school-initiated obesity intervention in a high-risk, hispanic elementary school. J. Pediatr. Gastroenterol. Nutr. 2012;54(1):113-6. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L51581122. [pmid: 21857252].
26 Lazaar N, Aucouturier J, Ratel S, Rance M, Meyer M, Duche P. Effect of physical activity intervention on body composition in young children: Influence of body mass index status and gender. Acta Paediatr. Int. J. Paediatr. 2007;96(9):1315-20. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L47300700.
27 Llargues E, Recasens A, Franco R, et al. Medium-term evaluation of an educational intervention on dietary and physical exercise habits in schoolchildren: The Avall 2 study: Evaluacion a medio plazo de una intervencion educativa en habitos alimentarios y de actividad fisica en escolares: Estudio Avall 2. Endocrinol. Nutr. 2012;59(5):288-95. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L51968868. [pmid: 22521298].
28 Lubans DR, Morgan PJ, Callister R. Potential moderators and mediators of intervention effects in an obesity prevention program for adolescent boys from disadvantaged schools. J. Sci. Med. Sport. 2012. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L51995159.
29 Lubans DR, Morgan PJ, Okely AD, et al. Preventing Obesity Among Adolescent Girls: One-Year Outcomes of the Nutrition and Enjoyable Activity for Teen Girls (NEAT Girls) Cluster Randomized Controlled Trial. Arch Pediatr Adolesc Med. 2012. [pmid: 22566517].
30 Madsen J, Sallis JF, Rupp JW, et al. Relationship between self-monitoring of diet and exercise change and subsequent risk factor changes in children and adults. PATIENT EDUC. COUNS. 1993;21(1-2):61-9. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L23208252. [pmid: 8337206].
31 Magnusson KT, Hrafnkelsson H, Sigurgeirsson I, Johannsson E, Sveinsson T. Limited effects of a 2-year school-based physical activity intervention on body composition and cardiorespiratory fitness in 7-year-old children. Health Education Research. 2012;27(3):484-94. PMID: http://search.ebscohost.com/login.aspx?direct=true&db=rzh&AN=2011543744&site=ehost-live. [pmid: 22456632].
32 Manios Y, Moschandreas J, Hatzis C, Kafatos A. Evaluation of a health and nutrition education program in primary school children of Crete over a three-year period. Prev Med. 1999;28(2):149-59. [pmid: 10048106].
33 Manios Y, Moschandreas J, Hatzis C, Kafatos A. Health and nutrition education in primary schools of Crete: Changes in chronic disease risk factors following a 6-year intervention programme. British Journal of Nutrition. 2002;88(3):315-24. PMID: SR-CHILD; SR-VASC. [pmid: 12207842].
34 Manios Y, Kafatos A. Health and nutrition education in primary schools in Crete: 10 years follow-up of serum lipids, physical activity and macronutrient intake. Br J Nutr. 2006;95(3):568-75. [pmid: 16578934].
35 Muckelbauer R, Libuda L, Clausen K, Toschke AM, Reinehr T, Kersting M. Promotion and provision of drinking water in schools for overweight prevention: randomized, controlled cluster trial. Pediatrics. 2009;123(4):e661-7. [pmid: 19336356].
36 Neumark-Sztainer DR, Friend SE, Flattum CF, et al. New moves-preventing weight-related problems in adolescent girls a group-randomized study. Am J Prev Med. 2010;39(5):421-32. [pmid: 20965379].
37 Newton RL Jr, Han H, Anton SD, et al. An environmental intervention to prevent excess weight gain in African-American students: a pilot study. Am J Health Promot. 2010;24(5):340-3. [pmid: 20465148].
38 Reed KE, Warburton DE, Macdonald HM, Naylor PJ, McKay HA. Action Schools! BC a school-based physical activity intervention designed to decrease cardiovascular disease risk factors in children. Preventive Medicine. 2008;46(6):525-31. PMID: SR-ENDOC; SR-HEALTHP; SR-HTN; SR-PUBHLTH; SR-VASC. [pmid: 18377970].
39 Rosario R, Oliveira B, Araujo A, et al. The impact of an intervention taught by trained teachers on childhood overweight. Int. J. Environ. Res. Public Health. 2012;9(4):1355-67. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L364687110. [pmid: 22690198].
40 Rush E, Reed P, McLennan S, Coppinger T, Simmons D, Graham D. A school-based obesity control programme: Project Energize. Two-year outcomes. British Journal of Nutrition. 2012;107(4):581-7. PMID: http://search.ebscohost.com/login.aspx?direct=true&db=rzh&AN=2011466732&site=ehost-live. [pmid: 21733268].
41 Sahota P, Rudolf MC, Dixey R, Hill AJ, Barth JH, Cade J. Randomised controlled trial of primary school based intervention to reduce risk factors for obesity. BMJ. 2001;323(7320):1029-32. [pmid: 11691759].
42 Sallis JF, McKenzie TL, Alcaraz JE, Kolody B, Hovell MF, Nader PR. Project SPARK. Effects of physical education on adiposity in childdren. ANN. NEW YORK ACAD. SCI. 1993;699:127-36. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L23359973. [pmid: 8267303].
43 Salmon J, Ball K, Hume C, Booth M, Crawford D. Outcomes of a group-randomized trial to prevent excess weight gain, reduce screen behaviours and promote physical activity in 10-year-old children: switch-play. Int J Obes (Lond). 2008;32(4):601-12. [pmid: 18253162].
44 Skybo TA, Ryan-Wenger N. A school-based intervention to teach third grade children about the prevention of heart disease. Pediatr Nurs. 2002;28(3):223-9. 235. [pmid: 12087641].
45 Smolak L, Levine MP. A two-year follow-up of a primary prevention program for negative body image and unhealthy weight regulation. Eating Disord. 2001;9(4):313-25. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L34552471.
46 Sollerhed AC, Ejlertsson G. Physical benefits of expanded physical education in primary school: Findings from a 3-year intervention study in Sweden. Scandinavian Journal of Medicine & Science in Sports. 2008;18(1):102-7. PMID: http://search.ebscohost.com/login.aspx?direct=true&db=psyh&AN=2008-02206-002&site=ehost-live ann-christin.sollerhed@husa.hkr.se. [pmid: 17490464].
47 Stenevi-Lundgren S, Daly RM, Linden C, Gardsell P, Karlsson MK. Effects of a daily school based physical activity intervention program on muscle development in prepubertal girls. Eur. J. Appl. Physiol. 2009;105(4):533-41. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L50337978. [pmid: 19018558].
48 Stock S, Miranda C, Evans S, et al. Healthy buddies: A novel, peer-led health promotion program for the prevention of obesity and eating disorders in children in elementary school. Pediatrics. 2007;120(4):e1059-e1068. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L47549553. [pmid: 17908726].
49 Taylor RW, McAuley KA, Barbezat W, Strong A, Williams SM, Mann JI. APPLE Project: 2-y findings of a community-based obesity prevention program in primary school age children. Am J Clin Nutr. 2007;86(3):735-42. [pmid: 17823440].
50 Thivel D, Isacco L, Lazaar N, et al. Effect of a 6-month school-based physical activity program on body composition and physical fitness in lean and obese schoolchildren. Eur. J. Pediatr. 2011:1-9. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L51365376.
51 Trevi±o RP, Hernandez AE, Yin Z, Garcia OA, Hernandez I. Effect of the Bienestar Health Program on Physical Fitness in Low-Income Mexican American Children. Hispanic Journal of Behavioral Sciences. 2005;27(1):120-32. PMID: http://search.ebscohost.com/login.aspx?direct=true&db=psyh&AN=2005-01342-007&site=ehost-live.
52 Tucker S, Lanningham-Foster L, Murphy J, et al. A school based community partnership for promoting healthy habits for life. J Community Health. 2011;36(3):414-22. [pmid: 20976532].
53 Valdimarsson O, Linden C, Johnell O, Gardsell P, Karlsson MK. Daily physical education in the school curriculum in prepubertal girls during 1 year is followed by an increase in bone mineral accrual and bone width--data from the prospective controlled Malmö pediatric osteoporosis prevention study. Calcified Tissue International. 2006;78(2):65-71. [pmid: 16467972].
54 Vandongen R, Jenner DA, Thompson C, et al. A controlled evaluation of a fitness and nutrition intervention program on cardiovascular health in 10- to 12-year-old children. Prev Med. 1995;24(1):9-22. [pmid: 7740021].
55 Viskic-Stalec N, Stalec J, Katic R, Podvorac D, Katovic D. The impact of dance-aerobics training on the morpho-motor status in female high-schoolers. Coll Antropol. 2007;31(1):259-66. [pmid: 17598411].
56 Martínez Vizcaíno V, Salcedo Aguilar F, Franquelo Gutiérrez R, et al. Assessment of an after-school physical activity program to prevent obesity among 9- to 10-year-old children: a cluster randomized trial. International Journal of Obesity (2005). 2008;32(1):12-22. PMID: SR-ENDOC; SR-HEALTHP; SR-HTN; SR-PUBHLTH. [pmid: 17895883].
57 Walter HJ, Hofman A, Connelly PA, Barrett LT, Kost KL. Primary prevention of chronic disease in childhood: changes in risk factors after one year of intervention. Am J Epidemiol. 1985;122(5):772-81. [pmid: 4050769].
58 Walther C, Gaede L, Adams V, et al. Effect of increased exercise in school children on physical fitness and endothelial progenitor cells: a prospective randomized trial. Circulation. 2009;120(22):2251-9. [pmid: 19920000].
59 Warren JM, Henry CJ, Lightowler HJ, Bradshaw SM, Perwaiz S. Evaluation of a pilot school programme aimed at the prevention of obesity in children. Health Promot Int. 2003;18(4):287-96. [pmid: 14695360].
60 Manios Y, Kafatos A, Mamalakis G. The effects of a health education intervention initiated at first grade over a 3 year period: physical activity and fitness indices. Health Educ Res. 1998;13(4):593-606. [pmid: 10345909].
61 Hatzis CM, Papandreou C, Kafatos AG. School health education programs in Crete: Evaluation of behavioural and health indices a decade after initiation. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2010;51(3-4):262-7. PMID: http://search.ebscohost.com/login.aspx?direct=true&db=psyh&AN=2010-19132-013&site=ehost-live papchris10@gmail.com.
62 Resaland GK, Anderssen SA, Holme IM, Mamen A, Andersen LB. Effects of a 2-year school-based daily physical activity intervention on cardiovascular disease risk factors: the Sogndal school-intervention study. Scandinavian Journal of Medicine & Science in Sports. 2011;21(6):e122-31. PMID: http://search.ebscohost.com/login.aspx?direct=true&db=rzh&AN=2011374136&site=ehost-live. [pmid: 22126720].
63 Yin Z, Gutin B, Johnson MH, et al. An environmental approach to obesity prevention in children: Medical College of Georgia FitKid Project year 1 results. Obes Res. 2005;13(12):2153-61. [pmid: 16421350].
64 Madsen KA, Thompson HR, Wlasiuk L, Queliza E, Schmidt C, Newman TB. After-school program to reduce obesity in minority children: A pilot study. Journal of Child Health Care. 2009;13(4):333-46. PMID: http://search.ebscohost.com/login.aspx?direct=true&db=psyh&AN=2009-22983-004&site=ehost-live madsenk@peds.ucsf.edu. [pmid: 19833672].
65 Madsen KA. School-Based Body Mass Index Screening and Parent Notification: A Statewide Natural Experiment. Arch Pediatr Adolesc Med. 2011. [pmid: 21727262].
66 Llargues E, Recasens A, Franco R, et al. Medium-term evaluation of an educational intervention on dietary and physical exercise habits in schoolchildren: the Avall 2 study. Endocrinol Nutr. 2012;59(5):288-95. [pmid: 22521298].
67 Salcedo Aguilar F, Martínez-Vizcaíno V, Sánchez López M, et al. Impact of an after-school physical activity program on obesity in children. The Journal of Pediatrics. 2010;157(1):36-42.e3. PMID: SR-ENDOC. [pmid: 20227726].
68 Haas TA, Jacobson MS. Childhood physical activity: Review of related factors and suggestions for effective counseling. CHILD. HOSP. Q. 1992;4(1):7-13. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L23290067.
69 Jago R, McMurray RG, Drews KL, et al. HEALTHY Intervention: Fitness, Physical Activity and Metabolic Syndrome Results. Med Sci Sports Exerc. 2011. [pmid: 21233778].
70 Sallis JF, McKenzie TL, Conway TL, et al. Environmental interventions for eating and physical activity: a randomized controlled trial in middle schools. Am J Prev Med. 2003;24(3):209-17. [pmid: 12657338].

## Key Question 1 School-home based

Evidence Table 7 Study characteristics for studies taking place in a school setting with a home component

Evidence Table 8 Participant characteristics for studies taking place in a school setting with a home component

Evidence Table 9 Description of the interventions used in school settings with a home component

Evidence Table 10a Weight related outcomes for diet intervention studies taking place in a school setting with a home component

Evidence Table 10b Weight related outcomes for diet intervention studies taking place in a school setting with a home component, subgroups

Evidence Table 11a Weight related outcomes for physical activity intervention studies taking place in a school setting with a home component

Evidence Table 11b Weight related outcomes for physical activity intervention studies taking place in a school setting with a home component, subgroups

Evidence Table 11c Clinical outcomes for physical activity intervention studies taking place in a school setting with a home component

Evidence Table 11d Intermediate related outcomes for physical activity intervention studies taking place in a school setting with a home component, subgroups

Evidence Table 12a Weight related outcomes for combined diet and physical activity intervention studies taking place in a school setting with a home component

Evidence Table 12b Weight related outcomes for combined diet and physical activity intervention studies taking place in a school setting with a home component, subgroups

Evidence Table 12c Intermediate related outcomes for combination diet and physical activity intervention studies taking place in a school setting with a home component, subgroups

### References, Key Question 1: School-home Setting

1 Burke V, Milligan RA, Thompson C, et al. A controlled trial of health promotion programs in 11-year-olds using physical activity “enrichment” for higher risk children. J Pediatr. 1998;132(5):840-8. [pmid: 9602197].
2 Caballero B, Clay T, Davis SM, et al. Pathways: a school-based, randomized controlled trial for the prevention of obesity in American Indian schoolchildren. Am J Clin Nutr. 2003;78(5):1030-8. [pmid: 14594792].
3 Coleman KJ, Tiller CL, Sanchez J, et al. Prevention of the epidemic increase in child risk of overweight in low-income schools: the El Paso coordinated approach to child health. Arch Pediatr Adolesc Med. 2005;159(3):217-24. [pmid: 15753263].
4 Danielzik S, Pust S, Muller MJ. School-based interventions to prevent overweight and obesity in prepubertal children: Process and 4-years outcome evaluation of the Kiel Obesity Prevention Study (KOPS). Acta Paediatr. Int. J. Paediatr. 2007;96(SUPPL. 454):19-25. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L46246517.
5 Plachta-Danielzik S, Landsberg B, Lange D, Seiberl J, Muller MJ. Eight-year follow-up of school-based intervention on childhood overweight--the Kiel Obesity Prevention Study. Obes Facts. 2011;4(1):35-43. [pmid: 21372609].
6 Dzewaltowski DA, Rosenkranz RR, Geller KS, et al. HOP'N after-school project: an obesity prevention randomized controlled trial. Int J Behav Nutr Phys Act. 2010;7:90. [pmid: 21144055].
7 Foster GD, Sherman S, Borradaile KE, et al. A policy-based school intervention to prevent overweight and obesity. Pediatrics. 2008;121(4):e794-802. [pmid: 18381508].
8 Hatzis CM, Papandreou C, Kafatos AG. School health education programs in Crete: Evaluation of behavioural and health indices a decade after initiation. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2010;51(3-4):262-7. PMID: http://search.ebscohost.com/login.aspx?direct=true&db=psyh&AN=2010-19132-013&site=ehost-live papchris10@gmail.com.
9 Hendy HM, Williams KE, Camise TS. Kid's Choice Program improves weight management behaviors and weight status in school children. Appetite. 2011;56(2):484-94. [pmid: 21277924].
10 Hoelscher DM, Springer AE, Ranjit N, et al. Reductions in child obesity among disadvantaged school children with community involvement: the Travis County CATCH Trial. Obesity (Silver Spring). Suppl 1. 2010;18:S36-44. [pmid: 20107459].
11 Hollar D, Messiah SE, Lopez-Mitnik G, Hollar TL, Almon M, Agatston AS. Effect of a two-year obesity prevention intervention on percentile changes in body mass index and academic performance in low-income elementary school children. Am J Public Health. 2010;100(4):646-53. [pmid: 20167892].
12 Hopper CA, Munoz KD, Gruber MB, Nguyen KP. The effects of a family fitness program on the physical activity and nutrition behaviors of third-grade children. Res Q Exerc Sport. 2005;76(2):130-9. [pmid: 16128481].
13 Kriemler S, Zahner L, Schindler C, et al. Effect of school based physical activity programme (KISS) on fitness and adiposity in primary schoolchildren: cluster randomised controlled trial. BMJ. 2010;340:c785. [pmid: 20179126].
14 Lionis C, Kafatos A, Vlachonikolis J, Vakaki M, Tzortzi M, Petraki A. The effects of a health education intervention program among Cretan adolescents. Preventive Medicine. 1991;20:685-99. PMID: SR-CHILD; SR-HEALTHP; SR-TOBACCO; SR-VASC. [pmid: 1766941].
15 Manios Y, Kafatos A, Mamalakis G. The effects of a health education intervention initiated at first grade over a 3 year period: physical activity and fitness indices. Health Educ Res. 1998;13(4):593-606. [pmid: 10345909].
16 Marcus C, Nyberg G, Nordenfelt A, Karpmyr M, Kowalski J, Ekelund U. A 4-year, cluster-randomized, controlled childhood obesity prevention study: STOPP. Int J Obes (Lond). 2009;33(4):408-17. [pmid: 19290010].
17 Mihas C, Mariolis A, Manios Y, et al. Evaluation of a nutrition intervention in adolescents of an urban area in Greece: short- and long-term effects of the VYRONAS study. Public Health Nutr. 2010;13(5):712-9. [pmid: 19781127].
18 Nader PR, Stone EJ, Lytle LA, et al. Three-year maintenance of improved diet and physical activity: The CATCH cohort. Archives of Pediatrics & Adolescent Medicine. 1999;153(7):695-704. PMID: SR-VASC. [pmid: 10401802].
19 Robinson TN. Reducing children's television viewing to prevent obesity: a randomized controlled trial. JAMA. 1999;282(16):1561-7. [pmid: 10546696].
20 Schetzina KE, Dalton WT 3rd, Lowe EF, et al. A coordinated school health approach to obesity prevention among Appalachian youth: the Winning with Wellness Pilot Project. Fam Community Health. 2009;32(3):271-85. [pmid: 19525708].
21 Shofan Y, Kedar O, Branski D, Berry E, Wilschanski M. A school-based program of physical activity may prevent obesity. Eur. J. Clin. Nutr. 2011;65(6):768-70. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L51332437. [pmid: 21427748].
22 Simon C, Schweitzer B, Oujaa M, et al. Successful overweight prevention in adolescents by increasing physical activity: a 4-year randomized controlled intervention. Int J Obes (Lond). 2008;32(10):1489-98. [pmid: 18626482].
23 Simonetti D'Arca A, Tarsitani G, Cairella M. Prevention of obesity in elementary and nursery school children. PUBLIC HEALTH. 1986;100(3):166-73. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L16083936. [pmid: 3737864].
24 Speroni KG, Earley C, Atherton M. Evaluating the effectiveness of the Kids Living Fit program: a comparative study. J Sch Nurs. 2007;23(6):329-36. [pmid: 18052518].
25 Trevino RP, Yin Z, Hernandez A, Hale DE, Garcia OA, Mobley C. Impact of the Bienestar school-based diabetes mellitus prevention program on fasting capillary glucose levels: a randomized controlled trial. Arch Pediatr Adolesc Med. 2004;158(9):911-7. [pmid: 15351759].
26 Story M, Hannan PJ, Fulkerson JA, et al. Bright Start: Description and Main Outcomes From a Group-Randomized Obesity Prevention Trial in American Indian Children. Obesity. 2012. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L52004515.
27 Brandstetter S, Klenk J, Berg S, et al. Overweight prevention implemented by primary school teachers: A randomised controlled trial. Obes. Facts. 2012;5(1):1-11. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L364498393. [pmid: 22433612].
28 Llargues E, Franco R, Recasens A, et al. Assessment of a school-based intervention in eating habits and physical activity in school children: the AVall study. Journal of Epidemiology & Community Health. 2011;65(10):896-901. PMID: http://search.ebscohost.com/login.aspx?direct=true&db=rzh&AN=2011295396&site=ehost-live. [pmid: 21398682].
29 Lloyd JJ, Wyatt KM, Creanor S. Behavioural and weight status outcomes from an exploratory trial of the Healthy Lifestyles Programme (HeLP): a novel school-based obesity prevention programme. BMJ Open. 2012;2(3). [pmid: 22586282].
30 Williamson DA, Champagne CM, Harsha DW, et al. Effect of an Environmental School-Based Obesity Prevention Programon Changes in Body Fat and Body Weight: A Randomized Trial. Obesity (Silver Spring). 2012. [pmid: 22402733].
31 Siegrist M, Lammel C, Haller B, Christle J, Halle M. Effects of a physical education program on physical activity, fitness, and health in children: The JuvenTUM project. Scand J Med Sci Sports. 2011. [pmid: 22092492].
32 Manios Y, Moschandreas J, Hatzis C, Kafatos A. Health and nutrition education in primary schools of Crete: Changes in chronic disease risk factors following a 6-year intervention programme. British Journal of Nutrition. 2002;88(3):315-24. PMID: SR-CHILD; SR-VASC. [pmid: 12207842].
33 Manios Y, Moschandreas J, Hatzis C, Kafatos A. Evaluation of a health and nutrition education program in primary school children of Crete over a three-year period. Prev Med. 1999;28(2):149-59. [pmid: 10048106].
34 Manios Y, Kafatos A. Health and nutrition education in primary schools in Crete: 10 years follow-up of serum lipids, physical activity and macronutrient intake. Br J Nutr. 2006;95(3):568-75. [pmid: 16578934].
35 Jago R, McMurray RG, Drews KL, et al. HEALTHY Intervention: Fitness, Physical Activity and Metabolic Syndrome Results. Med Sci Sports Exerc. 2011. [pmid: 21233778].
36 Fitzgibbon ML, Stolley MR, Schiffer L, Van Horn L, KauferChristoffel K, Dyer A. Hip-Hop to Health Jr. for Latino preschool children. Obesity (Silver Spring). 2006;14(9):1616-25. [pmid: 17030973].
37 Gorely T, Nevill ME, Morris JG, Stensel DJ, Nevill A. Effect of a school-based intervention to promote healthy lifestyles in 7-11 year old children. Int J Behav Nutr Phys Act. 2009;6:5. [pmid: 19154622].

## Key Question 1 School-home-community based

Evidence Table 13 Study characteristics for studies taking place in a school setting with home and community components

Evidence Table 14 Participant characteristics for studies taking place in a school setting with home and community components

Evidence Table 15 Description of the interventions used in school settings with home and community components

Evidence Table 16a Weight-related outcomes for physical activity intervention studies taking place in a school setting with home and community component

Evidence Table 16b Intermediate outcomes for physical activity intervention studies taking place in a school setting with home and community component

Evidence Table 17a Weight related outcomes for combined diet and physical activity intervention studies taking place in a school setting with home and community components

Evidence Table 17b Weight related outcomes for combined diet and physical activity intervention studies taking place in a school setting with home and community components, subgroups

Evidence Table 17c Clinical outcomes for combined diet and physical activity intervention studies taking place in a school setting with home and community components

Evidence Table 17d Intermediate outcomes for combined diet and physical activity intervention studies taking place in a school setting with home and community components

### References, Key Question 1: School-home-community Setting

1 Angelopoulos PD, Milionis HJ, Grammatikaki E, Moschonis G, Manios Y. Changes in BMI and blood pressure after a school based intervention: the CHILDREN study. Eur J Public Health. 2009;19(3):319-25. [pmid: 19208697].
2 De Coen V, De Bourdeaudhuij I, Vereecken C, et al. Effects of a 2-year healthy eating and physical activity intervention for 3-6-year-olds in communities of high and low socio-economic status: the POP (Prevention of Overweight among Pre-school and school children) project. Public Health Nutr. 2012:1-9. [pmid: 23294865].
3 de Meij JS, Chinapaw MJ, van Stralen MM, van der Wal MF, van Dieren L, van Mechelen W. Effectiveness of JUMP-in, a Dutch primary school-based community intervention aimed at the promotion of physical activity. Br J Sports Med. 2010. [pmid: 21112875].
4 Greening L, Harrell KT, Low AK, Fielder CE. Efficacy of a school-based childhood obesity intervention program in a rural southern community: TEAM Mississippi Project. Obesity (Silver Spring). 2011;19(6):1213-9. [pmid: 21233806].
5 Jansen W, Borsboom G, Meima A, et al. Effectiveness of a primary school-based intervention to reduce overweight. Int. J. Pediatr. Obes. 2011;6(2 -2):e70-e77. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L362077602. [pmid: 21609245].
6 Sanigorski AM, Bell AC, Kremer PJ, Cuttler R, Swinburn BA. Reducing unhealthy weight gain in children through community capacity-building: results of a quasi-experimental intervention program, Be Active Eat Well. Int J Obes (Lond). 2008;32(7):1060-7. [pmid: 18542082].
7 Millar L, Kremer P, de Silva-Sanigorski A, et al. Reduction in overweight and obesity from a 3-year community-based intervention in Australia: the ‘It's Your Move!’ project. Obes Rev. Suppl 2. 2011;12:20-8. [pmid: 22008556].
8 Naul R, Schmelt D, Dreiskaemper D, Hoffmann D, l'Hoir M. ‘Healthy children in sound communities’ (HCSC/gkgk)--a Dutch-German community-based network project to counteract obesity and physical inactivity. Fam Pract. Suppl 1. 2012;29:i110-i116. [pmid: 22399539].
9 Tomlin D, Naylor PJ, McKay H, Zorzi A, Mitchell M, Panagiotopoulos C. The impact of Action Schools! BC on the health of Aboriginal children and youth living in rural and remote communities in British Columbia. Int J Circumpolar Health. 2012;71:17999. [pmid: 22456048].

## Key Question 1 School-community based

Evidence Table 18 Study characteristics for studies taking place in a school setting with community components

Evidence Table 19 Participant characteristics for studies taking place in a school setting with community components

Evidence Table 20 Description of the interventions used in school settings with a community component

Evidence Table 21a Weight related outcomes for studies with a diet intervention in a school setting with a community component

Table 21b Weight related outcomes for diet intervention studies taking place in a school setting with community component, subgroup

Evidence Table 21c Intermediate outcomes for studies with a diet intervention in a school setting with a community component

Table 22a Weight related outcomes for physical activity intervention studies taking place in a school setting with community component

Evidence Table 22b Intermediate outcomes for physical activity intervention studies taking place in a school setting with a community component

Evidence Table 23a Weight-related outcomes for combined diet and physical activity interventions in a school setting with a community component

Evidence Table 23b Weight-related outcomes for combined diet and physical activity interventions in a school setting with a community component, subgroup

Evidence Table 23c Clinical outcomes for combined diet and physical activity intervention studies taking place in a school setting with community components

Evidence Table 23d Intermediate outcomes for combination diet and physical activity intervention studies taking place in a school setting with community components

### References, Key Question 1: School-community Setting

1 Macaulay AC, Paradis G, Potvin L, et al. The Kahnawake Schools Diabetes Prevention Project: intervention, evaluation, and baseline results of a diabetes primary prevention program with a native community in Canada. Prev Med. 1997;26(6):779-90. [pmid: 9388789].
2 Muckelbauer R, Libuda L, Clausen K, Reinehr T, Kersting M. A simple dietary intervention in the school setting decreased incidence of overweight in children. Obes Facts. 2009;2(5):282-5. [pmid: 20057194].
3 Muckelbauer R, Libuda L, Clausen K, Toschke AM, Reinehr T, Kersting M. Immigrational background affects the effectiveness of a school-based overweight prevention program promoting water consumption. Obesity (Silver Spring). 2010;18(3):528-34. [pmid: 19713953].
4 Webber LS, Catellier DJ, Lytle LA, et al. Promoting physical activity in middle school girls: Trial of Activity for Adolescent Girls. Am J Prev Med. 2008;34(3):173-84. [pmid: 18312804].
5 Utter J, Scragg R, Robinson E, et al. Evaluation of the Living 4 Life project: A youth-led, school-based obesity prevention study. Obes. Rev. 2011;12(SUPPL. 2):51-60. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L362791232. [pmid: 22008559].
6 Paradis G, Levesque L, Macaulay AC, et al. Impact of a diabetes prevention program on body size, physical activity, and diet among Kanien'keha:ka (Mohawk) children 6 to 11 years old: 8-year results from the Kahnawake Schools Diabetes Prevention Project. Pediatrics. 2005;115(2):333-9. [pmid: 15687441].

## Key Question 1 School-CHI and School-home-CHI based

Evidence Table 24 Study characteristics for studies taking place in a school setting with consumer health informatics components and in a school setting with home and consumer health informatics components

Evidence Table 25 Participant characteristics for studies taking place in a school setting with consumer health informatics components and in a school setting with home and consumer health informatics components

Evidence Table 26 Description of the interventions used in school settings with consumer health informatics components and in a school setting with home and consumer health informatics components

Evidence Table 27 Weight related outcomes for physical activity intervention studies taking place in a school setting with consumer health informatics components

Evidence Table 28a Weight related outcomes for combination diet and physical activity intervention studies taking place in a school setting with consumer health informatics components and in a school setting with home and consumer health informatics components

Evidence Table 28b Weight related outcomes for combination diet and physical activity intervention studies taking place in a school setting with consumer health informatics components and in a school setting with home and consumer health informatics components, subgroups

Evidence Table 28c Intermediate outcomes for combination diet and physical activity intervention studies taking place in a school setting with consumer health informatics components and in a school setting with home and consumer health informatics components

### References, Key Question 1: School-consumer health informatics and school-home-consumer health informatics Settings

1 Schneider M, Dunton GF, Bassin S, Graham DJ, Eliakim A, Cooper DM. Impact of a School-Based Physical Activity Intervention on Fitness and Bone in Adolescent Females. Journal of Physical Activity & Health. 2007;4(1):17-29. PMID: http://search.ebscohost.com/login.aspx?direct=true&db=psyh&AN=2007-00945-002&site=ehost-live. [pmid: 17489004].
2 Spiegel SA, Foulk D. Reducing overweight through a multidisciplinary school-based intervention. Obesity (Silver Spring Md.). 2006;14(1):88-96. PMID: SR-ENDOC; SR-VASC.
3 Gorely T, Morris JG, Musson H, Brown S, Nevill A, Nevill ME. Physical activity and body composition outcomes of the GreatFun2Run intervention at 20 month follow-up. International Journal of Behavioral Nutrition & Physical Activity. 2011;8:11. PMID: http://search.ebscohost.com/login.aspx?direct=true&db=rzh&AN=2011241938&site=ehost-live. [pmid: 21324105].
4 Prins RG, Brug J, van Empelen P, Oenema A. Effectiveness of YouRAction, an intervention to promote adolescent physical activity using personal and environmental feedback: A cluster RCT. PLoS ONE. 2012;7(3). PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L364370623.
5 Ezendam NPM, Brug J, Oenema A. Evaluation of the web-based computer-tailored FATaintPHAT intervention to promote energy balance among adolescents: Results from a school cluster randomized trial. Arch. Pediatr. Adolesc. Med. 2012;166(3):248-55. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L364397506. [pmid: 22064878].

## Key Question 2 Home-only

Evidence Table 29 Study characteristics for studies taking place in a home only setting

Evidence Table 30 Participant characteristics for studies taking place in a home only setting

Evidence Table 31 Description of the interventions used in home only settings

Evidence Table 32a Weight related outcomes for diet intervention studies taking place in a home only setting

Evidence Table32b Intermediate related outcomes for diet intervention studies taking place in a home only setting

Evidence Table 33a Weight related outcomes for combined diet and physical activity intervention studies taking place in a home only setting

Evidence Table 33b Intermediate related outcomes for combined diet and physical activity intervention studies taking place in a home only setting

### References, Key Question 2: Home-only Setting

1 Epstein LH, Gordy CC, Raynor HA, Beddome M, Kilanowski CK, Paluch R. Increasing fruit and vegetable intake and decreasing fat and sugar intake in families at risk for childhood obesity. Obes Res. 2001;9(3):171-8. [pmid: 11323442].
2 Lappe JM, Rafferty KA, Davies KM, Lypaczewski G. Girls on a high-calcium diet gain weight at the same rate as girls on a normal diet: a pilot study. J Am Diet Assoc. 2004;104(9):1361-7. [pmid: 15354150].
3 French SA, Gerlach AF, Mitchell NR, Hannan PJ, Welsh EM. Household obesity prevention: Take actiona group-randomized trial. Obesity. 2011;19(10):2082-8. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L51220196. [pmid: 21212771].
4 Fitzgibbon ML, Stolley MR, Schiffer L, et al. Family-Based Hip-Hop to Health: Outcome Results. Obesity (Silver Spring). 2012.

## Key Question 2 Home-primary care-CHI based

Evidence Table 34 Study characteristics for studies taking place in a home setting with primary care and consumer health informatics components

Evidence Table 35 Participant characteristics for studies taking place in a home setting with primary care and consumer health informatics components

Evidence Table 36 Description of the interventions used in home settings with primary care and consumer health informatics components

Evidence Table 37a Weight related outcomes for combination diet and physical activity intervention studies taking place in a home setting with primary care and consumer health informatics components

Evidence Table 37b Weight related outcomes for combination diet and physical activity intervention studies taking place in a home setting with primary care and consumer health informatics components, subgroups

Evidence Table 37c Intermediate outcomes for combination diet and physical activity intervention studies taking place in a home setting with primary care and consumer health informatics components

### References, Key Question 2: Home-primary care-consumer health informatics Setting

1 Patrick K, Calfas KJ, Norman GJ, et al. Randomized controlled trial of a primary care and home-based intervention for physical activity and nutrition behaviors: PACE+ for adolescents. Arch Pediatr Adolesc Med. 2006;160(2):128-36. [pmid: 16461867].

## Key Question 2 Home-school-community

Evidence Table 38 Study characteristics for studies taking place in a home setting with school and community components

Evidence Table 39 Participant characteristics for studies taking place in a home setting with school and community components

Evidence Table 40 Description of the interventions used in home settings with school and community components

Evidence Table 41a Weight related outcomes for combination diet and physical activity intervention studies taking place in a home setting with school and community components

Evidence Table 41b Weight related outcomes for combination diet and physical activity intervention studies taking place in a home setting with school and community components, subgroups

Evidence Table 41c Intermediate outcomes for combination diet and physical activity intervention studies taking place in a home setting with school and community components

### References, Key Question 2: Home-school-community Setting

1 Gentile DA, Welk G, Eisenmann JC, et al. Evaluation of a multiple ecological level child obesity prevention program: Switch what you Do, View, and Chew. BMC Med. 2009;7:49. [pmid: 19765270].

## Key Question 3 Primary care-based

Evidence Table 42 Study characteristics for studies taking place in a primary care setting

Evidence Table 43 Participant characteristics for studies taking place in a primary care setting

Evidence Table 44 Description of the interventions used in primary care settings

Evidence Table 45a Weight related outcomes for combination diet and physical activity intervention studies taking place in a primary care setting

Evidence Table 45b Intermediate outcomes for combination diet and physical activity intervention studies taking place in a primary care setting

### References, Key Question 3: Primary Care-only Setting

1 Polacsek M, Orr J, Letourneau L, et al. Impact of a primary care intervention on physician practice and patient and family behavior: Keep ME HealthyΓÇöThe Maine Youth Overweight Collaborative. Pediatrics. 2009;123(Suppl):258-66. PMID: http://search.ebscohost.com/login.aspx?direct=true&db=psyh&AN=2010-01456-001&site=ehost-live mpolacsek@mcph.org.

## Key Question 4 Child care-based

Evidence Table 46 Study characteristics for studies taking place in a child care setting

Evidence Table 47 Participant characteristics for studies taking place in a child care setting

Evidence Table 48 Description of the interventions used in child care settings

Evidence Table 49a Weight related outcomes for physical activity intervention studies taking place in a child care setting, subgroups

Evidence Table 49b Clinical outcomes for physical activity intervention studies taking place in a child care setting

Evidence Table 50a Weight related outcomes for combination diet and physical activity intervention studies taking place in a child care setting

Evidence Table 50b Weight related outcomes for combined diet physical activity intervention studies taking place in a childcare only setting, by subgroup

Evidence Table 50c Intermediate outcomes for combination diet and physical activity intervention studies taking place in a child care setting

### References, Key Question 4: Child care-Only Setting

1 Bayer O, von Kries R, Strauss A, et al. Short- and mid-term effects of a setting based prevention program to reduce obesity risk factors in children: a cluster-randomized trial. Clin Nutr. 2009;28(2):122-8. [pmid: 19303675].
2 Fitzgibbon ML, Stolley MR, Schiffer L, Van Horn L, KauferChristoffel K, Dyer A. Hip-Hop to Health Jr. for Latino preschool children. Obesity (Silver Spring). 2006;14(9):1616-25. [pmid: 17030973].
3 Scheffler C, Ketelhut K, Mohasseb I. Does physical education modify the body composition?--results of a longitudinal study of pre-school children. Anthropol Anz. 2007;65(2):193-201. [pmid: 17711151].
4 Metcalf B, Wilkin T, Puder J, et al. Lifestyle intervention has little effect on obesity. Puder JJ, Marques-Vidal P, Schindler C, Zahner L, Niederer I, Burgi F, et al. Effect of multidimensional lifestyle intervention on fitness and adiposity in predominantly migrant preschool children (Ballabeina): cluster randomised controlled trial. BMJ 2011;343:d6195. (13 October.). BMJ: British Medical Journal (Overseas & Retired Doctors Edition). 2012;344(7842):32-3. PMID: http://search.ebscohost.com/login.aspx?direct=true&db=rzh&AN=2011487132&site=ehost-live.
5 Burgi F, Niederer I, Schindler C, et al. Effect of a lifestyle intervention on adiposity and fitness in socially disadvantaged subgroups of preschoolers: A cluster-randomized trial (Ballabeina). Prev. Med. 2012;54(5):335-40. PMID: http://www.embase.com/search/results?subaction=viewrecord&from=export&id=L51914473. [pmid: 22373886].

## Key Question 5 Community-only

Evidence Table 51 Study characteristics for studies taking place in a community only setting

Evidence Table 52 Participant characteristics for studies taking place in a community only setting

Evidence Table 53 Description of the interventions used in community only settings

Evidence Table 54a Weight related outcomes for physical activity intervention studies taking place in a community only setting

Evidence Table 54b Intermediate outcomes for physical activity intervention studies taking place in a community only setting

### References, Key Question 5: Community-only Setting

1 Eiholzer U, Meinhardt U, Petro R, Witassek F, Gutzwiller F, Gasser T. High-intensity training increases spontaneous physical activity in children: a randomized controlled study. J Pediatr. 2010;156(2):242-6. [pmid: 19846114].

## Key Question 5 Community-school

Evidence Table 55 Study characteristics for studies taking place in a community setting with a school component

Evidence Table 56 Participant characteristics for studies taking place in a community setting with a school component

Evidence Table 57 Description of the interventions used in community settings with a school component

Evidence Table 58a Weight related outcomes for combination diet and physical activity intervention studies taking place in a community setting with a school component

Evidence Table 58b Weight related outcomes for combination diet and physical activity intervention studies taking place in a community setting with a school component, subgroups

Evidence Table 58c Intermediate outcomes for combination diet and physical activity intervention studies taking place in a community setting with a school component

### References, Key Question 5: Community-school Setting

1 Chomitz VR, McGowan RJ, Wendel JM, et al. Healthy Living Cambridge Kids: a community-based participatory effort to promote healthy weight and fitness. Obesity (Silver Spring). Suppl 1. 2010;18:S45-53. [pmid: 20107461].
2 Singh AS, Chin A, Paw MJ, Brug J, van Mechelen W. Dutch obesity intervention in teenagers: effectiveness of a school-based program on body composition and behavior. Arch Pediatr Adolesc Med. 2009;163(4):309-17. [pmid: 19349559].
3 Sallis JF, McKenzie TL, Conway TL, et al. Environmental interventions for eating and physical activity: a randomized controlled trial in middle schools. Am J Prev Med. 2003;24(3):209-17. [pmid: 12657338].

## Key Question 5 Community-school-home

Evidence Table 59 Study characteristics for studies taking place in a community setting with school and home components

Evidence Table 60 Participant characteristics for studies taking place in a community setting with home and school components

Evidence Table 61 Description of the interventions used in community settings with school and home components

Evidence Table 62a Weight related outcomes for combined diet and physical activity intervention studies taking place in a community setting with school and home components

Evidence Table 62b Weight related outcomes for combined diet and physical activity intervention studies taking place in a community setting with school and home components, subgroups

### References, Key Question 5: Community-school-home Setting

1 Economos CD, Hyatt RR, Goldberg JP, et al. A community intervention reduces BMI z-score in children: Shape Up Somerville first year results. Obesity (Silver Spring). 2007;15(5):1325-36. [pmid: 17495210].

## Key Question 5 Community-home

Evidence Table 63 Study characteristics for studies taking place in a community setting with a home component

Evidence Table 64 Participant characteristics for studies taking place in a community setting with a home component

Evidence Table 65 Description of the interventions used in community settings with a home component

Evidence Table 66a Weight related outcomes for combined diet and physical activity intervention studies taking place in a community setting with a home component

Evidence Table 66b Clinical outcomes for physical activity intervention studies taking place in a community setting with home components

### References, Key Question 5: Community-home Setting

1 Robinson TN, Matheson DM, Kraemer HC, et al. A randomized controlled trial of culturally tailored dance and reducing screen time to prevent weight gain in low-income African American girls: Stanford GEMS. Arch Pediatr Adolesc Med. 2010;164(11):995-1004. [pmid: 21041592].
2 Klesges RC, Obarzanek E, Kumanyika S, et al. The Memphis Girls' health Enrichment Multi-site Studies (GEMS): an evaluation of the efficacy of a 2-year obesity prevention program in African American girls. Arch Pediatr Adolesc Med. 2010;164(11):1007-14. [pmid: 21041593].

## Key Question 5 Community-home-primary care-child care

Evidence Table 67 Study characteristics for studies taking place in a community setting with home, primary care, and childcare components

Evidence Table 68 Participant characteristics for studies taking place in a community setting with home, primary care, and childcare components

Evidence Table 69 Description of the interventions used in community settings with home, primary care, and childcare components

Evidence Table 70a Weight related outcomes for combination diet and physical activity intervention studies taking place in a community setting with home, primary care, and childcare components

Evidence Table 70b Weight related outcomes for combination diet and physical activity intervention studies taking place in a community setting with home, primary care, and childcare components, subgroups

Evidence Table 70c Intermediate outcomes for combination diet and physical activity intervention studies taking place in a community setting with home, primary care, and childcare components

### References, Key Question 5: Community-home-primary care-child care Setting

1 de Silva-Sanigorski AM, Bell AC, Kremer P, et al. Reducing obesity in early childhood: results from Romp & Chomp, an Australian community-wide intervention program. Am J Clin Nutr. 2010;91(4):831-40. [pmid: 20147472].

## Key Question 5 Community-school-primary care-child care

Evidence Table 71 Study characteristics for studies taking place in a community setting with school, primary care, and childcare components

Evidence Table 72 Participant characteristics for studies taking place in a community setting with school, primary care, and childcare components

Evidence Table 73 Description of the interventions used in community settings with school, primary care, and childcare components

Evidence Table 74 Weight related outcomes for diet only intervention studies taking place in a community setting with school, primary care, and childcare components

### References, Key Question 5: Community-school-primary care-child care Setting

1 Chang DI, Gertel-Rosenberg A, Drayton VL, Schmidt S, Angalet GB. A statewide strategy to battle child obesity in Delaware. Health Aff (Millwood). 2010;29(3):481-90. [pmid: 20194990].