# List of Excluded Articles

## No original data

Adimoolam V, Charney P. Identification and management of overweight and obesity by internal medicine residents: Christopher B. Ruser Lisa Sanders et al. J Gen Intern Med. 2006;21(10):1128. [pmid: 16836619].
Aggarwal A. Stay healthy through game-care therapeutics: It's time to play the game!. Value Health. 2011;14(7):A298.
Alborzimanesh M, Kimiagar M, Rashidkhani B, et al. The relation between overweight and obesity with some lifestyle factors in the 3rd-5th grade primary schoolgirls in Tehran City 6th dist [Farsi]. Iranian Journal of Nutrition Sciences & Food Technology. 2011;6(3):84.
Allender S, Osborne R, Bowen S, et al. Measuring the ‘system’ in whole of system approaches to obesity prevention. Obes Res Clin Pract. 2011;5:S51.
Ambroz TA, Boucher JL. Childhood Obesity: reversing the trend to improve the health of the next generation. Diabetes Spectr. 2012;25(1):3-4.
An R, Sturm R. School and residential neighborhood food environment and diet among California youth. Am J Prev Med. 2012;42(2):129-35. [pmid: 22261208].
Anderson AS. Obesity prevention and management. evidence and policy. J Hum Nutr Diet. 2005;18(1):1-2. [pmid: 15647092].
Ashworth J. A sporting solution to improving long-term community health. Prim Health Care. 2011;21(3):22-4.
Bainbridge D. A History of FUNFitness. HPA Resource. 2011;11(4):1-7.
Bartholomew JB, Jowers EM. Physically active academic lessons in elementary children. Prev Med. 2011;52:S51-4. [pmid: 21281672].
Bartz S, Freemark M. Pathogenesis and prevention of type 2 diabetes: parental determinants, breastfeeding, and early childhood nutrition. Curr Diabetes Rep. 2012;12(1):82-7.
Bauer KW, Berge JM, Neumark-Sztainer D. The importance of families to adolescents' physical activity and dietary intake. Adolesc Med State Art Rev. 2011;22(3):601-13. xiii. [pmid: 22423466].
Berg A. New prevention program in obesity. When one becomes mobile then the pounds tumble too. MMW Fortschr Med. 2003;145(51-52):11. [pmid: 14974320].
Beyerlein A, von Kries R. Breastfeeding and body composition in children: will there ever be conclusive empirical evidence for a protective effect against overweight?. Am J Clin Nutr. 2011;94(6S):1772S-75. [pmid: 21525195].
Bohme MWJ, Schmolz GKK, Bohm BO. Pravention von Typ-2-Diabetes im Rahmen der Gesundheitsstrategie Baden-Wurttemberg Eine Einfuhrung. Prevention of type 2 diabetes within the framework of the health strategy of Baden-Wuerttemberg. Diabetes Aktuell. 2011;9(8):337-9.
Bolssonneault GA, Essary AC, Brenneman AE, et al. Childhood obesity: screening and early intervention. JAAPA. 2011;24(9):24-27.
Bonsergent E, Briancnullon S, Agrinier N, et al. Effectiveness of three overweight and obesity prevention strategies in high school adolescents: The PRALIMAP trial. Can J Diabetes. 2011;35(2):163.
Booker JM, Schluter JA, Carrillo K, et al. Quality improvement initiative in school-based health centers across New Mexico. J Sch Health. 2011;81(1):42-8. [pmid: 21158865].
Borys JM, Le Bodo Y, Walter L. EPODE European network: key recommendations for the setting of community-based interventions aimed at preventing childhood obesity. Obes Rev. 2011;12:6.
Borys JM, Walter L, Du Plessis H, et al. Lessons of the epode European network (EEN) for the prevention of childhood obesity through community-based interventions. Obes Facts. 2012;5:67-8.
Boyland EJ, Halford JC. Television advertising and branding: effects on eating behaviour and food preferences in children. Appetite. 2012. [Epub ahead of print].
Branscum P, Sharma M. After-school based obesity prevention interventions: a comprehensive review of the literature. Int J Environ Res Public Health. 2012;9(4):1438-57. [pmid: 22690204].
Bratina N, Hadzic V, Batellino T, et al. Slovenske smernice za telesno udejstvovanje otrok in mladostnikov v starostni skupini od 2 do 18 let. Slovenian guidelines for physical activity in children and adolescents in the age group 2-18 years. Zdravniski Vestn. 2011;80(12):885-96.
Brownell KD, Wadden TA, Foster GD. A comprehensive treatment plan for obese children and adolescents: Principles and practice. Pediatrician. 1984-85;12(2-3):89-96. [pmid: 6571156].
Brug J. Childhood obesity prevention in Europe: the science of behaviour change. Australas Med J. 2011;4(12):715.
Bruney TS. Childhood obesity: Eoffects of micronutrients, supplements, genetics, and oxidative stress. J Nurse Pract. 2011;7(8):647-63.
Buonani C, Fernandes RA, Silveira LS, et al. Prevencao da sindrome metabolica em criancas obesas: Uma proposta de intervencao. Prevention of metabolic syndrome in obese children: a proposal of intervention. Rev Paul Pediatr. 2011;29(2):186-92.
Cabodi J, Kelsberg G, Safranek S. Clinical inquiry: does brief physician counseling promote weight loss?. J Fam Pract. 2011;60(9):548-50. [pmid: 21901183].
Cardon G. Physical activity interventions in children. Obes Rev. 2011;12:17.
Cervoni E. Height and weight checks for children in primary care. Br J Gen Pract. 2011;61(582):65. [pmid: 21402001].
Chan CB, Anders S, Bell RC, et al. The 4-A Framework: a model for development and evaluation of behavioural interventions. Can J Diabetes. 2011;35(2):210.
Cheng G, Buyken AE, Shi L, et al. Beyond overweight: nutrition as an important lifestyle factor influencing timing of puberty. Nutr Rev. 2012;70(3):133-52. [pmid: 22364156].
Cheung L. Do media influence childhood obesity?. Ann New York Acad Sci. 1993;699:104-106. [pmid: 8267300].
Christian BJ. Targeting the obesity epidemic in children and adolescents: research evidence for oractice. J Pediatr Nurs. 2011;26(5):503-6. [pmid: 21930040].
Christie D, Hudson L, Mathiot A, et al. Assessing the efficacy of the Healthy Eating and Lifestyle Programme (HELP) compared with enhanced standard care of the obese adolescent in the community: study protocol for a randomized controlled trial. Trials. 2011;12:242. [pmid: 22088133].
Clinical digest. Delaying gratification helps children avoid gaining weight. Nurs Stand. 2010;25(3):17.
Cohen D, Rabinovich L. Addressing the proximal causes of obesity: the relevance of alcohol control policies. Prev Chronic Dis. 2012;9:E94. [pmid: 22554409].
Colchico K, Zybert P, Basch CE. Effects of after-school physical activity on fitness fatness and cognitive self-perceptions: A pilot study among urban minority adolescent girls. Am J Public Health. 2000;90(6):977-978. [pmid: 10846520].
Crawford PB, Gosliner W, Kayman H. The ethical basis for promoting nutritional health in public schools in the United States. Prev Chronic Dis. 2011;8(5):A98. [pmid: 21843428].
D I L. Rural health care providers in California look to telehealth to supply the training needed to manage childhood obesity. Res Activities. 2012;(381):11-12.
Dalton WT, Schetzina KE, Holt N, et al. Parent-led Activity and Nutrition (PLAN) for healthy living: design and methods. Contemp Clin Trials. 2011;32(6):882-92. [pmid: 21777701].
Daniels L, Magarey A. Obesity interventions in the very young: rationale and evidence. Obes Rev. 2011;12:25-6.
Daniels SR, Pratt CA, Hayman LL. Reduction of risk for cardiovascular disease in children and adolescents. Circulation. 2011;124(15):1673-86. [pmid: 21986774].
Dattilo AM, Birch L, Krebs NF, et al. Need for early interventions in the prevention of pediatric overweight: a review and upcoming directions. J Obes. 2012;2012:123023. [pmid: 22675610].
Davis SM, Going SB, Helitzer DL, et al. Pathways: a culturally appropriate obesity-prevention program for American Indian schoolchildren. Am J Clin Nutr. 1999;69(4 Suppl):796S-802S. [pmid: 10195605].
De Bourdeaudhuij I, Van Cauwenberghe E, Spittaels H, et al. School-based interventions promoting both physical activity and healthy eating in Europe: a systematic review within the HOPE project. (Provisional abstract). Obes Rev. 2011;12(3):205-16. [pmid: 20122137].
De Henauw S, Verbestel V, Marild S, et al. The IDEFICS community-oriented intervention programme: a new model for childhood obesity prevention in Europe?. Int J Obes(Lond). 2011;35(1 Suppl):S16-23. [pmid: 21483418].
De Ruyter JC, Olthof MR, Kuijper LDJ, et al. Effect of sugar-sweetened beverages on body weight in children: design and baseline characteristics of the double-blind, randomized intervention study in kids. Contemp Clin Trials. 2012;33(1):247-57. [pmid: 22056980].
Decker JW. Photovoice: An untapped method for community needs assessment in obesity research. Obesity. 2011;19:S145.
Deforche B, Haerens L, De Bourdeaudhuij I. How to make overweight children exercise and follow the recommendations. Int J Pediatr Obes. 2011;6(Suppl 1):35-41. [pmid: 21905814].
Dennisuk LA, Coutinho AJ, Suratkar S, et al. Food expenditures and food purchasing among low-income, urban, African-American youth. Am J Prev Med. 2011;40(6):625-8. [pmid: 21565654].
Diamond A. Healthy eating should be part of the school curriculum. Nurs Stand. 2011;26(2):28.
Dietz WH Jr. Childhood obesity: susceptibility cause and management. J Pediatr. 1983;103(5):676-86. [pmid: 6631594].
Ding D, Sallis JF, Kerr J, et al. Neighborhood environment and physical activity among youth a review. Am J Prev Med. 2011;41(4):442-55. [pmid: 21961474].
Dumontet J, Durksen A, Lamboo-Miln A, et al. Healthy Buddies Manitoba: a cluster randomized controlled effectiveness trial of a peer-led healthy living lesson plan on unhealthy weight gain and physical activity in early years students. Can J Diabetes. 2011;35(2):164.
Edwards MB, Miller JL, Blackburn L. After-school programs for health promotion in rural communities: Ashe county middle school 4-h after-school program. ClinJ Public Health Manag Pract. 2011;17(3):283-7.
Eisenmann JC, Alaimo K, Pfeiffer K, et al. Project FIT: rationale, design and baseline characteristics of a school- and community-based intervention to address physical activity and healthy eating among low-income elementary school children. BMC Public Health. 2011;11:607. [pmid: 21801411].
Elder JP, Holub CK, Arredondo E, et al. Obesity interventions among U.S. Latinos and Latin Americans: a systematic literature review. Obesity. 2011;19:S123.
Escalante Y, Saavedra JM, Garcia-Hermoso A, et al. Improvement of the lipid profile with exercise in obese children: a systematic review. Prev Med. 2012;54(5):293-301. [pmid: 22387009].
Evans WD, Necheles J, Longjohn M, et al. The 5-4-3-2-1 go! Intervention: social marketing strategies for nutrition. J Nutr Educ Behav. 2007;39(2 Suppl):S55-9. [pmid: 17336809].
Evenson Kl, Aytur S. DataBase: research and evaluation results. A national study of neighborhood safety outdoor play television viewing and obesity in preschool children. Am J Health Promot. 2006;21(1):59.
Faith MS, Van Horn L, Appel LJ, et al. Evaluating parents and adult caregivers as “agents of change”; for treating obese children: evidence for parent behavior change strategies and research gaps: a scientific statement from the American Heart Association. Circulation. 2012;125(9):1186-207. [pmid: 22271754].
Farpour-Lambert NJ, Lissner L. The two faces of childhood obesity monitoring. Obes Rev. 2011;12:25.
Fassihi M, Rudolf M, McElhone S, et al. Which factors predict unsuccessful outcome in a weight management intervention for obese children?. J Hum Nutr Diet. 2012;25(5):453-9. [pmid: 22515879].
Fernandez RV, Manning MA, Sanchez-Mata C, et al. Health promotion of competitive youth table tennis players. Effects of a nutritional intervention plan. Ann Nutr Metab. 2011;58:418.
Field P, Gauld R. How do vested interests maintain outdated policy? The case of food marketing to New Zealand children. Open Health Serv Policy J. 2011;4:30-8.
Fogelholm M, Lahti-Koski M. Community health-promotion interventions with physical activity: does this approach prevent obesity?. (Structured abstract). Scand J Nutr. 2002;46(4):173-177.
Foley L, Maddison R, Olds T, et al. Self-report use-of-time tools for the assessment of physical activity and sedentary behaviour in young people: systematic review. Obes Rev. 2012;13(8):711-22. [pmid: 22429291].
Foltz JL, May AL, Belay B, Nihiser AJ, et al. Population-level intervention strategies and examples for obesity prevention in children. Annu Rev Nutr. 2012;32:391-415. [pmid: 22540254].
Foreyt J, Kleinman R, Brown RJ, et al. The use of low-calorie sweeteners by children: implications for weight management. J Nutr. 2012;142(6):1155S-62S. [pmid: 22573780].
Froeschl B, Haas S, Wirl C. Overweight prevention in adolescents and children(behavioural and environmental prevention). (Structured abstract). Cologne. German Agency for Health Technology Assessment at the German Institute for Medical Documentation and Information(DAHTA DIMDI). 2009.
Ganley KJ, Paterno MV, Miles C, et al. Health-related fitness in children and adolescents. Pediatr Phys Ther. 2011;23(3):208-20. [pmid: 21829112].
Gardner CG, Hendrie GA, Brindal E, et al. Combined home and school obesity prevention interventions for children: what behaviour change strategies and intervention characteristics are associated with effectiveness?. Obes Res Clin Pract. 2011;5:S44.
Gardner J, Wilkinson P. Is family therapy the most effective treatment for anorexia nervosa?. Psychiatr Danub. 2011;23(Suppl 1):S175-7. [pmid: 21894130].
Geis C, Farris JW, Taylor L, et al. Your VISION for the future of fitness: a 12-week interdisciplinary intervention program for children who are obese. Cardiopulm Phys Ther J. 2012;9.22(1.4):50-51. 12. 20.
Golan M. Parents as the main agent of change in the management of childhood obesity-barriers and facilitators. Obes Facts. 2012;5:14.
Goldberg Patricia. A comparison of BMI percentiles and predictor variables for two Head Start childhood obesity prevention programs. dissertation. Virginia. George Mason University. 2010.
Goldfield GS, Harvey A, Grattan K, et al. Physical activity promotion in the preschool years: a critical period to intervene. Int J Environ Res Public Health. 2012;9(4):1326-42. [pmid: 22690196].
Golley RK, Burrows T, Khambalia A, et al. What is the quality of dietary intake methodology and reporting in intervention studies on child and adolescent obesity management? A systematic review. Obes Res Clin Pract. 2011;5:S74.
Golley RK, Hendrie GA, Slater A, et al. Interventions that involve parents to improve children's weight-related nutrition intake and activity patterns: what nutrition and activity targets and behaviour change techniques are associated with intervention effectiveness?. (Provisional abstract). Obes Rev. 2011;12(2):114-30. [pmid: 20406416].
Gostin LO, Pomeranz JL, Jacobson PD, et al. Assessing laws and legal authorities for obesity prevention and control. J Law Med Ethics. 2009;37(1Suppl):28-36. [pmid: 19493089].
Green LW, Brancati FL, Albright A. Primary prevention of type 2 diabetes: integrative public health and primary care opportunities, challenges and strategies. Fam Pract. 2012;29(Suppl 1):i13-i23. [pmid: 22399542].
Grunstein RR. Sleep, health and society. Sleep Biol Rhythms. 2011;9(4):194.
Guedes De Vasconcelos F, Bernardo G, Valerio dos Santos M, et al. A systematic review of school-based interventions for obesity reduction in children and adolescents. Ann Nutr Metab. 2011;58:402.
Guinhouya BC. Physical activity in the prevention of childhood obesity. Paediatr Perinat Epidemiol. 2012;26(5):438. [pmid: 22882788].
Gutin B. Physical activity and body composition in school-age youths. Obes Rev. 2011;12:33.
Haemer M, Cluett S, Hassink SG, et al. Building capacity for childhood obesity prevention and treatment in the medical community: call to action. Pediatrics. 2011;128:S71-7. [pmid: 21885648].
Hagger M. Promoting kids' sport and physical activity in physical education contexts: can it really make a difference outside of school?. J Sci Med Sport. 2011;14:e30.
Haroun D, Wood L, Harper C, et al. Nutrient-based standards for school lunches complement food-based standards and improve pupils' nutrient intake profile. Br J Nutr. 2011;106(4):472-4. [pmid: 21736822].
Harrison CM, Bunk EJ, Modany AD, et al. Building a curriculum to combat obesity in elementary schools. Pharmacotherapy. 2011;31(10):423e.
Hart CN, Cairns A, Jelalian E. Sleep and obesity in children and Aaolescents. Pediatr Clin North Am. 2011;58(3):715-33. [pmid: 21600351].
Hay S, Skinner B. Web alert: health-promotion resources for obesity and overweight. Qual Prim Care. 2008;16(3):211-5. [pmid: 18700103].
Healy A. Reading writing and arugula: the expanding role of schools in child nutrition. Children's Voice. 2011;20(1):10-13.
Hebebrand J. Family based interventions for the treatment of obesity. Obes Rev. 2011;12:37. [pmid: 20070541].
Hendrie GA, Brindal E, Corsini N, et al. Combined home and school obesity prevention interventions for children: what behavior change strategies and intervention characteristics are associated with effectiveness?. Health Educ Behav. 2012;39(2):159-71. [pmid: 21984691].
Hidalgo CG, Samur EA. Regulation of food advertising on television for the prevention of childhood obesity. Arch Latinoam Nutr. 2011;61(3):296-301. [pmid: 22696898].
Hohman KH, Price SN, Sonneville K, et al. Can the internet be used to reach parents for family-based childhood obesity interventions?. Clin Pediatr. 2012;51(4):314-20.
Holland K. America's healthiest schools 2010;these schools are fighting childhood obesity one student at a time. Health(Time Inc.). 2010;24(8):122.
Horodynski MA, Baker S, Coleman G, et al. The Healthy Toddlers Trial Protocol: an intervention to reduce risk factors for childhood obesity in economically and educationally disadvantaged populations. BMC Public Health. 2011;11:581. [pmid: 21777452].
Horodynski MA, Olson B, Baker S, et al. Healthy babies through infant-centered feeding protocol: an intervention targeting early childhood obesity in vulnerable populations. BMC Public Health. 2011;11:868. [pmid: 22085421].
How to prevent childhood obesity - news from the IDEFICS study. Food Today. Suppl 6. 2011:2-3.
Huang TTK, Grimm B, Hammond RA. A systems-based typological framework for understanding the sustainability, scalability, and reach of childhood obesity interventions. Child Health Care. 2011;40(3):253-66.
Hudson Lee, Christie D. Tackling overweight and obesity in the school setting. Br J Sch Nurs. 2011;6(7):329-33.
Hurst N, McStay RV. What role do U.S health policy and children's hospitals play in the promotion of breastfeeding and human milk feeding?. Breastfeed Med. 2011;6(5):299-301. [pmid: 22007815].
Ilardi D. Obesity wars continue. Home-based pediatric weight management. School Nurse News. 2008;25(2):22-4. [pmid: 18410056].
Imdad A, Sadiq K, Bhutta ZA. Evidence-based prevention of childhood malnutrition. Curr Opin Clin Nutr Metab Care. 2011;14(3):276-85. [pmid: 21415736].
Jaime PC, Lock K. Do school based food and nutrition policies improve diet and reduce obesity?. (Structured abstract). Prev Med. 2009;48(1):45-53. [pmid: 19026676].
Jensen BW, Nielsen BM, Husby I, et al. Soft drink intake at age 6 and 9 and the association with BMI 3 and 7 years later - A follow-up study based on the Copenhagen School Child Intervention Study (COSCIS). Obes Rev. 2011;12:96.
Jensen JD, Hartmann H, de Mul A, et al. Economic incentives and nutritional behavior of children in the school setting: a systematic review. Nutr Rev. 2011;69(11):660-74. [pmid: 22029832].
Jerum A, Melnyk BM. Effectiveness of interventions to prevent obesity and obesity-related complications in children and adolescents. (Structured abstract). Pediatric Nursing. 2001;27(6):606-610. [pmid: 12024535].
John J, Wolfenstetter SB, Wenig CM. An economic perspective on childhood obesity: recent findings on cost of illness and cost effectiveness of interventions. Nutrition. 2012;28(9):829-39. [pmid: 22452837].
Johnson T, Weed LD, Touger-Decker R. School-based interventions for overweight and obesity in minority school children. J Sch Nurs. 2012;28(2):116-12. [pmid: 22025102].
Johnson WG, Stewart R, Pusser AT. The perceptual threshold for overweight. Eating Behav. 2012;13(3):188-193.
Jordan KC, Erickson ED, Cox R, et al. Evaluation of the Gold Medal Schools program. J Am Diet Assoc. 2008;108(11):1916-20. [pmid: 18954584].
Kaplan SG. Motivational interviewing in the treatment of pediatric obesity: research and promise. Psychosom Med. 2011;73(3):A7.
Karnik S, Kanekar A. Childhood obesity: a global public health crisis. Intl J Prev Med. 2012;3(1):1-7.
Keegan F. Implementing a G3 community-based, childhood obesity prevention - OPAL in local communities. Obes Res Clin Pract. 2011;5:S52-3.
Kirk R. “Just start walking” activity module released. Dynamic Chiropractic. 2010;28(21):2p.
Klesges LM, Williams NA, Davis KS, et al. External validity reporting in behavioral treatment of childhood obesity: a systematic review. Am J Prev Med. 2012;42(2):185-92. [pmid: 22261216].
Klesges RC, Hare M. The DASH diet predicts weight gain: what does his mean for my pediatric practice?. Arch Pediatr Adolesc Med. 2011;165(6):567-8. [pmid: 21646591].
Koller M. Development of an obesity prevention strategy for Austria. Obes Facts. 2012;5:36.
Kreichauf S, Wildgruber A, Krombholz H, et al. Critical narrative review to identify educational strategies promoting physical activity in preschool. Obes Rev. 2012;13(Suppl 1):96-105. [pmid: 22309068].
Kruger S, de Villiers A. Do tuck shops contribute to an unhealthy, obesogenic lifestyle among schoolchildren?. South Afr J Clin Nutr. 2011;24(3):121-2.
Laframboise MA, deGraauw C. The effects of aerobic physical activity on adiposity in school-aged children and youth: a systematic review of randomized controlled trials. J Can Chiropr Assoc. 2011;55(4):256-68. [pmid: 22131562].
Lake AM. Pediatric obesity: preventive measures in early childhood. JPEN J Parenter Enteral Nutr. 2012;36(1Suppl):76S-80S. [pmid: 22237881].
Lambourne K, Donnelly JE. The role of physical activity in pediatric obesity. Pediatr Clin North Am. 2011;58(6):1481-91. [pmid: 22093864].
Larson N, Ward DS, Neelon SB, et al. What role can child-care settings play in obesity prevention? A review of the evidence and call for research efforts. J Am Diet Assoc. 2011;111(9):1343-62. [pmid: 21872698].
Laska MN, Pelletier JE, Larson NI, et al. Interventions for weight gain prevention during the transition to young adulthood: a review of the literature. J Adolesc Health. 2012;50(4):324-33. [pmid: 22443834].
Laure P, Mangin G. Advising parents on physical activity for children between 0 and 5 years. J Sports Med Phys Fitness. 2011;51(3):467-72. [pmid: 21904286].
Lawlor DA, Jago R, Noble SM, et al. The Active for Life Year 5 (AFLY5) school based cluster randomised controlled trial: study protocol for a randomized controlled trial. Trials. 2011;12:181. [pmid: 21781344].
Lazarou C, Kouta C. Preventing and managing obesity. Independent Nurse. 2011:32-34.
Learning on childhood obesity - sustaining healthy living after IDEFICS. Food Today. Suppl 3. 2012:5.
Leboyer M, Soreca I, Scott J, et al. Can bipolar disorder be viewed as a multi-system inflammatory disease?. J Affect Disord. 2012;141(1):1-10. [pmid: 22497876].
LeMaster JW, Matisziw T, McElroy J, et al. Playgrounds Without Borders: methods for a playground environmental intervention among U.S. schoolchildren. Internet Journal of Epidemiology. 2011;10(1):1.
Lent M, Hill TF, Dollahite JS, et al. Healthy Children, Healthy Families: parents making a difference! A curriculum integrating key nutrition, physical activity, and parenting practices to help prevent childhood obesity. J Nutr Educ Behav. 2012;44(1):90-2. [pmid: 21900051].
Linchey J, Madsen KA. State requirements and recommendations for school-based screenings for body mass index or body composition, 2010. Prev Chronic Dis. 2011;8(5):A101. [pmid: 21843404].
Linger R, Bakker I, Visscher T, et al. Environmental influences on physical activity: local policies and urban planning. Obes Rev. 2011;12:40.
Lloyd AB, Morgan PJ, Lubans DR, et al. Investigating the measurement and operationalisation of obesity-related parenting variables of overweight fathers in the Healthy Dads, Healthy Kids community program. Obes Res Clin Pract. 2011;5:S72.
Lloyd JJ, Logan S, Greaves CJ, et al. Evidence Theory and Context: Using intervention mapping to develop a school-based intervention to prevent obesity in children. Int J Behav Nutr Phys Act. 2011;8(1):73. [pmid: 21752261].
Lobstein T. Symposium III: metabolic health, weight management and obesity prevention in childhood and adolescence: maternal and child obesity: some policy challenges. Proc Nutr Soc. 2011;70(4):506-13. [pmid: 21880164].
Lu AS, Baranowski J, Islam N, et al. How to engage children in self-administered dietary assessment programmes. J Hum Nutr Diet. 2012. [Epub ahead of print].
Lubans DR, Morgan PJ, Weaver K, et al. Rationale and study protocol for the supporting children's outcomes using rewards, exercise and skills (SCORES) group randomized controlled trial:a physical activity and fundamental movement skills intervention for primary schools in low-income communities. BMC Public Health. 2012;12(1):427. [pmid: 22691451].
Luckner H, Moss JR, Gericke CA. Effectiveness of interventions to promote healthy weight in general populations of children and adults: a meta-analysis. Eur J Public Health. 2011;22(4):491-7. [pmid: 21967748].
Ludwig DS. Weight loss strategies for adolescents: a 14-year-old struggling to lose weight. JAMA. 2012;307(5):498-508. [pmid: 22215761].
Lueke L. Devouring Childhood Obesity by Helping Children Help Themselves. J Leg Med. 201. 2011;32(2):205-220. [pmid: 21623527].
Lynch WC, Martz J, Eldridge G, et al. Childhood obesity prevention in rural settings: background, rationale, and study design of ‘4-health,’ a parent-only intervention. BMC Public Health. 2012;12(1):255. [pmid: 22471650].
Manios Y, Grammatikaki E, Androutsos O, et al. A systematic approach for the development of a kindergarten-based intervention for the prevention of obesity in preschool age children: the ToyBox-study. Obes Rev. 2012;13(Suppl 1):3-12. [pmid: 22309061].
Maon S, Edirippulige S, Ware R, et al. The use of web-based interventions to prevent excessive weight gain. J Telemed Telecare. 2012;18(1):37-41. [pmid: 22101608].
Matus CD, Klaege K. Exercise and weight management. Prim Care. 2007;34(1):109-16. [pmid: 17481989].
Matusik P, Malecka-Tendera E. Overweight prevention strategies in preschool children. Int J Pediatr Obes. 2011;6(Suppl 2):2-5. [pmid: 21923286].
Mauriello LM, Sherman KJ, Driskell MM, et al. Using interactive behavior change technology to intervene on physical activity and nutrition with adolescents. Adolesc Med State Art Rev. 2007;18(2):383-99. xiii. [pmid: 18605653].
McKinnon R, Reedy J, Berrigan D. NCCOR's measures registry: a new tool to spur innovation in childhood obesity research. Obesity. 2011;19:S144.
McPherson ME, Homer CJ. Policies to support obesity prevention for children: a focus on of early childhood policies. Pediatr Clin North Am. 2011;58(6):1521-41. xii. [pmid: 22093867].
Mello M. Legal and policy approaches to the obesity epidemic. Surg Obes Relat Dis. 2012;8(5):507-13. [pmid: 22695172].
Metcalf B, Henley W, Wilkin T. The effectiveness of intervention on the physical activity of children: systematic review and meta-analysis of controlled trials with objectivelymeasured outcomes. Obes Facts. 2012;5:263.
Micheli L, Mountjoy M, Engebretsen L, et al. Fitness and health of children through sport: the context for action. Br J Sports Med. 2011;45(11):931-6. [pmid: 21836177].
Mikkelsen BE. Policies to promote on physical activity and healthy eating in kindergartens from theory to practice. Int J Pediatr Obes. 2011;6(Suppl 2):8-11. [pmid: 21923288].
Millar L, Kremer P, De Silva-Sanigorski A, et al. Behavioural and environmental changes and concomitant increases in schools' capacity during the it's your move! adolescent, community-based obesity prevention intervention. Obes Rev. 2011;12:67.
Millar L, Kremer P, Fotu K, et al. Preventing obesity in adolescents from different cultures: findings of the 3-year Pacific Obesity Prevention in Communities (OPIC) project. Obes Facts. 2012;5:246.
Mitka M. Programs to reduce childhood obesity seem to work, say Cochrane reviewers. JAMA. 2012;307(5):444-5. [pmid: 22298665].
Montero D, Walther G, Perez-Martin A, et al. Endothelial dysfunction, inflammation, and oxidative stress in obese children and adolescents: markers and effect of lifestyle intervention. Obes Rev. 2012;13(5):441-55. [pmid: 22133012].
Moore SN, Murphy S, Moore L. Health improvement, nutrition-related behaviour and the role of school meals: the usefulness of a socio-ecological perspective to inform policy design, implementation and evaluation. Crit Public Health. 2011;21(4):441-54.
Morgan D. Appetite regulation: new opportunities for weight control. Proc Nutr Soc. 2000;59(3):431. [pmid: 10997666].
Morgan PJ, Lubans DR, Plotnikoff RC, et al. The ‘Healthy Dads, Healthy Kids’ community effectiveness trial: study protocol of a community-based healthy lifestyle program for fathers and their children. BMC Public Health. 2011;11:876. [pmid: 22099889].
Morgan PJ. Child obesity prevention: interventions engaging mums and dads. Obes Res Clin Pract. 2011;5:S5.
Morinis J, Maguire J, Khovratovich M, et al. Paediatric obesity research in early childhood and the primary care setting: The TARGet Kids! research network. Int J Environ Res Public Health. 2012;9(4):1343-54. [pmid: 22690197].
Morris V. Community-based programming to treat childhood obesity. Curr Diab Rep. 2006;6(5):395-400. [pmid: 17077002].
Muckelbauer R, Kalhoff H, Muller-Nordhorn J, et al. Childhood overweight and obesity: introduction into epidemiology and prevention strategies. Curr Nutr Food Sci. 2011;7(3):191-9.
Muir L. Tackling obesity in adolescence. Aust Nurs J. 2012;19(8):30-1. [pmid: 22662430].
Myers J, Subczyk W, Ketterman K, et al. Health promotion schools of excellence: learning from the past to impact the future. J Ky Med Assoc. 2008;106(3):98-103. [pmid: 18488967].
Nelson MC. Environmental influences on diet and physical activity in childhood: opportunities for intervention. South Med J. 2005;98(12):1161-2. [pmid: 16440912].
Neumark-Sztainer D, Martin SL, Story M. School-based programs for obesity prevention: What do adolescents recommend?. Am J Health Promot. 2000;14(4):232-235. [pmid: 10915534].
Nichols P, Ussery-Hall A, Griffin-Blake S, et al. The evolution of the steps program, 2003-2010: transforming the federal public health practice of chronic disease prevention. Prev Chronic Dis. 2012;9:E50. [pmid: 22300870].
Niemeier BS, Hektner JM, Enger KB. Parent participation in weight-related health interventions for children and adolescents: a systematic review and meta-analysis. Prev Med. 2012;55(1):3-13. [pmid: 22575353].
Nixon CA, Moore HJ, Douthwaite W, et al. Identifying effective behavioural models and behaviour change strategies underpinning preschool- and school-based obesity prevention interventions aimed at 4-6-year-olds: a systematic review. Obes Rev. 2012;13(Suppl 1):106-17. [pmid: 22309069].
Nowicka P. Parents as gatekeepers: Introduction to family therapy in obesity treatment. Obes Facts. 2012;5:9.
Obesity prevention and control legal bibliography. J Law Med Ethics. 2009;37(1 Suppl):122-8. [pmid: 19493098].
Oen G, Stormark KM. ‘A healthy future’-the design of a community-based prevention program for overweight study on prevention of obesity in young children. Obes Facts. 2012;5:255.
Olson G. The relationship of birth weight to body mass index and blood pressure at ages 3-5 years. Am J Obstet Gynecol. 2012;206(1):S190.
Olteanu A, Matevich J, Arnberger R, et al. Addressing childhood obesity in an underserved community. Can J Diabetes. 2011;35(2):199.
O'Malley CL, Douthwaite W, Moore HJ, et al. TeesCAKE (teesside consumption and activity for kids experience) project: effectiveness of an evidence-based health promotion intervention in children aged 9-10 years living within a socially deprived area of the UK. Obes Rev. 2011;12:74-5.
Pate RR. Physically active video gaming: an effective strategy for obesity prevention?. Arch Pediatr Adolesc Med. 2008;162(9):895-6. [pmid: 18762611].
Pavey TG, Taylor AH, Fox KR, et al. Effect of exercise referral schemes in primary care on physical activity and improving health outcomes: systematic review and meta-analysis. BMJ (Online). 2011;343(7831):980.
Pereira G, Machado M, Meura P, et al. Interventions in the school environment in order to reduce obesity: a systematic review of the Bank of Thesis from the Higher Education Personnel Improvement Coordination (CAPES). Ann Nutr Metab. 2011;58:313.
Perryman ML. Ethical family interventions for childhood obesity. Prev Chronic Dis. 2011;8(5):A99. [pmid: 21843429].
Phillips MM, Ryan K, Raczynski JM. Public policy versus individual rights in childhood obesity interventions: perspectives from the Arkansas experience with Act 1220 of 2003. Prev Chronic Dis. 2011;8(5):A96. [pmid: 21843426].
Pigeot I, Siani A, Bammann K, et al. IDEFICS study - Baseline results and future perspectives. Obes Rev. 2011;12:5.
Pittson H, Wallace L. Weight management programme for children. Primary Health Care. 2010;20(5):16-21.
Plachta-Danielzik S, Kehden B, Landsberg B, et al. Estimating the effect of population-based preventive measures in children and adolescents with risk of overweight, overweight and obesity - The interdisciplinary consortium on obesity prevention in children and adolescents (Prevent). Obes Facts. 2012;5:258.
Pomeranz JL. Advanced policy options to regulate sugar-sweetened beverages to support public health. J Public Health Policy. 2012;33(1):75-88. [pmid: 21866177].
Pont K, Ziviani J, Wadley D, et al. The Model of Children's Active Travel (M-CAT): a conceptual framework for examining factors influencing children's active travel. Aust Occup Ther J. 2011;58(3):138-44. [pmid: 21599678].
Porter CM, Hererra H, Sequeira EJ. Community food system approaches to preventing obesity and hunger in the US. FASEB J. 2011;25:232.1. [pmid: 20847228].
Porter RM. Children's hospitals focus on pediatric obesity. Pediatr Nurs. 2011;37(1):39-40. [pmid: 21485621].
Puliti B. Young at heart: 3 areas of education for Healthy Kids/Weight. Adv Nurses. 2011;8. 18(9.6):13-14. 64. 65.
Quinzi DR. Obesity in children. Adv Nurse Pract. 1999;7(3):46-50. [pmid: 10373799].
Ray JW, Klesges RC. Influences on the eating behavior of children. Ann New York Acad Sci. 1993;699:57-69. [pmid: 8267337].
Reinehr T. Child-centred physical activity programme and parent-centred dietary programme alone or combined lead to sustainable reductions in BMI in 5-10-year-olds: diet alone or diet plus activity programmes seemed most effective. Evid Based Nurs. 2011;14(1):12-3. [pmid: 21163790].
Reinehr T. Effectiveness of lifestyle intervention in overweight children. Proc Nutr Soc. 2011;70(4):494-505. [pmid: 21801473].
Reis CEG, Vasconcelos IAL, de Barros JF. Politicas puoblicas de nutricao para o controle da obesidade infantile. Policies on nutrition for controlling childhood obesity. Rev Paul Pediatr. 2011;29(4):625-33.
Resnicow K. School-based obesity prevention. Population versus high-risk interventions. Ann New York Acad Sci. 1993;(699):154-166. [pmid: 8267306].
Rigby N. The role of communication and the prevention of obesity. West Indian Med J. 2002;51(1Suppl):55-9. [pmid: 12050977].
Riis J, Grason H, Strobino D, et al. State school policies and youth obesity. Matern Child Health J. 2012;16:111-8.
Robinson GA, Geier M, Rizzolo D, et al. Childhood obesity: complications, prevention strategies, treatment. JAAPA. 2011;24(12):58-63. [pmid: 22315918].
Robinson T. Improving the design of population- and family-based interventions to prevent and control obesity. Obes Facts. 2012;5:25.
Robinson TN. Obesity prevention in primary care. Arch Pediatr Adolesc Med. 2006;160(2):217-8. [pmid: 16461881].
Rodrigues JJ, Lopes IM, Silva BM, et al. A new mobile ubiquitous computing application to control obesity: SapoFit. Inform Health Soc Care. 2012. [Epub ahead of print].
Rona RJ. Genetic and environmental factors in the control of growth in childhood. Br Med Bull. 1981;37(3):265-72. [pmid: 7034851].
Ruble K, Hayat M, Stewart KJ, et al. Body composition after bone marrow transplantation in childhood. Oncol Nurs Forum. 2012;39(2):186-92. [pmid: 22374492].
Safron M, Cislak A, Gaspar T, et al. Micro-environmental characteristics related to body weight, diet, and physical activity of children and adolescents: a systematic umbrella review. Int J Environ Health Res. 2011;21(5):317-30. [pmid: 21547807].
Sakurai T, Ogasawara J, Kizaki T, et al. Preventive and improvement effects of exercise training and supplement intake in white adipose tissues on obesity and lifestyle-related diseases. Environ Health Prev Med. 2012;17(5):348-56. [pmid: 22362099].
Sal I, Papp I, Perczel Forintos D. Possibilities of behavior modification in the treatment of diabetes mellitus and obesity. Orv Hetil. 2012;153(11):410-7. [pmid: 22390865].
Salmon J, Arundell L, Hume C, et al. A cluster-randomized controlled trial to reduce sedentary behavior and promote physical activity and health of 8-9 year olds: the Transform-Us! study. BMC Public Health. 2011;11:759. [pmid: 21970511].
Salois MJ. Obesity and diabetes the built environment and the ‘local’ food economy in the United States 2007. Econ Hum Biol. 2011.
Salvy SJ. The importance of peers and friends to eating, physical activity, and obesity during childhood and adolescence. Appetite. 2011;57:S38.
Sanchez-Carracedo D, Neumark-Sztainer D, Lopez-Guimera G. Integrated prevention of obesity and eating disorders: barriers, developments and opportunities. Public Health Nutr. [Epub ahead of print]. 2012:1-15. [pmid: 23294865].
Sargent GM, Pilotto LS, Baur LA. Components of primary care interventions to treat childhood overweight and obesity: a systematic review of effect. (Structured abstract). Obes Rev. 2011;12(501):e219-35. [pmid: 20630025].
Sargent GM. Successful treatment of childhood overweight and obesity in Prim Health Care and appropriate outcome measures: development of a logic model. Obes Res Clin Pract. 2011;5:S22.
Sarkkola C, Simola S, Seppanen V, et al. Childhood growth environment and genetic factors as determinants of overweight and obesity - The Finnish health in teens study - Fin-hit. Obes Rev. 2011;12:248.
Saxe JS. Promoting healthy lifestyles and decreasing childhood obesity: increasing physician effectiveness through advocacy. Ann Fam Med. 2011;9(6):546-8. [pmid: 22084266].
Sbruzzi G, Eibel B, Cesa CC, et al. Educational and behavioral interventions in childhood obesity: a systematic review with metanalysis of randomized clinical trials. Eur Heart J. 2011;32:502-3.
Schmidt ME, Haines J, O'Brien A, et al. Systematic review of effective strategies for reducing screen time among young children. Obesity. 2012;20(7):1338-54. [pmid: 22222926].
Schreiner B. Promoting lifestyle and behavior change in overweight children and adolescents with type 2 diabetes. Diabetes Spectr. 2005;18(1):9-12.
Shin A, Dennisuk L, Martins P, et al. Adolescents improve healthy-eating outcome expectancy: impact of the Baltimore Healthy Eating Zones study. FASEB J. 2011;25:973.1.
Shroff MR, Jones SJ, Frongillo EA, et al. Policy instruments used by states seeking to improve school food environments. Am J Public Health. 2012;102(2):222-9. [pmid: 22390436].
Silveira JA, Taddei JA, Guerra PH, et al. Effectiveness of school-based nutrition education interventions to prevent and reduce excessive weight gain in children and adolescents: a systematic review. (Provisional abstract). J Pediatr. 2011;87(5):382-92.
Sinha LN, McKelvy DJ. Internet resources: childhood obesity. MLA News. 2011;51(10):7.
Sleddens EF, Gerards SM, Thijs C, et al. General parenting, childhood overweight and obesity-inducing behaviors: a review. Int J Pediatr Obes. 2011;6(2-2):e12-27. [pmid: 21657834].
Small L, Lane H, Vaughan L, et al. A systematic review of the evidence: the effects of portion size manipulation with children and portion education/training interventions on dietary intake with adults. Worldviews Evid Based Nurs. 2012. [Epub ahead of print].
Smallfield S, Anderson AJ. Using after-school programming to support health and wellness a physical activity engagement program description. Early Intervention & School Special Interest Section Quarterly. 2009;16(3):1-4.
Socha P, Grote V, Gruszfeld D, et al. Milk protein intake, the metabolic-endocrine response, and growth in infancy: data from a randomized clinical trial. Am J Clin Nutr. 2011;94(6):1776S-1784S. [pmid: 21849603].
Sothern MS, Gordon ST. Prevention of obesity in young children: a critical challenge for medical professionals. Clin Pediatr(Phila). 2003;42(2):101-11. [pmid: 12659382].
Stanley RM, Ridley K, Dollman J. Correlates of children's time-specific physical activity: a review of the literature. Int J Behav Nutr Phys Act. 2012;9(1):50. [pmid: 22546218].
Stunkard AJ. Adherence to medical treatment: overview and lessons from behavioral weight control. J Psychosom Res. 1981;25(3):187-97. [pmid: 7265022].
Stunkard AJ. Obesity: risk factors consequences and control. Med J Aust. 1988;148(Suppl):S21-8. [pmid: 3340057].
Summerbell CD, Moore HJ, Vogele C, et al. Evidence-based recommendations for the development of obesity prevention programs targeted at preschool children. Obes Rev. 2012;13(Suppl 1):129-32. [pmid: 22309071].
Swan E, Bouwman L, de Roos N, et al. How science thinks and practice acts: bridging the gap in weight management interventions for adolescents. Fam Pract. 2012;29(Suppl 1):i117-i125. [pmid: 22399540].
Sweet M. Childhood obesity can be prevented, says Cochrane. BMJ. 2011;343(7836):1231.
Szajewska H, Ruszczynski M. Systematic review demonstrating that breakfast consumption influences body weight outcomes in children and adolescents in Europe. (Provisional abstract). Crit Rev Food Sci Nutr. 2010;50(2):113-119. [pmid: 20112153].
Tabin R. Surcharge ponderale des enfants et des adolescents: prevention et traitement - Le programme Valaisan. Overweight children and adolescents: prevention and treatment - The Valais program. Rev Med Suisse. 2011;7(279):196-7. [pmid: 21387710].
Tanaka N, Miyoshi M. School lunch program for health promotion among children in Japan. Asia Pac J Clin Nutr. 2012;21(1):155-8. [pmid: 22374573].
Tandon PS, Garrison MM, Christakis DA. Physical activity and beverages in home- and center-based child care programs. J Nutr Educ Behav. 2012;44(4):355-9. [pmid: 22564855].
Tang MB. The effect of lifestyle modification for the metabolic syndrome. J Hypertens. 2011;29:e48.
Taylor A, Wilson C, Slater A, et al. Parent- and child-reported parenting. Associations with child weight-related outcomes. Appetite. 2011;57(3):700-6. [pmid: 21896297].
Taylor RW. Forget schools: how do we tackle the home environment for obesity prevention?. Australas Med J. 2011;4(12):716.
te Velde SJ, van Nassau F, Uijtdewilligen L, et al. Energy balance-related behaviours associated with overweight and obesity in preschool children: a systematic review of prospective studies. Obes Rev. 2012;13(Suppl 1):56-74. [pmid: 22309065].
Thorogood A, Mottillo S, Shimony A, et al. Isolated aerobic exercise and weight loss: a systematic review and meta-analysis of randomized controlled trials. Am J Med. 2011;124(8):747-55. [pmid: 21787904].
Thow AM, Snowdon W, Schultz JT, et al. The role of policy in improving diets: experiences from the Pacific Obesity Prevention in Communities food policy project. Obes Rev. 2011;12(Suppl 2):68-74. [pmid: 22008561].
Tripodi A, Severi S, Midili S, et al. “Community projects” in Modena (Italy): promote regular physical activity and healthy nutrition habits since childhood. Int J Pediatr Obes. 2011;6(Suppl 2):54-6. [pmid: 21923298].
Truby H, Baxter K, Ware R, et al. Successful weight loss for adolescents: what can diet offer?. Obes Res Clin Pract. 2011;5:S10.
Trygg Lycke S, Bjurvald L. Exergaming - A new way of increasing physical activity level in obese adolecents?. Obes Facts. 2012;5:207.
Tyndall Ann. Help end childhood obesity within a generation. KY Nurse. 2011;59(3):19.
Uauy R, Rojas J, Corvalan C, et al. Prevention and control of obesity in preschool children: importance of normative standards. J Pediatr Gastroenterol Nutr. 2006;43(Suppl 3):S26-37. [pmid: 17204976].
Utter J, Warbrick J, Scragg R, et al. Design development and achievements of a youth-led nutrition and physical activity intervention in a Pacific community in New Zealand. J Am Diet Assoc. 2010;110(11):1634-7. [pmid: 21034874].
Valde JG. Community program to prevent diabetes in school children. J Community Health Nurs. 2011;28(4):215-22. [pmid: 22053766].
Van Dorsten B, Lindley EM. Cognitive and behavioral approaches in the treatment of obesity. Med Clin North Am. 2011;95(5):971-88. [pmid: 21855703].
van Grieken A, Ezendam NPM, Paulis WD, et al. Primary prevention of overweight in children and adolescents: A meta-analysis of the effectiveness of interventions aiming to decrease sedentary behaviour. 2012;9(1):61.
Van Lippevelde W, Verloigne M, De Bourdeaudhuij I, et al. Does parental involvement make a difference in school-based nutrition and physical activity interventions? A systematic review of randomized controlled trials. Int J Public Health. 2012;57(4):673-8. [pmid: 22301709].
Van Mil EGAH, Goris AHC, Westerterp KR. Physical activity and the prevention of childhood obesity. Europe versus the United States. Int J Obes. 1999;23(3 Suppl):S41-S44.
Van Sluijs EMF. Energy balance and determinants in children. Obes Rev. 2011;12:24.
Vandewater EA, Denis LM. Media, social networking, and pediatric obesity. Pediatr Clin North Am. 2011;58(6):1509-19. [pmid: 22093866].
Vanhees L, Geladas N, Hansen D, et al. Importance of characteristics and modalities of physical activity and exercise in the management of cardiovascular health in individuals with cardiovascular risk factors: recommendations from the EACPR (Part II). Eur J Prev Cardiol. 2012. [Epub ahead of print].
Veldhuis L, Struijk MK, Kroeze W, et al. ‘Be active eat right’ evaluation of an overweight prevention protocol among 5-year-old children: Design of a cluster randomised controlled trial. BMC Public Health. 2009;9.
Vericker TC. Limited evidence that competitive food and beverage practices affect adolescent consumption behaviors. Health Educ Behav. 2012. [Epub ahead of print].
Viggiano A, Viggiano E, Viggiano A, et al. Kaledo, a new educational board-game for nutrition education: cluster randomized trial of healthy lifestyle promotion. Obes Facts. 2012;5:260.
Wake M, Lycett K, Sabin MA, et al. A shared-care model of obesity treatment for 3-10 year old children: protocol for the HopSCOTCH randomised controlled trial. 2012;12(1):39.
Walters BN. Personal carbon trading: a potential “stealth intervention” for obesity reduction?. Med J Aust. 2007;187(11-12):668. author reply. [pmid: 18072913].
Walton L. Childhood obesity is a family fight--one hospital's way. Health Prog. 2011;92(3):39-42. [pmid: 21648264].
Ward S, Farnsworth C, Babkes-Stellino M, et al. Parental influence and the attraction to physical activity for youths who sre visually impaired at a residential-day school. J Vis Impair Blind. 2011;105(8):493-8.
Weichselbaum E, Buttriss J. Nutrition, health and schoolchildren. Nutr Bull. 2011;36(3):295-355.
Weichselbaum E, Buttriss J. Nutrition, health and schoolchildren. Nutr Bull. 2011;36(3):295-355.
Werner D, Teufel J, Brown S. Exploring the experience of older adults volunteering with an intergenerational program to prevent childhood obesity. Californian J Health Promot. 2011;9(1):1-8.
Whitrow MJ, Moore VM, Davies MJ. Waist-to-height ratio is not a predictor of systolic blood pressure in 3-year-old children. J Pediatr. 2011;159(3):501-3. [pmid: 21723566].
Wilkin TJ. Can we modulate physical activity in children? No. Int J Obes (Lond). 2011;35(10):1270-6. [pmid: 21829160].
Williams A. CHILDHOOD OBESITY dooms day COUNTDOWN. IDEA Fitness J. 2011;8(10):48-57.
Williams G, Nicholls S, Voigt K, et al. Ethical and political aspects of obesity interventions in children. Int J Obes. 2011;35:S148.
Xu F, Ware RS, Tse LA, et al. A school-based comprehensive lifestyle intervention among Chinese kids against obesity (CLICK-Obesity): rationale, design and methodology of a randomized controlled trial in Nanjing city, China. BMC Public Health. 2012;12:316. [pmid: 22545755].
Yancey AT. Physical activity program for preschool children fails to reduce body mass index. J Pediatr. 2007;L-150(5):561. [pmid: 17452239].
Yang GP, Wang YR, Zuo SY, et al. Meta-analysis of intervention effects on obesity in Chinese pupils. Zhonghua Yu Fang Yi Xue Za Zhi. 2011;45(10):944-8. [pmid: 22321599].
Yildirim M, van Stralen MM, Chinapaw MJ, et al. For whom and under what circumstances do school-based energy balance behavior interventions work? Systematic review on moderators. Int J Pediatr Obes. 2011;6(2-2):e46-57. [pmid: 21651421].
Zhang Y, Wang S. Prevalent change in overweight and obesity in children and adolescents from 1995 to 2005 in Shandong, China. Asia Pac J Public Health. 2011;23(6):904-16. [pmid: 20460297].

## Does not measure weight as an outcome

Aburto NJ, Fulton JE, Safdie M, et al. Effect of a school-based intervention on physical activity: cluster-randomized trial. Med Sci Sports Exerc. 2011;43(10):1898-1906. [pmid: 21407129].
Adams A, Receveur O, Mundt M, Paradis, et al. Healthy lifestyle indicators in children(grades 4 to 6) from the Kahnawake Schools Diabetes Prevention Project. Can J Diabetes. 2005;29(4):403-409.
Affuso O, Kaiser K, Ingram KH, et al. Reporting quality of pediatric obesity randomized controlled trials - A preliminary analysis. Obesity. 2011;19:S110.
Al-Hazzaa HM, Al-Sobayel HI, Musaiger AO. Convergent validity of the Arab teens lifestyle study (ATLS) physical activity questionnaire. Int J Environ Res Public Health. 2011;8(9):3810-20. [pmid: 22016718].
Amis JM, Wright PM, Dyson B, et al. Implementing childhood obesity policy in a new educational environment: the cases of Mississippi and Tennessee. Am J Public Health. 2012;102(7):1406-13. [pmid: 22420819].
Apfelbacher C, Schmitt J, Loerbroks A. Overweight, obesity and atopic diseases: evidence from a population based cross-sectional study in Germany (KiGGS). Exp Dermatol. 2011;20(2):173.
Attalin V, Romain AJ, Avignon A. Physical-activity prescription for obesity management in primary care: attitudes and practices of GPs in a southern French city. Diabetes Metab. 2012;38(3):243-9. [pmid: 22386835].
Banks J, Williams J, Cumberlidge T, et al. Is healthy eating for obese children necessarily more costly for families?. Br J Gen Pract. 2012;62(594):e1-5. [pmid: 22520655].
Banos RM, Cebolla A, Oliver E, et al. Efficacy and acceptability of an Internet platform to improve the learning of nutritional knowledge in children: the ETIOBE mates. Health Educ Res. 2012. [Epub ahead of print].
Bartholomew JB, Jowers EM. Physically active academic lessons in elementary children. Prev Med. 2011;52:S51-4. [pmid: 21281672].
Bauer KW, Laska MN, Fulkerson JA, et al. Longitudinal and secular trends in parental encouragement for healthy eating, physical activity, and dieting throughout the adolescent years. J Adolesc Health. 2011;49(3):306-11. [pmid: 21856524].
Beam M, Ehrlich G, Black JD, et al. Evaluation of the healthy schools program: Part II. The role of technical assistance. Prev Chronic Dis. 2012;9:E64. [pmid: 22380937].
Beauchamp MR, Rhodes RE, Hua S, et al. Testing the effects of an expectancy-based intervention among adolescents: can placebos be used to enhance physical health?. Psychol Health Med. 2011;16(4):405-17. [pmid: 21749238].
Bergh IH, Bjelland M, Grydeland M, et al. Mid-way and post-intervention effects on potential determinants of physical activity and sedentary behavior, results of the HEIA study - a multicomponent school-based randomized trial. Int J Behav Nutr Phys Act. 2012;9:63. [pmid: 22643014].
Bin X, Chih-Ping C, Donna SM, et al. Longitudinal analysis of weight perception and psychological factors in Chinese adolescents. Am J Health Behav. 2011;35(1):92-104. [pmid: 20950162].
Bjelland M, Bergh IH, Grydeland M, et al. Changes in adolescents' intake of sugar-sweetened beverages and sedentary behaviour: Results at 8 month mid-way assessment of the HEIA study. a comprehensive multi-component school-based randomized trial. Int J Behav Nutr Phys Act. 2011;8(1):63. [pmid: 21679476].
Bleich SN, Herring B, Flagg D, et al. Reduction in purchases of sugar-sweetened beverages among low income, black adolescents after exposure to caloric information. Obesity. 2011;19:S52-3.
Boddy LM, Fairclough SJ, Atkinson G, et al. Changes in cardiorespiratory fitness in 9- to 10.9-year-old children: SportsLinx 1998-2010. Med Sci Sports Exerc. 2012;44(3):481-6. [pmid: 21814150].
Bohnert AM, Randall ET, Tharp S, et al. The development and evaluation of a portion plate for youth: a pilot study. J Nutr Educ Behav. 2011;43(4):268-73. [pmid: 21367664].
Boles M, Dilley JA, Dent C, et al. Changes in local school policies and practices in washington state after an unfunded physical activity and nutrition mandate. Prev Chronic Dis. 2011;8(6):A129. [pmid: 22005622].
Bonnet F, Lepicard EM, Cathrin L, et al. French children start their school day with a hydration deficit. Ann Nutr Metab. 2012;60(4):257-63. [pmid: 22677981].
Borys JM, Le Bodo Y, Jebb SA, et al. EPODE approach for childhood obesity prevention: methods, progress and international development. Obes Rev. 2012;13(4):299-315. [pmid: 22106871].
Borys JM, Le Bodo Y, Walter L. EPODE European network: key recommendations for the setting of community-based interventions aimed at preventing childhood obesity. Obes Rev. 2011;12:6.
Bratina N, Hadzic V, Batellino T, et al. Slovenske smernice za telesno udejstvovanje otrok in mladostnikov v starostni skupini od 2 do 18 let. Slovenian guidelines for physical activity in children and adolescents in the age group 2-18 years. Zdravniski Vestn. 2011;80(12):885-96.
Brennan L. Psychosocial comorbidities of adolescent obesity. Obes Res Clin Pract. 2011;5:S6.
Brindal E, Hendrie G, Noakes M, et al. A randomised controlled trial to compare the effect of breakfast cereals differing in fibre content on short-term appetite and mood in 8-12 year old children. Australas Med J. 2011;4(12):706.
Brodsgaard A, Wagner L, Peitersen B, et al. Child overweight-mothers' competence to take action. Obes Facts. 2011;4(4):305-11. [pmid: 21921654].
Bruening M, Larson N, Story M, et al. Predictors of adolescent breakfast consumption: longitudinal findings from Project EAT. J Nutr Educ Behav. 2011;43(5):390-5. [pmid: 21906551].
Buchheit M, Horobeanu C, Mendez-Villanueva A, et al. Effects of age and spa treatment on match running performance over two consecutive games in highly trained young soccer players. J Sports Sci. 2011;29(6):591-598. [pmid: 21337251].
Bundy AC, Naughton G, Tranter P, et al. The Sydney playground project: popping the bubblewrap-unleashing the power of play: a cluster randomized controlled trial of a primary school playground-based intervention aiming to increase children's physical activity and social skills. BMC Public Health. 2011;11:680. [pmid: 21884603].
Burns SF, Oo HH, Tran AT. Effect of sprint interval exercise on postexercise metabolism and blood pressure in adolescents. Int J Sport Nutr Exerc Metab. 2012;22(1):47-54. [pmid: 22248500].
Burrows T, Morgan PJ, Lubans DR, et al. Dietary outcomes of the healthy dads healthy kids Randomised controlled Trial. J Pediatr Gastroenterol Nutr. 2012. [Epub ahead of print].
Campbell K, McNaughton S, Lioret S, et al. The Melbourne InFANT Program positively impacts very young children's lifestyle patterns. Obes Res Clin Pract. 2011;5:S4-S5.
Campbell M, Benton JM, Werk LN. Parent perceptions to promote a healthier lifestyle for their obese child. Soc Work Health Care. 2011;50(10):787-800. [pmid: 22136345].
Casazza K, Hanks LJ, Hidalgo B, et al. Short-term physical activity intervention decreases femoral bone marrow adipose tissue in young children: a pilot study. Bone. 2012;50(1):23-7. [pmid: 21939791].
Cassola D, De Looy A, Jones R. Stress, coping and eating behaviours in maltese adolescents: developing a model for an effective online intervention. Obes Facts. 2012;5:195.
Chahal N, Wong H, Manlhiot C, et al. Lifestyle-based management of obesity-related and familial hyperlipidemias in children and adolescents enhanced by peer education. Can J Diabetes. 2011;35(2):165.
Champagne CM, McCabe-Sellers BJ, Allen R, et al. Can small changes in a summer camp program for the rural impoverished make a difference in healthy eating?. FASEB J. 2011;25:974.9.
Chang KJ, Kim SY. Understanding and utilization of nutrition labeling in Korean middle school students. FASEB J. 2011;25:770.21.
Chhichhia P, Khan FA, Kumar E, et al. Culturally tailored education to South Asian (SA) populations in Auckland successfully promotes early screening and prevention of cardiovascular diseases (CVD) and Diabetes. Obes Res Clin Pract. 2011;5:S59.
Chika S, Ferro ES, Goodell LS. Assessing teachers' perceptions of facilitators and motivators for promoting fruit and vegetable consumption in preschoolers. FASEB J. 2011;25:99.8. [pmid: 20826541].
Coleman KJ, Hsii AC, Koebnick C, et al. Implementation of clinical practice guidelines for pediatric weight management. J Pediatr. 2012;160(6):918-22.e1. [pmid: 22240108].
Cong Z, Feng D, Liu Y, et al. Sedentary behaviors among Hispanic children: influences of parental support in a school intervention program. Am J Health Promot. 2012;26(5):270-80. [pmid: 22548421].
Contento IR, Koch PA, Lee H, et al. Enhancing personal agency and competence in eating and moving: formative evaluation of a middle school curriculum--Choice Control and Change. J Nutr Educ Behav. 2007;39(5 Suppl):S179-86. [pmid: 17826699].
Cooper C, Nichols M, Lacy K, et al. A whole of systems approach to obesity prevention in the maternal and child health services. Obes Res Clin Pract. 2011;5:S73.
Courteix D, Lespessailles E, Peres SL, et al. Effect of physical training on bone mineral density in prepubertal girls: a comparative study between impact-loading and non-impact-loading sports. Osteoporos Int. 1998;8(2):152-8. [pmid: 9666939].
Cradock AL, McHugh A, Mont-Ferguson H, et al. Effect of school district policy change on consumption of sugar-sweetened beverages among high school students, Boston, Massachusetts, 2004-2006. Prev Chronic Dis. 2011;8(4):A74. [pmid: 21672398].
Croker H, Lucas R, Wardle J. Cluster-randomised trial to evaluate the ‘Change for Life’ mass media/ social marketing campaign in the UK. BMC Public Health. 2012;12(1):404. [pmid: 22672587].
Daly-Smith AJW, McKenna J, Radley D, et al. The impact of additional weekdays of active commuting to school on children achieving a criterion of 300+ minutes of moderate-to-vigorous physical activity. Health Educ J. 2011;70(4):428-34.
Danford CA, Martyn KK, Schultz CM. Event history calendars: An innovation in tracking eating and activity behaviors and barriers with parent-child dyads. Obesity. 2011;19:S108.
D'Ascenzi F, Maiorca S, Zaca V, et al. Circulating stem cells in adolescent football players and in sedentary subjects: impact of training and physical inactivity. G Ital Cardiol. 2011;12(12):e189.
Davis JN, Gyllenhammer L, Byrd-Williams C, et al. Moderate to vigorous physical activity (MVPA) reduces liver, subcutaneous, and visceral fat depots in overweight latino adolescents. Obesity. 2011;19:S52.
Davis JN, Ventura EE, Tung A, et al. Effects of a randomized maintenance intervention on adiposity and metabolic risk factors in overweight minority adolescents. Pediatr Obes. 2012;7(1):16-27. [pmid: 22434736].
Davis S, Gomez Y, Lambert L, Skipper B. Primary prevention of obesity in American Indian children. Ann New York Acad Sci. 1993;699:167-180. [pmid: 8267307].
Davison K, Jurkowski JM, Li K. Links between parents' underestimation of child weight status and their obesity-related attitudes and parenting practices. Obesity. 2011;19:S135.
De Henauw S, Verbestel V, Marild S, et al. The IDEFICS community-oriented intervention programme: a new model for childhood obesity prevention in Europe?. Int J Obes(Lond). 2011;35(1Suppl):S16-23. [pmid: 21483418].
De Ridder DT, Ouwehand C, Stok FM, et al. Hot or not: Visceral influences on coping planning for weight loss attempts. Psychol Health. 2011;26(5):501-16. [pmid: 20936566].
de Silva-Sanigorski AM, Waters E, Calache H, et al. Splash!: a prospective birth cohort study of the impact of environmental social and family-level influences on child oral health and obesity related risk factors and outcomes. BMC Public Health. 2011;11(1):505. [pmid: 21708037].
Denney-Wilson E, Robinson A, Laws R, et al. Child obesity prevention in primary care: The Healthy 4 Life pilot study. Obes Res Clin Pract. 2011;5:S18.
Dev DA, Kim J. Nutrition policies and practices in center-based child care. FASEB J. 2011;25:781.15.
D'Hondt E, Gentier I, Deforche B, et al. Weight loss and improved gross motor coordination in children as a result of multidisciplinary residential obesity treatment. Obesity. 2011;19(10):1999-2005. [pmid: 21720438].
Dickin KL, Lent M, Lu AH, et al. Developing a measure of behavior change in a program to help low-income parents prevent unhealthful weight gain in children. J Nutr Educ Behav. 2012;44(1):12-21. [pmid: 21996430].
Dorgan JF. Adolescent diet and metabolic syndrome components in young women: results of the dietary intervention study in children (DISC) follow-up study. Am J Epidemiol. 2011;173:S278.
Douglas A, Bhopal RS, Bhopal R, et al. Recruiting South Asians to a lifestyle intervention trial: experiences and lessons from PODOSA (Prevention of Diabetes and Obesity in South Asians). Trials. 2011;12:220. [pmid: 21978409].
Doyle-Lucas AF, Davy BM. Development and evaluation of an educational intervention program for pre-professional adolescent ballet dancers: Nutrition for Optimal Performance. J Dance Med Sci. 2011;15(2):65-75. [pmid: 21703095].
Edwards MB, Miller JL, Blackburn L. After-school programs for health promotion in rural communities: Ashe county middle school 4-h after-school program. ClinJ Public Health Manag Pract. 2011;17(3):283-7.
Fernandez-Alvira J, Hebestreit A, Mouratidou T, et al. Socio-economic status and food consumption frequencies in European children: IDEFICS study. Ann Nutr Metab. 2011;58:181-2. [pmid: 21734369].
Finch M, Wolfenden L, Edenden D, et al. Impact of a population health physical activity practice change intervention in childcare services. Obes Res Clin Pract. 2011;5:S44.
Findholt NE, Michael YL, Davis MM. Photovoice engages rural youth in childhood obesity prevention. Public Health Nurs. 2011;28(2):186-92. [pmid: 21732973].
Finni T, Saakslahti A, Laukkanen A, et al. A family based tailored counselling to increase non-exercise physical activity in adults with a sedentary job and physical activity in their young children: design and methods of a year-long randomized controlled trial. BMC Public Health. 2011;11:944. [pmid: 22185647].
Fisher KL, Von Tigerstrom B, Larre T, et al. Uptake of the children's fitness tax credit in Canada: a provincial/territorial comparison. Obesity. 2011;19:S126.
Fitzhugh EC, Bassett DR Jr, et al. Urban trails and physical activity: A natural experiment. Am J Prev Med. 2010;39(3):259-262. [pmid: 20709258].
Flament MF, Hill EM, Buchholz A, et al. Internalization of the thin and muscular body ideal and disordered eating in adolescence: the mediation effects of body esteem. Body Image. 2012;9(1):68-75. [pmid: 21889429].
Flattum C, Friend S, Story M, et al. evaluation of an individualized counseling approach as part of a multicomponent school-based program to prevent weight-related problems among adolescent girls. J Am Diet Assoc. 2011;111(8):1218-23. [pmid: 21802570].
Flores G, Maldonado J, Durbn P. Making tortillas without lard: Latino parents' perspectives on healthy eating, physical activity, and weight-management strategies for overweight Latino children. J Acad Nutr Diet. 2012;112(1):81-9. [pmid: 22717179].
Foley JT, Beets, Cardinal BJ. Monitoring children's physical activity with pedometers: reactivity revisited. J Exerc Sci Fit. 2011;9(2):82-86.
Franze M, Fendrich K, Schmidt C, et al. Implementation and evaluation of the population-based programme “health literacy in school-aged children” (GeKo). J Public Health. 2011;19(4):339-47.
Gaines AB, Lonis-Shumate SR, Gropper SS. Evaluation of Alabama public school wellness policies and state school mandate implementation. J Sch Health. 2011;81(5):281-7. [pmid: 21517868].
Galhardo J, Hunt LP, Lightman SL, et al. Normalizing eating behavior reduces body weight and improves gastrointestinal hormonal secretion in obese adolescents. J Clin Endocrinol Metab. 2012;97(2):E193-201. [pmid: 22162463].
Gates M, Hanning RM, Isogai A, et al. A comprehensive school nutrition program improves knowledge and intentions for milk and alternatives intake among youth in Fort Albany First Nation (FN). Can J Diabetes. 2011;35(2):208.
Gatto NM, Ventura EE, Cook LT, et al. LA sprouts: a garden-based nutrition intervention impacts motivation and preferences for fruits and vegetables in latino youth. Am J Epidemiol. 2011;173:S114.
Gatto NM, Ventura EE, Cook LT, et al. LA sprouts: a garden-based nutrition intervention pilot program influences motivation and preferences for fruits and vegetables in latino youth. J Acad Nutr Diet. 2012;112(6):913-20. [pmid: 22516551].
Gebremariam M, Bergh I, Andersen L, et al. Stability and change in potential correlates of physical activity and association with pubertal status among Norwegian children in the transition between childhood and adolescence. Int J Behav Nutr Phys Act. 2012;9(1):56. [pmid: 22577969].
Giralt M, Albaladejo R, Tarro L, et al. A primary-school-based study to reduce prevalence of childhood obesity in Catalunya(Spain)--EDAL-Educacio en alimentacio: study protocol for a randomised controlled trial. Trials. 2011;12:54. [pmid: 21352597].
Gittelsohn J, Toporoff EG, Story M, et al. Food perceptions and dietary behavior of American-Indian children their caregivers and educators: formative assessment findings from Pathways. J Nutr Educ Behav. 2000;32(1):2-13.
Golley RK, Magarey AM, Daniels LA. Children's food and activity patterns following a six-month child weight management program. Int J Pediatr Obes. 2011;6(5-6):409-14. [pmid: 21838569].
Gonzblez M, Penelo E, Gutiqrrez T, et al. Disordered eating prevention programme in schools: a 30-month follow-up. Eur Eat Disord Rev. 2011;19(4):349-56. [pmid: 21400636].
Gortmaker SL, Lee RM, Mozaffarian RS, et al. Effect of an after-school intervention on increases in children's physical activity. Med Sci Sports Exerc. 2012;44(3):450-7. [pmid: 21814151].
Granacher U, Muehlbauer T, Doerflinger B, et al. Promoting strength and balance in adolescents during physical education: effects of a short-term resistance training. J Strength Cond Res. 2011;25(4):940-9. [pmid: 20661162].
Granner ML, Evans AE. Variables associated with fruit and vegetable intake in adolescents. Am J Health Behav. 2011;35(5):591-602. [pmid: 22040620].
Gray LJ, Khunti K, Williams S, et al. Let's Prevent Diabetes: Study protocol for a cluster randomised controlled trial of an educational intervention in a multi-ethnic UK population with screen detected impaired glucose regulation. Cardiovasc Diabetol. 2012;11(1):56. [pmid: 22607160].
Gregory J, Robling M, Bennert K, et al. Development and evaluation by a cluster randomised trial of a psychosocial intervention in children and teenagers experiencing diabetes: the DEPICTED study. Health Technol Assess. 2011;15(29):1-202. [pmid: 21851764].
Guajardo-Barron VJ, Gutierrez-Delgado MC, Rivera-Pena G. Addressing childhood obesity in Mexico: savings on health care expenditures from regulating food and beverage sales in basic education schools. Value Health. 2011;14(7):A558.
Gueugnon C, Mougin F, Simon-Rigaud ML, et al. Effects of an in-patient treatment program based on regular exercise and a balanced diet on high molecular weight adiponectin, resistin levels, and insulin resistance in adolescents with severe obesity. Appl Physiol Nutr Metab. 2012;37(4):672-9. [pmid: 22574715].
Guzman A, Irby MB, Pulgar C, et al. Adapting a tertiary-care pediatric weight management clinic to better reach Spanish-speaking families. J Immigr Minor Health. 2012;14(3):512-5. [pmid: 21909984].
Hacker K, Dryden E, Hardin J, et al. Physician's perspectives on electronic decision support alerts for obesity management. Obesity. 2011;19:S105-6.
Hall Laura, Collins CE, Morgan PJ, et al. Children's intake of fruit and selected energy-dense nutrient-poor foods is associated with fathers' intake. J Am Diet Assoc. 2011;111(7):1039-44. [pmid: 21703382].
Hamon J. Healthy Schools Plus. Food Factor. Education & Health. 2011;29(1):11-15.
Hampl S, Paves H, Laubscher K, et al. Patient engagement and attrition in pediatric obesity clinics and programs: results and recommendations. Pediatrics. 2011;128:S59-64. [pmid: 21885646].
Hartwick CA, Queval I, Sue R, et al. Food culture and nutrition education in France. The implications of a national health campaign against obesity. Appetite. 2011;56(2):531.
Haugstvedt KT, Graff-Iversen S, Bechensteen, et al. Parenting an overweight or obese child: A process of ambivalence. J Child Health Care. 2011;15(1):71-80. [pmid: 21451012].
Hawley SR, Beckman H, Bishop T. Development of an obesity prevention and management program for children and adolescents in a rural setting. J Community Health Nurs. 2006;23(2):69-80. [pmid: 16643097].
Hawthorne A, Shaibi G, Gance-Cleveland B, et al. Grand Canyon Trekkers: School-based lunchtime walking program. J Sch Nurs. 2011;27(1):43-50. [pmid: 21123848].
Hebden LA, King L, Grunseit A, et al. Advertising of fast food to children on Australian television: the impact of industry self-regulation. Med J Aust. 2011;195(1):20-4. [pmid: 21728936].
Hills AP, Andersen LB, Byrne NM. Physical activity and obesity in children. Br J Sports Med. 2011;45(11):866-70. [pmid: 21836171].
Hinkle KA, Kirschenbaum DS, Pecora KM, et al. Parents may hold the keys to success in immersion treatment of adolescent obesity. Child Fam Behav Ther. 2011;33(4):273-88.
Holmes AS, Serrano EL, Davis G. Effect of nutrition labeling of children's meals on purchases and parent-child decision-making. FASEB J. 2011;25:30.5.
Huang JS, Norman GJ, Zabinski MF, et al. Body Image and Self-Esteem among Adolescents Undergoing an Intervention Targeting Dietary and Physical Activity Behaviors. J Adolesc Health. 2007;40(3):245-251. [pmid: 17321425].
Hughes SO, Shewchuk RM. Child temperament, parent emotions, and perceptions of the child's feeding experience. 2012;9:64.
Huh J, Riggs NR, Spruijt-Metz D, et al. Identifying patterns of eating and physical activity in children: a latent class analysis of obesity risk. Obesity. 2011;19(3):652-8. [pmid: 20930718].
Idalski Carcone A, MacDonell KE, Naar-King S, et al. Treatment engagement in a weight loss intervention for African American adolescents and their families. Child Health Care. 2011;40(3):232-52.
Jackson EA, Eagle T, Leidal A, et al. Childhood obesity: A comparison of health habits of middle-school students from two communities. Clin Epidemiol. 2009;1:133-9. [pmid: 20865095].
Jacobson D, Melnyk BM. Psychosocial correlates of healthy beliefs, choices, and behaviors in overweight and obese school-age children: a primary care healthy choices interbention pilot study. J Pediatr Nurs. 2011;26(5):456-64. [pmid: 21930032].
James N, Shilton T, Maitland C, et al. Encouraging children to unplug and play: results of research with parents. J Sci Med Sport. 2011;14:e42.
Jansen E, Mulkens S, Emond Y, et al. From the Garden of Eden to the land of plenty. Restriction of fruit and sweets intake leads to increased fruit and sweets consumption in children. Appetite. 2008;51(3):570-5. [pmid: 18501474].
Jimenez-Pavon D, Ortega FB, Artero EG, et al. Physical activity, fitness, and serum leptin concentrations in adolescents. J Pediatr. 2012;160(4):598-603.e2. [pmid: 22082954].
John J, Wolfenstetter SB, Wenig CM. An economic perspective on childhood obesity: recent findings on cost of illness and cost effectiveness of interventions. Nutrition. 2012;28(9):829-39. [pmid: 22452837].
Jones MG, Verity FE. Message in postbox: eat well be active community programs from a child's world-view. Obes Res Clin Pract. 2011;5:S70-1.
Jones RA, Riethmuller A, Hesketh K, et al. Promoting fundamental movement skill development and physical activity in early childhood settings: a cluster randomized controlled trial. Pediatr Exerc Sci. 2011;23(4):600-15. [pmid: 22109783].
Jordan AB, Mallya G, Hennessy M, et al. Developing media interventions to reduce household sugar-sweetened beverage consumption. Obesity. 2011;19:S144.
Kaczmarski JM, DeBate RD, Marhefka SL, et al. State-mandated school-based BMI screening and parent notification: a descriptive case study. Health Promot Pract. 2011;12(6):797-801. [pmid: 22068272].
Kaiser KA, Affuso HO, Cox TL, et al. Is intervention intensity related to dropout rates in diet/supplement randomized weight control trials?. Obes Rev. 2011;12:35.
Kalten MR, Ardito DA, Cimino C, et al. A Web-accessible core weight management program. Diabetes Educ. 2000;26(6):929-36. [pmid: 11912805].
Kargarfard M, Kelishadi R, Ziaee V, et al. The impact of an after-school physical activity program on health-related fitness of mother/daughter pairs: CASPIAN study. Prev Med. 2012;54(3-4):219-23. [pmid: 22289783].
Keane PC, Davis SM, Myers OB, et al. Effect of an obesity prevention intervention on fruit, vegetable and whole grain intake in American Indian and Hispanic preschoolers. FASEB J. 2011;25:30.3.
Keegan F. Implementing a G3 community-based, childhood obesity prevention - OPAL in local communities. Obes Res Clin Pract. 2011;5:S52-3.
Keller K, Forman J, Lee NM, et al. Use of licensed spokes-characters to increase intake of fruits and vegetables as part of a childhood obesity prevention program: pilot study results. Obesity. 2011;19:S109.
King MA, Nkoy F, Halbern S, et al. Identification and management of overweight and obese pediatric patients hospitalized in an academic hospital. J Invest Med. 2011;59(1):150.
Klein D, Koch B, Dordel S, et al. The KiMo test: A motor screening for pre-school children aged 3-6 years. Gazz Med Ital Arch Sci Med. 2012;171(1):13-26.
Klesges RC, Hare M. The DASH diet predicts weight gain: what does this mean for my pediatric practice?. Arch Pediatr Adolesc Med. 2011;165(6):567-8. [pmid: 21646591].
Kocken PL, Eeuwijk J, Van Kesteren NM, et al. Promoting the purchase of low-calorie foods from school vending machines: a cluster-randomized controlled study. J Sch Health. 2012;82(3):115-22. [pmid: 22320335].
Kong AS, Farnsworth S, Canaca JA, et al. An adaptive community-based participatory approach to formative assessment with high schools for obesity intervention. J Sch Health. 2012;82(3):147-54. [pmid: 22320339].
Korsten-Reck U, Bauer S, Keul J. Sports and nutrition--an out-patient program for adipose children(long-term experience). Int J Sports Med. 1994;15(5):242-8. [pmid: 7960318].
Krukowski RAG, Bursac Z, Goodell M, et al. Development and evaluation of the school cafeteria nutrition assessment measures. J Sch Health. 2011;81(8):431-6. [pmid: 21740427].
Kubik MY, Story M, Davey C, et al. Providing obesity prevention counseling to children during a primary care clinic visit: results from a pilot study. J Am Diet Assoc. 2008;108(11):1902-6. [pmid: 18954581].
Kunitsugu I, Okuda M, Sugiyama S, et al. Meat intake frequency and anemia in Japanese children and adolescents. Nurs Health Sci. 2012;14(2):197-203. [pmid: 22435780].
Kuo S, Smith KJ, Piatt GA, et al. Cost-effectiveness of multiple modalities of lifestyle intervention in the community: projections from the rethinking eating and activity study. Diabetes. 2011;60:A67.
Kuru NK, Nerganullrdh R, Bohlin A, et al. Experience of creating multi-disciplinary treatment team to treat children obesity at pediatric outpatient clinics: a preliminary report of the SVK-project “Develop and evaluate a coherent chain of care for children and adolescents with obesity in the Stockholm county”. Obes Rev. 2011;12:193.
Lajunen HR, Kaprio J, Rose RJ, et al. Genetic and environmental influences on BMI from late childhood to adolescence are modified by parental education. Obesity. 2012;20(3):583-9. [pmid: 21996670].
Lazzeri G, Pammolli A, Simi R, et al. BMI from nutritional surveillance of 8-9 years old children in Tuscany (Italy). J Prev Med Hyg. 2011;52(4):181-5. [pmid: 22442922].
Le TH. Engaging children in physical activity and health awareness, Seattle WA. J Invest Med. 2011;59(1):103.
Linger R, Bakker I, Visscher T, et al. Environmental influences on physical activity: local policies and urban planning. Obes Rev. 2011;12:40.
Lloyd JJ, Logan S, Greaves CJ, et al. Evidence Theory and Context. Using intervention mapping to develop a school-based intervention to prevent obesity in children. Int J Behav Nutr Phys Act. 2011;8(1):73. [pmid: 21752261].
Lopes L, Lopes V, Pereira B. Physical activity levels in normal weight and overweight Portuguese children: an intervention study during an elementary school recess. Int Electron J Health Educ. 2009;12:175-184.
Lopez-Alarcon M, Martinez-Coronado A, Velarde-Castro O, et al. Supplementation of n3 long-chain polyunsaturated fatty acid synergistically decreases insulin resistance with weight loss of obese prepubertal and pubertal children. Arch Med Res. 2011;42(6):502-508. [pmid: 22136960].
Loureiro MIG, Freudenberg N. Engaging municipalities in community capacity building for childhood obesity control in urban settings. Fam Pract. 2012;29(Suppl 1):i24-i30. [pmid: 22399552].
Louzada MLDC, Campagnolo PDB, Rauber F, et al. Long-term effectiveness of maternal dietary counseling in a low-income population: A randomized field trial. Pediatrics. 2012;129(6):e1477-84. [pmid: 22566413].
Lu AS, Baranowski J, Islam N, et al. How to engage children in self-administered dietary assessment programmes. J Hum Nutr Diet. 2012. [Epub ahead of print].
Lubans DR, Morgan PJ, Callister R. Potential moderators and mediators of intervention effects in an obesity prevention program for adolescent boys from disadvantaged schools. J Sci Med Sport. 2012. [Epub ahead of print].
Ma M, Bai HX, Park A, et al. Novel characterization of biliary pancreatitis in children. Gastroenterology. 2011;140(5):S383.
Magnusson KT, Sigurgeirsson I, Sveinsson T, et al. Assessment of a two-year school-based physical activity intervention among 7-9-year-old children. Int J Behav Nutr Phys Act. 2011;8:1-13. [pmid: 21194492].
Mann DM, Lin JJ. Increasing efficacy of primary care-based counseling for diabetes prevention: rationale and design of the ADAPT (Avoiding Diabetes Thru Action Plan Targeting) trial. Implement Sci. 2012;7:6. [pmid: 22269066].
Markert J, Alff F, Gausche R, et al. T.A.F.F.-Telephone-based Adiposity prevention For Families: Socio-demographic description of participants and barriers to participation. Horm Res Paediatr. 2011;76:188-9.
Marks J, Barnett L, Foulkes C, et al. A systems-based approach within long day care centres for obesity prevention in children aged 3-5. Obes Res Clin Pract. 2011;5:S71.
Martinez Vizcaino V, Martinez M, Sotos E, et al. Cost-effectiveness reducing and preventing obesity of a physical activity program in school-age children. the cuenca study. Obes Facts. 2012;5:211.
Martins DL, Branco AI, Fernandes JL, et al. Estudo expo 2010: Excesso de Peso e Obesidade Infantil. Study expo 2010: overweight and obesity in childwood. Acta Med Port. 2011;24(6):871-6. [pmid: 22713179].
Mauriello LM, Ciavatta MM, Paiva AL, et al. Results of a multi-media multiple behavior obesity prevention program for adolescents. Preventive medicine. 2010;51(6):451-6. [pmid: 20800079].
McAndrew S, Jackman C, Sisto PP. Medical student-developed obesity education program uses modified team-based learning to motivate adolescents. Med Teach. 2012;34(5):414-6. [pmid: 22449273].
McGaffey AL, Abatemarco DJ, Jewell IK, et al. Fitwits MD™:An office-based tool and games for conversations about obesity with 9- to 12-year-old children. J Am Board Fam Med. 2011;24(6):768-71. [pmid: 22086823].
McNeil DA, Wilson BN, Siever JE, et al. Connecting children to recreational activities: results of a cluster randomized trial. Am J Health Promot. 2009;23(6):376-87. [pmid: 19601477].
McPherson ME, Homer CJ. Policies to support obesity prevention for children: a focus on of early childhood policies. Pediatr Clin North Am. 2011;58(6):1521-41. xii. [pmid: 22093867].
Melino B, Valerie LW, Judith B, et al. BodyWorks: A parent-focused program to promote healthful eating and physical activity for children and adolescents. J Nutr Educ Behav. 2012;44(2):192-3. [pmid: 22245164].
Mendoza JA, Watson K, Baranowski T, et al. The walking school bus and children's physical activity: a pilot cluster randomized controlled trial. Pediatrics. 2011;128(3):e537-e544. [pmid: 21859920].
Mikkelsen BE. Policies to promote on physical activity and healthy eating in kindergartens from theory to practice. Int J Pediatr Obes. 2011;6(Suppl 2):8-11. [pmid: 21923288].
Milder I, Mikolajczak J, Van Den Berg S, et al. Changes in school environment and actions regarding overweight prevention among dutch secondary schools between 2006-2007 and 2010-2011. Obes Facts. 2012;5:257.
Miller J, Gibson S. Positive impact of water on children's health and wellbeing. Br J Sch Nurs. 2012;7(1):8-9.
Miyahara M, Schreiber NG, Green C, et al. Associated movement reduction training for children with developmental coordination disorder: a pilot trial.. ..including commentary by Wilson PH and Rivilis I. Int J Ther Rehabil. 2011;18(6):336-42.
Mobley CC, Stadler DD, Staten MA, et al. Effect of nutrition changes on foods selected by students in a middle school-based diabetes prevention intervention program: The HEALTHY Experience. J Sch Health. 2012;82(2):82-90. [pmid: 22239133].
Molnar BE, Gortmaker SL, Bull FC, et al. Unsafe to Play? Neighborhood Disorder and Lack of Safety Predict Reduced Physical Activity among Urban Children and Adolescents. Am J Health Promot. 2004;18(5):378-386. [pmid: 15163139].
Moodie M, Herbert J, De Silva-Sanigorski A, et al. The cost-effectiveness, affordability and sustainability of the be active eat well community-based intervention project. Obes Rev. 2011;12:64.
Moore SN, Murphy S, Moore L. Health improvement, nutrition-related behaviour and the role of school meals: the usefulness of a socio-ecological perspective to inform policy design, implementation and evaluation. Crit Public Health. 2011;21(4):441-54.
Morano M, Colella D, Capranica L. Body image, perceived and actual physical abilities in normal-weight and overweight boys involved in individual and team sports. J Sports Sci. 2011;29(4):355-362. [pmid: 21184344].
Morano M, Colella D, Caroli M. Gross motor skill performance in a sample of overweight and non-overweight preschool children. Int J Pediatr Obes. 2011;6(Suppl 2):42-6. [pmid: 21923296].
Morgan PJ. Child obesity prevention: interventions engaging mums and dads. Obes Res Clin Pract. 2011;5:S5.
Mourao Carvalhal MIM, Fonseca S, De Castro Coelho EMRT. ELSa interventional portuguese health program to promote physical activity. Int J Pediatr Obes. 2011;6(Suppl 2):39-41. [pmid: 21923295].
Nakahara S, Poudel KC, Lopchan M, et al. Differential effects of out-of-home day care in improving child nutrition and augmenting maternal income among those with and without childcare support: A prospective before-after comparison study in Pokhara Nepal. Health Policy. 2010;1997(1):16-25. [pmid: 20236723].
Navarro-Cruz RA, Navarro-Cruz AR, Vera-Lopez O, et al. Development of a child animation for the promotion of good eating habits. Obes Rev. 2011;12:71.
Nethe A, Dorgelo A, Kugelberg S, et al. Existing policies, regulation, legislation and ongoing health promotion activities related to physical activity and nutrition in pre-primary education settings: an overview. Obes Rev. 2012;13(Suppl 1):118-28. [pmid: 22309070].
Neumark-Sztainer D, Martin SL, Story M. School-based programs for obesity prevention: What do adolescents recommend?. Am J Health Promot. 2000;14(4):232-235. [pmid: 10915534].
Nkansah-Amankra S, Walker AD. The relation between adolescent self assessment of health and risk behaviours: could a global measure of health provide indications of health risk exposures?. Health Educ J. 2012;71(1):39-52.
Noonan K, Corman H, Schwartz-Soicher O, et al. Effects of Prenatal Care on Child Health at Age 5. Matern Child Health J. 2012. [Epub ahead of print].
Nordstrom J. Willingness to pay for wholesome canteen takeaway. Appetite. 2012;58(1):168-79. [pmid: 21983052].
Nourian M, Yassin Z, Kelishadi R. Impact of a nutrition education intervention on weight loss in obese adolescents with metabolic syndrome. Cardiovasc Res. 2012;93:S117.
Nowicka P. Parents as gatekeepers: Introduction to family therapy in obesity treatment. Obes Facts. 2012;5:9.
Noyes FR, Barber-Westin SD, Smith ST, et al. A training program to improve neuromuscular indices in female high school volleyball players. J Strength Cond Res. 2011;25(8):2151-60. [pmid: 21659890].
Noyes FR, Barber-Westin SD, Smith ST, et al. A training program to improve neuromuscular indices in female high school volleyball players. J Strength Cond Res. 2012;26(3):709-19. [pmid: 22289699].
Nunez-Gaunaurd A, Kirk-Sanchez N. Health outcomes of an extracurricular family-based intervention for physical activity in three hispanic male children: a case series. HPA Resource. 2011;11(3):J2-9.
O'Hara BJ, Phongsavan P, Venugopal K, et al. Characteristics of participants in Australia's Get Healthy telephone-based lifestyle information and coaching service: reaching disadvantaged communities and those most at need. Health Educ Res. 2011;26(6):1097-106. [pmid: 21987479].
Ohkawara K, Cornier MA, Melanson EL, et al. Six versus three meals per day: effects on energy expenditure, fat oxidation, and hunger. Obesity. 2011;19:S61.
Olstad DL, Raine KD, McCargar LJ. Adopting and implementing nutrition guidelines in recreational facilities: Public and private sector roles. A multiple case study. BMC Public Health. 2012;12(1):376. [pmid: 22632384].
Oosthuizen D, Oldewage-Theron WH, Napier C. The impact of a nutrition programme on the dietary intake patterns of primary school children. S Afr J Clin Nutr. 2011;24(2):75-81.
Pasch KE, Lytle LA, Samuelson AC, et al. Are school vending machines loaded with calories and fat: an assessment of 106 middle and high schools. J Sch Health. 2011;81(4):212-8. [pmid: 21392013].
Paschoal MA, Fontana CC. Metodo do limiar de variabilidade da frequencia cardiaca aplicado em pre-adolescentes obesos e nao obesos. Method of heart rate variability threshold applied in obese and non-obese pre-adolescents. Arq Bras Cardiol. 2011;96(6):450-6. [pmid: 21537531].
Patel AI, Bogart LM, Elliott MN, et al. Increasing the availability and consumption of drinking water in middle schools: a pilot study. Prev Chronic Dis. 2011;8(3):A60. [pmid: 21477500].
Patel SL, Holub SC. Body size matters in provision of help: factors related to children's willingness to help overweight peers. Obesity. 2012;20(2):382-8. [pmid: 21996656].
Pathmasiri W, Pratt KJ, Collier DN, et al. Integrating metabolomic signatures and psychosocial parameters in responsivity to an immersion treatment model for adolescent obesity. Metabolomics. 2012:1-15. [pmid: 22593720].
Paulis W, Van Middelkoop M, Bueving H, et al. Determinants of (sustained) overweight and complaints in children and adolescents in primary care: the Doerak cohort study design. Obes Facts. 2012;5:239.
Pentz MA, Durand CP, Huh J. Relationship of community policies to child obesity risk. Obesity. 2011;19:S128.
Perez-Gallardo L, Martinez JM, Rubiales C, et al. Assessment of the performance of PERSEO programme to prevent obesity in children through a pilot study in Soria. Obes Rev. 2011;12:76.
Perryman ML. Ethical family interventions for childhood obesity. Prev Chronic Dis. 2011;8(5):A99. [pmid: 21843429].
Petrova S, Duleva V. Nutritional status of Bulgarian 1-st grade schoolchildren - WHO childhood obesity surveillance initiative in Bulgaria. Ann Nutr Metab. 2011;58:286-7.
Pietrobelli A, Tosi C, Malavolti M, et al. A child is not a small adult: Development of pediatric obesity intervention in Italy. Obes Facts. 2012;5:10.
Piziak V. A pilot study of a pictorial bilingual nutrition education game to improve the consumption of healthful foods in a head start population. Int J Environ Res Public Health. 2012;9(4):1319-25. [pmid: 22690195].
Podrabsky M, Streichert LC, Levinger D, et al. Campus-community-school partnerships to evaluate a multicomponent nutrition intervention. Public Health Rep. 2007;122(4):566-569. [pmid: 17639662].
Potdevin FJ, Alberty ME, Chevutschi A, et al. Effects of a 6-week plyometric training program on performances in pubescent swimmers. J Strength Cond Res. 2011;25(1):80-6. [pmid: 21157388].
Potter SC, Schneider D, Coyle KK, et al. What works? Process evaluation of a school-based fruit and vegetable distribution program in Mississippi. J Sch Health. 2011;81(4):202-11. [pmid: 21392012].
Prelip M, Slusser W, Thai CL, et al. Effects of a school-based nutrition program diffused throughout a large urban community on attitudes, beliefs, and behaviors related to fruit and vegetable consumption. J Sch Health. 2011;81(9):520-9. [pmid: 21831064].
Quiles-Marcos Y, Balaguer-Sola I, Pamies-Aubalat L, et al. Eating habits, physical activity, consumption of substances and eating disorders in adolescents. Span J Psychol. 2011;14(2):712-23. [pmid: 22059317].
Rabiei S. The association of nutrition style through the first 2 years of life with type 1 diabetes mellitus and some of the other effective factors in 2-15 years old children. Iran J Endocrinology Metab. 2011;13(1):113.
Riley M, Locke AB, Skye EP. Health maintenance in school-aged children: part I. history, physical examination, screening, and immunizations. Am Fam Physician. 2011;83(6):683-8. [pmid: 21404978].
Roberta Vilarouca A, Zanetti MLC, Costa RW, et al. Evaluating two educational interventions to prevent type 2 Diabetes Mellitus among adolescents [Portuguese]. Texto and Contexto Enfermagem. 2011;20(4):782-7.
Robinson T. Improving the design of population- and family-based interventions to prevent and control obesity. Obes Facts. 2012;5:25.
Rodriguez VM, Etaio I, Mauleon JR, et al. Application of an intervention program to improve fruit and vegetable acceptance among children: Preliminary results. Obes Facts. 2012;5:256.
Rodriguez-Oliveros G, Haines J, Ortega-Altamirano D, et al. Obesity determinants in Mexican preschool children: parental perceptions and practices related to feeding and physical activity. Arch Med Res. 2011;42(6):532-9. [pmid: 22019411].
Romero AJ. A pilot test of the Latin active hip hop intervention to increase physical activity among low-income Mexican-American adolescents. Am J Health Promot. 2012;26(4):208-11. [pmid: 22375569].
Roofe NL. Improving families' nutrition knowledge through service learning. J Allied Health. 2011;40(4):194-8. [pmid: 22138874].
Saint-Maurice PF, Welk GJ, Silva P, et al. Assessing children's physical activity behaviors at recess: a multi-method approach. Pediatr Exerc Sci. 2011;23(4):585-99. [pmid: 22109782].
Salmon J, Ball K, Crawford D, et al. Reducing sedentary behaviour and increasing physical activity among 10-year-old children: overview and process evaluation of the ‘Switch-Play’ intervention. Health Promot Int. 2005;20(1):7-17. [pmid: 15668218].
Salois MJ. The built environment and obesity among low-income preschool children. Health Place. 2012;18(3):520-7. [pmid: 22390893].
Salvatore D, Messina C, Kier C. Nutrition risk assessment: pathway to improve mean BMI percentile in our pediatric population. Pediatr Pulmonol. 2011;46:380.
Sanchez-Vaznaugh EV, Sanchez BN, Rosas LG, et al. Physical education policy compliance and children's physical fitness. Am J Prev Med. 2012;42(5):452-9. [pmid: 22516484].
Sanchis-Moysi J, Dorado C, Arteaga-Ortiz R, et al. Effects of training frequency on physical fitness in male prepubertal tennis players. J Sports Med Phys Fitness. 2011;51(3):409-16. [pmid: 21904279].
Sandercock G, Voss C, Cohen D, et al. Centile curves and normative values for the twenty metre shuttle-run test in English schoolchildren. J Sports Sci. 2012;30(7):679-87. [pmid: 22339646].
Santos AP, Marinho DA, Costa AM, et al. The effects of concurrent resistance and endurance training follow a detraining period in elementary school students. J Strength Cond Res. 2012;26(6):1708-16. [pmid: 21912296].
Santos EMC, Tassitano RM, do Nascimento WMF, et al. Satisfacao com o peso corporal e fatores associados em estudantes do ensino medio. Body satisfaction and associated factors among high school students. Rev Paul Pediatr. 2011;29(2):214-23.
Sargent GM. Successful treatment of childhood overweight and obesity in Prim Health Care and appropriate outcome measures: development of a logic model. Obes Res Clin Pract. 2011;5:S22.
Savard M, Gagnon J, Nadeau L, et al. The effectiveness of a school-based nutrition education intervention on the fruit, vegetable and dairy consumption of children - results from team nutriathlon. Obes Facts. 2012;5:263.
Sekhobo JP, Egglefield K, Edmunds LS, et al. Evidence of the adoption and implementation of a statewide childhood obesity prevention initiative in the New York State WIC Program: the NY Fit WIC process evaluation. Health Educ Res. 2012;27(2):281-91. [pmid: 22052217].
Seo DCl, Lee CG. Association of school nutrition policy and parental control with childhood overweight. J Sch Health. 2012;82(6):285-293. [pmid: 22568464].
Shah P, Misra A. Spreading awareness for prevention of obesity and diabetes in school age children [Project ‘MARG’: The Path]. Int J Obes. 2011;35:S165.
Shaikh U, Nettiksimmons J, Bell RA, et al. Accuracy of parental report and electronic health record documentation as measures of diet and physical activity counseling. Acad Pediatr. 2012;12(2):81-87. [pmid: 22209035].
Sharma S, Ru-Jye C, Hedberg AM. Pilot-testing catch early childhood: a preschool-based healthy nutrition and physical activity program. J Health Educ. 2011;42(1):12-23.
Siega-Riz AM, El Ghormli L, Mobley C, et al. The effects of the HEALTHY study intervention on middle school student dietary intakes. Int J Behav Nutr Phys Act. 2011;8:7. [pmid: 21294869].
Sigman-Grant M, Byington T, Lindsay A, et al. Preschoolers distinguish between healthy and unhealthy snack foods. FASEB J. 2011;25. 30.2.
Sim F, Ahmad R. Building grass roots capacity to tackle childhood obesity. Perspect Public Health. 2011;131(4):165-9. [pmid: 21888118].
Slusser W, Staten K, Stephens K, et al. Payment for obesity services: examples and recommendations for stage 3 comprehensive multidisciplinary intervention programs for children and adolescents. Pediatrics. 2011;128(Suppl 2):S78-85. [pmid: 21885649].
Smallfield S, Anderson AJ. Using after-school programming to support health and wellness: a physical activity engagement program description. Early Intervention & School Special Interest Section Quarterly. 2009;16(3):1-4.
Smith H, Grogan S, Davey R, et al. Developing a successful physical activity intervention in primary schools. Education & Health. 2009;27(3):67-70.
Socha P, Grote V, Gruszfeld D, et al. Milk protein intake, the metabolic-endocrine response, and growth in infancy: Data from a randomized clinical trial. Am J Clin Nutr. 2011;94(6):1776S-84S. [pmid: 21849603].
Souissi H, Chtourou H, Chaouachi A, et al. The Effect of Training at a Specific Time-of-Day on the Diurnal Variations of Short-Term Exercise Performances in 10- to 11-Year-Old Boys. Pediatr Exerc Sci. 2012;24(1):84-99. [pmid: 22433267].
Speers SE, Harris JL, Schwartz MB. Child and adolescent exposure to food and beverage brand appearances during prime-time television programming. Am J Prev Med. 2011;41(3):291-6. [pmid: 21855743].
Stahl C, Necheles J, Mayefsky J. Pediatric resident education to address the obesity epidemic in the clinical setting: Reported changes in teens. J Adolesc Health. 2011;48(2):S40.
Stewart D, Anne C, Jacqueline C, et al. Modification of eating attitudes and behavior in adolescent girls: A controlled study. Int J Eat Disord. 2001;29(2):107-118. [pmid: 11429973].
Stockton M, McClanahan B, Clark S, et al. Activity friendly communities: Participatory approach for maximizing partnerships. Obesity. 2011;19:S146.
Story M, Snyder MP, Anliker J, et al. Changes in the nutrient content of school lunches: results from the Pathways study. Preventive medicine. 2003;37(6 Pt 2):S35-45. [pmid: 14636807].
Straker L, Abbott R. Effect of screen-based media on energy expenditure and heart rate in 9- to 12-year-old children. Pediatr Exerc Sci. 2007;19(4):459-471. [pmid: 18089912].
Sugerman S, Backman D, Foerster SB, et al. Using an opinion poll to build an obesity-prevention social marketing campaign for low-income Asian and Hispanic immigrants: report of findings. J Nutr Educ Behav. 2011;42(4S2):S53-66. [pmid: 21683292].
Swan E, Bouwman L, de Roos N, et al. How science thinks and practice acts: bridging the gap in weight management interventions for adolescents. Fam Pract. 2012;29(Suppl 1):i117-i125. [pmid: 22399540].
Sweat V, Bruzzese JM, Albert S, Pinero D, et al. The Banishing Obesity and Diabetes in Youth (BODY) Project: description and feasibility of a program to halt obesity-associated disease among urban high school students. J Community Health. 2012;37(2):365-71. [pmid: 21826529].
Tabacchi G, Bianco A, Mammina C. A web-based system for nutritional surveillance. The project asso - adolescents and surveillance system for obesity prevention. Ann Nutr Metab. 2011;58:416.
Tabak RG, Tate DF, Stevens J, et al. Family ties to health program: a randomized intervention to improve vegetable intake in children. J Nutr Educ Behav. 2012;44(2):166-71. [pmid: 22154131].
Tabak RG, Tate DF, Stevens J, et al. Family ties to health study: A randomized intervention to improve vegetable intake in children. Obesity. 2011;19:S109.
Tamam S, Bellissimo N, Patel BP, et al. Overweight and obese boys reduce food intake in response to a glucose drink but fail to increase intake in response to exercise of short duration. Appl Physiol Nutr Metab. 2012;37(3):520-9. [pmid: 22530879].
Taylor RW. Forget schools: How do we tackle the home environment for obesity prevention?. Australas Med J. 2011;4(12):716.
Thebaud V, Nicholson J, Meedeniya J, et al. Process evaluation of the nourish-rct, an obesity prevention intervention commencing in infancy. Obes Facts. 2012;5:78.
Thompson C, Russell-Mayhew S, Saraceni R. Evaluating the effects of a peer-support model: reducing negative body esteem and disordered eating attitudes and behaviours in grade eight girls. Eating Disorders. 2012;20(2):113-26. [pmid: 22364343].
Tonnessen E, Shalfawi SA, Haugen T, et al. The effect of 40-m repeated sprint training on maximum sprinting speed, repeated sprint speed endurance, vertical jump, and aerobic capacity in young elite male soccer players. J Strength Cond Res. 2011;25(9):2364-70. [pmid: 21869624].
Tripodi A, Severi S, Midili S, et al. “Community projects” in Modena (Italy): promote regular physical activity and healthy nutrition habits since childhood. Int J Pediatr Obes. 2011;6(Suppl 2):54-6. [pmid: 21923298].
Troupe S, Blake R, O'Rourke F, et al. The obesity epidemic: Does socioeconomic status exacerbate sedentary behavior?. Obesity. 2011;19:S111.
Ulrich DA, Burghardt AR, Lloyd M, et al. Physical activity benefits of learning to rise a two-wheel bicycle for children with down syndrome: a randomized trial. Phys Ther. 2011;91(10):1463-77. [pmid: 21852519].
Van Lippevelde W, van Stralen M, Verloigne M, et al. Mediating effects of home-related factors on fat intake from snacks in a school-based nutrition intervention among adolescents. Health Educ Res. 2012;27(1):36-45. [pmid: 22156234].
Van Lippevelde W, Verloigne M, De Bourdeaudhuij I, et al. What do parents think about parental participation in school-based interventions on energy balance-related behaviours? A qualitative study in 4 countries. BMC Public Health. 2011;11:881. [pmid: 22112159].
Van Ryzin MJ, Nowicka P. Family-based intervention prevents early adulthood obesity: 10-years follow up of the family check-up, a randomized controlled trial. Obes Facts. 2012;5:33.
Vasickova L, Stavek P, Suchanek P. Possible effect of DHA intake on body weight reduction and lipid metabolism in obese children. Neuro Endocrinol Lett. 2011;32(Suppl 2):64-7. [pmid: 22101886].
Vericker TC. Limited evidence that competitive food and beverage practices affect adolescent consumption behaviors. Health Educ Behav. 2012. [Epub ahead of print].
Villalba J, Amirehsani K, Lewis T. Increasing healthy behaviors in adolescents of Mexican heritage in rural emerging Latino communities: results from a school-based health intervention pilot study. J Immigr Minor Health. 2011;13(3):629-32. [pmid: 20803071].
Villiard H, Moreno M. An analysis of fitness behaviors promoted on facebook for adolescents. Pediatr Res. 2011;70(4):440.
Virtanen SM, Barlund S, Salonen M, et al. Feasibility and compliance in a nutritional primary prevention trial in infants at increased risk for type 1 diabetes. Acta Paediatr Int J Paediatr. 2011;100(4):557-64.
Voigt K. Tackling childhood obesity through the education system: opportunities and ethical challenges. Obes Rev. 2011;12:21.
Walter HJ, Hofman A, Connelly PA, et al. Coronary heart disease prevention in childhood: one-year results of a randomized intervention study. Am J Prev Med. 1986;2(4):239-45. [pmid: 3453186].
Wang Jensen B, Nichols M, Allender S, et al. High levels of sweet drink consumption in an Australian population of children and adolescents; however some evidence of small decreases over time. Obes Res Clin Pract. 2011;5:S39-40.
Warschburger P, Kroller K. Childhood overweight and obesity: maternal perceptions of the time for engaging in child weight management. BMC Public Health. 2012;12(1):295. [pmid: 22520114].
Weaver CM, Campbell WW, Teegarden D, et al. Calcium, dairy products, and energy balance in overweight adolescents: a controlled trial. Am J Clin Nutr. 2011;94(5):1163-70. [pmid: 21918216].
Wen LM, Baur LA, Rissel C, et al. A randomized controlled trial of an early intervention on childhood obesity: results from the first 12 months. Obesity. 2011;19:S67.
Whitt-Glover MC, Ham SA, Yancey AK. Instant Recess^®^: a practical tool for increasing physical activity during the school day. Prog Community Health Partnersh. 2011;5(3):289-97. [pmid: 22080777].
Willi SM, Hirst K, Jago R, et al. Cardiovascular risk factors in multi-ethnic middle school students: the HEALTHY primary prevention trial. Pediatr Obes. 2012;7(3):230-9. [pmid: 22461375].
Williams CL, Squillace MM, Bollella MC. Healthy Start: a comprehensive health education program for preschool children. Prev Med. 1998;27(2):216-23. [pmid: 9578999].
Williams MA. Translating a G3 community-based, childhood obesity prevention intervention from Europe to Australia - EPODE to OPAL. Obes Res Clin Pract. 2011;5:S74-S75.
Wilson DK, Lawman HG, Segal M, et al. Neighborhood and parental supports for physical activity in minority adolescents. Am J Prev Med. 2011;41(4):399-406. [pmid: 21961467].
Wilson TA, Butte NF, Barlow SE, et al. Predictors of BMI improvement in hispanic children participating in mind, exercise, nutrition, do it! (MEND) weight management program. Obesity. 2011;19:S108.
Woodruff S, Fryer K, Cole MM, et al. Associations among blood pressure, salt consumption, and obesity status of grade 7 students from south western Ontario. Obesity. 2011;19:S217.
Wordell D, Daratha K, Mandal B, et al. Changes in a middle school food environment affect food behavior and food choices. J Acad Nutr Diet. 2012;112(1):137-41. [pmid: 22709644].
Wright KN. Influence of body mass index, gender, and Hispanic ethnicity on physical activity in urban children. J Spec Pediatr Nurs. 2011;16(2):90-104. [pmid: 21438999].
Young K, Serrano V, Castillo F, et al. Healthy lifestyle intervention: Educating fifth and sixth grade students with the Health4Life program. J Invest Med. 2011;59(1):104.
Yu ML, Ziviani JM, Haynes M. Sleep, structured and social time use and young Australian children's physical activity. Health Promot J Austr. 2011;22(3):203-9. [pmid: 22497064].
Zahner L, Puder JJ, Roth R, et al. A school-based physical activity program to improve health and fitness in children aged 6-13 years(“Kinder-Sportstudie KISS”): Study design of a randomized controlled trial [ISRCTN15360785]. BMC Public Health. 2006:6. [pmid: 16409633].
Zandian M, Ioakimidis I, Bergstrom J, et al. Children eat their school lunch too quickly: an exploratory study of the effect on food intake. BMC Public Health. 2012;12(1):351. [pmid: 22583917].
Zhao J, Bradfield JP, Li M, et al. BMD-associated variation at the osterix locus is correlated with childhood obesity in females. Obesity. 2011;19(6):1311-4. [pmid: 21212767].

## No abstractable data

Adimoolam V, Charney P. Identification and management of overweight and obesity by internal medicine residents: Christopher B. Ruser Lisa Sanders, et al. J Gen Intern Med. 2006;21(10):1128. [pmid: 16836619].
Bagby K, Adams S. Evidence-based practice guideline: Increasing physical activity in schools--Kindergarten through 8th grade. J Sch Nurs. 2007;23(3):137-143. [pmid: 17536917].
Briancon S, Bonsergent E, Agrinier N, et al. Improving nutritional behaviours and knowledge in high school adolescents: The PRALIMAP overweight and obesity prevention trial. Can J Diabetes. 2011;35(2):180.
Bucher Della Torre S, Dudley-Martin F, Kruseman M. Development and testing of an obesity prevention program for young children at risk, and their parents. Ann Nutr Metab. 2011;58:260.
Davis SM, Going SB, Helitzer DL, et al. Pathways: a culturally appropriate obesity-prevention program for American Indian schoolchildren. Am J Clin Nutr. 1999;69(4 Suppl):796S-802S. [pmid: 10195605].
Dubois L, Girard M. Genetic and environmental influences on children's food intake and obesity in a Canadian twin birth cohort. Twin Res Hum Genet. 2010;13(3):255.
Gance-Cleveland B, Renteria F, Choi M, et al. Obesity prevention intervention for middle school youth. Commun Nurs Res. 2010;43:565.
Hamon Jane. Healthy Schools Plus. Food Factor. Education & Health. 2011;29(1):11-15.
Hartmann T, Zahner L, Pnhse U, et al. Physical activity bodyweight health and fear of negative evaluation in primary school children. Scand J Med Sci Sports. 2010;20(1):e27-e34. [pmid: 19422648].
Jeffery RW, Gray CW, French S, et al. Evaluation of weight reduction in a community intervention for cardiovascular disease risk: changes in body mass index in the Minnesota Heart Health Program. Int J Obes Relat Metab Disord. 1995;19(1):30-9. [pmid: 7719388].
Kalten MR, Ardito DA, Cimino C, Wylie-Rosett J. A Web-accessible core weight management program. Diabetes Educ. 2000;26(6):929-36. [pmid: 11912805].
Mauriello LM, Ciavatta MM, Paiva AL, et al. Results of a multi-media multiple behavior obesity prevention program for adolescents. Preventive medicine. 2010;51(6):451-6. [pmid: 20800079].
Moodie M, Haby MM, Swinburn B, et al. Assessing cost-effectiveness in obesity: active transport program for primary school children: TravelSMART Schools Curriculum program (Provisional abstract). J Phys Act Health. 2011;8(4):503-515. [pmid: 21597123].
Motl RW, Dishman RK, Felton G, et al. Self-motivation and physical activity among black and white adolescent girls. Med Sci Sports Exerc. 2003;35(1):128-136. [pmid: 12544646].
Nemet D, Geva D, Eliakim A. Health promotion intervention in low socioeconomic kindergarten children. J Pediatr. 2011;158(5):796-801.e1. [pmid: 21244862].
O'Neil ME. The Kids Fitness Program: community-based intervention for children who are overweight. Pediatric Physical Therapy. 2006;18(1):101-102.
Puliti B. Young at heart: 3 areas of education for Healthy Kids/Weight. Adv Nurses. 2011;8.18(9.6):13-14. 64. 65.
Schneider M, Cooper DM. Enjoyment of exercise moderates the impact of a school-based physical activity intervention. Int J Behav Nutr Phys Act. 2011;8.
Smith H, Grogan S, Davey R, Cochrane T. Developing a successful physical activity intervention in primary schools. Education & Health. 2009;27(3):67-70.
Utter J, Warbrick J, Scragg R, et al. Design development and achievements of a youth-led nutrition and physical activity intervention in a Pacific community in New Zealand. J Am Diet Assoc. 2010;110(11):1634-7. [pmid: 21034874].
Water in schools may cut obesity risks in children. Nutrition Health Review: The Consumer's Medical Journal. 2010;(102):13.
Zahner L, Puder JJ, Roth R, et al. A school-based physical activity program to improve health and fitness in children aged 6-13 years(“Kinder-Sportstudie KISS”): Study design of a randomized controlled trial [ISRCTN15360785]. BMC Public Health. 2006;6.

## Study includes only overweight or obese children

Alff F, Markert J, Zschaler S, et al. Reasons for (non)participating in a telephone-based intervention program for families with overweight children. PLoS One. 2012;7(4). [Epub ahead of print].
Antonina Starodubova AV, Kaganov B, Pavlovskaya E, et al. Inpatient treatment and rehabilitation of obese children and adolescents with metabolic syndrome. Eur J Cardiovasc Prev Rehabil. 2011;18(1):S22.
Bachlin A, Ritzel G. Intervention study on obese school-aged children. Bibl Nutr Dieta. 1989;(44):38-44. [pmid: 2783108].
Backlund C, Sundelin G, Larsson C. Effect of a 1-year lifestyle intervention on physical activity in overweight and obese children. Adv Physiother. 2011;13(3):87-96.
Balagopal P, Bayne E, Sager B, et al. Effect of lifestyle changes on whole-body protein turnover in obese adolescents. Int J Obes Relat Metab Disord. 2003;27(10):1250-7. [pmid: 14513074].
Ball GDC, Mackenzie-Rife KA, Newton MS, et al. One-on-one lifestyle coaching for managing adolescent obesity: findings from a pilot, randomized controlled trial in a real-world, clinical setting. Paediatr Child Health. 2011;16(6):345-50. [pmid: 22654546].
Banks J, Sharp DJ, Hunt LP, et al. Evaluating the transferability of a hospital-based childhood obesity clinic to primary care: a randomised controlled trial. Br J Gen Pract. 2012;62(594):e6-12. [pmid: 22520658].
Banks J, Shield JP, Sharp D. Barriers engaging families and GPs in childhood weight management strategies. Br J Gen Pract. 2011;61(589):e492-7. [pmid: 21801549].
Banks J, Williams J, Cumberlidge T, et al. Is healthy eating for obese children necessarily more costly for families?. Br J Gen Pract. 2012;62(594):e1-5. [pmid: 22520655].
Baur L. Effectiveness of a home-based early intervention on children's BMI at age two years: randomised controlled trial. Obes Facts. 2012;5:34. [pmid: 22433615].
Baxter KA, Ware RS, Batch JA, et al. Predicting success: factors associated with weight change in obese youth undertaking a weight management program. Obes Res Clin Pract. 2011. [Epub ahead of print].
Bille DS, Chabanova E, Gamborg M, et al. Chronic care childhood obesity treatment and concomitant treatment of non-alcoholic fatty liver disease. Obes Facts. 2012;5:218-219.
Bocca G, Stolk R, Sauer P. Long lasting positive effects of a multidisciplinary intervention program to treat obesity in preschool children. Horm Res Paediatr. 2011;76:181.
Boutelle KN, Cafri G, Crow SJ. Parent predictors of child weight change in family based behavioral obesity treatment. Obesity. 2012;20(7):1539-43. [pmid: 22421896].
Boutelle KN, Cafri G, Crow SJ. Parent-only treatment for childhood obesity: A randomized controlled trial. Obesity. 2011;19(3):574-80. [pmid: 20966907].
Braet C, Van Winckel M, Van LK. Follow-up results of different treatment programs for obese children. Acta Paediatr Int J Paediatr. 1997;86(4):397-402.
Brennan L, Walkley J, Wilks R, et al. Physiological and behavioural outcomes of a randomised controlled trial of a cognitive behavioural lifestyle intervention for overweight and obese adolescents. Obes Res Clin Pract. 2012:e1-e19.
Brennan L, Walkley J, Wilks R. Parent and adolescent reported barriers to participation in an adolescent overweight and obesity intervention. Obesity. 2012;20(6):1319-24. [pmid: 22193923].
Brownell KD, Wadden TA, Foster GD. A comprehensive treatment plan for obese children and adolescents: Principles and practice. Pediatrician. 1984;85;12(2-3):89-96. [pmid: 6571156].
Bryant M, Farrin A, Christie D, et al. Results of a feasibility randomised controlled trial (RCT) for WATCH IT: A programme for obese children and adolescents. Clin Trials. 2011;8(6):755-64. [pmid: 22024104].
Buonani C, Fernandes RA, Silveira LS, et al. Prevencao da sindrome metabolica em criancas obesas: Uma proposta de intervencao. Prevention of metabolic syndrome in obese children: A proposal of intervention. Rev Paul Pediatr. 2011;29(2):186-192.
Burnet DL, Plaut AJ, Wolf SA, et al. Reach-out: a family-based diabetes prevention program for African American youth. J Natl Med Assoc. 2011;103(3):269-77. [pmid: 21671531].
Burrows T, Janet WM, Collins CE. Long-term changes in food consumption trends in overweight children in the HIKCUPS intervention. J Pediatr Gastroenterol Nutr. 2011;53(5):543-7. [pmid: 21670711].
Camacho-Minano MJ, Galiano IR, Diaz AM. Body image and weight control strategies in overweight adolescent girls: implications for preventing eating disorders. Arch Women's Ment Health. 2011;14:S131-2.
Campbell M, Benton JM, Werk LN. Parent perceptions to promote a healthier lifestyle for their obese child. Soc Work Health Care. 2011;50(10):787-800. [pmid: 22136345].
Carrel AL, Clark RR, Peterson SE, et al. Improvement of fitness body composition and insulin sensitivity in overweight children in a school-based exercise program: a randomized controlled study. Arch Pediatr Adolesc Med. 2005;159(10):963-8. [pmid: 16203942].
Casazza K, Cardel M, Dulin-Keita A, et al. Reduced carbohydrate diet to improve metabolic outcomes and decrease adiposity in obese peripubertal African American girls. J Pediatr Gastroenterol Nutr. 2012;54(3):336-342. [pmid: 22067112].
Chae HW, Kwon YN, Rhie YJ, et al. Effects of a structured exercise program on insulin resistance inflammatory markers and physical fitness in obese Korean children. J Pediatr Endocrinol Metab. 2010;23(10):1065-72. [pmid: 21158218].
Chisholm KW, Alexander S. Tertiary level management of overweight and obese children and adolescents - Does intensive dietetic intervention using a moderate protein intake have a positive impact on weight control in children?. Obes Res Clin Pract. 2011;5:S24.
Christison A, Khan HA. Exergaming for health: a community-based pediatric weight management program using active video gaming. Clin Pediatr. 2012;51(4):382-8.
Coleman KJ, Hsii AC, Koebnick C, et al. Implementation of clinical practice guidelines for pediatric weight management. J Pediatr. 2012;160(6):918-22. [pmid: 22240108].
Coleman KJ, Ocana LL, Walker C, et al. Outcomes from a culturally tailored diabetes prevention program in Hispanic families from a low-income school: Horton Hawks Stay Healthy(HHSH). Diabetes Educ. 2010;36(5):784-92. [pmid: 20651100].
Collins CE, Okely AD, Morgan PJ Jones, et al. Parent diet modification child activity or both in obese children: an RCT. Pediatrics. 2011;127(4):619-27. [pmid: 21444600].
Cong Z, Feng D, Liu Y, et al. Sedentary behaviors among Hispanic children: influences of parental support in a school intervention program. Am J Health Promot. 2012;26(5):270-80. [pmid: 22548421].
Coppins DF, Margetts BM, Fa JL, Brown M, Garrett F, Huelin S. Effectiveness of a multi-disciplinary family-based programme for treating childhood obesity(The Family Project). Eur J Clin Nutr. 2011.
Craven KW, Moore JB, Swart AS, et al. School-based nutrition education intervention: effect on achieving a healthy weight among overweight ninth-grade students. ClinJ Public Health Manag Pract. 2011;17(2):141-6.
Croker H, Viner RM, Nicholls D, et al. Family-based behavioural treatment of childhood obesity in a UK National Health Service setting: randomized controlled trial. Int J Obes (Lond). 2012;36(1):16-26. [pmid: 21931327].
Dahiya R, Shultz S, Clark S, et al. Effect of a resistance weight training intervention on body composition and left ventricular structure and function in obese adolescents. Endocr Rev. 2011;32(3):P1-462.
Danielsson P, Svensson V, Kowalski J, et al. Importance of age for 3-year continuous behavioral obesity treatment success and dropout rate. Obes Facts. 2012;5(1):34-44. [pmid: 22433615].
Davis I, Gick M, Sigal RJ, et al. The relationship between aerobic fitness and psychological adjustment in overweight and obese adolescents. Obesity. 2011;19:S148.
Davis JN, Ventura EE, Tung A, et al. Effects of a randomized maintenance intervention on adiposity and metabolic risk factors in overweight minority adolescents. Pediatr Obes. 2012;7(1):16-27. [pmid: 22434736].
de Mello ED, Luft VC, Meyer F. Individual outpatient care versus group education programs. Which leads to greater change in dietary and physical activity habits for obese children?. J Pediatr(Rio J). 2004;80(6):468-74. [pmid: 15622423].
de Mello MT, de Piano A, Carnier J, et al. Long-term effects of aerobic plus resistance training on the metabolic syndrome and adiponectinemia in obese adolescents. J Clin Hypertens(Greenwich). 2011;13(5):343-50. [pmid: 21545395].
DeBar LL, Stevens VJ, Perrin N, et al. A primary care-based, multicomponent lifestyle intervention for overweight adolescent females. Pediatrics. 2012;129(3):e611-20. [pmid: 22331335].
Deforche B, Haerens L, De Bourdeaudhuij I. How to make overweight children exercise and follow the recommendations. Int J Pediatr Obes. 2011;6(Suppl 1):35-41. [pmid: 21905814].
Demirdag G, Kinik ST, Yazici AC. Re-evaluation of metabolic parameters of obese children after 5-7 years. Horm Res Paediatr. 2011;76:308.
D'Hondt E, Deforche B, Gentier I, et al. A longitudinal analysis of gross motor coordination in overweight and obese children versus normal-weight peers. Int J Obes. 2012. [Epub ahead of print].
D'Hondt E, Gentier I, Deforche B, et al. Weight loss and improved gross motor coordination in children as a result of multidisciplinary residential obesity treatment. Obesity. 2011;19(10):1999-2005. [pmid: 21720438].
Dias I, Maranhao P, Panazzolo D, et al. Effects of 3-month resistance exercise training on microvascular endothelial-dependent reactivity in obese adolescents. Obes Facts. 2012;5:220.
Dreyfus M. Psychological approach to obese children and adolescents as part of a multidisciplinary management strategy: abord psychologique de l'obesite de l'enfant et de l'adolescent dans une consultation pluridisciplinaire. Ann Pediatr. 1993;40(5):305-312.
Ehehalt S, Schweizer R, Blumenstock G, et al. Investigation of myostatin serum levels before and after a 6-month lifestyle intervention program in obese children. Exp Clin Endocrinol Diabetes. 2011;119(4):238-42. [pmid: 21104587].
Eisenmann JC. Assessment of obese children and adolescents: a survey of pediatric obesity management programs. Pediatrics. 2011;128:S51-8. [pmid: 21885645].
Elmahgoub SS, Calders P, Lambers S, et al. The effect of combined exercise training in adolescents who are overweight or obese with intellectual disability: the role of training frequency. J Strength Cond Res. 2011;25(8):2274-82. [pmid: 21734606].
Epstein LH, Valoski A, Wing RR, et al. Ten-year outcomes of behavioral family-based treatment for childhood obesity. Health Psychol. 1994;13(5):373-83. [pmid: 7805631].
Epstein LH, Wing RR Koeske, et al. Effects of diet plus exercise on weight change in parents and children. J consult clin psychol. 1984;52(3):429-437. [pmid: 6747061].
Epstein LH, Wing RR Koeske, et al. Long-term effects of family-based treatment of childhood obesity. J consult clin psychol. 1987;55(1):91-95. [pmid: 3106445].
Epstein LH, Wing RR, Valoski A, et al. Stability of food preferences during weight control. A study with 8- to 12-year-old children and their parents. Behav Modif. 1987;11(1):87-101. [pmid: 3508378].
Epstein LH. Comparison of family-based behavior modification and nutrition education for childhood obesity. Journal of Pediatric Psychology. 1980;5(1):25-36. [pmid: 7452420].
Estabrooks PA, Shoup JA, Gattshall M, et al. Automated telephone counseling for parents of overweight children: a randomized controlled trial. Am J Prev Med. 2009;36(1):35-42. [pmid: 19095163].
Fagg J, Law C. Does scaling up a family-based community intervention for childhood overweight and obesity impact socio-economic inequalities in health?. Obes Facts. 2012;5:36-7.
Faith MS, Van Horn L, Appel LJ, et al. Evaluating parents and adult caregivers as “agents of change” for treating obese children: evidence for parent behavior change strategies and research gaps: a scientific statement from the American Heart Association. Circulation. 2012;125(9):1186-207. [pmid: 22271754].
Farpour-Lambert N, Maggio A, Martin X, et al. Effects of family-based behavioral therapy in group or in individual setting in pre-pubertal obese children: a randomized controlled trial. Obes Facts. 2012;5:221. [pmid: 22647304].
Fassihi M, Rudolf M, McElhone S, et al. Which factors predict unsuccessful outcome in a weight management intervention for obese children?. J Hum Nutr Diet. 2012;25(5):453-9. [pmid: 22515879].
Fitzgibbon ML, Stolley MR, Schiffer L Sharp, et al. Obesity Reduction Black Intervention Trial(ORBIT):18-month results. Obesity. 2010;18(12):2317-2325. [pmid: 20300081].
Fortune R, Love-Osborne K, Sheeder J. Use of text messaging as an adjunct to obesity prevention and treatment in school-based health clinics. J Adolesc Health. 2012;50(2):S33.
Fortune R, Love-Osborne K, Sheeder J. Use of text messaging as an adjunct to obesity prevention and treatment in school-based health clinics. J Adolesc Health. 2012;50(2):S33.
Foucart J, De Buck C, Verbanck P. Etude factorielle des composantes psychopathologiques de l'obesite severe chez l'adolescent. Factorial study of the psychopathological factors of morbid obesity in the adolescent. Encephale. 2012;38(4):310-7. [pmid: 22980472].
Fraser C, Lewis K, Manby M. Steps in the Right Direction, Against the Odds, an evaluation of a community based program aiming to reduce inactivity and improve health and morale in overweight and ovese school age children. Children and Society. 2012;26(2):124-37.
Fuller NR, Lau N, Denyer G, et al. A 12-week, randomised, controlled trial to examine the acceptability of the Korean diet and its effectiveness on weight, blood pressure, metabolic parameters and disease control in an Australian overweight and obese population. Obes Rev. 2011;12:221-2.
Fullerton G, Tyler C, Johnston CA, et al. Quality of life in Mexican-American children following a weight management program. Obesity(Silver Spring Md.). 2007;15(11):2553-6.
Gajewska J, Ambroszkiewicz J, Chelchowska M, et al. Effect of lifestyle intervention on the level of carboxylated and undercarboxylated osteocalcin in obese children. Bone. 2011;48:S249.
Galhardo J, Hunt LP, Lightman SL, et al. Normalizing eating behavior reduces body weight and improves gastrointestinal hormonal secretion in obese adolescents. J Clin Endocrinol Metab. 2012;97(2):E193-201. [pmid: 22162463].
Gerards SM, Dagnelie PC, Jansen MW, et al. Lifestyle Triple P: a parenting intervention for childhood obesity. BMC Public Health. 2012;12(1):267. [pmid: 22471971].
Goldfield GS, Kenny GP, Hadjiyannakis S, et al. Video game playing is independently associated with blood pressure and lipids in overweight and obese adolescents. PLoS One. 2011;6(11):e26643. [pmid: 22069461].
Goldfield GS. Making access to TV contingent on physical activity: effects on liking and relative reinforcing value of TV and physical activity in overweight and obese children. J Behav Med. 2012;35(1):1-7. [pmid: 21344320].
Goldschmidt AB, Stein RI, Saelens BE, et al. Importance of early weight change in a pediatric weight management trial. Pediatrics. 2011;128(1):e33-9. [pmid: 21690118].
Golley RK, Burrows T, Khambalia A, et al. What is the quality of dietary intake methodology and reporting in intervention studies on child and adolescent obesity management? A systematic review. Obes Res Clin Pract. 2011;5:S74.
Golley RK, Magarey AM, Daniels LA. Children's food and activity patterns following a six-month child weight management program. Int J Pediatr Obes. 2011;6(5-6):409-14. [pmid: 21838569].
Grey M, Berry D, Davidson M, et al. Preliminary testing of a program to prevent type 2 diabetes among high-risk youth. J Sch Health. 2004;74(1):10-5. [pmid: 15022370].
Grey M, Jaser SS, Holl MG, et al. A multifaceted school-based intervention to reduce risk for type 2 diabetes in at-risk youth. Prev Med. 2009;49(2-3):122-8. [pmid: 19643125].
Gronbaek HN, Madsen SA, Michaelsen KF. Family involvement in the treatment of childhood obesity: The Copenhagen approach. Eur J Pediatr. 2009;168(12):1437-1447. [pmid: 19234719].
Grulich-Henn J, Lichtenstein S, Horster F, et al. Moderate weight reduction in an outpatient obesity intervention program significantly reduces insulin resistance and risk factors for cardiovascular disease in severely obese adolescents. Intl J Endocrinol. 2011;2011:541021.
Gueugnon C, Mougin F, Simon-Rigaud ML, et al. Effects of an in-patient treatment program based on regular exercise and a balanced diet on high molecular weight adiponectin, resistin levels, and insulin resistance in adolescents with severe obesity. Appl Physiol Nutr Metab. 2012;37(4):672-9. [pmid: 22574715].
Guzman A, Irby MB, Pulgar C, et al. Adapting a tertiary-care pediatric weight management clinic to better reach Spanish-speaking families. J Immigr Minor Health. 2012;14(3):512-5. [pmid: 21909984].
Handelman GJ, Lee AJ, Gellar L, et al. Community-based diet and exercise program for overweight and insulin-resistant youth. Diabetes. 2011;60:A330.
Hardy OT, Wiecha J, Kim A, et al. Effects of a multicomponent wellness intervention on dyslipidemia among overweight adolescents. J Pediatr Endocrinol Metab. 2012;25(1-2):79-82. [pmid: 22570954].
Hare ME, Coday M, Williams NA, et al. Methods and baseline characteristics of a randomized trial treating early childhood obesity: The Positive Lifestyles for Active Youngsters (Team PLAY) trial. Contemp Clin Trials. 2012;33(3):534-49. [pmid: 22342450].
Hasson RE, Adam TC, Davis JN, et al. Randomized controlled trial to improve adiposity, inflammation, and insulin resistance in obese African-American and Latino youth. Obesity. 2012;20(4):811-8. [pmid: 21293446].
He YF, Wang WY, Fu P, et al. Effects of a comprehensive intervention program on simple obesity of children in kindergarten. Zhonghua Er Ke Za Zhi. 2004;42(5):333-6. [pmid: 15189687].
Heideman WH, Nierkens V, Stronks K, et al. DiAlert: a lifestyle education programme aimed at people with a positive family history of type 2 diabetes and overweight, study protocol of a randomised controlled trial. BMC Public Health. 2011;11:751. [pmid: 21961949].
Ho M, Dunkley ML, Garnett SP, et al. Acceptability of structured meal plan in adolescents with insulin resistance: RESIST study. Obes Res Clin Pract. 2011;5:S29-30.
Hobkirk JP, King RF, Gately P, et al. Longitudinal factor analysis reveals a distinct clustering of cardiometabolic improvements during intensive, short-term dietary and exercise intervention in obese children and adolescents. Metab Syndr Relat Disord. 2012;10(1):20-5. [pmid: 21936669].
Hoeger K, Davidson K, Kochman L, et al. The impact of metformin oral contraceptives and lifestyle modification on polycystic ovary syndrome in obese adolescent women in two randomized placebo-controlled clinical trials. J Clin Endocrinol Metab. 2008;93(11):4299-306. [pmid: 18728175].
Hollingworth W, Hawkins J, Lawlor DA, et al. Economic evaluation of lifestyle interventions to treat overweight or obesity in children. Int J Obes. 2012;36(4):559-66.
Hruby A, Chomitz V, Arsenault LN, et al. School-based fitness: impact on remission of overweight/obesity in urban children. Obesity. 2011;19:S70.
Huang F, Del-Rio-Navarro B, Perez-Ontivero J, et al. Effect of weight loss induced by 6-month lifestyle intervention on adipokines in obese adolescents. Ann Nutr Metab. 2011;58:306-7.
Huang JS, Gottschalk M, Norman GJ, et al. Compliance with behavioral guidelines for diet physical activity and sedentary behaviors is related to insulin resistance among overweight and obese youth. BMC Res Notes. 2011;4(1):29. [pmid: 21281521].
Hunter HL, Steele RG, Steele MM. Family-based treatment for pediatric overweight: Parental weight loss as a predictor of children's treatment success. Child Health Care. 2008;37(2):112-125.
Hustyi KM, Normand MP, Larson TA. Behavioral assessment of physical activity in obese preschool children. J Appl Behav Anal. 2011;44(3):635-9. [pmid: 21941396].
Intense diet behavior and physical activity intervention effective for obese children. J Fam Pract. 2005;54(7):579.
Israel AC, Solotar LC, Zimand E. An investigation of two parental involvement roles in the treatment of obese children. Int J Eating Disord. 1990;9(5):557-564.
Izadpanah A, Barnard RJ, Almeda AJ, et al. A short term diet and exercise intervention ameliorates inflammation and markers of metabolichealth in overweight/obese children. Am J Physiol Endocrinol Metab. 2012;303(4):E542-50. [pmid: 22713506].
Jacobson D, Melnyk BM. A primary care healthy choices intervention program for overweight and obese school-age children and their parents. J Pediatr Health Care. 2012;26(2):126-138. [pmid: 22360932].
Jacobson D, Melnyk BM. Psychosocial correlates of healthy beliefs, choices, and behaviors in overweight and obese school-age children: a primary care healthy choices interbention pilot study. J Pediatr Nurs. 2011;26(5):456-64. [pmid: 21930032].
Janicke DM, Gray WN, Mathews AE, et al. A pilot study examining a group-based behavioral family intervention for obese children enrolled in Medicaid: differential outcomes by race. Child Health Care. 2011;40(3):212-31.
Janicke DM, Sallinen BJ, Perri MG, et al. Comparison of parent-only vs family-based interventions for overweight children in underserved rural settings: outcomes from project STORY. Arch Pediatr Adolesc Med. 2008;162(12):1119-25. [pmid: 19047538].
Jelalian E, Sato A, Hadley W, et al. Parental involvement in adolescent weight control: preliminary findings. Obesity. 2011;19:S106.
Jelalian E, Sato A, Hart CN. The effect of group based weight-control intervention on adolescent psychosocial outcomes: Percieved peer rejection, social anxiety, and self-concept. Child Health Care. 2011;40(3):197-211. [pmid: 23258948].
Jensen CD, Aylward BS, Steele RG. Predictors of attendance in a practical clinicl trial of two pediatric weight management interventions. Obesity. 2012. [Epub ahead of print].
Jensen CD, Steele RG. Longitudinal associations between teasing and health-related quality of life among treatment-seeking overweight and obese youth. J Pediatr Psychol. 2012;37(4):438-47. [pmid: 22262915].
Jensen ME, Collins CE, Gibson PG, et al. Dietary induced weight loss improves asthma control and lung function after 10 weeks in obese children and adolescents with asthma. Australas Med J. 2011;4(12):711.
John R. Effects of parent-focused media interventions on body mass index waist size self-perception family eating habits and family activity habits in overweight Hispanic children. Teachers College, Columbia University. 2009;(70).
Johnston CA, Palcic J, George CS, et al. Weight change among Mexican American students involved in an intensive intervention to prevent and treat obesity: 5-year results. Obesity. 2011;19:S111-2.
Johnston CA, Tyler C, Fullerton G, et al. P. Effects of a school-based weight maintenance program for Mexican-American children: results at 2 years. Obesity(Silver Spring). 2010;18(3):542-7. [pmid: 19661957].
Junnila R, Aromaa M, Heinonen OJ, et al. The Weighty Matter intervention: a family-centered way to tackle an overweight childhood. J Community Health Nurs. 2012;29(1):39-52. [pmid: 22313184].
Parents are satisfied with telemedicine care for their child's obesity. Res Activities. 2011;(375):10-1.
Kalavainen M, Utriainen P, Vanninen E, et al. Impact of childhood obesity treatment on body composition and metabolic profile. World J Pediatrics. 2012;8(1):31-7.
Kelishadi R, Malekahmadi M, Hashemipour M, et al. Can a trial of motivational lifestyle counseling be effective for controlling childhood obesity and the associated cardiometabolic risk factors?. Pediatr Neonatol. 2012;53(2):90-7. [pmid: 22503255].
Kesman RL, Ebbert JO, Harris KI, et al. Portion control for the treatment of obesity in the primary care setting. BMC Res Notes. 2011;4(1):346. [pmid: 21906302].
King MA, Nkoy F, Halbern S, et al. Identification and management of overweight and obese pediatric patients hospitalized in an academic hospital. J Invest Med. 2011;59(1):150.
Kirk S, Brehm B, Saelens BE, et al. Role of carbohydrate modification in weight management among ovese children: a randomized trial. J Pediatr. 2012;161(2):320-7. [pmid: 22381024].
Kirschenbaum DS, Germann JN, Rich BH. Treatment of morbid obesity in low-income adolescents: effects of parental self-monitoring. Obes Res. 2005;13(9):1527-9. [pmid: 16222054].
Kolsgaard ML, Joner G, Brunborg C, et al. Reduction in BMI z-score and improvement in cardiometabolic risk factors in obese children and adolescents. The Oslo Adiposity Intervention Study. a hospital/public health nurse combined treatment. BMC Pediatr. 2011;11:47. [pmid: 21619652].
Kong AS, Sussman A, Yahne C, et al. Feasibility study of a school-based health center intervention to decrease metabolic syndrome risks in overweight/obese teens. J Diabetes. 2011;3:82-3. [pmid: 21143428].
Korsten-Reck U, Bauer S, Keul J. Sports and nutrition--an out-patient program for adipose children(long-term experience). Int J Sports Med. 1994;15(5):242-8. [pmid: 7960318].
Kotb NA, Gaber R, Salama M, et al. Clinical and biochemical predictors of increased carotid intima-media thickness in overweight and obese adolescents with type 2 diabetes. Diab Vasc Dis Res. 2012;9(1):35-41. [pmid: 21985955].
Kovacs VA, Fajcsak Z, Gabor A, et al. School-based exercise program improves fitness body composition and cardiovascular risk profile in overweight/obese children. Acta Physiol Hung. 2009;96(3):337-47. [pmid: 19706375].
Krzystek-Korpacka M, Patryn E, Kustrzeba-Wojcicka I, et al. The effect of a one-year weight reduction program on serum uric acid in overweight/obese children and adolescents. Clin Chem Lab Med. 2011;49(5):915-21. [pmid: 21288171].
Lansky D, Vance MA. School-based intervention for adolescent obesity: Analysis of treatment randomly selected control and self-selected control subjects. J consult clin psychol. 1983;51(1):147-148. [pmid: 6826860].
Lau N, Fuller N, Conigrave A, et al. The effects of weight loss arising from a diet and exercise program on fasting serum levels of adiponectin, total ghrelin, glucagon-like-peptide 1, insulin and leptin in overweight and obese subjects. Obes Facts. 2012;5:130.
Laurent JS. How parents promote health for their overweight or obese child. Obesity. 2011;19:S134.
Lazzer S, Lafortuna CL, Agosti F, et al. Effects of exercise intensity on body composition and lipid oxidation in obese adolescents. Obes Rev. 2011;12:132.
Lewis JA, Hayman LL. Toward evidence based practice: Parent diet modification, child activity or both in obese children: an rct. MCN Am J Matern Child Nurs. 2012;37(1):69.
Li L, Wang ZY. Clinical therapeutic effects of body acupuncture and ear acupuncture on juvenile simple obesity and effects on metabolism of blood lipids. Zhongguo Zhen Jiu. 2006;26(3):173-6. [pmid: 16570435].
Lindsley K, Milone C, Aikens AC, et al. Perception changes towards eating among mothers and children after a three-phase family intervention. Obesity. 2011;19:S120.
Lison JF, Real-Montes JM, Torro I, et al. Exercise intervention in childhood obesity: a randomized controlled trial comparing hospital versus home based groups. Acad Pediatr. 2012;12(4):319-25. [pmid: 22634075].
Lopez-Alarcon M, Martinez-Coronado A, Velarde-Castro O, et al. Supplementation of n3 long-chain polyunsaturated fatty acid synergistically decreases insulin resistance with weight loss of obese prepubertal and pubertal children. Arch Med Res. 2011;42(6):502-8. [pmid: 22136960].
Maddison RNi, Mhurchu C, Foley L, et al. Screen-time Weight-loss Intervention Targeting Children at Home(SWITCH): A randomized controlled trial study protocol. BMC Public Health. 2011;11(1):524. [pmid: 21718543].
Maggio ABR, Aggoun Y, Martin XE, et al. Long-term follow-up of cardiovascular risk factors after exercise training in obese children. Int J Pediatr Obes. 2011;6(2 -2):e603-10. [pmid: 21142752].
Magnusson MB, Kjellgren KI, Winkvist A. Enabling overweight children to improve their food and exercise habits - school nurses' counselling in multilingual settings. J Clin Nurs. 2012;21(17-18):2452-60. [pmid: 22686241].
Makkes S, Halberstadt J, Renders CM, et al. Cost-effectiveness of intensive inpatient treatments for severely obese children and adolescents in the Netherlands; a randomized controlled trial(HELIOS). BMC Public Health. 2011;11(1):518. [pmid: 21718471].
Makkes S, Halberstadt J, Renders CM, et al. Health effects of lifestyle interventions in obese children and adolescents study (Helios) - a randomised controlled trial. Obes Rev. 2011;12:58.
Makkes S, Renders C, Bosmans J, et al. High prevalance of cardiovascular risk factors in severely obese children and adolescents in the Netherland, participating in helios (health effects of lifestyle intervention in severely obese children and adolescents study). Obes Facts. 2012;5:101.
Mallows RJ, Walkley J, Taylor LS, et al. Exercise leader led healthy lifestyle intervention for overweight and obese adolescents: 12-Month evaluation of a cognitive behaviour therapy based program. Obes Res Clin Pract. 2011;5:S25.
Manes RL. Health conceptions among overweight and obese adolescents. Obesity. 2011;19:S109.
Marques M, Moleres A, Rendo-Urteaga T, et al. Design of the nutritional therapy for overweight and obese Spanish adolescents conducted by registered dieticians: the EVASYON study. Nutr Hosp. 2012;27(1):165-76. [pmid: 22566317].
Martins DL, Branco AI, Fernandes JL, et al. Estudo expo 2010: Excesso de Peso e Obesidade Infantil. Study expo 2010: Overweight and obesity in childhood. Acta Med Port. 2011;24(6):871-6. [pmid: 22713179].
Mazzeo SE, Kelly NR, Thornton L, et al. Parent skills training to enhance weight loss in overweight children: evaluation of NOURISH. Obesity. 2011;19:S106.
Miller WM, Goslin B, Veri S, et al. Baseline dietary intake is associated with childhood obesity treatment outcomes. Obesity. 2011;19:S110.
Mockus DS, MacEra CA, Wingard DL, et al. Dietary self-monitoring and its impact on weight loss in overweight children. Int J Pediatr Obes. 2011;6(3-4):197-205. [pmid: 21722068].
Moens E, Braet C, Van Winckel M. An 8-year follow-up of treated obese children: children's process and parental predictors of successful outcome. Behav Res Ther. 2010;48(7):626-33. [pmid: 20398894].
Moleres A, Campion J, Milagro F, et al. Epigenetic biomarkers for weight loss response after a lifestyle intervention in overweight/obese Spanish adolescents: The Evasyon study. Obes Facts. 2012;5:173.
Montero D, Walther G, Perez-Martin A, et al. Endothelial dysfunction, inflammation, and oxidative stress in obese children and adolescents: markers and effect of lifestyle intervention. Obes Rev. 2011;13(5):441-55. [pmid: 22133012].
Moon YI, Park HR, Koo HY, et al. Effects of behavior modification on body image depression and body fat in obese Korean elementary school children. Yonsei Med J. 2004;45(1):61-67. [pmid: 15004870].
Moreles A, Rendo T, Campoy C, et al. Influence of eight obesity-related snps with body mass index and weight loss in spanish adolescents after a lifestyle intervention. Obes Rev. 2011;12:43-4.
Motykova E, Zlatohlavek L, Prusikova M, et al. Lifestyle modification induced weight loss and changes of cardiometabolic risk factors including lowering of inflammatory response in obese children. Neuro Endocrinol Lett. 2011;32(Suppl 2):55-9. [pmid: 22101884].
Nguyen B, Shrewsbury V, O'Connor J, et al. Two-year outcomes of an extended adolescent weight-loss maintenance intervention involving novel additional therapeutic contact: The Loozit(registered trademark)R randomised controlled trial. Obes Facts. 2012;5:188-9.
Nguyen B, Shrewsbury VA, O'Connor J, et al. Community-based adolescent weight management with additional therapeutic contact: twelve month outcomes of the Loozit(registered trademark) RCT. Obes Rev. 2011;12:278-9.
Nguyen B, Shrewsbury VA, O'Connor J, et al. Twelve-month outcomes of the loozit randomized controlled trial: a community-based healthy lifestyle program for overweight and obese adolescents. Arch Pediatr Adolesc Med. 2012;166(2):170-7. [pmid: 22312175].
Nguyen B, Shrewsbury VA, O'Connor J, et al. Two-year outcomes of an adjunctive telephone coaching and electronic contact intervention for adolescent weight-loss maintenance: the Loozit randomized controlled trial. Int J Obes. 2012. [Epub ahead of print].
Ning Y, Yang S, Evans R, et al. Determinants of weight loss among obese children enrolled in a multidisciplinary weight management program. Diabetes. 2011;60:A330-1.
Nourian M, Yassin Z, Kelishadi R. Impact of a nutrition education intervention on weight loss in obese adolescents with metabolic syndrome. Cardiovasc Res. 2012;93:S117.
Nuutinen O, Knip M. Long-term weight control in obese children: persistence of treatment outcome and metabolic changes. Int J Obes Relat Metab Disord. 1992;16(4):279-87. [pmid: 1318282].
Oliveira A, Albuquerque C, Cunha M, et al. Physical activity in obese adolescent Portuguese. Obes Rev. 2011;12:256.
O'Neil ME. The Kids Fitness Program: community-based intervention for children who are overweight. Pediatric Physical Therapy. 2006;18(1):101-102.
Pal S, Khossousi A, Binns C, et al. The effects of 12-week psyllium fibre supplementation or healthy diet on blood pressure and arterial stiffness in overweight and obese individuals. Br J Nutr. 2012;107(5):725-34. [pmid: 21787454].
Panagiotopoulos C, Ronsley R, Al-Dubayee M, et al. The Centre for Healthy Weights-Shapedown BC: a family-centered, multidisciplinary program that reduces weight gain in obese children over the short-term. Int J Environ Res Public Health. 2011;8(12):4662-78. [pmid: 22408595].
Parra-Medina D, Mojica CM, Parma DL, et al. Preliminary results from an obesity management intervention in a rural pediatric practice: the NEST study. Obesity. 2011;19:S110.
Pathmasiri W, Pratt KJ, Collier DN, et al. Integrating metabolomic signatures and psychosocial parameters in responsivity to an immersion treatment model for adolescent obesity. 2012:1-15.
Pedrosa C, Oliveira BMPM, Albuquerque I, et al. Markers of metabolic syndrome in obese children before and after 1-year lifestyle intervention program. Eur J Nutr. 2011;50(6):391-400. [pmid: 21107585].
Pittson H, Wallace L. Using intervention mapping to develop a family-based childhood weight management programme. J Health Serv Res Policy. 2011;16(1Suppl):2-7. [pmid: 21460343].
Pittson H, Wallace L. Weight management programme for children. J Prim Health Care. 2010;20(5):16-21.
Plotnikoff R, Lubans D, Costigan S, et al. A test of the theory of planned behavior to predict physical activity in an overweight/obese population sample of adolescents (Alberta, Canada). J Sci Med Sport. 2011;14:e52.
Pretlow R. Addiction to highly pleasurable foods as a cause of the childhood obesity epidemic. Obesity. 2011;19:S135-6.
Preud'Homme D, Higginbotto L, Pettry A, et al. Chewing sugar-free gum (SFG) decreases non-nutritive snacking in a population of obese children. Obesity. 2011;19:S119.
Ranstrom BB. Taking Steps Together: a family centered lifestyle education and behavioral modification program for overweight and obese children and their families. North Dakota State University. 2009.
Ray R, Lim LH, Ling SL. Obesity in preschool children: an intervention programme in primary health care in Singapore. Ann Acad Med Singapore. 1994;23(3):335-41. [pmid: 7944246].
Reinehr T, Kersting M, Wollenhaupt A, et al. Evaluation of the training program “OBELDICKS” for obese children and adolescents. Klin Padiatr. 2005;217(1):1-8. [pmid: 15640963].
Reinehr T, Kersting M, Wollenhaupt A, et al. Evaluation of the training program “OBELDICKS” for obese children and adolescents. Evaluation der schulung “OBELDICKS” fur adipose kinder und jugendliche. Klin Padiatr. 2005;217(1):1-8. [pmid: 15640963].
Reinehr T, Schaefer A, Winkel K, et al. Development and evaluation of the lifestyle intervention ‘Obeldicks light’ for overweight children and adolescents. J Public Health. 2011;19(4):377-84.
Reinehr T, Widhalm K, l'Allemand D, et al. W. Two-year follow-up in 21784 overweight children and adolescents with lifestyle intervention. Obesity(Silver Spring). 2009;17(6):1196-9. [pmid: 19584877].
Resende C, Vieira M, Monteiro J. Body composition change after re-education in portioning food servings among obese boys and girls. Ann Nutr Metab. 2011;58:187.
Rhoades DR, Al-Oballi Kridli S, Penprase B. Understanding overweight adolescents' beliefs using the theory of planned behaviour. Int J Nurs Pract. 2011;17(6):562-570. [pmid: 22103822].
Rice J, Thombs D, Leach R, et al. Successes and barriers for a youth weight-management program. Clin Pediatr(Phila). 2008;47(2):143-7. [pmid: 17766579].
Rodearmel SJ, Wyatt HR, Stroebele N. Small changes in dietary sugar and physical activity as an approach to preventing excessive weight gain: the America on the Move family study. Pediatrics. 2007;120(4):e869-79. [pmid: 17908743].
Rodriguez VM, Perales A, Diez-Lopez I, et al. Childhood obesity and metabolic syndrome: effectiveness of a group intervention program addressed to children and their parents. Obes Facts. 2012;5:191.
Rooney BL, Gritt LR, Havens SJ, et al. Growing healthy families: family use of pedometers to increase physical activity and slow the rate of obesity. WMJ. 2005;104(5):54-60. [pmid: 16138517].
Ruest Haarmark Nielsen T, Gamborg M, Fonvig CE, et al. Changes in lipidemia during chronic care treatment of childhood obesity. Obes Facts. 2012;5:218.
Russell L, Huang RC, Curran J, et al. Multidisciplinary obesity clinic for children-short and long term improvements in BMI z scores. Obes Res Clin Pract. 2011;5:S22-3.
Ryder J, Ortega R, Konopken Y, et al. Effects of a lifestyle intervention on cardiometabolic risk factors in overweight/obese latino adolescents. Diabetes. 2011;60:A331.
Rynders C, Weltman A, Delgiorno C, et al. Lifestyle intervention improves fitness independent of metformin in obese adolescents. Med Sci Sports Exerc. 2012;44(5):786-92. [pmid: 22015710].
Sabin MA, Ford A, Hunt L, et al. Which factors are associated with a successful outcome in a weight management programme for obese children?. J Eval Clin Pract. 2007;13(3):364-368. [pmid: 17518800].
Sallinen BJ, Carr D, Woolford SJ. Community-university collaboration: psychosocial factors associated with attrition from pediatric obesity treatment program. Obesity. 2011;19:S106.
Santomauro M, Paoli-Valeri M, Fernandez M, et al. Non-alcoholic fatty liver disease and its association with clinical and biochemical variables in obese children and adolescents: effect of a one-year intervention on lifestyle. Endocrinol Nutr. 2012;59(6):346-53. [pmid: 22717644].
Sartorio A, Rigamonti A, De Col A, et al. Changes in plasma levels of ghrelin, leptin and other hormone and metabolic parameters following standardized breakfast, lunch and physical exercise before and after a multidisciplinary weight-reduction programme in obese adolescents. Obes Rev. 2011;12:142. [pmid: 20158617].
Schaefer A, Winkel K, Finne E, et al. An effective lifestyle intervention in overweight children: One-year follow-up after the randomized controlled trial on “Obeldicks light”. Clin Nutr. 2011.
Schau B, Bielfeldt M. Non-healthy food of higher psychosocial value than healthy nutrition? Insights from a European study on overweight children and teenagers. Diabetologia. 2011;54:S385.
Schiel R, Kaps A, Bieber G. Electronic health technology for the assessment of physical activity and eating habits in children and adolescents with overweight and obesity IDA. Appetite. 2012;58(2):432-7. [pmid: 22155072].
Schreiner B. Promoting lifestyle and behavior change in overweight children and adolescents with type 2 diabetes. Diabetes Spectr. 2005;18(1):9-12.
Seltzer CC, Mayer J. An effective weight control program in a public school system. Am J Public Health Nations Health. 1970;60(4):679-89. [pmid: 5461722].
Shai I. The effect of low-carb, mediterranean and low-fat diets on renal function; a 2-year dietary intervention randomized controlled trial (direct). Obes Facts. 2012;5:19.
Shaibi GQ, Davis JN, Weigensberg MJ, et al. Improving insulin resistance in obese youth: choose your measures wisely. Int J Pediatr Obes. 2011;6(2-2):e290-6. [pmid: 21070095].
Shaibi GQ, Greenwood-Ericksen MB, Chapman CR, et al. Development Implementation and Effects of Community-Based Diabetes Prevention Program for Obese Latino Youth. J Prim Care Community Health. 2010;1(3):206-212. [pmid: 21461141].
Shaibi GQ, Konopken Y, Hoppin E, et al. Effects of a culturally grounded community-based diabetes prevention program for obese Latino adolescents. Diabetes Educ. 2012;38(4):504-12. [pmid: 22585870].
Shaw M, Savoye M, Cali A, et al. Effect of a successful intensive lifestyle program on insulin sensitivity and glucose tolerance in obese youth. Diabetes Care. 2009;32(1):45-7. [pmid: 18840769].
Skow A, Black J, Falconer C, et al. Development of an electronic tool to estimate health risks and provide personalised weight management advice for overweight and obese children in the United Kingdom. Obes Facts. 2012;5:205-206.
Smith K, Straker L, Kerr D, et al. The beginnings of CAFAP - A family centred, multi-disciplinary program for overweight and obese adolescents, and their families. Obes Res Clin Pract. 2011;5:S23.
Sonneville KR, Calzo JP, Horton NJ, et al. Body satisfaction, weight gain and binge eating among overweight adolescent girls. Int J Obes. 2012;36(7):944-9.
Sonneville KR, Rifas-Shiman SL, Kleinman KP, et al. Associations of obesogenic behaviors in mothers and obese children participating in a randomized trial. Obesity (Silver Spring). 2012;20(7):1449-54. [pmid: 22349735].
Soo KL, Wan Abdul M, Abdul Manaf H, et al. Dietary practices among overweight and obese Chinese children in kota bharu, Kelantan. Malays J Nutr. 2011;17(1):87-95. [pmid: 22135868].
Sothern MS, Loftin JM, Udall JN, et al. Safety feasibility and efficacy of a resistance training program in preadolescent obese children. Am J Med Sci. 2000;319(6):370-375. [pmid: 10875292].
Stark LJ, Spear S, Boles R, et al. A pilot randomized controlled trial of a clinic and home-based behavioral intervention to decrease obesity in preschoolers. Obesity (Silver Spring). 2011;19(1):134-41. [pmid: 20395948].
Steele MM, Steele RG, Cushing CC. Weighing the pros and cons in family-based pediatric obesity intervention: parent and child decisional balance as a predictor of child outcomes. Child Health Care. 2012;41(1):43-55.
Straker LM, Smith KL, Fenner AA, et al. Rationale, design and methods for a staggered-entry, waitlist controlled clinical trial of the impact of a community-based, family-centred, multidisciplinary program focussed on activity, food and attitude habits (Curtin University's Activity, Food and Attitudes Program-CAFAP) among overweight adolescents. BMC Public Health. 2012;12(1):471. [pmid: 22721261].
Sun MX, Huang XQ, Yan Y, et al. One-hour after-school exercise ameliorates central adiposity and lipids in overweight Chinese adolescents: a randomized controlled trial. Chin Med J. 2011;124(3):323-9. [pmid: 21362327].
Sweat V, Bruzzese JM, Albert S, et al. The Banishing Obesity and Diabetes in Youth (BODY) Project: description and feasibility of a program to halt obesity-associated disease among uran high school students. J Community Health. 2012;37(2):365-71. [pmid: 21826529].
Tamam S, Bellissimo N, Patel BP, et al. Overweight and obese boys reduce food intake in response to a glucose drink but fail to increase intake in response to exercise of short duration. Appl Physiol Nutr Metab. 2012;37(3):520-9. [pmid: 22530879].
Teder M, Morelius E, Bolme P, et al. Family-based behavioural intervention programme for obese children: a feasibility study. BMJ Open. 2012;2(2):e000268.
Theim KR, Sinton MM, Stein RI, et al. Preadolescents' and parents' dietary coping efficacy during behavioral family-based weight control treatment. J Youth Adolesc. 2012;41(1):86-97. [pmid: 22081241].
Toulabi T, Khosh Niyat Nikoo M, Amini F, et al. The influence of a behavior modification interventional program on body mass index in obese adolescents. J Formos Med Assoc. 2012;111(3):153-9. [pmid: 22423669].
Treuth MS, Hunter GR, Pichon C, et al. Fitness and energy expenditure after strength training in obese prepubertal girls. Med Sci Sports Exerc. 1998;30(7):1130-1136. [pmid: 9662684].
Trygg Lycke S, Bjurvald L. Exergaming - A new way of increasing physical activity level in obese adolecents?. Obes Facts. 2012;5:207.
Turner KM, Salisbury C, Shield JP. Parents' views and experiences of childhood obesity management in primary care: a qualitative study. Fam Pract. 2011;29(4):476-81. [pmid: 22117082].
Twiddy M, Wilson I, Bryant M, et al. Lessons learned from a family-focused weight management intervention for obese and overweight children. Public Health Nutr. [Epub ahead of print]. 2012:1-8. [pmid: 23294865].
Vajda I, Meszaros J, Meszaros Z, et al. Effects of 3 hours a week of physical activity on body fat and cardio-respiratory parameters in obese boys. Acta Physiol Hung. 2007;94(3):191-8. [pmid: 17853771].
Van Hoek E, Feskens E. Treating young obese children: a pilot study. Obes Facts. 2012;5:231-2.
Vanhelst J, Fardy PS, Mikulovic J, et al. Changes in obesity, cardiorespiratory fitness and habitual physical activity following a one-year intervention program in obese youth: a pilot study. J Sports Med Phys Fitness. 2011;51(4):670-5. [pmid: 22212271].
Vanhelst J, Mikulovic J, Hurdiel R, et al. L'impact d'un programme de prise en charge ambulatoire de l'obesite infantile sur les performances academiques, le sommeil et la composition corporelle. Effects of multidisciplinary program intervention in obese youth on academic performance, sleep, and body composition. Sci Sports. 2011;27(3):154-9.
Veldhuis L, Struijk MK, Kroeze W, et al. ‘Be active eat right’ evaluation of an overweight prevention protocol among 5-year-old children: Design of a cluster randomised controlled trial. BMC Public Health. 2009;9.
Vissers D, De Meulenaere A, Vanroy C, et al. Effect of a multidisciplinary school-based lifestyle intervention on body weight and metabolic variables in overweight and obese youth. e-SPEN. 2008;3(5):e196-e202.
Volkenant KR, Quinlan NP, Ubinger M, et al. Early childhood obesity intervention in primary care: parent stress levels and child mental health symptoms. Obesity. 2011;19:S108.
Vos RC, Huisman SD, Houdijk EC, et al. The effect of family-based multidisciplinary cognitive behavioral treatment on health-related quality of life in childhood obesity. Qual Life Res. 2011. [Epub ahead of print].
Vos RC, Pijl H, Wit JM, et al. The effect of multidisciplinary lifestyle intervention on the pre- and postprandial plasma gut peptide concentrations in children with obesity. ISRN Endocrinol. 2011;2011:353756. [pmid: 22363876].
Wake M, Baur LA, Gerner B, et al. Outcomes and costs of primary care surveillance and intervention for overweight or obese children: the LEAP 2 randomised controlled trial. BMJ. 2009;339:b3308. [pmid: 19729418].
Wake M, Gold L, McCallum Z, et al. Economic evaluation of a primary care trial to reduce weight gain in overweight/obese children: the LEAP trial. Ambul Pediatr. 2008;8(5):336-41. [pmid: 18922508].
Wake M, Lycett K, Sabin MA, et al. A shared-care model of obesity treatment for 3-10 year old children: protocol for the HopSCOTCH randomised controlled trial. BMC Pediatr. 2012;12(1):39. [pmid: 22455381].
Wald ER, Moyer SC, Eickhoff J, et al. Treating Childhood Obesity in Primary Care. Clin Pediatr(Phila). 2011.
Walpole B, Dettmer E, Morrongiello B, McCrindle B, Hamilton J. Motivational Interviewing as an intervention to increase adolescent self-efficacy and promote weight loss: Methodology and design. BMC Public Health. 2011;11(1):459. [pmid: 21663597].
Ward E, Straker L, Smith K, et al. Behaviour changes following a multidisciplinary intervention for overweight and obese adolescents. J Sci Med Sport. 2011;14:e42-3.
Watson PM, Dugdill L, Pickering K, et al. A whole family approach to childhood obesity management (GOALS): Relationship between adult and child BMI change. Ann Hum Biol. 2011;38(4):445-52. [pmid: 21682574].
Watson-Jarvis K, Johnston C, Clark C. Evaluation of a family educationa program for overweight children and adolescents. Can J Diet Pract Res. 2011;72(4):191-6. [pmid: 22146119].
Weaver CM, Campbell WW, Teegarden D, et al. Calcium, dairy products, and energy balance in overweight adolescents: a controlled trial. Am J Clin Nutr. 2011;94(5):1163-70. [pmid: 21918216].
Wengle JG, Hamilton JK, Manlhiot C, et al. The ‘Golden Keys’ to health - A healthy lifestyle intervention with randomized individual mentorship for overweight and obesity in adolescents. Pediatr Child Health. 2011;16(8):473-8.
West F, Sanders MR, Cleghorn GJ, et al. Randomised clinical trial of a family-based lifestyle intervention for childhood obesity involving parents as the exclusive agents of change. Behav Res Ther. 2010;48(12):1170-9. [pmid: 20883981].
White J, Jago R. Prospective associations between physical activity and obesity among adolescent girls: Racial differences and implications for prevention. Arch Pediatr Adolesc Med. 2012;166(6):522-7. [pmid: 22665029].
Wildes JE, Marcus MD, Kalarchian MA, Levine, et al. Self-reported binge eating in severe pediatric obesity: impact on weight change in a randomized controlled trial of family-based treatment. Int J Obes(Lond). 2010;34(7):1143-8. [pmid: 20157322].
Wile H, McIntyre L. Weight control counselling in children: is it effective?. J Can Diet Assoc. 1992;53(2):168-71. [pmid: 10119753].
Wong EM, Sit JW, Tarrant MA, et al. The perceptions of obese school children in Hong Kong toward their weight-loss experience. J Sch Nurs. 2012. [Epub ahead of print].
Yoshinaga M, Sameshima K, Miyata K, et al. Prevention of mildly overweight children from development of more overweight condition. Prev Med. 2004;38(2):172-174. [pmid: 14715208].
Yurt S, Save D, Yildiz A. The impact of the motivation interviews with the adolescents on eating habits, behaviours and weight. Obes Rev. 2011;12:243.
Zapatera B, Diaz LE, Gomez S, et al. Lipid profile in adolescents with overweight/obesity under a treatment programme. Preliminary results of the EVASYON study. Int J Obes. 2011;35:S168.
Ziv A, Shalom N, Lerner L, et al. Sustained effects of a summer camp program for overweight children. Obes Rev. 2011;12:194.
Zorba E, Cengiz T, Karacabey K. Exercise training improves body composition, blood lipid profile and serum insulin levels in obese children. J Sports Med Phys Fitness. 2011;51(4):664-9. [pmid: 22212270].

## Followup less than 1 year

Adkins S, Sherwood NE, Story M, et al. Physical activity among African-American girls: the role of parents and the home environment. Obes Res. 2004;12(Suppl):38S-45S. [pmid: 15489466].
Beauchamp MR, Rhodes RE, Hua S, et al. Testing the effects of an expectancy-based intervention among adolescents: Can placebos be used to enhance physical health?. Psychol Health Med. 2011;16(4):405-17. [pmid: 21749238].
Beech BM, Klesges RC, Kumanyika SK, et al. Child- and parent-targeted interventions: the Memphis GEMS pilot study. Ethn Dis. 2003;13(1 Suppl):S40-53. [pmid: 12713210].
Berry D, Colindres M, Sanchez-Lugo L, et al. Adapting, feasibility testing, and pilot testing a weight management intervention for recently immigrated spanish-speaking women and their 2- to 4-Year-old children. Hisp Health Care Int. 2011;9(4):186-93.
Bleich SN, Herring B, Flagg D, et al. Reduction in purchases of sugar-sweetened beverages among low income, black adolescents after exposure to caloric information. Obesity. 2011;19:S52-S53.
Briancon S, Bonsergent E, Agrinier N, Tessier, et al. Improving nutritional behaviours and knowledge in high school adolescents: The PRALIMAP overweight and obesity prevention trial. Can J Diabetes. 2011;35(2):180.
Bruening KS, Gilbride JA, Passannante MR, et al. Dietary intake and health outcomes among young children attending 2 urban day-care centers. J Am Diet Assoc. 1999;99(12):1529-35. [pmid: 10608946].
Burrows T, Morgan PJ, Lubans DR, et al. Dietary outcomes of the healthy dads healthy kids Randomised controlled Trial. J Pediatr Gastroenterol Nutr. 2012. [Epub ahead of print].
Byrd-Williams C, Hoelscher DM, Butte NF, et al. Behavioral outcomes following a pilot study to test the USA version of the mind, exercise, nutrition, do it! (MEND) program to low-income 7-14 year old obese children. Obesity. 2011;19:S107.
Chen JL, Weiss S, Heyman MB, et al. The efficacy of the web-based childhood obesity prevention program in chinese american adolescents (web abc study). J Adolesc Health. 2011.
Colchico K, Zybert P, Basch CE. Effects of after-school physical activity on fitness fatness and cognitive self-perceptions: A pilot study among urban minority adolescent girls. Am J Public Health. 2000;90(6):977-978. [pmid: 10846520].
Coleman KJ, Ocana LL, Walker C, et al. Outcomes from a culturally tailored diabetes prevention program in Hispanic families from a low-income school: Horton Hawks Stay Healthy(HHSH). Diabetes Educ. 2010;36(5):784-92. [pmid: 20651100].
Croker H, Lucas R, Wardle J. Cluster-randomised trial to evaluate the ‘Change for Life’ mass media/ social marketing campaign in the UK. BMC Public Health. 2012;12(1):404. [pmid: 22672587].
Dabboussi R. The food adventures workshop: A five week nutrition/food science intervention program provided to children 8-11 years old. J Pediatr Gastroenterol Nutr. 2011;52:E127.
Danford CA, Martyn KK, Schultz CM. Event history calendars: An innovation in tracking eating and activity behaviors and barriers with parent-child dyads. Obesity. 2011;19:S108.
Davis JN, Gyllenhammer L, Byrd-Williams C, et al. Moderate to vigorous physical activity (MVPA) reduces liver, subcutaneous, and visceral fat depots in overweight latino adolescents. Obesity. 2011;19:S52.
Davis JN, Ventura EE, Cook LT, et al. LA sprouts: A gardening, nutrition and cooking intervention for latino youth improves diet and attenuates weight gain. Am J Epidemiol. 2011;173:S114.
Davis JN, Ventura EE, Cook LT, et al. LA sprouts: a gardening, nutrition, and cooking intervention for Latino youth improves diet and reduces obesity. J Am Diet Assoc. 2011;111(8):1224-30. [pmid: 21802571].
Dias I, Maranhao P, Panazzolo D, et al. Effects of 3-month resistance exercise training on microvascular endothelial-dependent reactivity in obese adolescents. Obes Facts. 2012;5:220.
Doyle-Baker PK, Venner AA, Lyon ME, et al. Impact of a combined diet and progressive exercise intervention for overweight and obese children: the B.E. H.I.P. study. Appl Physiol Nutr Metab. 2011;36(4):515-25. [pmid: 21848443].
Eagle TF, Gurm R, Smith C, et al. Immediate impact of a 10-week middle school intervention to improve health behaviors and reduce cardiovascular risk factors-project healthy schools in michigan. J Am Coll Cardiol. 2012;59(13):E1797.
Ebbeling CB, Feldman HA, Osganian SK, et al. Effects of decreasing sugar-sweetened beverage consumption on body weight in adolescents: a randomized controlled pilot study. Pediatrics. 2006;117(3):673-80. [pmid: 16510646].
Echevarria M, Pacquiao DF. Outcomes of a culturally and linguistically appropriate nutrition and exercise family-school program. UPNAAI Nursing Journal. 2008;4(1):32-41.
Eliakim A, Nemet D, Balakirski Y, et al. The effects of nutritional-physical activity school-based intervention on fatness and fitness in preschool children. J Pediatr Endocrinol Metab. 2007;20(6):711-8. [pmid: 17663296].
Farshidfar F, Koleini N, Sadramely M. Is metformin effective to prevent weight gain associated with risperidone?. Eur Psychiatry. 2011;26:1713.
Flores R. Dance for health: Improving fitness in African American and Hispanic adolescents. Public Health Rep. 1995;110(2):189-193. [pmid: 7630998].
Foley JT, Beets, Cardinal BJ. Monitoring children's physical activity with pedometers: reactivity revisited. J Exerc Sci Fit. 2011;9(2):82-6.
Fortune R, Love-Osborne K, Sheeder J. Use of text messaging as an adjunct to obesity prevention and treatment in school-based health clinics. J Adolesc Health. 2012;50(2):S33.
Frenn M, Malin S, Brown RL, et al. Changing the tide: an Internet/video exercise and low-fat diet intervention with middle-school students. Appl Nurs Res. 2005;18(1):13-21. [pmid: 15812731].
de Groot JF, Takken T, Gooskens RH, Schoenmakers MA, Wubbels M, Vanhees L, Helders PJ. Reproducibility of maximal and submaximal exercise testing in “normal ambulatory” and “community ambulatory” children and adolescents with spina bifida: which is best for the evaluation and application of exercise training?. Phys Ther. 2011;91(2):267-6. [pmid: 21212378].
Gabel S, Radigan M, Wang R, et al. Health monitoring and promotion among youths with psychiatric disorders: Program development and initial findings. Psychiatr Serv. 2011;62(11):1331-7. [pmid: 22211213].
Gates M, Hanning RM, Isogai A, et al. A comprehensive school nutrition program improves knowledge and intentions for milk and alternatives intake among youth in Fort Albany First Nation (FN). Can J Diabetes. 2011;35(2):208.
Gatto NM, Ventura EE, Cook LT, et al. LA sprouts: A garden-based nutrition intervention impacts motivation and preferences for fruits and vegetables in latino youth. Am J Epidemiol. 2011;173:S114.
Geis C, Farris JW, Taylor L, et al. your VISION for the future of fitness.: A 12-week interdisciplinary intervention program for children who are obese. IDEA Fitness J: Cardiopulm Phys Ther J. 9. 2012;22(1.4):50-51. 12. 20.
Goldstein TR, Goldstein BI, Mantz MB, et al. A brief motivational intervention for preventing medication-associated weight gain among youth with bipolar disorder: Treatment development and case report. J Child Adolesc Psychopharmacol. 2011;21(3):275-80. [pmid: 21663430].
Hahn A, Postler J. Multifactorial intervention for weight loss. Obes Rev. 2011;12:278.
Haire-Joshu D, Nanney MS, Elliott M, et al. The use of mentoring programs to improve energy balance behaviors in high-risk children. Obesity(Silver Spring). 2010;18(1Suppl):S75-83. [pmid: 20107465].
Haisfield L, Fisher JO, Savage JS, et al. Influence of family-style meals on young children's self-selected portions and intake. Obesity. 2011;19:S66-7.
Hardy OT, Wiecha J, Kim A, et al. Effects of a multicomponent wellness intervention on dyslipidemia among overweight adolescents. J Pediatr Endocrinol Metab. 2012;25(1-2):79-82. [pmid: 22570954].
Harrell JS, McMurray RG, Bangdiwala SI, et al. Effects of a school-based intervention to reduce cardiovascular disease risk factors in elementary-school children: The Cardiovascular Health in Children(CHIC) study. J Pediatr. 1996;128(6):797-805. [pmid: 8648539].
Harrison M, Burns CF, McGuinness M, et al. Influence of a health education intervention on physical activity and screen time in primary school children: ‘Switch Off-Get Active’. J Sci Med Sport. 2006;9(5):388-394. [pmid: 16872900].
Hasson RE, Adam TC, Davis JN, et al. Randomized controlled trial to improve adiposity, inflammation, and insulin resistance in obese African-American and Latino youth. Obesity. 2012;20(4):811-18. [pmid: 21293446].
Hawthorne A, Shaibi G, Gance-Cleveland B, et al. Grand Canyon Trekkers: School-based lunchtime walking program. J Sch Nurs. 2011;27(1):43-50. [pmid: 21123848].
Hill DL, Faith MS, Wrotniak B, et al. Obesity prevention in pediatric primary care: Six-month results for the smart steps project. Obesity. 2011;19:S51.
Ho M, Dunkley ML, Garnett SP, et al. Acceptability of structured meal plan in adolescents with insulin resistance: RESIST study. Obes Res Clin Pract. 2011;5:S29-S30.
Hourigan SE, Schmidt K, Schmidt HJ, et al. Behavioral parent training to improve mealtime behavior and nutrition adherence in toddler and preschool children. Pediatr Pulmonol. 2011;46:411.
Huang F, Del-Rio-Navarro B, Perez-Ontivero J, et al. Effect of weight loss induced by 6-month lifestyle intervention on adipokines in obese adolescents. Ann Nutr Metab. 2011;58:306-7.
Huang SY, Hogg J, Zandieh S, et al. A ballroom dance classroom program promotes moderate to vigorous physical activity in elementary school children. Am J Health Promot. 2012;26(3):160-5. [pmid: 22208413].
Jones M, Luce KH, Osborne MI, et al. Randomized controlled trial of an internet-facilitated intervention for reducing binge eating and overweight in adolescents. Pediatrics. 2008;121(3):453-62. [pmid: 18310192].
Kargarfard M, Kelishadi R, Ziaee V, et al. The impact of an after-school physical activity program on health-related fitness of mother/daughter pairs: CASPIAN study. Prev Med. 2012;54(3-4):219-23. [pmid: 22289783].
Keller K, Forman J, Lee NM, et al. Use of licensed spokes-characters to increase intake of fruits and vegetables as part of a childhood obesity prevention program: Pilot study results. Obesity. 2011;19:S109.
Kipping RR, Payne C, Lawlor DA. Randomised controlled trial adapting US school obesity prevention to England. Arch Dis Child. 2008;93(6):469-473. [pmid: 18252756].
Kokanovic A, Mandic M, Banjari I. Impact of dietary intervention on cardiovascular risks in adolescents. Ann Nutr Metab. 2011;58:285-286.
Kong AS, Burks N, Conklin C, et al. A pilot walking school bus program to prevent obesity in hispanic elementary school children: Role of physician involvement with the school community. Clin Pediatr. 2010;49(10):989-991.
Kral TV, Moore RH, Berkowitz RI, et al. Willing to work for fruits and vegetables: Role of youth's obesity predisposition in a behavioral choice paradigm. Obesity. 2011;19:S104.
Kramer MK, Venditti EM, Kriska AM, et al. Evaluation of group lifestyle balance long-term maintenance strategies. Diabetes. 2011;60:A201.
Kubik MY, Story M, Davey C, et al. Providing obesity prevention counseling to children during a primary care clinic visit: results from a pilot study. J Am Diet Assoc. 2008;108(11):1902-6. [pmid: 18954581].
Lamberg EM, McKenna RF. Development of an after-school wellness club to promote physical activity and healthy lifestyle. Internet J Allied Health Sci Pract. 2011;9(1):10p.
Lansky D, Vance MA. School-based intervention for adolescent obesity: Analysis of treatment randomly selected control and self-selected control subjects. J consult clin psychol. 1983;51(1):147-148. [pmid: 6826860].
Leahey TM, Larose JG, Fava JL, et al. Social influences are associated with BMI and weight loss intentions in young adults. Obesity. 2011;19(6):1157-62. [pmid: 21164501].
Lee LL, Kuo YC, Fanaw Dil, et al. The effect of an intervention combining self-efficacy theory and pedometers on promoting physical activity among adolescents. J Clin Nurs. 2012;21(7/8):914-22. [pmid: 22082301].
Leonard CP, D'Augelli AR, Smiciklas-Wright H. Effects of a weight-control promotion program on parents' responses to family eating situations. J Am Diet Assoc. 1984;84(4):424-7. [pmid: 6707397].
Logue EE, Bourguet CC, Palmieri PA, et al. The better weight-better sleep study: a pilot intervention in primary care. Am J Health Behav. 2012;36(3):319-34. [pmid: 22370434].
Manley D. Self-efficacy physical activity and aerobic fitness in middle school children: examination of a pedometer intervention program. 2008.
Mcmurray RG, Harrell JS, Bangdiwala SI, et al. A school-based intervention can reduce body fat and blood pressure in young adolescents. J Adolesc Health. 2002;31(2):125-132. [pmid: 12127382].
Mendoza JA, Watson K, Baranowski T, et al. The walking school bus and children's physical activity: A pilot cluster randomized controlled trial. Pediatrics. 2011;128(3):e537-44. [pmid: 21859920].
Miller WM, Goslin B, Veri S, et al. Baseline dietary intake is associated with childhood obesity treatment outcomes. Obesity. 2011;19:S110.
Mitchell NG, Moore JB, Bibeau WS, et al. Cardiovascular fitness moderates the relations between estimates of obesity and physical self-perceptions in rural elementary school students. J Phys Act Health. 2012;9(2):288-94. [pmid: 22368227].
Moore JB, Pawloski LR, Goldberg P, Kyeung MO, Stoehr A, Baghi H. Childhood obesity study: a pilot study of the effect of the nutrition education program Color My Pyramid. J Sch Nurs. 2009;25(3):230-9. [pmid: 19363107].
Moreles A, Rendo T, Campoy C, et al. Influence of eight obesity-related snps with body mass index and weight loss in spanish adolescents after a lifestyle intervention. Obes Rev. 2011;12:43-4.
Mourao Carvalhal MIM, Fonseca S, De Castro Coelho EMRT. ELSa interventional portuguese health program to promote physical activity. Int J Pediatr Obes. 2011;6(Suppl2):39-41. [pmid: 21923295].
Nemet D, Geva D, Pantanowitz M, et al. Health promotion intervention in Arab-Israeli kindergarten children. J Pediatr Endocrinol Metab. 2011;24(11-12):1001-1007. [pmid: 22308855].
Neumark-Sztainer D, Story M, Hannan PJ, et al. New Moves: a school-based obesity prevention program for adolescent girls. Prev Med. 2003;37(1):41-51. [pmid: 12799128].
Nunez-Gaunaurd A, Kirk-Sanchez N. Health outcomes of an extracurricular family-based intervention for physical activity in three hispanic male children: a case series. HPA Resource. 2011;11(3):J2-9.
Paineau DL, Beaufils F, Boulier A, et al. Family dietary coaching to improve nutritional intakes and body weight control: a randomized controlled trial. Arch Pediatr Adolesc Med. 2008;162(1):34-43. [pmid: 18180410].
Patel BP, Bellissimo N, Thomas SG, et al. Television viewing at mealtime reduces caloric compensation in peripubertal, but not postpubertal, girls. Pediatr Res. 2011;70(5):513-7. [pmid: 21772226].
Perez-Gallardo L, Martinez JM, Rubiales C, et al. Assessment of the performance of PERSEO programme to prevent obesity in children through a pilot study in Soria. Obes Rev. 2011;12:76.
Perez-Lizaur AB, Melendez-Mier G, Rocha-Aguilar R, et al. Promotion of physical activity and adequate nutrition in children during the summer school holidays. Obes Rev. 2011;12:72.
Pittman DW, Parker JS, Getz BR, et al. Cost-free and sustainable incentive increases healthy eating decisions during elementary school lunch. Int J Obes. 2012;36(1):76-9.
Pompa Guajardo EG, Meza Pena C. Multidisciplinary program to reduce anxiety, depression and body mass index in obese children. Obes Facts. 2012;5:193-4.
Robinson TN, Killen JD, Kraemer HC, Wilson, et al. Dance and reducing television viewing to prevent weight gain in African-American girls: the Stanford GEMS pilot study. Ethn Dis. 2003;13(1Suppl):S65-77. [pmid: 12713212].
Rodearmel SJ, Wyatt HR, Barry MJ, et al. A family-based approach to preventing excessive weight gain. Obesity(Silver Spring). 2006;14(8):1392-401. [pmid: 16988082].
Rodearmel SJ, Wyatt HR, Stroebele N, et al. Small changes in dietary sugar and physical activity as an approach to preventing excessive weight gain: the America on the Move family study. Pediatrics. 2007;120(4):e869-79. [pmid: 17908743].
Romero AJ. A pilot test of the Latin active hip hop intervention to increase physical activity among low-income Mexican-American adolescents. Am J Health Promot. 2012;26(4):208-11. [pmid: 22375569].
Rooney BL, Gritt LR, Havens SJ, et al. Growing healthy families: family use of pedometers to increase physical activity and slow the rate of obesity. WMJ. 2005;104(5):54-60. [pmid: 16138517].
Rosenbaum M, Nonas C, Weil R, et al. School-based intervention acutely improves insulin sensitivity and decreases inflammatory markers and body fatness in junior high school students. J Clin Endocrinol Metab. 2007;92(2):504-8. [pmid: 17090635].
Rosenkranz RR, Behrens TK, Dzewaltowski DA. A group-randomized controlled trial for health promotion in Girl Scouts: healthier troops in a SNAP(Scouting Nutrition & Activity Program). BMC Public Health. 2010;10:81. [pmid: 20170502].
Shaibi GQ, Konopken Y, Hoppin E, et al. Effects of a culturally grounded community-based diabetes prevention program for obese Latino adolescents. Diabetes Educ. 2012;38(4):504-12. [pmid: 22585870].
Sharma S, Ru-Jye C, Hedberg AM. Pilot-testing catch early childhood: a preschool-based healthy nutrition and physical activity program. J Health Educ. 2011;42(1):12-23.
Skow A, Black J, Falconer C, et al. Development of an electronic tool to estimate health risks and provide personalised weight management advice for overweight and obese children in the United Kingdom. Obes Facts. 2012;5:205-6.
Slawta J. Be a fit kid: promoting healthful lifestyles in adolescents with special needs. American Journal of Recreation Therapy. 2006;5(1):7-17.
Smiciklas-Wright H, D'Augelli AR. Primary prevention for overweight: Preschool Eating Patterns (PEP) Program. J Am Diet Assoc. 1978;72(6):626-9. [pmid: 670616].
Souissi H, Chtourou H, Chaouachi A, et al. The Effect of training at a specific time-of-day on the diurnal variations of short-term exercise performances in 10- to 11-year-old boys. Pediatr Exerc Sci. 2012;24(1):84-99. [pmid: 22433267].
Staiano A, Abraham A, Calvert S. The Wii club: Promoting weight loss, psychosocial health, and sports involvement through an exergaming intervention for overweight and obese youth. J Adolesc Health. 2012;50(2):S9-S10.
Steele MM, Steele RG, Cushing CC. Weighing the pros and cons in family-based pediatric obesity intervention: Parent and child decisional balance as a predictor of child outcomes. Child Health Care. 2012;41(1):43-55.
Stephens MB, Wentz SW. Supplemental fitness activities and fitness in urban elementary school classrooms. Fam Med. 1998;30(3):220-3. [pmid: 9532446].
Stolley MR, Fitzgibbon ML. Effects of an obesity prevention program on the eating behavior of African American mothers and daughters. Health Educ Behav. 1997;24(2):152-64. [pmid: 9079575].
Straker L, Abbott R. Effect of screen-based media on energy expenditure and heart rate in 9- to 12-year-old children. Pediatr Exerc Sci. 2007;19(4):459-471. [pmid: 18089912].
Sun MX, Huang XQ, Yan Y, et al. One-hour after-school exercise ameliorates central adiposity and lipids in overweight Chinese adolescents: A randomized controlled trial. Chin Med J. 2011;124(3):323-9. [pmid: 21362327].
Sunami Y, Nguyen DMT, Kumahara H, et al. Effects of The physical activity during school physical education on daily physical activities among swiss elementary school children. Obes Facts. 2012;5:240.
Tabak RG, Tate DF, Stevens J, et al. Family ties to health program: a randomized intervention to improve vegetable intake in children. J Nutr Educ Behav. 2012;44(2):166-71. [pmid: 22154131].
Tabak RG, Tate DF, Stevens J, et al. Family ties to health study: A randomized intervention to improve vegetable intake in children. Obesity. 2011;19:S109.
Terwilliger SH. A study of children enrolled in a school-based physical activity program with attention to overweight and depression. 2008.
Tolfrey K, Campbell IG, Batterham AM. Exercise training induced alterations in prepubertal children's lipid-lipoprotein profile. Med Sci Sports Exerc. 1998;30(12):1684-92. [pmid: 9861600].
Vance DE, Wright MA, McKie PR, et al. Evaluating the impact of an interactive telephone technology and incentives when combined with a behavioral intervention for weight loss. Obesity. 2011;19:S115.
Wang R, Chen PJ, Chen WH. Diet and exercise improve neutrophil to lymphocyte ratio in overweight adolescents. Int J Sports Med. 2011;32(12):982-6. [pmid: 22131204].
Young K, Serrano V, Castillo F, et al. Healthy lifestyle intervention: Educating fifth and sixth grade students with the Health4Life program. J Invest Med. 2011;59(1):104.
Yurt S, Save D, Yildiz A. The impact of the motivation interviews with the adolescents on eating habits, behaviours and weight. Obes Rev. 2011;12:243.

## Study of adults only

Attalin V, Romain AJ, Avignon A. Physical-activity prescription for obesity management in primary care: Attitudes and practices of GPs in a southern French city. Diabetes Metab. 2012;38(3):243-9. [pmid: 22386835].
Basoor A, Cotant J, Patel K, et al. Obesity and st elevation myocardial infarction in young. Chest. 2011;140(4):984A.
Bateman LA, Slentz CA, Willis LH, et al. Comparison of aerobic versus resistance exercise training effects on metabolic syndrome (from the Studies of a Targeted Risk Reduction Intervention Through Defined Exercise - STRRIDE-AT/RT). Am J Cardiol. 2011;108(6):838-44. [pmid: 21741606].
Becker CB, McDaniel L, Bull S, et al. Can we reduce eating disorder risk factors in female college athletes? A randomized exploratory investigation of two peer-led interventions. Body Image. 2012;9(1):31-42. [pmid: 22019502].
Boehm G, Bracharz N, Schoberberger R. Evaluation of the sustainability of the Public Health Program “Slim without diet (Schlank ohne Diat)”. Wien Klin Wochenschr. 2011.
Burke LE, Conroy MB, Sereika SM, et al. The effect of electronic self-monitoring on weight loss and dietary intake: A randomized behavioral weight loss trial. Obesity. 2011;19(2):338-44. [pmid: 20847736].
Cabodi J, Kelsberg G, Safranek S. Clinical inquiry: does brief physician counseling promote weight loss?. J Fam Pract. 2011;60(9):548-50. [pmid: 21901183].
Campbell K, McNaughton S, Lioret S, et al. The Melbourne InFANT Program positively impacts very young children's lifestyle patterns. Obes Res Clin Pract. 2011;5:S4-5.
Conroy MB, Yang K, Elci OU, et al. Physical activity self-monitoring and weight loss: 6-month results of the SMART trial. Med Sci Sports Exerc. 2011;43(8):1568-74. [pmid: 21200337].
Damschoder LJ, Goodrich DE, Robinson CH, et al. A systematic exploration of differences in contextual factors related to implementing the MOVE! weight management program in VA: a mixed methods study. BMC Health Serv Res. 2011;11:248. [pmid: 21961925].
De Ridder DT, Ouwehand C, Stok FM, et al. Hot or not: Visceral influences on coping planning for weight loss attempts. Psychol Health. 2011;26(5):501-16. [pmid: 20936566].
Domingo MLJ, Gonzalez B, Crespo E, et al. Evaluation of a telemedicine system for heart failure patients: Feasibility acceptance rate satisfaction and changes in patient behavior. Results from the CARME(CAtalan Remote Management Evaluation) study. Eur J Cardiovasc Nurs. 2011.
Douris PC, Mcdonald B, Vespi F, et al. Comparison between Nintendo Wii fit aerobics and traditional aerobic exercice in sedentary young adults. J Strength Cond Res. 2012;26(4):1052-7. [pmid: 22446674].
Durward CM, Zack MK, Shlisky JD, et al. Predictors of early weight loss in a diet and exercise weight loss trial. FASEB J. 2011;25:774.13.
Espeland MA, Neiberg RH, Bray GA, et al. Patterns of weight changes over the first year of an intensive weight loss intervention are associated with longer term weight maintenance and changes in cardiovascular disease risk factors: Results from the action for health in diabetes (Look AHEAD). Diabetes. 2011;60:A516.
Fitzgibbon ML, Stolley MR, Schiffer L, et al. Obesity Reduction Black Intervention Trial(ORBIT):18-month results. Obesity. 2010;18(12):2317-2325. [pmid: 20300081].
Forster M, Veerman JL, Barendregt JJ, et al. Cost-effectiveness of diet and exercise interventions to reduce overweight and obesity. Int J Obes. 2011;35(8):1071-8.
Fortier MS, Hogg W, O'Sullivan TL, et al. Impact of integrating a physical activity counsellor into the Prim Health Care team: physical activity and health outcomes of the physical activity counselling randomized controlled trial. Appl Physiol Nutr Metab. 2011;36(4):503-14. [pmid: 21848444].
Fuller A, Razvi H, Denstedt JD, et al. The CROES Percutaneous Nephrolithotomy Global Study: the influence of Body Mass Index on outcome. J Urol. 2012;188(1):138-44. [pmid: 22591971].
Gabriel Kamensky G, Dlesk A, Murin J. The successful three-year educational campaign MOST as a powerful instrument for the implementation of the European guidelines on cardiovascular prevention in Slovakia. Eur J Cardiovasc Prev Rehabil. 2011;18(1):S8.
Giesen JC, Payne CR, Havermans RC, et al. Exploring how calorie information and taxes on high-calorie foods influence lunch decisions. The Am J Clin Nutr. 2011;93(4):689-94. [pmid: 21270376].
Grelaud A, Grolleau A, Demeaux JL, et al. Results of prisme, a french cohort pilot study investigating multidisciplinary care on the one-year improvement of metabolic syndrome. Pharmacoepidemiol Drug Saf. 2011;20:S290-1.
Hansen HS. Blood pressure and physical fitness in children: Odense schoolchild study. J. Hypertens. 1992;10(8):897.
Heideman WH, Nierkens V, Stronks K, et al. DiAlert: a lifestyle education programme aimed at people with a positive family history of type 2 diabetes and overweight, study protocol of a randomised controlled trial. BMC Public Health. 2011;11:751. [pmid: 21961949].
Hessler K, Siegrist M. Nurse practitioner attitudes and treatment practices for childhood overweight: How do rural and urban practitioners differ?. J Am Acad Nurse Pract. 2012;24(2):97-106. [pmid: 22324865].
Hinkle KA, Kirschenbaum DS, Pecora KM, et al. Parents may hold the keys to success in immersion treatment of adolescent obesity. Child Fam Behav Ther. 2011;33(4):273-88.
Huffman KM, Redman LM, Landerman LR, et al. Caloric restriction alters the metabolic response to a mixed-meal: results from a randomized, controlled trial. PLoS One. 2012;7(4):e28190. [pmid: 22523532].
Inguaggiato R, Cisternino A, Caruso M, et al. Mediterranean diet at low glycemic index in the treatment of metabolic syndrome. A randomized controlled trial. Ann Nutr Metab. 2011;58:356.
Jurkowski JM, Green Mills LL, Lawson HA, et al. Engaging low-income parents in childhood obesity prevention from start to finish: a case study. J Community Health. 2012. [Epub ahead of print].
Parents are satisfied with telemedicine care for their child's obesity. Res Activities. 2011;(375):10-11.
Kemper HC, Koppes LL, de Vente W, et al. Effects of health information in youth and young adulthood on risk factors for chronic diseases--20-year study results from the Amsterdam Growth and Health Longitudinal Study. Prev Med. 2002;35(6):533-9. [pmid: 12460520].
Kesman RL, Ebbert JO, Harris KI, et al. Portion control for the treatment of obesity in the primary care setting. BMC Res Notes. 2011;4(1):346. [pmid: 21906302].
Kramer MK, Venditti EM, Kriska AM, et al. Evaluation of group lifestyle balance long-term maintenance strategies. Diabetes. 2011;60:A201.
Kreider RB, Serra M, Beavers KM, et al. A structured diet and exercise program promotes favorable changes in weight loss, body composition, and weight maintenance. J Am Diet Assoc. 2011;111(6):828-43. [pmid: 21616195].
Kuo S, Smith KJ, Piatt GA, et al. Cost-effectiveness of multiple modalities of lifestyle intervention in the community: Projections from the rethinking eating and activity study. Diabetes. 2011;60:A67.
Lachausse RG. My student body: effects of an internet-based prevention program to decrease obesity among college students. J Am Coll Health. 2012;60(4):324-30. [pmid: 22559092].
Lanier WA, Wagstaff RS, DeMill JH, et al. Teacher awareness and implementation of food and physical activity policies in Utah elementary schools, 2010. Prev Chronic Dis. 2012;9:E18. [pmid: 22172185].
Leahey TM, Larose JG, Fava JL, et al. Social influences are associated with BMI and weight loss intentions in young adults. Obesity. 2011;19(6):1157-62. [pmid: 21164501].
Lioret S, Campbell KJ, Crawford D, et al. Does an early childhood obesity intervention impact on mothers' dietary patterns, physical activity and sedentary behaviour? Results of the Melbourne InFANT (infant feeding activity and nutrition trial) program. Obes Res Clin Pract. 2011;5:S43.
Logue EE, Bourguet CC, Palmieri PA, et al. The better weight-better sleep study: a pilot intervention in primary care. Am J Health Behav. 2012;36(3):319-34. [pmid: 22370434].
McDowell I, Black A, Collishaw N. The healthstyles health promotion program: Description and behavioural outcomes. Can J Public Health. 1988;79(6):447-454. [pmid: 3233571].
Novo S, Peritore A, Guarneri FP, et al. Metabolic syndrome (MetS) predicts cardio and cerebrovascular events in a twenty years follow-up. A prospective study. Atherosclerosis. 2012;223(2):468-72. [pmid: 22704563].
Ohkawara K, Cornier MA, Melanson EL, et al. Six versus three meals per day: Effects on energy expenditure, fat oxidation, and hunger. Obesity. 2011;19:S61.
Persichetti T, Sica A, Pierangeli S, et al. Take weight off food!: From diet to lifestyle. Obes Rev. 2011;12:75.
Porter CM. ‘Choice’: what we mean by it, and what that means for preventing childhood obesity. Public Health Nutr. [Epub ahead of print]. 2012:1-7. [pmid: 23294865].
Ramos-Goni JM, Valcarcel-Nazco C, Castilla-Rodriguez I. Cost-effectiveness of interventions against childhood obesity. Value Health. 2011;14(7):A402.
Reimers KJ, Rippe J. Effect of portion controlled frozen meals on quality of life and diet quality during a community intervention. FASEB J. 2011;25:593.4.
Rodrigues JJ, Lopes IM, Silva BM, et al. A new mobile ubiquitous computing application to control obesity: SapoFit. Inform Health Soc Care. 2012. [Epub ahead of print].
Roohafza H, Sadeghi M, Talaei M, et al. Psychological status and quality of life in relation to the metabolic syndrome: Isfahan cohort study. Intl J Endocrinol. 2012;2012:380902.
Scazzina F, Russi P, Carboni E, et al. Glycemic index and sleep quality: A pilot intervention study. Ann Nutr Metab. 2011;58:235.
Shai I. The effect of low-carb, mediterranean and low-fat diets on renal function; a 2-year dietary intervention randomized controlled trial (direct). Obes Facts. 2012;5:19.
Shaibi G, Ortega R. Intervention for obese latino youth improves health in parents. Obesity. 2011;19:S99.
Shapiro S, Stuckey M, Sabourin K, et al. Smartphone technology versus paper-based logs for type II diabetes prevention: Psychological and behavioral outcomes. Can J Cardiol. 2011;27(5):S180-1.
Shih SC, McCullough CM, Wang JJ, et al. Health information systems in small practices. Improving the delivery of clinical preventive services. Am J Prev Med. 2011;41(6):603-9. [pmid: 22099237].
Sim F, Ahmad R. Building grass roots capacity to tackle childhood obesity. Perspect Public Health. 2011;131(4):165-169. [pmid: 21888118].
Siqueira-Catania A, Cezaretto A, Barros CR, et al. Effectiveness of lifestyle interventions in public health system of developing country in reducing inflammation and insulin resistance of individuals at high-risk for type 2 diabetes. J Diabetes. 2011;3:89.
Thebaud V, Nicholson J, Meedeniya J, et al. Process evaluation of the nourish-rct, an obesity prevention intervention commencing in infancy. Obes Facts. 2012;5:78-1.
Tompkins KB, Tate DF, Polzien K, et al. Effect of children in the home environment on weight loss and adherence in a behavioral weight loss intervention. Obesity. 2011;19:S99.
Triay J, Mundi M, Klein S, et al. Does rimonabant independently affect free fatty acid and glucose metabolism?. J Clin Endocrinol Metab. 2012;97(3):819-27. [pmid: 22170727].
Van Ryzin MJ, Nowicka P. Family-based intervention prevents early adulthood obesity: 10-years follow up of the family check-up, a randomized controlled trial. Obes Facts. 2012;5:33.
Wake M, Turner MJ, Price A, et al. How confident are general paediatricians at assessing and managing obesity in childhood?. Arch Dis Child. 2011;96:A63-A64.
Willits-Smith A, Dickin KL. Factors that influence low-income families' use of recommended nutrition and parenting practices to prevent unhealthy weight gain in children: An exploratory study. FASEB J. 2011;25:781.8.
Wilson A, Magarey A, Jones M, et al. Strategies for best practice in community-based obesity prevention in aboriginal communities. Obes Res Clin Pract. 2011;5:S43.
Ye S, Muntner P, Shimbo D, et al. Do behavioral risk factors explain the association between depressive symptoms and cardiovascular risk in individuals with coronary heart disease? Report from the reasons for geographic and racial differences in stroke (REGARDS) study. J Am Coll Cardiol. 2012;59(13):E1375.

## Study does not take place in a setting of interest

Arango CM, Parra DC, Eyler A, et al. Walking or bicycling to school and weight status among adolescents from Monteria, Colombia. J Phys Act Health. 2011;8(Suppl 2):S171-7. [pmid: 21918230].
Bajraktarevic A, Trninic S, Penava S, et al. Relationship between obese children and prevalence metabolic syndrome in children. J Diabetes. 2011;3:141.
Bang KS, Chae SM, Hyun MS, et al. The mediating effects of perceived parental teasing on relations of body mass index to depression and self-perception of physical appearance and global self-worth in children. J Adv Nurs. 2012. [Epub ahead of print].
Black MM, Hurley KM, Hager ER, et al. Toddler obesity prevention: Effects of parenting and maternal lifestyles interventions. Obesity. 2011;19:S109.
Cao YT, Svensson V, Marcus C, et al. Eating behaviour patterns in Chinese children aged 12-18 months and association with relative weight - factorial validation of the Children's Eating Behaviour Questionnaire. Int J Behav Nutr Phys Act. 2012;9:5. [pmid: 22272572].
Dias L, Gomes CDB, Arruda CM, et al. The overweight and obesity in preschool agechildren in low come population: The impact in of nutrition education programming. Obes Facts. 2012;5:263.
Fuller NR, Lau N, Denyer G, et al. A 12-week, randomised, controlled trial to examine the acceptability of the Korean diet and its effectiveness on weight, blood pressure, metabolic parameters and disease control in an Australian overweight and obese population. Obes Rev. 2011;12:221-2.
Grelaud A, Grolleau A, Demeaux JL, et al. Results of prisme, A french cohort pilot study investigating multidisciplinary care on the one-year improvement of metabolic syndrome. Pharmacoepidemiol Drug Saf. 2011;20:S290-1.
Jones M, Luce KH, Osborne MI, et al. Randomized controlled trial of an internet-facilitated intervention for reducing binge eating and overweight in adolescents. Pediatrics. 2008;121(3):453-62. [pmid: 18310192].
Louzada MLDC, Campagnolo PDB, Rauber F, et al. Long-term effectiveness of maternal dietary counseling in a low-income population: A randomized field trial. Pediatrics. 2012;129(6):e1477-84. [pmid: 22566413].
Mehta NM, Bechard LJ, Cahill N, et al. Nutritional practices and their relationship to clinical outcomes in critically ill children-an international multicenter cohort study. Crit Care Med. 2012;40(7):2204-11. [pmid: 22564954].
Menezes AM, Hallal PC, Dumith SC, et al. Adolescent blood pressure, body mass index and skin folds: sorting out the effects of early weight and length gains. J Epidemiol Community Health. 2012;66(2):149-154. Epidemiol Community Health. 2012;66(2):149-54. [pmid: 21325148].
Nemet D, Geva D, Pantanowitz M, et al. Health promotion intervention in Arab-Israeli kindergarten children. J Pediatr Endocrinol Metab. 2011;24(11-12):1001-7. [pmid: 22308855].
Padilla N, Ruiz L, Diaz R. Intervention in lifystyle as management of obesity in school age children in celaya. Obes Facts. 2012;5:222-3.
Pereira G, Machado M, Meura P, et al. Interventions in the school environment in order to reduce obesity: a systematic review of the Bank of Thesis from the Higher Education Personnel Improvement Coordination (CAPES). Ann Nutr Metab. 2011;58:313.
Perez-Morales ME, Bacardi-Gascon M, Jimenez-Cruz A. Long-term randomized school-based intervention: effect on obesity and lifestyles in Mexico. Obes Rev. 2011;12:74.
Petrova S, Duleva V. Nutritional status of Bulgarian 1-st grade schoolchildren - WHO childhood obesity surveillance initiative in Bulgaria. Ann Nutr Metab. 2011;58:286-7.
Rankin J, Spear BA, Bouler R, et al. Using indirect calorimetry (RMR) to establish energy requirements in adolescents participating in a summer weight loss camp. J Adolesc Health. 2012;50(2):S58-S59.
Roberta Vilarouca A, Zanetti MLC, Costa RW, et al. Evaluating two educational interventions to prevent type 2 Diabetes Mellitus among adolescents [Portuguese]. Texto and Contexto Enfermagem. 2011;20(4):782-7.
Samani SG, Kelishadi R, Adibi A, et al. Association of serum alanine aminotransferase levels with cardiometabolic risk factors in normal-weight and overweight children. Iran J Pediatr. 2011;21(3):287-93. [pmid: 23056803].
Shah P, Misra A. Spreading awareness for prevention of obesity and diabetes in school age children [Project ‘MARG’: The Path]. Int J Obes. 2011;35:S165.
Taveras EM, Blackburn K, Gillman MW, et al. First steps for mommy and me: a pilot intervention to improve nutrition and physical activity behaviors of postpartum mothers and their infants. Matern Child Health J. 2011;15(8):1217-27. [pmid: 20957514].
Taylor BJ, Heath AL, Galland BC, et al. Prevention of Overweight in Infancy (POI.nz) study: a randomised controlled trial of sleep, food and activity interventions for preventing overweight from birth. BMC Public Health. 2011;11:942. [pmid: 22182309].
Toulabi T, Khosh Niyat Nikoo M, Amini F, et al. The influence of a behavior modification interventional program on body mass index in obese adolescents. J Formos Med Assoc. 2012;111(3):153-9. [pmid: 22423669].
Trang NH, Hong TK, Dibley MJ. Active commuting to school among adolescents in Ho Chi Minh City, Vietnam: change and predictors in a longitudinal study, 2004 to 2009. Am J Prev Med. 2012;42(2):120-8. [pmid: 22261207].
Tuan NT, Butte F, Nicklas TA. Body mass index distribution affects discrepancies in weight classifications in children. Pediatr Int. 2012;54(2):256-65. [pmid: 22168359].
Veghari G. Ethnic differences in body mass index, weight and height among school children in the North of Iran. Eurasian Journal of Medicine. 2012;44(1):22-7. [pmid: 25610200].
Wang N, Xu F, Zheng LQ, et al. Effects of television viewing on body fatness among Chinese children and adolescents. Chin Med J. 2012;125(8):1500-3. [pmid: 22613659].
Wen LM, Baur LA, Rissel C, et al. Healthy Beginnings Trial Phase 2 study: follow-up and cost-effectiveness analysis. Contemp Clin Trials. 2012;33(2):396-401. [pmid: 22101220].
Wijesuriya M, Gulliford M, Vasantharajah L, et al. DIABRISK-SL prevention of cardio-metabolic disease with life style modification in young urban Sri Lankan's - study protocol for a randomized controlled trial. Trials. 2011;12:209. [pmid: 21943067].
Wong OL. Gendered power in eating habits: insight into childhood obesity in a Chinese family context. J Fam Ther. 2011;33(3):332-52.
Xu F, Ware RS, Tse LA, et al. A school-based comprehensive lifestyle intervention among chinese kids against obesity (CLICK-Obesity): rationale, design and methodology of a randomized controlled trial in Nanjing city, China. BMC Public Health. 2012;12:316. [pmid: 22545755].

## Study does not take place in an included country

Aboud FE, Shafique S, Akhter S. A responsive feeding intervention increases children's self-feeding and maternal responsiveness but not weight gain. J Nutr. 2009;139(9):1738-43. [pmid: 19587124].
Alexandrov AA, Maslennikova GY, Kulikov SM, et al. Primary prevention of cardiovascular disease:3-year intervention results in boys of 12 years of age. Prev Med. 1992;21(1):53-62. [pmid: 1738768].
Arsenault JE, Mora-Plazas M, Forero Y, et al. Micronutrient and anthropometric status indicators are associated with physical fitness in Colombian schoolchildren. Br J Nutr. 2011;105(12):1832-42. [pmid: 21281544].
Asenova R, Konstantinov P, Dimova R. 30-Month follow-up study concerning the prevalence of overweight in primary school children and the role of general practitioners in its prevention. Gen. Med. 2006;8(3):24-26.
Berry D, Colindres M, Sanchez-Lugo L, et al. Adapting, feasibility testing, and pilot testing a weight management intervention for recently immigrated spanish-speaking women and their 2- to 4-Year-old children. Hisp Health Care Int. 2011;9(4):186-93.
Bhargava A, Gupta SD, Mangal DK, et al. Nutritional intervention among rural pre-school children--an evaluatory study. Indian J Pediatr. 1982;49(400):695-9. [pmid: 7188194].
Chiolero A, Paradis G, Madeleine G, et al. Discordant secular trends in elevated blood pressure and obesity in children and adolescents in a rapidly developing country. Circulation. 2009;119(4):558-565. [pmid: 19153270].
Farias ES, Paula F, Carvalho WRG, Goncalves EM, et al. Influence of programmed physical activity on body composition among adolescent students: Efeito da atividade fisica programada sobre a composica o corporal em escolares adolescentes. J Pediatr. 2009;85(1):28-34.
He YF, Wang WY, Fu P, et al. Effects of a comprehensive intervention program on simple obesity of children in kindergarten. Zhonghua Er Ke Za Zhi. 2004;42(5):333-6. [pmid: 15189687].
Jiang J, Xia X, Greiner T, et al. The effects of a 3-year obesity intervention in schoolchildren in Beijing. Child Care Health Dev. 2007;33(5):641-6. [pmid: 17725789].
Martinez ME. Prevention of diabetes and obesity in children and teenagers through the Coubertin educational model. Diabetologia. 2011;54:S351.
Mo-suwan L, Pongprapai S, Junjana C, et al. Effects of a controlled trial of a school-based exercise program on the obesity indexes of preschool children. Am J Clin Nutr. 1998;68(5):1006-11. [pmid: 9808215].
Rahmani K, Djazayery A, Habibi M, et al. Effects of daily milk supplementation on improving the physical and mental function as well as school performance among children: Results from a school feeding program. J Res Med Sci. 2011;16(4):469-476. [pmid: 22091261].
Rattanagreethakul S, Lapvongwatana P, Thiangtham W, et al. Development of a model of family management for overweight prevention in urban Thai preschoolers. Pacific Rim International Journal of Nursing Research. 2010;14(1):45-60.
Ribaya-Mercado JD, Maramag CC, Tengco LW, et al. Relationships of body mass index with serum carotenoids tocopherols and retinol at steady-state and in response to a carotenoid-rich vegetable diet intervention in Filipino schoolchildren. Biosci Rep. 2008;28(2):97-106. [pmid: 18384277].
Salimzadeh H, Shojaeizadeh D, Pashaee T, et al. School-based physical activity intervention improves the physical fitness of the adolescent girls and their mothers. Pak J Med Sci. 2010;26(3):595-600.

## Entire study population is defined by a disease

Banks J, Sharp DJ, Hunt LP, et al. Evaluating the transferability of a hospital-based childhood obesity clinic to primary care: a randomised controlled trial. Br J Gen Pract. 2012;62(594):E6-12. [pmid: 22520658].
Chan CB, Anders S, Bell RC, et al. The 4-A Framework: A model for development and evaluation of behavioural interventions. Can J Diabetes. 2011;35(2):210.
Feehan K, O'Neil ME, Abdalla D, et al. Factors influencing physical activity in children and youth with special health care needs: a pilot study. Int J Pediatr. 2012;2012:583249. [pmid: 22611411].
Gabel S, Radigan M, Wang R, et al. Health monitoring and promotion among youths with psychiatric disorders: Program development and initial findings. Psychiatr Serv. 2011;62(11):1331-7. [pmid: 22211213].
Gidding SS, Barton BA, Dorgan JA, et al. Higher self-reported physical activity is associated with lower systolic blood pressure: the Dietary Intervention Study in Childhood(DISC). Pediatrics. 2006;118(6):2388-93. [pmid: 17142523].
Gray LJ, Khunti K, Williams S, et al. Let's Prevent Diabetes: Study protocol for a cluster randomised controlled trial of an educational intervention in a multi-ethnic UK population with screen detected impaired glucose regulation. Cardiovasc Diabetol. 2012;11(1):56. [pmid: 22607160].
Gregory J, Robling M, Bennert K, et al. Development and evaluation by a cluster randomised trial of a psychosocial intervention in children and teenagers experiencing diabetes: the DEPICTED study. Health Technol Assess. 2011;15(29):1-202. [pmid: 21851764].
Hartman A, te Winkel ML, van Beek RD, et al. A randomized trial investigating an exercise program to prevent reduction of bone mineral density and impairment of motor performance during treatment for childhood acute lymphoblastic leukemia. Pediatric blood & cancer. 2009;53(1):64-71. [pmid: 19283791].
Inguaggiato R, Cisternino A, Caruso M, et al. Mediterranean diet at low glycemic index in the treatment of metabolic syndrome. A randomized controlled trial. Ann Nutr Metab. 2011;58:356.
Ip M. Preventing obesity in kids with special needs. Today's Dietitian. 2011;13(5):50-1.
Kotb NA, Gaber R, Salama M, et al. Clinical and biochemical predictors of increased carotid intima-media thickness in overweight and obese adolescents with type 2 diabetes. Diab Vasc Dis Res. 2012;9(1):35-41. [pmid: 21985955].
Leacy KA, Cane JN. Effect of non-select menus on weight and eating concern in adolescents hospitalized with anorexia nervosa. Eating Disord. 2012;20(2):159-67.
Lima VP, Mesquita MLG, Colucci ACA, et al. Nutritional intervention with hypocaloric diet for children and adolescents with prader willi syndrome. Clin Nutr Suppl. 2011;6(1):60.
Ma M, Bai HX, Park A, et al. Novel characterization of biliary pancreatitis in children. Gastroenterology. 2011;140(5):S383.
Mann DM, Lin JJ. Increasing efficacy of primary care-based counseling for diabetes prevention: rationale and design of the ADAPT (Avoiding Diabetes Thru Action Plan Targeting) trial. Implement Sci. 2012;7:6. [pmid: 22269066].
Obarzanek E, Kimm SY, Barton BA, Van, et al. Long-term safety and efficacy of a cholesterol-lowering diet in children with elevated low-density lipoprotein cholesterol: seven-year results of the Dietary Intervention Study in Children (DISC). Pediatrics. 2001;107(2):256-64. [pmid: 11158455].
Salvatore D, Messina C, Kier C. Nutrition risk assessment: pathway to improve mean BMI percentile in our pediatric population. Pediatr Pulmonol. 2011;46:380.
Stice E, Rohde P, Shaw H, et al. An effectiveness trial of a selected dissonance-based eating disorder prevention program for female high school students: long-term effects. J Consult Clin Psychol. 2011;79(4):500-8. [pmid: 21707136].
Ward S, Farnsworth C, Babkes-Stellino M, et al. Parental influence and the attraction to physical activity for youths who are visually impaired at a residential-day school. J Vis Impair Blind. 2011;105(8):493-8.
Wilson AC, Palermo TM. Physical activity and function in adolescents with chronic pain: A controlled study using actigraphy. J Pain. 2012;13(2):121-130. [pmid: 22099608].
Wu MP, Wu SF, Wang TC, et al. Effectiveness of a community-based health promotion program targeting people with hypertension and high cholesterol. Nurs Health Sci. 2012;14(2):173-81. [pmid: 22380735].

## No intervention

Adachi-Mejia AM, Sutherland LA, Longacre MR, et al. Adolescent weight status and receptivity to food TV advertisements. J Nutr Educ Behav. 2011;43(6):441-8. [pmid: 21665550].
Adkins S, Sherwood NE, Story M, et al. Physical activity among African-American girls: the role of parents and the home environment. Obes Res. 2004;12(Suppl):38S-45S. [pmid: 15489466].
Ahrens W, Siani A, Bammann K, et al. Introduction to the IDEFICS study - obesity prevalence in European children. Int J Obes. 2011;35:S146.
Akdemir A, Inandi T, Akbas D, et al. Validity and reliability of a turkish version of the body shape questionnaire among female high school students: preliminary examination. Eur Eating Disord Rev. 2012;20(1):e114-e115.
Alborzimanesh M, Kimiagar M, Rashidkhani B, et al. The relation between overweight and obesity with some lifestyle factors in the 3rd-5th grade primary schoolgirls in Tehran City 6th dist [Farsi]. Iranian Journal of Nutrition Sciences and Food Technology. 2011;6(3):84.
Alexandrov AA, Rozanov VB, Smirnova SG. Epidemiology and prevention of obesity in children and adolescents. Obes Rev. 2011;12:245.
An R, Sturm R. School and residential neighborhood food environment and diet among california youth. Am J Prev Med. 2012;42(2):129-35. [pmid: 22261208].
Aparicio MG, Duarte J, Pereira A, et al. Maternal metabolic risk: a challenge in children's overweight prevention. Obes Facts. 2012;5:260.
Apete GK, Zitouni D, Hubert H, et al. Compliance of children in northern France with physical activity recommendations. Perspect Public Health. 2012;132(2):81-8. [pmid: 22616428].
Apfelbacher C, Schmitt J, Loerbroks A. Overweight, obesity and atopic diseases: evidence from a population based cross-sectional study in Germany (KiGGS). Exp Dermatol. 2011;20(2):173.
Arcan C, Hannan PJ, Fulkerson JA, et al. Associations of home food availability, dietary intake, screen time and physical activity with BMI in young American-Indian children. Public Health Nutr. [Epub ahead of print]. 2012:1-10. [pmid: 23294865].
Arsenault JE, Mora-Plazas M, Forero Y, et al. Micronutrient and anthropometric status indicators are associated with physical fitness in Colombian schoolchildren. Br J Nutr. 2011;105(12):1832-42. [pmid: 21281544].
Asenova R, Konstantinov P, Dimova R. 30-Month follow-up study concerning the prevalence of overweight in primary school children and the role of general practitioners in its prevention. Gen Med. 2006;8(3):24-26.
Ashworth J. A sporting solution to improving long-term community health. Prim Health Care. 2011;21(3):22-4.
Au WW, Yu IT. Socio-economic influence on weight status through time in schoolchildren. J Paediatr Child Health. 2012. [Epub ahead of print].
Avula R, Gonzalez W, Shapiro CJ, et al. Positive parenting practices associated with subsequent childhood weight change. J Prim Prev. 2011;32(5-6):271-81. [pmid: 22143321].
Barber Foss KD, Hornsby M, Edwards NM, et al. Is body composition associated with an increased risk of developing anterior knee pain in adolescent female athletes?. Phys Sportsmed. 2012;40(1):13-9. [pmid: 22508247].
Barnett T, Maximova K, Sabiston C, et al. Physical activity growth curves and adiposity in adolescents. Am J Epidemiol. 2011;173:S280.
Bartz S, Freemark M. Pathogenesis and prevention of type 2 diabetes: Parental determinants, breastfeeding, and early childhood nutrition. Curr Diabetes Rep. 2012;12(1):82-7.
Bas M, Metin S, Bilici S. Body mass index among Turkish female adolescents: the role of emotional eating, restrained eating, external eating and depression. Obes Rev. 2011;12:191.
Basoor A, Cotant J, Patel K, et al. Obesity and st elevation myocardial infarction in young. Chest. 2011;140(4):984A.
Bauer KW, Laska MN, Fulkerson JA, et al. Longitudinal and secular trends in parental encouragement for healthy eating, physical activity, and dieting throughout the adolescent years. J Adolesc Health. 2011;49(3):306-311. [pmid: 21856524].
Bell JF, Wilson JS, Liu GC. Neighborhood Greenness and 2-Year Changes in Body Mass Index of Children and Youth. Am J Prev Med. 2008;35(6):547-553. [pmid: 19000844].
Berge JM. What is being served for dinner? Associations between the emotional atmosphere at family meals and health outcomes. Obesity. 2011;19:S130.
Berger M, Day SE, Konty K. Trends in prevalence of overweight and obesity in New York city public school students 2006-2009. Obesity. 2011;19:S151.
Berz JP, Singer MR, Guo X, et al. Use of a DASH food group score to predict excess weight gain in adolescent girls in national growth and health study. Arch Pediatr Adolesc Med. 2011;165(6):540-6. [pmid: 21646587].
Blood E, Grogan S. Children's perspectives on height and weight screenings. Br J Sch Nurs. 2011;6(10):482-8.
Boddy LM, Fairclough SJ, Atkinson G, et al. Changes in cardiorespiratory fitness in 9 to 10.9-year-old children: SportsLinx 1998-2010. Med Sci Sports Exerc. 2012;44(3):481-6. [pmid: 21814150].
Bohlin A, Klaesson S, aKowalski J. Can telephone consultations substitute visits in treatment of childhood obesity? Results from a randomized trial. Obes Facts. 2012;5:237.
Boyland EJ, Halford JC. Television advertising and branding: effects on eating behaviour and food preferences in children. Appetite. 2012. [Epub ahead of print].
Boyland EJ, Harrold JA, Kirkham TC, et al. Food requests in children. The role of habitual commercial television exposure, weight status and meal patterns. Appetite. 2012;58(3):1170.
Brennan L. Psychosocial comorbidities of adolescent obesity. Obes Res Clin Pract. 2011;5:S6.
Brodsgaard A, Wagner L, Peitersen B, et al. Child overweight-mothers' competence to take action. Obes Facts. 2011;4(4):305-11. [pmid: 21921654].
Brouwer R, Ostbye T, Benjamin-Neelon S. Child care arrangement and BMI/activity levels in preschoolers. Obes Facts. 2012;5:257.
Bruening M, Larson N, Story M, et al. Predictors of adolescent breakfast consumption: longitudinal findings from Project EAT. J Nutr Educ Behav. 2011;43(5):390-5. [pmid: 21906551].
Brug J, van Stralen MM, Te Velde SJ, et al. Differences in weight status and energy-balance related behaviors among schoolchildren across Europe: the ENERGY-Project. PLoS One. 2012;7(4):e34742. [pmid: 22558098].
Burgic Radmanovic M, Burgic S. Female adolescents and body image. Eur Child Adolesc Psychiatry. 2011;20:S173.
Burns SF, Oo HH, Tran AT. Effect of sprint interval exercise on postexercise metabolism and blood pressure in adolescents. Int J Sport Nutr Exerc Metab. 2012;22(1):47-54. [pmid: 22248500].
Byrd-Williams C, Sharma S, Evans A, et al. Differences in obesity, obesity-related behaviors, and the home food environment in African American and hispanic preschoolers in texas head start centers. Obesity. 2011;19:S139.
Caixinha MP, Lopes N. Maternal controlling feeding practices, child food choices and child weight status in a sample of primary school aged children in the Algarve region of Portugal. Obes Rev. 2011;12:86.
Calzo JP, Sonneville KR, Haines J, et al. The development of associations among body mass index, body dissatisfaction, and weight and shape concern in adolescent boys and girls. J Adolesc Health. 2012. [Epub ahead of print].
Camacho-Minano MJ, Galiano IR, Diaz AM. Body image and weight control strategies in overweight adolescent girls: implications for preventing eating disorders. Arch Women's Ment Health. 2011;14:S131-2.
Cao YT, Svensson V, Marcus C, et al. Eating behaviour patterns in Chinese children aged 12-18 months and association with relative weight - factorial validation of the Children's Eating Behaviour Questionnaire. Int J Behav Nutr Phys Act. 2012;9:5. [pmid: 22272572].
Casey R, Chaix B, Weber C, et al. Spatial accessibility to physical activity facilities and to food outlets and overweight in French youth. Int J Obes. 2012;36(7):914-9.
Cassola D, De Looy A, Jones R. Stress, coping and eating behaviours in maltese adolescents: developing a model for an effective online intervention. Obes Facts. 2012;5:195.
Champion SL, Rumbold AR, Steele EJ, et al. Parental work schedules and child overweight and obesity. Int J Obes. 2012;36(4):573-80.
Chen JL, Weiss S, Heyman M, et al. Risk factors for obesity and high blood pressure in Chinese-American children: maternal acculturation and children's food choices. J Immigr Minor Health. 2011;13(2):268-75. [pmid: 19757055].
Chen X, Wang Y. Is ideal body image related to obesity and lifestyle behaviours in African American adolescents?. Child Care Health Dev. 2012;38(2):219-28. [pmid: 21434968].
Chen TJ, Modin B, Ji CY, et al. Regional, socioeconomic and urban-rural disparities in child and adolescent obesity in China: a multilevel analysis. Acta Paediatr Int J Paediatr. 2011;100(12):1583-9.
Cherkaoui Dekkaki I, Mouane N, Ettair S, et al. Prevalence of obesity and overweight in children: a study in government primary schools in Rabat, Morocco. Arch Med Res. 2011;42(8):703-8. [pmid: 22227044].
Chiolero A, Paradis G, Madeleine G, et al. Discordant secular trends in elevated blood pressure and obesity in children and adolescents in a rapidly developing country. Circulation. 2009;119(4):558-565. [pmid: 19153270].
Chisholm KW, Alexander S. Tertiary level management of overweight and obese children and adolescents - Does intensive dietetic intervention using a moderate protein intake have a positive impact on weight control in children?. Obes Res Clin Pract. 2011;5:S24.
Chu YH, Liu J, Frongillo EA, et al. Higher generational and acculturation status are associated with poorer diet and greater body weight among Mexican American adolescents. FASEB J. 2011;25:770.15.
Clinical digest. Delaying gratification helps children avoid gaining weight. Nursing Standard. 2010;25(3):17.
Colella D, Morano M. Gross motor development and physical activity in kindergarten age children. Int J Pediatr Obes. 2011;6(Suppl 2):33-6. [pmid: 21923293].
Cooper C, Nichols M, Lacy K, et al. A whole of systems approach to obesity prevention in the maternal and child health services. Obes Res Clin Pract. 2011;5:S73.
Cradock AL, McHugh A, Mont-Ferguson H, et al. Effect of school district policy change on consumption of sugar-sweetened beverages among high school students, Boston, Massachusetts, 2004-2006. Prev Chronic Dis. 2011;8(4):A74. [pmid: 21672398].
Crouch P, O'Dea JA, Battisti R. Child feeding practices and perceptions of childhood overweight and childhood obesity risk among mothers of preschool children. Nutrition & Dietetics. 2007;64(3):151-158.
Dai S, Steffen LM, Mihalopoulos NL, Labarthe DR. Non-HDL cholesterol in children: Age-related patterns and association with body fat indices, project heartbeat!. Circulation. 2011;124(21).
Dattilo AM, Birch L, Krebs NF, Lake A, Taveras EM, Saavedra JM. Need for early interventions in the prevention of pediatric overweight: a review and upcoming directions. J Obes. 2012;2012:123023. [pmid: 22675610].
Davison K, Jurkowski JM, Li K. Links between parents' underestimation of child weight status and their obesity-related attitudes and parenting practices. Obesity. 2011;19:S135.
De Jong E, Visscher TLS, HiraSing RA, Seidell JC, Renders CM. Explaining the association between screen time and overweight in 4-12-year-old-children. Obes Rev. 2011;12:42-43.
Dedoussis GV, Yannakoulia M, Timpson NJ, Manios Y, Kanoni S, Scott RA, Papoutsakis C, Deloukas P, Pitsiladis YP, Davey-Smith G, Hirschhorn JN, Lyon HN. Does a short breastfeeding period protect from FTO-induced adiposity in children?. Int J Pediatr Obes. 2011;6(2-2):e326-35. [pmid: 20863147].
Delvaux K, Lefevre J, Philippaerts R, et al. Bone mass and lifetime physical activity in Flemish males: a 27-year follow-up study. Med Sci Sports Exerc. 2001;33(11):1868-75. [pmid: 11689737].
Dennisuk LA, Coutinho AJ, Suratkar S, et al. Food expenditures and food purchasing among low-income, urban, African-American youth. Am J Prev Med. 2011;40(6):625-8. [pmid: 21565654].
D'Hondt E, Deforche B, Gentier I, et al. A longitudinal analysis of gross motor coordination in overweight and obese children versus normal-weight peers. Int J Obes. 2012. [Epub ahead of print].
Diamond A. Healthy eating should be part of the school curriculum. Nurs Stand. 2011;26(2):28.
Dong-Chul S, Kaigang L. Longitudinal trajectories of perceived body weight: adolescence to early adulthood. Am J Health Behav. 2012;36(2):242-53. [pmid: 22370261].
Dorsey KB, Wells C, Krumholz HM, et al. Diagnosis evaluation and treatment of childhood obesity in pediatric practice. Arch Pediatr Adolesc Med. 2005;159(7):632-638. [pmid: 15996996].
Dovey TM, Taylor L, Stow R, et al. Responsiveness to healthy television (TV) food advertisements/commercials is only evident in children under the age of seven with low food neophobia. Appetite. 2011;56(2):440-6. [pmid: 21256170].
Dryden EM, Hardin J, McDonald J, et al. Provider perspectives on electronic decision supports for obesity prevention. Clin Pediatr. 2012;51(5):490-7.
Du S, Popkin BM. Barriers to physical activity among Chinese children and adolescents, 2000-2009. Obesity. 2011;19:S124-5.
Dubois L, Farmer A, Girard M, et al. Family food insufficiency is related to overweight among preschoolers'. Soc Sci Med. 2006;63(6):1503-1516. [pmid: 16777308].
Duncan DT, Castro MC, Gortmaker SL, et al. Racial differences in the built environment-body mass index relationship? A geospatial analysis of adolescents in urban neighborhoods. Int J Health Geogr. 2012;11(1):11. [pmid: 22537116].
Dunton GF, Intille SS, Wolch J, et al. Investigating the impact of a smart growth community on the contexts of children's physical activity using Ecological Momentary Assessment. Health Place. 2012;18(1):76-84. [pmid: 22243909].
Educating parents might help to manage childhood overweight. Nat Clin Pract Endocrinol Metab. 2007;3(8):560.
Ehrenstein V, Froslev T, Bakketeig LS, et al. Prenatal exposure to systemic antiinfectives and overweight and obesity at school age. Pharmacoepidemiol Drug Saf. 2011;20:S47-S48.
Eiben G, Lissner L. Food consumption and obesity in European children. Int J Obes. 2011;35:S149.
Ekberg J, Angbratt M, Valter L, et al. History matters: childhood weight trajectories as a basis for planning community-based obesity prevention to adolescents. Int J Obes (Lond). 2012;36(4):524-8. [pmid: 22249226].
Eloranta AM, Lindi V, Schwab U, et al. Dietary factors associated with overweight and body adiposity in Finnish children aged 6-8 years: the PANIC Study. Int J Obes. 2012;36(7):950-5.
Enkelejda S, Shtiza D. Obesity and the factors related to it in high school students in the city of Tirana. Obes Facts. 2012;5:243. [pmid: 22647305].
Everley S. What do children value in physical activity? The role of physical, social, and cultural capital in encouraging health behaviours. Obes Facts. 2012;5:264.
Ezendam NP, Oenema A, Brug J. Predictors of the intention to prevent excessive weight gain in youth. Am J Health Behav. 2012;36(4):472-82. [pmid: 22488397].
Fagg J, Law C. Does scaling up a family-based community intervention for childhood overweight and obesity impact socio-economic inequalities in health?. Obes Facts. 2012;5:36-7.
Fairclough SJ, Beighle A, Erwin H, et al. School day segmented physical activity patterns of high and low active children. BMC Public Health. 2012;12(1):406. [pmid: 22672654].
Fallahzadeh H, Golestan M, Rezvanian T, et al. Breast-feeding history and overweight in 11 to 13-year-old children in Iran. World J Pediatr. 2009;5(1):36-41. [pmid: 19172330].
Farajian P, Panagiotakos DB, Risvas G, et al. Socio-economic and demographic determinants of childhood obesity prevalence in Greece: the GRECO (Greek Childhood Obesity) study. Public Health Nutr. [Epub ahead of print]. 2012:1-8. [pmid: 23294865].
Fernandez-Alvira J, Hebestreit A, Mouratidou T, et al. Socio-economic status and food consumption frequencies in European children: IDEFICS study. Ann Nutr Metab. 2011;58:181-2. [pmid: 21734369].
Ferreira F, Mota JA, Duarte J. Prevalencia de excesso de peso e obesidade em estudantes adolescentes do distrito de Castelo Branco: um estudo centrado no indice de massa corporal, perimetro da cintura e percentagem de massa gorda. Prevalence of overweight and obesity in school adolescents of Castelo Branco district, Portugal: a study based in body mass index, waist circumference and percentage of body fat. Revista Port Saude Publica. 2012;30(1):47-54.
Flament MF, Hill EM, Buchholz A, et al. Internalization of the thin and muscular body ideal and disordered eating in adolescence: The mediation effects of body esteem. Body Image. 2012;9(1):68-75. [pmid: 21889429].
Foreyt J, Kleinman R, Brown RJ, et al. The use of low-calorie sweeteners by children: implications for weight management. J Nutr. 2012;142(6):1155S-62S. [pmid: 22573780].
Foucart J, De Buck C, Verbanck P. Etude factorielle des composantes psychopathologiques de l'obesite severe chez l'adolescent. Factorial study of the psychopathological factors of morbid obesity in the adolescent. Encephale. 2011;38(4):310-7. [pmid: 22980472].
Freeman E, Fletcher R, Collins CE, et al. Preventing and treating childhood obesity: time to target fathers. Int J Obes. 2012;36(1):12-15.
Frenn M, Heinrich A, Dohmen CS, et al. What can parents do to reduce you obesity? An intial study with a diverse sample. J Pediatr Nurs. 2011;26(5):428-34. [pmid: 21930029].
Frizzell L, Canning P. High rates of high birthweight, accelerated early growth, and overweight and obesity at preschool: further support for pre-and post-natal intervention. Obes Facts. 2012;5:242.
Frqmeaux AE, Mallam KM, Metcalf BS, et al. The impact of school-time activity on total physical activity: the activitystat hypothesis (EarlyBird 46). Int J Obes. 2011;35(10):1277-1283.
Gali V, Krishna Venkatesh V, Ganesan V. Recognition of overweight-obesity in children-are paediatricians missing the opportunity in outpatient clinics?. Arch Dis Child. 2011;96:A60.
Ganley KJ, Paterno MV, Miles C, et al. Health-related fitness in children and adolescents. Pediatr Phys Ther. 2011;23(3):208-20. [pmid: 21829112].
Gebremariam M, Bergh I, Andersen L, et al. Stability and change in potential correlates of physical activity and association with pubertal status among Norwegian children in the transition between childhood and adolescence. Int J Behav Nutr Phys Act. 2012;9(1):56. [pmid: 22577969].
Gibson D. Long-term food stamp program participation is differentially related to overweight in young girls and boys. J Nutr. 2004;134(2):372-9. [pmid: 14747674].
Gillaspy SR, Fedele DA, Wagener T, et al. Parenting characteristics of parents of obese and non-obese children. J Invest Med. 2011;59(2):383.
Going SB, Lohman TG, Cussler EC, et al. Percent body fat and chronic disease risk factors in U.S. children and youth. Am J Prev Med. 2011;41(4Suppl 2):S77-86. [pmid: 21961616].
Goldfield GS, Harvey A, Grattan K, et al. Physical activity promotion in the preschool years: a critical period to intervene. Int J Environ Res Public Health. 2012;9(4):1326-42. [pmid: 22690196].
Goldfield GS, Kenny GP, Hadjiyannakis S, et al. Video game playing is independently associated with blood pressure and lipids in overweight and obese adolescents. PLoS One. 2011;6(11):e26643. [pmid: 22069461].
Goldfield GS, Murray MA, Buchholz A, et al. Family meals and body mass index among adolescents: effects of gender. Appl Physiol Nutr Metab. 2011;36(4):539-46. [pmid: 21851205].
Gopinath B, Baur LA, Burlutsky G, et al. Socio-economic, familial and perinatal factors associated with obesity in Sydney schoolchildren. J Paediatr Child Health. 2012;48(1):44-51. [pmid: 21988560].
Gostin LO, Pomeranz JL, Jacobson PD, et al. Assessing laws and legal authorities for obesity prevention and control. J Law Med Ethics. 2009;37(1Suppl):28-36. [pmid: 19493089].
Govea J. Ethical concerns regarding interventions to prevent and control childhood obesity. Prev Chronic Dis. 2011;8(5):A91. [pmid: 21843421].
Granner ML, Evans AE. Variables associated with fruit and vegetable intake in adolescents. Am J Health Behav. 2011;35(5):591-602. [pmid: 22040620].
Gregori D, Baldi I, Scire AS. Understanding the role of physical- and screenactivity in promoting overweight in children:an international perspective. Obes Facts. 2012;5:108.
Grunseit AC, Taylor AJ, Hardy LL, et al. Composite measures quantify households'obesogenic potential and adolescents' risk behaviors. Pediatrics. 2011;128(2):e308-16. [pmid: 21727105].
Gubbels JS, Thijs C, Stafleu A, et al. Association of breast-feeding and feeding on demand with child weight status up to 4 years. Int J Pediatr Obes. 2011;6(2-2):e515-22. [pmid: 20858157].
Guevara-Cruz M, Serralde-Zuniga AE, Frigolet Vazquez-Vela ME, et al. Association between maternal perceptions and actual nutritional status for children in a study group in Mexico. Nutr Hosp. 2012;27(1):209-12. [pmid: 22566323].
Hacker K, Dryden E, Hardin J, et al. Physician's perspectives on electronic decision support alerts for obesity management. Obesity. 2011;19:S105-6.
Haga C, Kondo N, Suzuki K, et al. Exploring BMI trajectory patterns of children and effects of maternal BMI and behaviour during pregnancy: a trajectory analysis of Japanese birth cohort. Obes Rev. 2011;12:93. [pmid: 20406414].
Haisfield L, Fisher JO, Savage JS, et al. Influence of family-style meals on young children's self-selected portions and intake. Obesity. 2011;19:S66-7.
Hakkak R, Carroll P, Gonzales D, et al. A longitudinal study of body mass index in head start children: a ten year follow-up. J Invest Med. 2011;59(2):475.
Hall L, Collins CE, Morgan PJ, et al. Children's intake of fruit and selected energy-dense nutrient-poor foods is associated with fathers' intake. J Am Diet Assoc. 2011;111(7):1039-44. [pmid: 21703382].
Harris DE, Blum JW, Bampton M, et al. Location of food stores near schools does not predict the weight status of Maine high school students. J Nutr Educ Behav. 2011;43(4):274-8. [pmid: 21683275].
Hart CN, Cairns A, Jelalian E. Sleep and obesity in children and adolescents. Pediatr Clin North Am. 2011;58(3):715-33. [pmid: 21600351].
Hartmann T, Zahner L, Pnhse U, et al. Physical activity bodyweight health and fear of negative evaluation in primary school children. Scand J Med Sci Sports. 2010;20(1):e27-e34. [pmid: 19422648].
Hartwick CA, Queval I, Sue R, et al. Food culture and nutrition education in France - the implications of a national health campaign against obesity. Appetite. 2011;56(2):531.
Harvey J, Eime R, Symons C, et al. Perceived physical competence mediates health benefits of club sport in adolescent girls beyond the effects of physical activity. J Sci Med Sport. 2011;14:e51-2.
Hassapidou M. The who childhood obesity surveillance initiative (COSI) in Greece. Obes Facts. 2012;5:14.
Haugstvedt KT, Graff-Iversen S, Bechensteen, et al. Parenting an overweight or obese child: A process of ambivalence. J Child Health Care. 2011;15(1):71-80. [pmid: 21451012].
Hawley SR, Beckman H, Bishop T. Development of an obesity prevention and management program for children and adolescents in a rural setting. J Community Health Nurs. 2006;23(2):69-80. [pmid: 16643097].
Helfert S, Warschburger P. A prospective study on the impact of peer and parental pressure on body dissatisfaction in adolescent girls and boys. Body Image. 2011;8(2):101-109. [pmid: 21354379].
Hills AP, Andersen LB, Byrne NM. Physical activity and obesity in children. Br J Sports Med. 2011;45(11):866-70. [pmid: 21836171].
Hobin EP, Leatherdale ST, Manske S, et al. A multilevel examination of gender differences in the association between features of the school environment and physical activity among a sample of grades 9 to 12 students in Ontario, Canada. BMC Public Health. 2012;12(1):74. [pmid: 22272717].
Horodynski MA, Baker S, Coleman G, et al. The Healthy Toddlers Trial Protocol: an intervention to reduce risk factors for childhood obesity in economically and educationally disadvantaged populations. BMC Public Health. 2011;11:581. [pmid: 21777452].
Hruby A, Chomitz V, Arsenault LN, et al. Predicting maintenance or achievement of healthy weight in children: the impact of changes in physical fitness. Obesity. 2012;20(8):1710-7. [pmid: 22307068].
Hudson L, Christie D. Tackling overweight and obesity in the school setting. Br J Sch Nurs. 2011;6(7):329-33.
Hughes SO, Shewchuk RM. Child temperament, parent emotions, and perceptions of the child's feeding experience. 2012;9:64.
Huh J, Riggs NR, Spruijt-Metz D, et al. Identifying patterns of eating and physical activity in children: a latent class analysis of obesity risk. Obesity. 2011;19(3):652-8. [pmid: 20930718].
Hunsberger M, Eiben G, Lanfer A, Reeske A. Infant feeding practices and prevalence of obesity and overweight in eight European countries. Clin Nutr Suppl. 2011;6(1):179.
Hur IY. Reicks M. Relationship between whole-grain intake, chronic disease risk indicators, and weight status among adolescents in the National Health and Nutrition Examination Survey, 1999-2004. J Acad Nutr Diet. 2012;112(1):46-55. [pmid: 22717176].
Ip M. Preventing obesity in kids with special needs. Today's Dietitian. 2011;13(5):50-1.
Jacka FN, Kremer PJ, Berk M, et al. A prospective study of diet quality and mental health in adolescents. PLoS One. 2011;6(9):e24805. [pmid: 21957462].
Jackson EA, Eagle T, Leidal A, et al. Childhood obesity: A comparison of health habits of middle-school students from two communities. Clin Epidemiol. 2009;1:133-9. [pmid: 20865095].
Jacobson Vann JC, Finkle J, Ammerman A, et al. Use of a tool to determine perceived barriers to children's healthy eating and physical activity and relarionships to health behaviors. J Pediatr Nurs. 2011;26(5):404-415. [pmid: 21930027].
Janitz AE, Moore WE, Stephens AL, et al. Weight status of American Indian and white elementary school students living in the same rural environment, Oklahoma, 2005-2009. Prev Chronic Dis. 2012;9:E78. [pmid: 22482137].
Jansen E, Mulkens S, Emond Y, et al. From the Garden of Eden to the land of plenty. Restriction of fruit and sweets intake leads to increased fruit and sweets consumption in children. Appetite. 2008;51(3):570-5. [pmid: 18501474].
Jensen CD, Steele RG. Longitudinal associations between teasing and health-related quality of life among treatment-seeking overweight and obese youth. J Pediatr Psychol. 2012;37(4):438-47. [pmid: 22262915].
Jimenez-Pavon D, Ortega FB, Artero EG, et al. Physical activity, fitness, and serum leptin concentrations in adolescents. J Pediatr. 2012;160(4):598-603.e2. [pmid: 22082954].
Kaestner R, Xin X. Title IX girls' sports participation and adult female physical activity and weight. Eval Rev. 2010;34(1):52-78. [pmid: 20130236].
Kapantais E, Chala E, Kaklamanou D, et al. Breakfast skipping and its relation to BMI and health-compromising behaviours among Greek adolescents. Public Health Nutr. 2011;14(1):101-8. [pmid: 20529399].
Kaufmann NA, Poznanski R, Guggenheim K. Teen-agers dieting for weight control. Nutr Metab. 1974;16(1):30-7. [pmid: 4836681].
Keane PC, Davis SM, Myers OB, et al. Effect of an obesity prevention intervention on fruit, vegetable and whole grain intake in American Indian and Hispanic preschoolers. FASEB J. 2011;25:30.3.
Keast DR, Rosen RA, Arndt EA, et al. Dietary modeling shows that substitution of whole-grain for refined-grain ingredients of foods commonly consumed by US children and teens can increase intake of whole grains. J Am Diet Assoc. 2011;111(9):1322-8. [pmid: 21872695].
Keller SK, Schulz PJ. Distorted food pyramid in kids programmes: a content analysis of television advertising watched in Switzerland. Eur J Public Health. 2011;21(3):300-5. [pmid: 20478835].
Kesten J, Griffiths P, Cameron N. The role of community readiness in reducing the risk of overweight and obesity in a uk community of pre-adolescent girls. Obes Facts. 2012;5:25.
Khoury M, Manlhiot C, Dobbin S, et al. The association of cardiovascular risk and high body mass index in adolescents is influenced by waist circumference. Can J Diabetes. 2011;35(2):145.
Kibayashi M. The relationships among child's ability of mastication, dietary behaviour and physical fitness. Int J Dent Hyg. 2011;9(2):127-31. [pmid: 21435180].
King AC, Parkinson KN, Adamson AJ, et al. Correlates of objectively measured physical activity and sedentary behaviour in English children. Eur J Public Health. 2011;21(4):424-31. [pmid: 20650946].
Kohlboeck G, Sausenthaler S, Standl M, et al. Food intake, diet quality and behavioral problems in children: results from the GINI-plus/LISA-plus studies. Ann Nutr Metab. 2012;60(4):247-56. [pmid: 22677949].
Koller M. Development of an obesity prevention strategy for Austria. Obes Facts. 2012;5:36.
Kong AS, Farnsworth S, Canaca JA, et al. An adaptive community-based participatory approach to formative assessment with high schools for obesity intervention. J Sch Health. 2012;82(3):147-54. [pmid: 22320339].
Kramer RF, Coutinho AJ, Vaeth E, et al. Healthier home food preparation methods and youth and caregiver psychosocial factors are associated with lower BMI in African American youth. J Nutr. 2012;142(5):948-54. [pmid: 22457390].
Kranz S, Zuercher J, Marshall YW. Low-income children in rural eastern North Carolina: specific diet and lifestyle factors put them at high risk for obesity. FASEB J. 2011;25:781.5.
Kruger S, de Villiers A. Do tuck shops contribute to an unhealthy, obesogenic lifestyle among schoolchildren?. South Afr J Clin Nutr. 2011;24(3):121-2.
Kunitsugu I, Okuda M, Sugiyama S, et al. Meat intake frequency and anemia in Japanese children and adolescents. Nurs Health Sci. 2012;14(2):197-203. [pmid: 22435780].
Kytta AM, Broberg AK, Kahila MH. Urban environment and children's active lifestyle: softGIS revealing children's behavioral patterns and meaningful places. Am J Health Promot. 2012;26(5):e137-48. [pmid: 22548432].
Lachausse RG. My student body: effects of an internet-based prevention program to decrease obesity among college students. J Am Coll Health. 2012;60(4):324-30. [pmid: 22559092].
Lajunen HR, Kaprio J, Rose RJ, et al. Genetic and environmental influences on BMI from late childhood to adolescence are modified by parental education. Obesity. 2012;20(3):583-9. [pmid: 21996670].
Larouche R, Lloyd M, Knight E, et al. Relationship between active school transport and Body Mass Index in grades- 4 to 6 children. Pediatr Exerc Sci. 2011;23(3):322-30. [pmid: 21881153].
Lazarou C, Kouta C. Preventing and managing obesity. Independent Nurse. 2011:32-34.
Lazorick S, Peaker B, Perrin EM, et al. Prevention and treatment of childhood obesity: care received by a state Medicaid population. Clin Pediatr. 2011;50(9):816-26.
Lazzeri G, Pammolli A, Simi R, et al. BMI from nutritional surveillance of 8-9 years old children in Tuscany (Italy). J Prev Med Hyg. 2011;52(4):181-5. [pmid: 22442922].
Lee HA, Lee WK, Kong KA, et al. The effect of eating behavior on being overweight or obese during preadolescence. J Prev Med Public Health. 2011;44(5):226-33. [pmid: 22020188].
Lenders CM, Heinricks JR, Debiasse MA, et al. Secondary prevention of obesity among children age 5 and under. FASEB J. 2011;25:593.8.
Lenhart CM, Daly BP, Eichen DM. Is accuracy of weight perception associated with health risk behaviors in a diverse sample of obese adolescents?. J Sch Nurs. 2011;27(6):416-23. [pmid: 21976189].
Li M, Dibley MJ, Yan H. School environment factors were associated with BMI among adolescents in Xi'an City, China. BMC Public Health. 2011;11:792. [pmid: 21988882].
Li Y, Wedick NM, Lai J, et al. Lack of dietary diversity and dyslipidaemia among stunted overweight children: the 2002 China National Nutrition and Health Survey. Public Health Nutr. 2011;14(5):896-903. [pmid: 21306667].
Lin SL, Leung GM, Hui LL, et al. Is informal child care associated with childhood obesity? Evidence from Hong Kong's “Children of 1997” birth cohort. Int J Epidemiol. 2011;40(5):1238-46. [pmid: 21624932].
Linchey J, Madsen KA. State requirements and recommendations for school-based screenings for body mass index or body composition, 2010. Prev Chronic Dis. 2011;8(5):A101. [pmid: 21843404].
Lind C, Mirchandani GG, Castrucci BC, et al. The effects of acculturation on healthy lifestyle characteristics among Hispanic fourth-grade children in Texas public schools, 2004-2005. J Sch Health. 2012;82(4):166-74. [pmid: 22385089].
Lohr C, Fladung AK. Stress, emotionsregulation und essstorungsrisiko in der adoleszenz.Ergebnisse einer schulerbefragung. Stress, emotion regulation and risk of eating disorder in adolescence-results of a survey among schoolchildren. Nervenheilkunde. 2012;31(6):461-6.
Lourencnullo A, Gama A, Rosado V, et al. The impact of place of residence on childhood obesity: an exploratory analysis in aveiro. Obes Facts. 2012;5:56-7.
Lowry KW, Lavigne JV. Behavior, psychiatric diagnoses and weight in early childhood. Clin Transl Sci. 2011;4(2):99.
Lumeng JC, Kaciroti N, Frisvold DE. Changes in body mass index Z score over the course of the academic year among children attending head start. Acad Pediatr. 2010;10(3):179-186. [pmid: 20399173].
Machado M, Cecilia Resen E, Simpson CA. Revista da Rede de Enfermagem do Nordeste. Students' health conditions and nursing intervention: experience report. 2011;12(4):841-8.
Mahfouz AA, Shatoor AS, Khan MY, et al. Nutrition, physical activity, and gender risks for adolescent obesity in Southwestern Saudi Arabia. Saudi J Gastroenterol. 2011;17(5):318-22. [pmid: 21912058].
Mahoney JL. Adolescent summer care arrangements and risk for obesity the following school year. J Adolesc. 2011;34(4):737-49. [pmid: 20863556].
Mark S, Wang J, Gray-Donald K, et al. Sugar-sweetened beverage intake and metabolic syndrome omponents among children at high risk of obesity. Can J Diabetes. 2011;35(2):142.
Martin SB, Rhea DJ, Greenleaf CA, et al. Weight control beliefs, body shape attitudes, and physical activity among adolescents. J Sch Health. 2011;81(5):244-50. [pmid: 21517863].
Martinez-Gomez D, Eisenmann JC, Tucker J, et al. Associations between moderate-to-vigorous physical activity and central body fat in 3-8-year-old children. Int J Pediatr Obes. 2011;6(2-2):e611-4. [pmid: 21091103].
Matus CD, Klaege K. Exercise and weight management. Prim Care. 2007;34(1):109-16. [pmid: 17481989].
Mauriello LM, Sherman KJ, Driskell MM, et al. Using interactive behavior change technology to intervene on physical activity and nutrition with adolescents. Adolesc Med State Art Rev. 2007;18(2):383-99. xiii. [pmid: 18605653].
McCormack GR, Hawe P, Perry R, et al. Associations between familial affluence and obesity risk behaviours among children. Paediatr Child Health. 2011;16(1):19-24. [pmid: 22211068].
Mehta K, Phillips C, Ward P, et al. Marketing foods to children through product packaging: prolific, unhealthy and misleading. Public Health Nutr. 2012:1-8. [pmid: 23294865].
Mehta SH, Kruger M, Sokol RJ. Is maternal diabetes a risk factor for childhood obesity?. J Matern Fetal Neonatal Med. 2012;25(1):41-4. [pmid: 21955140].
Menezes AM, Hallal PC, Dumith SC, et al. Adolescent blood pressure, body mass index and skin folds: sorting out the effects of early weight and length gains. J Epidemiol Community Health. 2012;66(2):149-54. [pmid: 21325148].
Meyer KA, Friend S, Hannan PJ, et al. Ethnic variation in body composition assessment in a sample of adolescent girls. Int J Pediatr Obes. 2011;6(5-6):481-90. [pmid: 21749194].
Miller J, Gibson S. Positive impact of water on children's health and wellbeing. Br J Sch Nurs. 2012;7(1):8-9.
Miller P, Moore RH. Children's daily fruit and vegetable intake: associations with maternal intake and child weight status. J Nutr Educ Behav. 2011;43(5):396-400. [pmid: 21764642].
Mirhosseini NZ, Shahar S, Yusoff NM, et al. Lower level of physical activity predisposes iranian adolescent girls to obesity and its metabolic consequences. Pak J Nutr. 2011;10(8):728-34.
Mitchell K, Pauls J. Adolescent health study: an analysis of female adolescent sports-related activity patterns on body mass index over time. J Womens Health Phys Therap. 2006;30(2):5-9.
Mitchell NG, Moore JB, Bibeau WS, et al. Cardiovascular fitness moderates the relations between estimates of obesity and physical self-perceptions in rural elementary school students. J Phys Act Health. 2012;9(2):288-94. [pmid: 22368227].
Miyazaki T, Kurokawa J, Arai S. AIMing at metabolic syndrome - Towards the development of novel therapies for metabolic diseases via apoptosis inhibitor of macrophage (AIM). Circ J. 2011;75(11):2522-31. [pmid: 21970839].
Moleres A, Campion J, Milagro F, et al. Epigenetic biomarkers for weight loss response after a lifestyle intervention in overweight/obese Spanish adolescents: The Evasyon study. Obes Facts. 2012;5:173.
Molnar BE, Gortmaker SL, Bull FC, et al. Unsafe to Play? Neighborhood Disorder and Lack of Safety Predict Reduced Physical Activity among Urban Children and Adolescents. Am J Health Promot. 2004;18(5):378-386. [pmid: 15163139].
Morano M, Colella D, Caroli M. Gross motor skill performance in a sample of overweight and non-overweight preschool children. Int J Pediatr Obes. 2011;6(Suppl 2):42-6. [pmid: 21923296].
Morin P, Roy MA. Perceptions of employed parents about early childhood obesity and the need for prevention strategies. Health Promot Pract. 2011. [Epub ahead of print].
Moroshko I, Brennan L. Parent-preschooler feeding interaction and its association with child diet and weight. Obes Res Clin Pract. 2011;5:S69-70.
Msengi I, Killion L. An analysis of overweight and obesity levels of adolescents in a southeast texas region. Obesity. 2011;19:S140.
Murashima M, Hoerr SL, Hughes SO, et al. Feeding behaviors of low-income mothers: directive control relates to a lower BMI in children, and a nondirective control relates to a healthier diet in preschoolers. Am J Clin Nutr. 2012;95(5):1031-7. [pmid: 22456658].
Nettlefold L, McKay HA, Naylor PJ, et al. The Relationship between objectively measured physical activity, sedentary time, and vascular health in children. Am J Hypertens. 2012;25(8):914-9. [pmid: 22673018].
Nichols P, Ussery-Hall A, Griffin-Blake S, et al. The evolution of the steps program, 2003-2010: transforming the federal public health practice of chronic disease prevention. Prev Chronic Dis. 2012;9:E50. [pmid: 22300870].
Nielsen BM, Husby I, Tholstrup T, et al. Intake of protein and fat from dairy products and their relation to metabolic risk components among danish children. Obes Rev. 2011;12:43.
Nkansah-Amankra S, Walker AD. The relation between adolescent self assessment of health and risk behaviours: could a global measure of health provide indications of health risk exposures?. Health Educ J. 2012;71(1):39-52.
Oh JE, Gil JH, Seo JW, et al. The usefulness of waist circumference to height ratio in screening of obesity in Korean children and adolescents. J Pediatr Gastroenterol Nutr. 2011;52:E200.
O'Haver J, Szalacha LA, Kelly S, et al. The relationships among body size, biological sex, ethnicity, and healthy lifestyles in adolescents. J Spec Pediatr Nurs. 2011;16(3):199-206. [pmid: 21702880].
Olafsdottir S, Eiben G, Prell H, et al. Lower consumption of soft drinks among children with parents who limit TV-commercials. Ann Nutr Metab. 2011;58:189.
Olstad DL, Raine KD, McCargar LJ. Adopting and implementing nutrition guidelines in recreational facilities: public and private sector roles - A multiple case study. BMC Public Health. 2012;12(1):376. [pmid: 22632384].
Olteanu A, Matevich J, Arnberger R, et al. Addressing childhood obesity in an underserved community. Can J Diabetes. 2011;35(2):199.
Ornelas RT, Silva AM, Minderico CS, et al. Changes in cardiorespiratory fitness predict changes in body composition from childhood to adolescence: findings from the European youth heart study. Phys Sportsmed. 2011;39(3):78-86. [pmid: 21673487].
Ozturk C, Sari HY, Bektas M, et al. Health screening: a survey of children's growth and development in Turkey. Paediatr Nurs. 2011;23(1):24-28. [pmid: 21473493].
Park S, Blanck HM, Sherry B, et al. Factors associated with sugar-sweetened beverage intake among United States high school students. J Nutr. 2012;142(2):306-12. [pmid: 22223568].
Pasch KE, Lytle LA, Samuelson AC, et al. Are school vending machines loaded with calories and fat: an assessment of 106 middle and high schools. J Sch Health. 2011;81(4):212-8. [pmid: 21392013].
Paschoal MA, Fontana CC. Metodo do limiar de variabilidade da frequencia cardiaca aplicado em pre-adolescentes obesos e nao obesos. Method of heart rate variability threshold applied in obese and non-obese pre-adolescents. Arq Bras Cardiol. 96. 6. 450. 2011;96(6):4511-6.
Patel BP, Bellissimo N, Thomas SG, et al. Television viewing at mealtime reduces caloric compensation in peripubertal, but not postpubertal, girls. Pediatr Res. 2011;70(5):513-7. [pmid: 21772226].
Patel SL, Holub SC. Body size matters in provision of help-Factors related to children's willingness to help overweight peers. Obesity. 2012;20(2):382-8. [pmid: 21996656].
Patsopoulou A, Hadjichristodoulou C, Semertzi E. Overweight and obesity status in adolescents from Greece. Acta Paediatr Int J Paediatr. 2011;100:101.
Paulis W, Van Middelkoop M, Bueving H, et al. Determinants of (sustained) overweight and complaints in children and adolescents in primary care: The Doerak cohort study design. Obes Facts. 2012;5:239.
Pearson N, Salmon J, Campbell K, et al. Tracking of children's body-mass index, television viewing and dietary intake over five-years. Prev Med. 2011;53(4-5):268-70. [pmid: 21820008].
Peart T, Eduardo RY, Deborah B, et al. Weight status in US youth: the role of activity, diet, and sedentary behaviors. Am J Health Behav. 2011;35(6):756-64. [pmid: 22251766].
Pentz MA, Durand CP, Huh J. Relationship of community policies to child obesity risk. Obesity. 2011;19:S128.
Perez-Lizaur AB, Melendez-Mier G, Rocha-Aguilar R, et al. Promotion of physical activity and adequate nutrition in children during the summer school holidays. Obes Rev. 2011;12:72.
Petrauskiene A, Albaviciute E, Valeviciene R. Organization of catering for elementary school age children in Kaunas schools. Ann Nutr Metab. 2011;58:195.
Petrova S, Rangelova L, Konstantinova M, et al. Prevalence of overweight and obesity in Bulgarian schoolchildren: comparison of Cole standards with WHO reference for body mass index. Obes Facts. 2012;5:246.
Pierce JP, Yong CS, Dwyer T, et al. A survey of health promotion priorities in the community. Community Health Stud. 1985;9(3):263-9. [pmid: 4085203].
Pigeot I, Siani A, Bammann K, et al. IDEFICS study-Baseline results and future perspectives. Obes Rev. 2011;12:5.
Pinard CA, Davy BM, Estabrooks PA. Beverage intake in low-income parent-child dyads. Eat Beh. 2011;12(4):313-6.
Plachta-Danielzik S, Kehden B, Landsberg B, et al. Estimating the effect of population-based preventive measures in children and adolescents with risk of overweight, overweight and obesity-The interdisciplinary consortium on obesity prevention in children and adolescents (Prevent). Obes Facts. 2012;5:258.
Porter RM. Children's hospitals focus on pediatric obesity. Pediatr Nurs. 2011;37(1):39-40. [pmid: 21485621].
Powell LM, Chriqui J, Chaloupka FJ. Associations between State-level Soda Taxes and Adolescent Body Mass Index. J Adolesc Health. 2009;45(3 Suppl):S57-S63. [pmid: 19699437].
Pqrez Gallardo L, Bayona I, Mingo T, et al. Performance of nutritional education programmes to prevent obesity in children through a pilot study in Soria. Nutr Hosp. 2011;26(5):1161-7. [pmid: 22072368].
Pretlow R. Addiction to highly pleasurable foods as a cause of the childhood obesity epidemic. Obesity. 2011;19:S135-6.
Puder JJ, Schindler C, Zahner L, et al. Adiposity, fitness and metabolic risk in children:a cross-sectional and longitudinal study. Int J Pediatr Obes. 2011;6(2-2):e297-e306. [pmid: 21091100].
Quiles-Marcos Y, Balaguer-Sola I, Pamies-Aubalat L, et al. Eating habits, physical activity, consumption of substances and eating disorders in adolescents. Span J Psychol. 2011;14(2):712-23. [pmid: 22059317].
Rabiei S. The association of nutrition style through the first 2 years of life with type 1 diabetes mellitus and some of the other effective factors in 2-15 years old children. Iran J Endocrinology Metab. 2011;13(1):113.
Racine EF, DeBate RD, Gabriel KP, et al. The relationship between media use and psychological and physical assets among third- to fifth-grade girls. J Sch Health. 2011;81(12):749-55. [pmid: 22070506].
Redsell S, Atkinson P, Nathan D, et al. Primary prevention of childhood obesity: views from primary care. Arch Dis Child. 2011;96:A9-11.
Reinehr T, Schaefer A, Winkel K, et al. Development and evaluation of the lifestyle intervention ‘Obeldicks light’ for overweight children and adolescents. J Public Health. 2011;19(4):377-84.
Rey-Lopez JP, Ruiz JR, Ortega FB, et al. Meal frequency while watching TV and obesity risk in adolescents: The HELENA study. Int J Obes. 2011;35:S149.
Ridgers ND, Carter LM, Stratton G, et al. Examining children's physical activity and play behaviors during school playtime over time. Health Educ Res. 2011;26(4):586-95. [pmid: 21422119].
Riis J, Grason H, Strobino D, et al. State school policies and youth obesity. Matern Child Health J. 2012;16:111-8.
Riley M, Locke AB, Skye EP. Health maintenance in school-aged children: part I. history, physical examination, screening, and immunizations. Am Fam Physician. 2011;83(6):683-8. [pmid: 21404978].
Ritchie LD. Less frequent eating predicts greater BMI and waist circumference in female adolescents. Am J Clin Nutr. 2012;95(2):290-6. [pmid: 22218154].
Robinson GA, Geier M, et al. Childhood obesity: complications, prevention strategies, treatment. JAAPA. 2011;24(12):58-63. [pmid: 22315918].
Rockell JE, Parnell WR, Wilson NC, et al. Nutrients and foods consumed by New Zealand children on schooldays and non-schooldays. Public Health Nutr. 2011;14(2):203-8. [pmid: 20624332].
Romon M, Lommez A, Tafflet M, et al. Downward trends in the prevalence of childhood overweight in the setting of 12-year school- and community-based programmes. Public Health Nutr. 2009;12(10):1735-42. [pmid: 19102807].
Roohafza H, Sadeghi M, Talaei M, et al. Psychological status and quality of life in relation to the metabolic syndrome: Isfahan cohort study. Intl J Endocrinol. 2012;2012:380902.
Saelens BE, Sallis JF, Frank LD, et al. Obesogenic neighborhood environments, child and parent obesity: the Neighborhood Impact on Kids study. Am J Prev Med. 2012;42(5):e57-64. [pmid: 22516504].
Salois MJ. Obesity and diabetes the built environment and the ‘local’ food economy in the United States 2007. Econ Hum Biol. 2011.
Salois MJ. The built environment and obesity among low-income preschool children. Health Place. 2012;18(3):520-7. [pmid: 22390893].
Salvy SJ. The importance of peers and friends to eating, physical activity, and obesity during childhood and adolescence. Appetite. 2011;57:S38.
Sanchez-Vaznaugh EV, Sanchez BN, Rosas LG, et al. Physical education policy compliance and children's physical fitness. Am J Prev Med. 2012;42(5):452-9. [pmid: 22516484].
Sandercock G, Voss C, Cohen Dl, et al. Centile curves and normative values for the twenty metre shuttle-run test in English schoolchildren. J Sports Sci. 2012;30(7):679-687. [pmid: 22339646].
Sandoval A, Turner L, Nicholson L, et al. The relationship among state laws, district policies and elementary school-based measurement of children's body mass index. J Sch Health. 2012;82(5):239-45. [pmid: 22494095].
Sands CD, Hensarling RW, Angel JB. Comparison of health-related measures of two groups of adolescents in a rural southeastern country in the United States. Health Education Journal. 2009;68(4):273-283.
Santos EMC, Tassitano RM, do Nascimento WMF, et al. Satisfacao com o peso corporal e fatores associados em estudantes do ensino medio. Body satisfaction and associated factors among high school students. Rev Paul Pediatr. 2011;29(2):214-23.
Sarkkola C, Simola S, Seppanen V, et al. Childhood growth environment and genetic factors as determinants of overweight and obesity - The Finnish Health in Teens study - Fin-hit. Obes Rev. 2011;12:248.
Sarra A, Papaefthymiou M, Karantza M, et al. Bone density and physical fitness status in female Greek adolescents. Bone. 2011;48:S246.
Schoffl I, Schoffl V, Dotsch J, et al. Correlations between high level sport-climbing and the development of adolescents. Pediatr Exerc Sci. 2011;23(4):477-86. [pmid: 22109775].
Schonbeck Y, Talma H, Van Dommelen P, et al. Trends in overweight and obesity among children of Dutch, Turkish and Moroccan origin in The Netherlands: 1997-2009. Obes Rev. 2011;12:252.
Schwandt P, Bertsch T, Liepold E, et al. Nutrition and cardiovascular risk factors in children: The PEP Family Heart Study. Eur Heart J. 2011;32:721. [pmid: 21177700].
Sekhobo JP, Egglefield K, Edmunds LS, et al. Evidence of the adoption and implementation of a statewide childhood obesity prevention initiative in the New York State WIC Program: the NY Fit WIC process evaluation. Health Educ Res. 2012;27(2):281-91. [pmid: 22052217].
Seo DC, Lee CG. Association of school nutrition policy and parental control with childhood overweight. J Sch Health. 2012;82(6):285-93. [pmid: 22568464].
Shaikh U, Nettiksimmons J, Bell RA, et al. Accuracy of parental report and electronic health record documentation as measures of diet and physical activity counseling. Acad Pediatr. 2012;12(2):81-7. [pmid: 22209035].
Shroff MR, Jones SJ, Frongillo EA, et al. Policy instruments used by states seeking to improve school food environments. Am J Public Health. 2012;102(2):222-9. [pmid: 22390436].
Siegrist M, Hanssen H, Lammel C, et al. Inflammation factors, physical fitness and obesity in children: cross-sectional results of a comprehensive school-based intervention study (JuvenTUM). Eur J Cardiovasc Prev Rehabil. 2011;18(1):S17.
Sigman-Grant M, Byington T, Lindsay A, et al. Preschoolers distinguish between healthy and unhealthy snack foods. FASEB J. 2011;25:30.2.
Silva AL, Ramos C, Carvalho MA, et al. Demographic variables and childhood obesity in a community-based program in Portugal. Obes Rev. 2011;12:102.
Singh A. ENERGY-project. Obes Rev. 2011;12:5-6.
Skatrud-Mickelson M, Adachi-Mejia AM, Sutherland LA. Tween sex differences in snacking preferences during television viewing. J Am Diet Assoc. 2011;111(9):1385-90. [pmid: 21872703].
Skatrud-Mickelson M, Adachi-Mejia AM, Sutherland LA. Tween sex differences in snacking preferences during television viewing. J Am Diet Assoc. 2011;111(9):1385-90. [pmid: 21872703].
Slingerland M, Borghouts LB, Hesselink MK. Physical activity energy expenditure in Dutch adolescents: contribution of active transport toschool, physical education, and leisure time activities. J Sch Health. 2012;82(5):225-232. [pmid: 22494093].
Sonneville KR, Calzo JP, Horton NJ, et al. Body satisfaction, weight gain and binge eating among overweight adolescent girls. Int J Obes. 2012;36(7):944-9.
Speers SE, Harris JL, Schwartz MB. Child and adolescent exposure to food and beverage brand appearances during prime-time television programming. Am J Prev Med. 2011;41(3):291-296. [pmid: 21855743].
Spurrier NJ, Volkmer RE, Abdallah CA, et al. South Australian four-year-old Aboriginal children: residence and socioeconomic status influence weight. Aust N Z J Public Health. 2012;36(3):285-90. [pmid: 22672037].
St George SM, Wilson DK, Lawman HG, et al. The effects of BMI status and motivation on physical activity in underserved adolescents. Obesity. 2011;19:S203.
Stojanovic D, Markovic D, Radjen S. Prevalence of obesity in preschool children. Ann Nutr Metab. 2011;58:240.
Storfer-Isser A, Patel SR, Babineau DC, et al. Relation between sleep duration and BMI varies by age and sex in youth age 8-19. Pediatr Obes. 2012;7(1):53-64. [pmid: 22434739].
Strutz KL, Richardson LJ, Husse JM. Preconception health trajectories and birth weight in a national prospective cohort. J Adolesc Health. 2012. [Epub ahead of print].
Stubbs J, Pallister C, Avery A, et al. Weight, body mass index and behaviour change in a commercially run lifestyle programme for young people. J Hum Nutr Diet. 2012;25(2):161-6. [pmid: 22320706].
Sturm R, Datar A. Food prices and weight gain during elementary school:5-year update. Public Health. 2008;122(11):1140-1143. [pmid: 18539306].
Suarez C, Ferreira Monteiro A, Macri E, et al. High-fat diets and body composition over two generations. An experimental study. Endocrinol Nutr. 2012;59(4):232-8. [pmid: 22406127].
Sugerman S, Backman D, Foerster SB, et al. Using an opinion poll to build an obesity-prevention social marketing campaign for low-income Asian and Hispanic immigrants: report of findings. J Nutr Educ Behav. 2011;42(4S2):S53-66. [pmid: 21683292].
Sunami Y, Nguyen DMT, Kumahara H, et al. Effects of the physical activity during school physical education on daily physical activities among swiss elementary school children. Obes Facts. 2012;5:240.
Svensson V, Lundborg L, Cao Y, et al. Obesity related eating behaviour patterns in Swedish preschool children and association with age, gender, relative weight and parental weight - factorial validation of the children's eating behaviour questionnaire. Int J Behav Nutr Phys Act. 2011;8:1-27. [pmid: 21194492].
Tabacchi G, Bianco A, Mammina C. A web-based system for nutritional surveillance. The project asso - Adolescents and surveillance system for obesity prevention. Ann Nutr Metab. 2011;58:416.
Taber D, Stevens J, Poole C, et al. State disparities in time trends of adolescent Body Mass Index percentile and weight-related behaviors in the United States. J Community Health. 2012;37(1):242-52. [pmid: 21773818].
Taras HL, Sallis JF, Patterson TL, et al. Television's influence on children's diet and physical activity. J Dev Behav Pediatr. 1989;10(4):176-180. [pmid: 2768484].
Taylor A, Wilson C, Slater A, et al. Parent- and child-reported parenting. Associations with child weight-related outcomes. Appetite. 2011;57(3):700-6. [pmid: 21896297].
Taylor JP, MacLellan D, Caiger JM, et al. Implementing elementary school nutrition policy: Principals' perspectives. Can J Diet Pract Res. 2011;72(4):176. [pmid: 22146114].
Teevale T, Scragg R, Faeamani G, et al. Pacific parents' rationale for purchased school lunches and implications for obesity prevention. Asia Pac J Clin Nutr. 2012;21(2):282-90. [pmid: 22507616].
Thow AM, Snowdon W, Schultz JT, et al. The role of policy in improving diets: experiences from the pacific obesity prevention in communities food policy project. Obes Rev. 2011;12(Suppl 2):68-74. [pmid: 22008561].
Tin SP, Ho SY, Mak KH, et al. Location of breakfast consumption predicts body mass index change in young Hong Kong children. Int J Obes (Lond). 2012;36(7):925-30. [pmid: 22234278].
Torio CM. The role of the geographic information systems infrastructure in childhood obesity prevention: perspective from the Robert Wood Johnson Foundation. Am J Prev Med. 2012;42(5):513-5. [pmid: 22516492].
Townsend N, Murphy S, Moore L. The more schools do to promote healthy eating, the healthier the dietary choices by students. J Epidemiol Community Health. 2011;65(10):889-95. [pmid: 21118953].
Trang NH, Hong TK, Dibley MJ. Active commuting to school among adolescents in Ho Chi Minh City, Vietnam: change and predictors in a longitudinal study, 2004 to 2009. Am J Prev Med. 2012;42(2):120-8. [pmid: 22261207].
Treiber F, Harshfield G, Davis H, et al. Stress responsivity and body fatness: Links between socioeconomic status and cardiovascular risk factors in youth. 1999;896:435-438.
Troupe S, Blake R, O'Rourke F, et al. The obesity epidemic: Does socioeconomic status exacerbate sedentary behavior?. Obesity. 2011;19:S111.
Tuan NT, Butte NF, Nicklas TA. Body mass index distribution affects discrepancies in weight classifications in children. Pediatr Int. 2012;54(2):256-65. [pmid: 22168359].
Tyndall A. Help end childhood obesity within a generation. KY Nurse. 2011;59(3):19.
Vafa M, Afshari Sh, Moslehi N, et al. Relationship between infant nutrition feeding and childhood obesity in first grade Tehranian students of primary schools, 2009. Iran J Endocrinology Metab. 2011;12(5):505-60.
Van Mil EGAH, Goris AHC, Westerterp KR. Physical activity and the prevention of childhood obesity. Europe versus the United States. Int J Obes. 1999;23(3Suppl):S41-S44.
Van Sluijs EMF. Energy balance and determinants in children. Obes Rev. 2011;12:24.
van Stralen MM, te Velde SJ, van Nassau F, et al. Weight status of European preschool children and associations with family demographics and energy balance-related behaviours: a pooled analysis of six European studies. Obes Rev. 2012;13(Suppl 1):29-41. [pmid: 22309063].
Vander Ploeg K, Maximova K, Veugelers P. Self -reporteand pedometer measured physical activity of Canadian children. Am J Epidemiol. 2011;173:S331.
Vander Wal JS. The relationship between body mass index and unhealthy weight control behaviors among adolescents: The role of family and peer social support. Econ Hum Biol. 2012;10(4):395-404. [pmid: 22609397].
Vania A, Parisella V, Capasso F, et al. Early childhood caries underweight or overweight, that is the question. Eur J Paediatr Dent. 2011;12(4):231-5. [pmid: 22185246].
Vasquez-Garibay EM, Gonzalez-Rico JL, Cabrera-Pivaral C, et al. Differences in the score of areas of family dynamic between obese vs. non obese school children. FASEB J. 2011;25:591.4.
Vassiloudis I, Yiannakouris N, Apostolopoulos K, et al. Lifestyle and behavioural factors associated with increased Body Mass Index (BMI) in Greek primary school children. Proc Nutr Soc. 2011;70(6):E388.
Veltsista A, Kanaka C, Palili A, et al. Predictors of change in BMI z-score from childhood to adolescence in a Greek birth cohort. Eur J Clin Invest. 2011;41:67.
Verloigne M, Van Lippevelde W, Maes L, et al. Levels of physical activity and sedentary time among 10- to 12-year-old boys and girls across 5 European countries using accelerometers: An observational study within the ENERGY-project. Int. J. Behav. Nutr. Phys. Act. 2012;9:34. [pmid: 22462550].
Virus A, Wojtanowski A, Veur S, et al. Breakfast consumption among low-income, ethnically diverse 4th-8th graders. Obesity. 2011;19:S109-S110.
Visich PS, Saltarelli B, Doshi M, et al. The cardiovascular health intervention program (CHIP): A university-based program to assess obesity, cardiovascular risk factors and metabolic syndrome in 6th grade students. Obesity. 2011;19:S221.
von Kries R, Beyerlein A, Muller MJ, et al. Different age-specific incidence and remission rates in pre-school and primary school suggest need for targeted obesity prevention in childhood. Int J Obes (Lond). 2012;36(4):505-10. [pmid: 22184059].
Voorhees CC, Yan AF, Clifton KJ, et al. Am J of Health Behav. 2011;35(6):674-88. [pmid: 22251759].
Wang N, Xu F, Zheng L-Q, et al. Effects of television viewing on body fatness among Chinese children and adolescents. Chin Med J. 2012;125(8):1500-03. [pmid: 22613659].
Wang YC, Orleans CT, Gortmaker SL. Reaching the healthy people goals for reducing childhood obesity: Closing the energy gap. Am. J Prev Med. 2012;42(5):437-44. [pmid: 22516482].
Ward DS, Mazzucca S, Hales D, et al. Parenting self-efficacy for children's healthy weight behaviors: Relationship to body weight status in preschool-aged children. Obesity. 2011;19:S122.
Wardle J, Brodersen NH, Boniface D. School-based physical activity and changes in adiposity. Int J Obes(Lond). 2007;31(9):1464-8. [pmid: 17515912].
Warschburger P, Kroller K. Childhood overweight and obesity: maternal perceptions of the time for engaging in child weight management. BMC Public Health. 2012;12(1):295. [pmid: 22520114].
Watanabe E, Lee JS, Kawakubo K. Associations of maternal employment and three-generation families with pre-school children's overweight and obesity in Japan. Int J Obes. 2011;35(7):945-52.
Welk GJ, De Saint-Maurice Maduro PF, Laurson KR, et al. Field evaluation of the new FITNESSGRAM criterion-referenced standards. Am J Prev Med. 2011;41(4 Suppl 2):S131-42. [pmid: 21961613].
White A, O'Brien B, Houlihan T, et al. Childhood obesity; parents fail to recognise. General practitioners fail to act. Ir Med J. 2012;105(1):10-3. [pmid: 22397205].
White J, Jago R. Prospective associations between physical activity and obesity among adolescent girls: racial differences and implications for preventing physical and obesity among girls. Arch Pediatr Adolesc Med. 2012;166(6):522-7. [pmid: 22665029].
Whitrow MJ, Moore VM, Davies MJ. Waist-to-height ratio is not a predictor of systolic blood pressure in 3-year-old children. J Pediatr. 2011;159(3):501-3. [pmid: 21723566].
Wijnhoven TMA, Van Raaij JMA, Spinelli A, et al. WHO european childhood obesity surveillance initiative: inter-country results from first 12 WHO member states. Obes Facts. 2012;5:13-4.
Wilkin TJ. Can we modulate physical activity in children? No. Int J Obes (Lond). 2011;35(10):1270-6. [pmid: 21829160].
Wilksch S. Role of schools in prevention of obesity and eating disorders. Obes Res Clin Pract. 2011;5:S10.
Williams A. CHILDHOOD OBESITY dooms day COUNTDOWN. IDEA Fitness J. 2011;8(10):48-57.
Williamson DA, Han H, Johnson WD, et al. Longitudinal study of body weight changes in children: Who is gaining and who is losing weight. Obesity. 2011;19(3):667-70. [pmid: 20885393].
Willits-Smith A, Dickin KL. Factors that influence low-income families' use of recommended nutrition and parenting practices to prevent unhealthy weight gain in children: an exploratory study. FASEB J. 2011;25:781.8.
Wilson DK, Schneider EM, Kugler KA, et al. The relationship between parenting factors and pediatric obesity. Obesity. 2011;19:S119.
Wilson TA, Butte NF, Barlow SE, et al. Predictors of BMI improvement in Hispanic children participating in mind, exercise, nutrition, do it! (MEND) weight management program. Obesity. 2011;19:S108.
Wolnicka K, Jaczewska-Schuetz J, Taraszewska A. Eating habits in relation to the Body Mass Index (BMI) in group of Polish adolescents from selected primary schools. Ann Nutr Metab. 2011;58:245. [pmid: 21846975].
Wright KN. Influence of body mass index, gender, and Hispanic ethnicity on physical activity in urban children. J Spec Pediatr Nurs. 2011;16(2):90-104. [pmid: 21438999].
Wu MP, Wu SF, Wang TC, et al. Effectiveness of a community-based health promotion program targeting people with hypertension and high cholesterol. Nurs Health Sci. 2012;14(2):173-81. [pmid: 22380735].
Wu XY, Ohinmaa A, Veugelers PJ. Diet quality, physical activity, body weight and health-related quality of life among grade 5 students in Canada. Public Health Nutr. [Epub ahead of print]. 2011:1-7. [pmid: 21211099].
Yeh Y, Lin K, Jen C, et al. Preschoolers' nutrition knowledge correlated with making healthy food choices and body weight status. Obesity. 2011;19:S210.
Yu ML, Ziviani JM, Haynes M. Sleep, structured and social time use and young Australian children's physical activity. Health Promot J Austr. 2011;22(3):203-9. [pmid: 22497064].
Zandian M, Ioakimidis I, Bergstrom J, et al. Children eat their school lunch too quickly: an exploratory study of the effect on food intake. BMC Public Health. 2012;12(1):351. [pmid: 22583917].
Zhang J, Himes JH, Hannan PJ, et al. Summer effects on body mass index (BMI) gain and growth patterns of American Indian children from kindergarten to first grade: a prospective study. BMC Public Health. 2011;11:951. [pmid: 22192795].
Zhang N, Zhang Q. Does early school entry prevent obesity among adolescent girls?. J Adolesc Health. 2011;48(6):644-6. [pmid: 21575829].
Zhang X, Sun J. Hypertension in children and adolescents within community and its risk factors. Int J Cardiol. 2011;152:S62.
Zhao J, Bradfield JP, Li M, et al. BMD-associated variation at the Osterix Locus is correlated with childhoof obesity in females. Obesity. 2011;19(6):1311-4. [pmid: 21212767].

## Abstract only

Adams A, LaRowe T, Cronin KA, et al. Healthy children, strong families: Results of a randomized trial of obesity prevention for preschool American Indian children and their families. Obesity. 2011;19:S110.
Antoine B, Jerome B, Susi K, et al. Effects of a physical activity intervention in children attending child care (youp'la bouge program): A cluster-randomized controlled trial. Obes Facts. 2012;5:71.
Bohlin A, Klaesson S, Kowalski J. Can telephone consultations substitute visits in treatment of childhood obesity? Results from a randomized trial. Obes Facts. 2012;5:237.
Brindal E, Hendrie G, Noakes M, et al. A randomised controlled trial to compare the effect of breakfast cereals differing in fibre content on short-term appetite and mood in 8-12 year old children. Australas Med J. 2011;4(12):706.
Brown BD, Noonan C, Harris KJ, et al. Diabetes prevention program for native american youth: The journey to native youth health feasibility study. Diabetes. 2011;60:A82.
Bucher Della Torre S, Dudley-Martin F, Kruseman M. Development and testing of an obesity prevention program for young children at risk, and their parents. Ann Nutr Metab. 2011;58:260.
Dubois L, Girard M. Genetic and environmental influences on children's food intake and obesity in a Canadian twin birth cohort. Twin Res Hum. Genet. 2010;13(3):255.
Dumontet J, Durksen A, Lamboo-Miln A, et al. Healthy Buddies Manitoba: A cluster randomized controlled effectiveness trial of a peer-led healthy living lesson plan on unhealthy weight gain and physical activity in early years students. Can J Diabetes. 2011;35(2):164.
Eagle TF, Gurm R, Smith C, et al. Immediate impact of a 10-week middle school intervention to improve health behaviors and reduce cardiovascular risk factors-project healthy schools in michigan. J Am Coll Cardiol. 2012;59(13):E1797.
Fogelholm M, Lahti-Koski M. Community health-promotion interventions with physical activity: does this approach prevent obesity?. (Structured abstract). Scand J Nutr. 2002;46(4):173-177.
Fung C, Purcell M, Lu C, et al. The effectiveness of comprehensive school health in improving healthy eating and physical activity and preventing childhood obesity: The Alberta project promoting active living and healthy eating in schools APPLE schools. Can J Diabetes. 2011;35(2):190.
Gance-Cleveland B, Renteria F, Choi M, et al. Obesity prevention intervention for middle school youth. Commun Nurs Res. 2010;43:565.
Golley RK, Hendrie GA, Slater A, et al. Interventions that involve parents to improve children's weight-related nutrition intake and activity patterns: what nutrition and activity targets and behaviour change techniques are associated with intervention effectiveness?. (Provisional abstract). Obes Rev. 2011;12(2):114-30. [pmid: 20406416].
Greig E, Davis S, Myers O. Women Infants and Children (WIC) Policy change: Effects on fruit and vegetable consumption among low-income children New Mexico. J Invest Med. 2011;59(1):144.
Gubanich PJ, Kimmerlee K, Gubanich KM, et al. Interim analysis of a 2-year childhood wellness intervention: A gain in knowledge. Clin J Sport Med. 2011;21(2):155-6.
Hansen HS1. Blood pressure and physical fitness in children: Odense schoolchild study. J Hypertens. 1992;10(8):897.
Hollar D, Messiah SE, Lopez-Mitnik G, et al. School-based obesity and related cardiovascular disease prevention intervention effect on weight and academic performance: Three-year results. Can J Diabetes. 2011;35(2):164.
Hruby A, Chomitz V, Arsenault LN, et al. School-based fitness: Impact on remission of overweight/obesity in urban children. Obesity. 2011;19:S70.
Jensen BW, Nielsen BM, Husby I, et al. Soft drink intake at age 6 and 9 and the association with BMI 3 and 7 years later-A follow-up study based on the Copenhagen School Child Intervention Study (COSCIS). Obes Rev. 2011;12:96.
Kellou N, Schweitzer B, Dugas J, et al. Low parental intention to exercise is associated with a higher impact of a physical activity program in adolescents: Results from icaps, a 4-year multilevel randomized study. Obes Facts. 2012;5:37.
Kovacs VA, Varga A, Balogh L, et al. School-based interventions against childhood obesity in Hungary. Obes Rev. 2011;12:69. [pmid: 20524997].
Kuru NK, Nerganullrdh R, Bohlin A, et al. Experience of creating multi-disciplinary treatment team to treat children obesity at pediatric outpatient clinics: A preliminary report of the SVK-project ‘Develop and evaluate a coherent chain of care for children and adolescents with obesity in the Stockholm county’. Obes Rev. 2011;12:193.
Lamerson M, Corrigan J. Healthy Kids Program. J Pediatr Nurs. 2006;21(3):234-235.
Martinez ME. Prevention of diabetes and obesity in children and teenagers through the Coubertin educational model. Diabetologia. 2011;54:S351.
Martins S, Palmeira A, Minderico C, et al. Longitudinal outcomes of a school-based lifestyle promotion program: Preliminary results. J Adolesc Health. 2011;48(2):S79.
Millar L, Kremer P, De Silva-Sanigorski A, et al. Behavioural and environmental changes and concomitant increases in schools' capacity during the it's your move! adolescent, community-based obesity prevention intervention. Obes Rev. 2011;12:67.
Millar L, Kremer P, Fotu K, et al. Preventing obesity in adolescents from different cultures: Findings of The 3-year pacific Obesity Prevention in Communities (OPIC) project. Obes Facts. 2012;5:246.
Mistry AM, Blake M. Differences in food intake, nutrition knowledge and fitness assessment measurements in high school students who have completed the nutricise 4 life program and students who have not. FASEB J. 2011;25:781.27.
Mitchell M. Do African American Latino and Caucasian parents and children benefit equally from a weight management intervention?. South Online J Nurs Res. 2008;8(2):2p.
Mohan S, Gurm R, Corriveau N, et al. Response to a school-based wellness intervention program in four communities with differing resources. J Am Coll Cardiol. 2012;59(13):E1852.
Niederer I, Burgi F, Ebenegger V, Schindler C, et al. Effect of a lifestyle intervention on adiposity and fitness in high-risk subgroups of preschoolers (Ballabeina): A cluster-randomized trial. Endocr Rev. 2011;32(3).
Nielsen BM, Husby I, Tholstrup T, et al. Intake of protein and fat from dairy products and their relation to metabolic risk components among danish children. Obes Rev. 2011;12:43.
O'Malley C, Batterham A, Summerbell C, et al. Preventing childhood obesity: The teescake project. Obes Facts. 2012;5:246.
Ostbye T, Fuemmeler B, Malhotra R, et al. The effect of the home environment on directly measured physical activity in young children: Results from kan-do. Obes Facts. 2012;5:19.
Pentz MA, Huh J, Riggs NR, et al. Effects of a childhood obesity prevention program aimed at executive cognitive function: The pathways trial. Obesity. 2011;19:S121.
Persichetti T, Sica A, Pierangeli S, et al. Take weight off food!: From diet to lifestyle. Obes Rev. 2011;12:75.
Serge B, Emilie B, Nelly A, et al. Effectiveness of three overweight and obesity prevention strategies in high school adolescents. the pralimap controlled cluster randomised trial. Obes Rev. 2011;12:65-6.
Shin A, Dennisuk L, Martins P, et al. Adolescents improve healthy-eating outcome expectancy: Impact of the Baltimore Healthy Eating Zones study. FASEB J. 2011;25:973.1.
Simhaee D, Gurm R, Jackson EA, et al. Heart Rate Recovery: An indicator of fitness among middle school children. J Am Coll Cardiol. 2011;57(14):E482.
Simon C, Schweitzer B, Drai J, et al. Overweight prevention in adolescents by increasing physical activity: 6-year results of the randomized ICAPS study. Obes Rev. 2011;12:26. [pmid: 20070542].
Slawson DL, Maury JJ, Dalton WT, et al. Reductions in the prevalence of overweight and obesity among children in Tennessee. Obesity. 2011;19:S127.
Stahl C, Necheles J, Mayefsky J. Pediatric resident education to address the obesity epidemic in the clinical setting: Reported changes in teens. J Adolesc Health. 2011;48(2):S40.
Stoddard SA, Kubik MY, Savik K. Primary and secondary prevention of obesity in older female adolescents attending a reproductive health clinic: a missed opportunity to intervene. J Adolesc Health. 2007;40(2):S34.
Swinburn B, Malakellis M, De Silva-Sanigorski A, et al. Is The ‘obesity prevention virus’ spreading? Childhood obesity substantially reduced in both intervention and comparison areas 3 years after completion of The be active eat well project in Colac, Victoria. Obes Facts. 2012;5:242-3.
Vargo K, Kennedy E, Fisher J, et al. Sustaining change: Long term maintenance of weight loss following completion of a weight management program for children and adolescents. J Adolesc Health. 2012;50(2):S34-5.
Viggiano A, Viggiano E, Viggiano A, et al. Kaledo, a new educational board-game for nutrition education: Cluster randomized trial of healthy lifestyle promotion. Obes Facts. 2012;5:260.
Viggiano E, Amaro S, Viggiano AL, et al. Kaledo, a new educational board-game for nutrition education. Obes Rev. 2011;12:72-3.
Water in schools may cut obesity risks in children. Nutrition Health Review: The Consumer's Medical Journal. 2010;(102):13.
Winham DM, Wolven JR, Thompson SV, et al. Changes in BMI and dietary intakes after implementation of the USDA fresh fruit and vegetable program. FASEB J. 2011;25.
Wyatt KM, Lloyd J. Is the healthy lifestyle programme an acceptable and feasible school-based intervention to prevent obesity?. Obes Rev. 2011;12:270-1.
Wyse R, Wolfenden L, Campbell E, et al. Increasing fruit and vegetable consumption in 3- 5 year old children: Results from a cluster randomised controlled trial of a telephone-based parent intervention, hunter region, NSW, Australia. Obes Rev. 2011;12:68. [pmid: 22008561].
Yancey AT. Physical activity program for preschool children fails to reduce body mass index. J Pediatr. 2007;150(5):561. [pmid: 17452239].

## Qualitative study

Anderson DM, Skemp KM. Self-image differences as related to body image of students in a middle school. Am J Health Behav. 2012;36(4):533-41. [pmid: 22488403].
Anzeljc SA, Murray R. A comprehensive plan for helping children avoid obesity - A pilot study. FASEB J. 2011;25:781.18.
Bagwell R, Wong SS. What do health professionals, limited-income parents and children ages 6-11 think are practical ways to prevent childhood obesity?. FASEB J. 2011;25:99.5. [pmid: 20826541].
Berge JM, Arikian A, Doherty WJ, et al. Healthful eating and physical activity in the home environment: results from multifamily focus groups. J Nutr Educ Behav. 2012;44(2):123-31. [pmid: 22192951].
Berge JM. What is being served for dinner? Associations between the emotional atmosphere at family meals and health outcomes. Obesity. 2011;19:S130.
Berger M, Day SE, Konty K. Trends in prevalence of overweight and obesity in New York city public school students 2006-2009. Obesity. 2011;19:S151.
Berz JP, Singer MR, Guo X, et al. Use of a DASH food group score to predict excess weight gain in adolescent girls in the National Growth and Health Study. Arch Pediatr Adolesc Med. 2011;165(6):540-6. [pmid: 21646587].
Borys JM, Le Bodo Y, Jebb SA, et al. EPODE approach for childhood obesity prevention: methods, progress and international development. Obes Rev. 2012;13(4):299-315. [pmid: 22106871].
Burgic Radmanovic M, Burgic S. Female adolescents and body image. Eur Child Adolesc Psychiatry. 2011;20:S173.
Chang KJ, Kim SY. Understanding and utilization of nutrition labeling in Korean middle school students. FASEB J. 2011;25:770.21.
Chhichhia P, Khan FA, Kumar E, et al. Culturally tailored education to South Asian (SA) populations in Auckland successfully promotes early screening and prevention of cardiovascular diseases (CVD) and diabetes. Obes Res Clin Pract. 2011;5:S59.
Chika S, Ferro ES, Goodell LS. Assessing teachers' perceptions of facilitators and motivators for promoting fruit and vegetable consumption in preschoolers. FASEB J. 2011;25:99.8. [pmid: 20826541].
Christiansen K, Qureshi F, Schaible A, et al. Influence of the built and social environment on adolescent eating behaviors in Baltimore City: findings from the Baltimore Healthy Eating Zones study. FASEB J. 2011;25:973.5.
Downs SM, Farmer A, Quintanilha M, et al. Alberta nutrition guidelines for children and youth: awareness and use in schools. Can J Diet Pract Res. 2011;72(3):137-40. [pmid: 21896251].
Dryden EM, Hardin J, McDonald J, et al. Provider perspectives on electronic decision supports for obesity prevention. Clin Pediatr. 2012;51(5):490-7.
Ehrenstein V, Froslev T, Bakketeig LS, et al. Prenatal exposure to systemic antiinfectives and overweight and obesity at school age. Pharmacoepidemiol Drug Saf. 2011;20:S47-S48.
Eloranta AM, Lindi V, Schwab U, et al. Dietary factors associated with overweight and body adiposity in Finnish children aged 6-8 years: the PANIC Study. Int J Obes. 2012;36(7):950-5.
Everley S. What do children value in physical activity? the role of physical, social, and cultural capital in encouraging health behaviours. Obes Facts. 2012;5:264.
Farajian P, Panagiotakos DB, Risvas G, et al. Socio-economic and demographic determinants of childhood obesity prevalence in Greece: the GRECO (Greek Childhood Obesity) study. Public Health Nutr. [Epub ahead of print]. 2012:1-8. [pmid: 23294865].
Ferreira F, Mota JA, Duarte J. Prevalencia de excesso de peso e obesidade em estudantes adolescentes do distrito de Castelo Branco: um estudo centrado no indice de massa corporal, perimetro da cintura e percentagem de massa gorda. Prevalence of overweight and obesity in school adolescents of Castelo Branco district, Portugal: a study based in body mass index, waist circumference and percentage of body fat. Revista Port Saude Publica. 2012;30(1):47-54.
Field P, Gauld R. How do vested interests maintain outdated policy? The case of food marketing to New Zealand children. Open Health Serv Policy J. 2011;4:30-38.
Frenn M, Heinrich A, Dohmen CS, et al. What can parents do to reduce youth obesity? An initial study with a diverse sample. J Pediatr Nurs. 2011;26(5):428-34. [pmid: 21930029].
Frizzell L, Canning P. High rates of high birthweight, accelerated early growth, and overweight and obesity at preschool: further support for pre-and post-natal intervention. Obes Facts. 2012;5:242.
Fromson JA, Sutton-Skinner KM, Gorrindo T, et al. Attention to body mass index by child psychiatry providers when prescribing second-generation antipsychotic medication to children: a survey study using a clinical vignette. Early Intervent Psychiatry. 2012;6(2):195-200.
Gellar L, Druker S, Osganian SK, et al. Exploratory research to design a school nurse-delivered intervention to treat adolescent overweight and obesity. J Nutr Educ Behav. 2012;44(1):46-54. [pmid: 21962865].
Gerards SM, Dagnelie PC, Jansen MW, et al. Barriers to successful recruitment of parents of overweight children for an obesity prevention intervention: a qualitative study among youth health care professionals. BMC Fam Pract. 2012;13(1):37. [pmid: 22591134].
Gittelsohn J, Toporoff EG, Story M, Evans, et al. Food perceptions and dietary behavior of American-Indian children their caregivers and educators: formative assessment findings from Pathways. J Nutr Educ Behav. 2000;3(1):2-13.
Goldstein TR, Goldstein BI, Mantz MB, et al. A brief motivational intervention for preventing medication-associated weight gain among youth with bipolar disorder: treatment development and case report. J Child Adolesc Psychopharmacol. 2011;21(3):275-80. [pmid: 21663430].
Gubbels JS, Thijs C, Stafleu A, et al. Association of breast-feeding and feeding on demand with child weight status up to 4 years. Int J Pediatr Obes. 2011;6(2-2):e515-22. [pmid: 20858157].
Hakkak R, Carroll P, Gonzales D, et al. A longitudinal study of body mass index in head start children: a ten year follow-up. J Invest Med. 2011;59(2):475.
Hampl S, Paves H, Laubscher K, et al. Patient engagement and attrition in pediatric obesity clinics and programs: results and recommendations. Pediatrics. 2011;128:S59-64. [pmid: 21885646].
Helfert S, Warschburger P. A prospective study on the impact of peer and parental pressure on body dissatisfaction in adolescent girls and boys. Body Image. 2011;8(2):101-109. [pmid: 21354379].
Hessler K, Siegrist Mary. Nurse practitioner attitudes and treatment practices for childhood overweight: how do rural and urban practitioners differ?. J Am Acad Nurse Pract. 2012;24(2):97-106. [pmid: 22324865].
Holst M, Rasmussen HH, Mortensen MN, et al. Improving communication in nutritional practice: an intervention study. Clin Nutr Suppl. 2011;6(1):178.
Huang SY, Hogg J, Zandieh S, et al. A ballroom dance classroom program promotes moderate to vigorous physical activity in elementary school children. Am J Health Promot. 2012;26(3):160-5. [pmid: 22208413].
Hunsberger M, Eiben G, Lanfer A, et al. Infant feeding practices and prevalence of obesity and overweight in eight European countries. Clin Nutr Suppl. 2011;6(1):179.
Hur IY, Reicks M. Relationship between whole-grain intake, chronic disease risk indicators, and weight status among adolescents in the National Health and Nutrition Examination Survey, 1999-2004. J Acad Nutr Diet. 2012;112(1):46-55. [pmid: 22717176].
Hwang KO, Stuckey H, Chen M, et al. Primary care providers' attitudes and experiences with online weight control programs. J. Gen. Intern Med. 2011;26:S123.
James N, Shilton T, Maitland C, et al. Encouraging children to Unplug and Play: Results of research with parents. J Sci Med Sport. 2011;14:e42.
Janitz AE, Moore WE, Stephens AL, et al. Weight status of American Indian and white elementary school students living in the same rural environment, Oklahoma, 2005-2009. Prev Chronic Dis. 2012;9:E78. [pmid: 22482137].
Jones MG, Verity FE. Message in postbox: Eat Well Be Active community programs from a child's world-view. Obes Res Clin Pract. 2011;5:S70-1.
Jurkowski JM, Green Mills LL, Lawson HA, et al. Engaging Low-Income Parents in Childhood Obesity Prevention from Start to Finish: A Case Study. J Community Health. 2012. [Epub ahead of print].
Kaczmarski JM, DeBate RD, Marhefka SL, et al. State-mandated school-based BMI screening and parent notification: a descriptive case study. Health Promot Pract. 2011;12(6):797-801. [pmid: 22068272].
Kesten J, Griffiths P, Cameron N. The role of community readiness in reducing the risk of overweight and obesity in a UK community of pre-adolescent girls. Obes Facts. 2012;5:25.
Kipping RR, Jago R, Lawlor DA. Developing parent involvement in a school-based child obesity prevention intervention: a qualitative study and process evaluation. J Public Health (Oxf). 2012;34(2):236-44. [pmid: 21937589].
Kranz S, Zuercher J, Marshall YW. Low-income children in rural eastern North Carolina: specific diet and lifestyle factors put them at high risk for obesity. FASEB J. 2011;25:781.5.
Kytta AM, Broberg AK, Kahila MH. Urban environment and children's active lifestyle: softGIS revealing children's behavioral patterns and meaningful places. Am J Health Promot. 2012;26(5):e137-48. [pmid: 22548432].
Laurent JS. How parents promote health for their overweight or obese child. Obesity. 2011;19:S134.
Lawrence HP, Romanetz M, Rutherford L, et al. Effects of a community-based prenatal nutrition program on the oral health of Aboriginal preschool children in northern Ontario. Probe(08341494). 2004;38(4):172.
Leacy KA, Cane JN. Effect of non-select menus on weight and eating concern in adolescents hospitalized with anorexia nervosa. Eating Disord. 2012;20(2):159-167.
Leonard CP, D'Augelli AR, Smiciklas-Wright H. Effects of a weight-control promotion program on parents' responses to family eating situations. J Am Diet Assoc. 1984;84(4):424-7. [pmid: 6707397].
Magnusson MB, Kjellgren KI, Winkvist A. Enabling overweight children to improve their food and exercise habits.school nurses' counselling in multilingual settings. J Clin Nurs. 2012;21(17-18):2452-60. [pmid: 22686241].
Mahfouz AA, Shatoor AS, Khan MY, et al. Nutrition, physical activity, and gender risks for adolescent obesity in Southwestern Saudi Arabia. Saudi J Gastroenterol. 2011;17(5):318-22. [pmid: 21912058].
Mark S, Wang J, Gray-Donald K, et al. Sugar-sweetened beverage intake and metabolic syndrome omponents among children at high risk of obesity. Can J Diabetes. 2011;35(2):142.
Marks J, Barnett L, Foulkes C, et al. A systems-based approach within long day care centres for obesity prevention in children aged 3-5. Obes Res Clin Pract. 2011;5:S71.
Martinez-Gomez D, Eisenmann JC, Tucker J, et al. Associations between moderate-to-vigorous physical activity and central body fat in 3-8-year-old children. Int J Pediatr Obes. 2011;6(2-2):e611-4. [pmid: 21091103].
Mazzeo SE, Kelly NR, Palmberg A, et al. Developing an intervention for binge eating among African American adolescent girls: results of focus groups with mothers and daughters. Obesity. 2011;19:S107-8.
Meyer KA, Friend S, Hannan PJ, et al. Ethnic variation in body composition assessment in a sample of adolescent girls. Int J Pediatr Obes. 2011;6(5-6):481-90. [pmid: 21749194].
Mikulec EJ, Goniu NF, Brockman LN, et al. Urban, suburban, and rural: adolescents' use and preferences for fitness promotion technologies across communities. Pediatr Res. 2011;70(4):437.
Milder I, Mikolajczak J, Van Den Berg S, et al. Changes in school environment and actions regarding overweight prevention among dutch secondary schools between 2006-2007 and 2010-2011. Obes Facts. 2012;5:257.
Moroshko I, Brennan L. Parent-preschooler feeding interaction and its association with child diet and weight. Obes Res Clin Pract. 2011;5:S69-70.
Msengi I, Killion L. An analysis of overweight and obesity levels of adolescents in a southeast texas region. Obesity. 2011;19:S140.
Muckelbauer R, Kalhoff H, Muller-Nordhorn J, et al. Childhood overweight and obesity: introduction into epidemiology and prevention strategies. Curr Nutr Food Sci. 2011;7(3):191-9.
Olstad DL, L R, Kim D, et al. Implementing the Alberta nutrition guidelines for children and youth in a recreational facility. Can J Diet Pract Res. 2011;72(4):177. [pmid: 22146115].
O'Malley CL, Douthwaite W, Moore HJ, et al. TeesCAKE (teesside consumption and activity for kids experience) project: Effectiveness of an evidence-based health promotion intervention in children aged 9-10 years living within a socially deprived area of the UK. Obes Rev. 2011;12:74-5.
Ornelas RT, Silva AM, Minderico CS, et al. Changes in cardiorespiratory fitness predict changes in body composition from childhood to adolescence: findings from the European youth heart study. Phys Sportsmed. 2011;39(3):78-86. [pmid: 21673487].
Peart T, Eduardo RY, Deborah B, et al. Weight status in US youth: the role of activity, diet, and sedentary behaviors. Am J Health Behav. 2011;35(6):756-64. [pmid: 22251766].
Porter CM. ‘Choice’: what we mean by it, and what that means for preventing childhood obesity. Public Health Nutr. [Epub ahead of print]. 2012:1-7. [pmid: 23294865].
Redsell S, Atkinson P, Nathan D, et al. Primary prevention of childhood obesity: views from primary care. Arch Dis Child. 2011;96:A9-A11.
Rhoades DR, Al-Oballi KS, Penprase B. Understanding overweight adolescents' beliefs using the theory of planned behaviour. Int J Nurs Pract. 2011;17(6):562-70. [pmid: 22103822].
Rios V, Gasca A, Flores ARO, et al. Child narrative as a resource for health promotion in school environments. Obesity. 2011;19:S146.
Ritchie LD. Less frequent eating predicts greater BMI and waist circumference in female adolescents. Am J Clin Nutr. 2012;95(2):290-6. [pmid: 22218154].
Rodriguez-Oliveros G, Haines J, Ortega-Altamirano D, et al. Obesity determinants in Mexican preschool children: parental perceptions and practices related to feeding and physical activity. Arch Med Res. 2011;42(6):532-9. [pmid: 22019411].
Schoffl I, Schoffl V, Dotsch J, et al. Correlations between high level sport-climbing and the development of adolescents. Pediatr Exerc Sci. 2011;23(4):477-86. [pmid: 22109775].
Schonbeck Y, Talma H, Van Dommelen P, et al. Trends in overweight and obesity among children of Dutch, Turkish and Moroccan origin in The Netherlands: 1997-2009. Obes Rev. 2011;12:252.
Schwandt P, Bertsch T, Liepold E, et al. Nutrition and cardiovascular risk factors in children: The PEP Family Heart Study. Eur Heart J. 2011;32:721. [pmid: 21177700].
Sigman-Grant M, Christiansen E, Fernandez G, et al. Child care provider training and a supportive feeding environment in child care settings in 4 states, 2003. Prev Chronic Dis. 2011;8(5):A113. [pmid: 21843416].
Silva AL, Ramos C, Carvalho MA, et al. Demographic variables and childhood obesity in a community-based program in Portugal. Obes Rev. 2011;12:102.
Slusser W, Staten K, Stephens K, et al. Payment for obesity services: examples and recommendations for stage 3 comprehensive multidisciplinary intervention programs for children and adolescents. Pediatrics. 2011;128(Suppl 2):S78-85. [pmid: 21885649].
Southerland J, Slawson DL, Schetzina KE, et al. Implementation of the go slow whoa meal pattern in schools through the winning with wellness project: food service workers' perceptions of implementation feasibility and impact. Obesity. 2011;19:S150.
Turner KM, Salisbury C, Shield JP. Parents' views and experiences of childhood obesity management in primary care: a qualitative study. Fam Pract. 2011;29(4):476-81. [pmid: 22117082].
Twiddy M, Wilson I, Bryant M, et al. Lessons learned from a family-focused weight management intervention for obese and overweight children. Public Health Nutr. [Epub ahead of print]. 2012:1-8. [pmid: 23294865].
Utter J, Denny S, Ameratunga S. Identifying the ‘red flags’ for weight control behaviors among adolescents: findings from an item response theory analysis. J Adolesc Health. 2012;50(2):S44.
Vafa M, Afshari SH, Moslehi N, et al. Relationship between infant nutrition feeding and childhood obesity in first grade Tehranian students of primary schools, 2009. Iran J Endocrinology Metab. 2011;12(5):505-560.
Van Lippevelde W, Verloigne M, De Bourdeaudhuij I, et al. What do parents think about parental participation in school-based interventions on energy balance-related behaviours? a qualitative study in 4 countries. BMC Public Health. 2011;11:881. [pmid: 22112159].
Vania A, Parisella V, Capasso F, et al. Early childhood caries underweight or overweight, that is the question. Eur J Paediatr Dent. 2011;12(4):231-5. [pmid: 22185246].
Veltsista A, Kanaka C, Palili A, et al. Predictors of change in BMI z-score from childhood to adolescence in a Greek birth cohort. Eur J Clin Invest. 2011;41:67.
White J, Jago R. Prospective associations between physical activity and obesity among adolescent girls: racial differences and implications for prevention. Arch Pediatr Adolesc Med. 2012;166(6):522-7. [pmid: 22665029].
Wilson A, Magarey A, Jones M, et al. Strategies for best practice in community-based obesity prevention in aboriginal communities. Obes Res Clin Pract. 2011;5:S43.
Wong EM, Sit JW, Tarrant MA, et al. The perceptions of obese school children in Hong Kong toward their weight-loss experience. J Sch Nurs. 2012. [Epub ahead of print].
Wyatt KM, Lloyd J. Is the healthy lifestyle programme an acceptable and feasible school-based intervention to prevent obesity?. Obes Rev. 2011;12:270-1.
Yeh Y, Lin K, Jen C, et al. Preschoolers' nutrition knowledge correlated with making healthy food choices and body weight status. Obesity. 2011;19:S210.

## Does not apply to key questions

Aboud F, Shafique S, Akhter S. A responsive feeding intervention increases children's self-feeding and maternal responsiveness but not weight gain. J Nutr. 2009;139(9):1738-43. [pmid: 19587124].
Affuso O, Kaiser K, Ingram KH, et al. Reporting quality of pediatric obesity randomized controlled trials - A preliminary analysis. Obesity. 2011;19:S110.
Alexandrov AA, Maslennikova GY, Kulikov S, et al. Primary prevention of cardiovascular disease:3-year intervention results in boys of 12 years of age. Prev Med. 1992;21(1):53-62. [pmid: 1738768].
Al-Hazzaa HM, Al-Sobayel HI, Musaiger AO. Convergent validity of the Arab teens lifestyle study (ATLS) physical activity questionnaire. Int J Environ Res Public Health. 2011;8(9):3810-20. [pmid: 22016718].
Anderson D M, Skemp Karen M. Self-image differences as related to body image of students in a middle school. Am J Health Behav. 2012;36(4):533-41. [pmid: 22488403].
Anzeljc SA, Murray R. A comprehensive plan for helping children avoid obesity - A pilot study. FASEB J. 2011;25:781.
Arango CM, Parra DC, Eyler A, et al. Walking or bicycling to school and weight status among adolescents from Monteria, Colombia. J Phys Act Health. 2011;8(Suppl 2):S171-7. [pmid: 21918230].
Aryana M, Li Z, Bommer WJ. Obesity and physical fitness in California school children. Am Heart J. 2012;163(2):302-12. [pmid: 22305851].
Bagby K, Adams S. Evidence-based practice guideline: Increasing physical activity in schools--Kindergarten through 8th grade. J Sch Nurs. 2007;23(3):137-143. [pmid: 17536917].
Bajraktarevic A, Trninic S, Penava S, et al. Relationship between obese children and prevalence metabolic syndrome in children. J Diabetes. 2011;3:141.
Bang KS, Chae SM, Hyun MS, et al. The mediating effects of perceived parental teasing on relations of body mass index to depression and self-perception of physical appearance and global self-worth in children. J Adv Nurs. 2012. [Epub ahead of print].
Baur L. Effectiveness of a home-based early intervention on children's BMI at age two years: randomised controlled trial. Obes Facts. 2012;5:34. [pmid: 22433615].
Berggren GG, Hebert JR, Waternaux CM. Comparison of Haitian children in a nutrition intervention programme with children in the Haitian national nutrition survey. Bull World Health Organ. 1985;63(6):1141-50. [pmid: 3879678].
Beyerlein A, von Kries R. Breastfeeding and body composition in children: will there ever be conclusive empirical evidence for a protective effect against overweight?. Am J Clin Nutr. 2011;94(6S):1772S-1775. [pmid: 21525195].
Bin X, Chih-Ping C, Donna S, et al. Longitudinal analysis of weight perception and psychological factors in Chinese adolescents. Am J Health Behav. 2011;35(1):92-104. [pmid: 20950162].
Bindler RM, Short RA, Cooney SK, et al. Interventions to decrease cardiovascular risk factors in children: the Northwest Pediatric Heart project. National Academies of Practice Forum. 2000;2(1):43-48.
Borys JM, Walter L, Du Plessis H, et al. Lessons of the epode European network (EEN) for the prevention of childhood obesity through community-based interventions. Obes Facts. 2012;5:67-8.
Boutelle KN, Cafri G, Crow SJ. Parent predictors of child weight change in family based behavioral obesity treatment. Obesity (Silver Spring). 2012;20(7):1539-43. [pmid: 22421896].
Bruening KS, Gilbride JA, Passannante MR, et al. Dietary intake and health outcomes among young children attending 2 urban day-care centers. J Am Diet Assoc. 1999;99(12):1529-35. [pmid: 10608946].
Bryant M, Farrin A, Christie D, et al. Results of a feasibility randomised controlled trial (RCT) for WATCH IT: a programme for obese children and adolescents. Clin Trials. 2011;8(6):755-64. [pmid: 22024104].
Buchheit M, Horobeanu C, Mendez-Villanueva A, et al. Effects of age and spa treatment on match running performance over two consecutive games in highly trained young soccer players. J Sports Sci. 2011;29(6):591-8. [pmid: 21337251].
Burke LE, Conroy MB, Sereika SM, et al. The effect of electronic self-monitoring on weight loss and dietary intake: a randomized behavioral weight loss trial. Obesity. 2011;19(2):338-44. [pmid: 20847736].
Cervoni E. Height and weight checks for children in primary care. Br J Gen Pract. 2011;61(582):65. [pmid: 21402001].
Chae HW, Kwon YN, Rhie YJ, et al. Effects of a structured exercise program on insulin resistance inflammatory markers and physical fitness in obese Korean children. J Pediatr Endocrinol Metab. 2010;23(10):1065-72. [pmid: 21158218].
Chen TJ, Modin B, Ji CY, et al. Regional, socioeconomic and urban-rural disparities in child and adolescent obesity in China: a multilevel analysis. Acta Paediatr Int J Paediatr. 2011;100(12):1583-9.
Cherkaoui Dekkaki I, Mouane N, Ettair S, et al. Prevalence of obesity and overweight in children: a study in government primary schools in Rabat, Morocco. Arch Med Res. 2011;42(8):703-8. [pmid: 22227044].
Cohen DJ, Clark EC, Lawson PJ, et al. Identifying teachable moments for health behavior counseling in primary care. Patient Educ Couns. 2011;85(2):e8-e15. [pmid: 21183305].
Courteix D, Lespessailles E, Peres SL, et al. Effect of physical training on bone mineral density in prepubertal girls: a comparative study between impact-loading and non-impact-loading sports. Osteoporos Int. 1998;8(2):152-8. [pmid: 9666939].
Coyne T, Dowling M, Condon-Paoloni D. Evaluation of preschool meals programmes on the nutritional health of Aboriginal children. Med J Aust. 1980;2(7):369-75. [pmid: 7453609].
Coyne T, Dowling M, Condon-Paoloni D. Evaluation of preschool meals programmes on the nutritional health of Aboriginal children. Med J Aust. 1980;2(7):369-75. [pmid: 7453609].
Daniels LA, Magarey AM, Nicholson JM. The NOURISH early feeding trial: an innovative approach to child obesity prevention. Obes Res Clin Pract. 2011;5:S5.
De Groot JF, Takken T, Gooskens RH, et al. Reproducibility of maximal and submaximal exercise testing in “normal ambulatory” and “community ambulatory” children and adolescents with spina bifida: which is best for evaluation and application of exercise training?. Phys Ther. 2011;91(2):267-76. [pmid: 21212378].
De Ruyter JC, Olthof MR, Kuijper LDJ, et al. Effect of sugar-sweetened beverages on body weight in children: design and baseline characteristics of the double-blind, randomized intervention study in kids. Contemp Clin Trials. 2012;33(1):247-57. [pmid: 22056980].
de Silva-Sanigorski AM, Waters E, Calache H, et al. Splash!: a prospective birth cohort study of the impact of environmental social and family-level influences on child oral health and obesity related risk factors and outcomes. BMC Public Health. 2011;11(1):505. [pmid: 21708037].
Decker JW. Photovoice: an untapped method for community needs assessment in obesity research. Obesity. 2011;19:S145.
Dedoussis GV, Yannakoulia M, Timpson NJ, et al. Does a short breastfeeding period protect from FTO-induced adiposity in children?. Int J Pediatr Obes. 2011;6(2-2):e326-35. [pmid: 20863147].
Delvaux K, Lefevre J, Philippaerts R, et al. Bone mass and lifetime physical activity in Flemish males: a 27-year follow-up study. Med Sci Sports Exerc. 2001;33(11):1868-75. [pmid: 11689737].
Denney-Wilson E, Robinson A, Laws R, et al. Child obesity prevention in primary care: The Healthy 4 Life pilot study. Obes Res Clin Pract. 2011;5:S18.
Dev DA, Kim J. Nutrition policies and practices in center-based child care. FASEB J. 2011;25:781.15.
Dovey TM, Taylor L, Stow R, et al. Responsiveness to healthy television (TV) food advertisements/commercials is only evident in children under the age of seven with low food neophobia. Appetite. 2011;56(2):440-6. [pmid: 21256170].
Downs SM, Farmer A, Quintanilha M, et al. Alberta nutrition guidelines for children and youth: awareness and use in schools. Can J Diet Pract Res. 2011;72(3):137-40. [pmid: 21896251].
Eisenmann JC. Assessment of obese children and adolescents: a survey of pediatric obesity-management programs. Pediatrics. 2011;128:S51-8. [pmid: 21885645].
Ekberg J, Angbratt M, Valter L, et al. History matters: childhood weight trajectories as a basis for planning community-based obesity prevention to adolescents. Int J Obes (Lond). 2012;36(4):524-8. [pmid: 22249226].
Fallahzadeh H, Golestan M, Rezvanian T, et al. Breast-feeding history and overweight in 11 to 13-year-old children in Iran. World J Pediatr. 2009;5(1):36-41. [pmid: 19172330].
Flores G, Maldonado J, Durbn P. Making tortillas without lard: Latino parents perspectives on healthy eating, physical activity, and weight-management strategies for overweight Latino children. J Acad Nutr Diet. 2012;112(1):81-9. [pmid: 22717179].
Foley L, Maddison R, Olds T, et al. Self-report use-of-time tools for the assessment of physical activity and sedentary behaviour in young people: systematic review. Obes Rev. 2012;13(8):711-22. [pmid: 22429291].
Forster M, Veerman JL, Barendregt JJ, et al. Cost-effectiveness of diet and exercise interventions to reduce overweight and obesity. Int J Obes. 2011;35(8):1071-8.
Fotu KF, Millar L, Mavoa H, et al. Outcome results for the Ma'alahi Youth Project, a Tongan community-based obesity prevention programme for adolescents. Obes Rev. 2011;12(Suppl 2):41-50. [pmid: 22008558].
Francis M, Nichols SS, Dalrymple N. The effects of a school-based intervention programme on dietary intakes and physical activity among primary-school children in Trinidad and Tobago. Public Health Nutrition. 2010;13(5):738-47. [pmid: 20144259].
Fromson JA, Sutton-Skinner KM, Gorrindo T, et al. Attention to body mass index by child psychiatry providers when prescribing second-generation antipsychotic medication to children: a survey study using a clinical vignette. Early Intervent Psychiatry. 2012;6(2):195-200.
Gardner J, Wilkinson P. Is family therapy the most effective treatment for anorexia nervosa?. Psychiatr Danub. 2011;23(Suppl 1):S175-S177. [pmid: 21894130].
Gronbaek HN, Madsen SA, Michaelsen KF. Family involvement in the treatment of childhood obesity: The Copenhagen approach. Eur J Pediatr. 2009;168(12):1437-1447. [pmid: 19234719].
Grunstein RR. Sleep, health and society. Sleep Biol Rhythms. 2011;9(4):194.
Guajardo-Barron VJ, Gutierrez-Delgado MC, Rivera-Pena G. Addressing childhood obesity in Mexico: Savings on health care expenditures from regulating food and beverage sales in basic education schools. Value Health. 2011;14(7):A558.
Guevara-Cruz M, Serralde-Zuniga AE, Frigolet Vazquez-Vela ME, et al. Association between maternal perceptions and actual nutritional status for children in a study group in Mexico. Nutr Hosp. 2012;27(1):209-12. [pmid: 22566323].
Halvorson R. Mom's workload and childhood obesity linked?. IDEA Fitness J. 2011;8(6):17.
Hare ME, Coday M, Williams NA, et al. Methods and baseline characteristics of a randomized trial treating early childhood obesity: The Positive Lifestyles for Active Youngsters (Team PLAY) trial. Contemp Clin Trials. 2012;33(3):534-49. [pmid: 22342450].
Harvey J, Eime R, Symons C, et al. Perceived physical competence mediates health benefits of club sport in adolescent girls beyond the effects of physical activity. J Sci Med Sport. 2011;14:e51-2.
Holst M, Rasmussen HH, Mortensen MN, et al. Improving communication in nutritional practice: an intervention study. Clin Nutr Suppl. 2011;6(1):178.
Huang JS, Norman GJ, Zabinski MF, et al. Body Image and Self-Esteem among Adolescents Undergoing an Intervention Targeting Dietary and Physical Activity Behaviors. J Adolesc Health. 2007;40(3):245-251. [pmid: 17321425].
Hunter HL, Steele RG, Steele MM. Family-based treatment for pediatric overweight: Parental weight loss as a predictor of children's treatment success. Child Health Care. 2008;37(2):112-125.
Hurst N, McStay RV. What role do U.S. health policy and children's hospitals play in the promotion of breastfeeding and human milk feeding?. Breastfeed Med. 2011;6(5):299-301. [pmid: 22007815].
Ilardi D. Obesity wars continue. Home-based pediatric weight management. School Nurse News. 2008;25(2):22-4. [pmid: 18410056].
Israel AC, Solotar LC, Zimand E. An investigation of two parental involvement roles in the treatment of obese children. Int J Eating Disord. 1990;9(5):557-564.
Jeffery RW, Gray CW, French SA, et al. Evaluation of weight reduction in a community intervention for cardiovascular disease risk: changes in body mass index in the Minnesota Heart Health Program. International journal of obesity and related metabolic disorders : journal of the International Association for the Study of Obesity. 1995;19(1):30-9.
Kaestner R, Xin XU. Title IX girls' sports participation and adult female physical activity and weight. Eval Rev. 2010;34(1):52-78. [pmid: 20130236].
Kaiser KA, Affuso HO, Cox TL, et al. Is intervention intensity related to dropout rates in diet/supplement randomized weight control trials?. Obes Rev. 2011;12:35.
Kaufmann NA, Poznanski R, Guggenheim K. Teen-agers dieting for weight control. Nutr Metab. 1974;16(1):30-7. [pmid: 4836681].
Kemper HC, Koppes LL, de Vente W, et al. Effects of health information in youth and young adulthood on risk factors for chronic diseases--20-year study results from the Amsterdam Growth and Health Longitudinal Study. Prev Med. 2002;35(6):533-9. [pmid: 12460520].
Khoury M, Manlhiot C, Dobbin S, et al. The association of cardiovascular risk and high body mass index in adolescents is influenced by waist circumference. Can J Diabetes. 2011;35(2):145.
Kirschenbaum DS, Pecora K, Raphaeli T, et al. Do as I do? Prospects for parental participation 1.5 years after immersion treatment for adolescent obesity. Clin Obes. 2011;1(2-3):92-8. [pmid: 25585574].
Koletzko B, von KR, Closa R, Escribano J, et al. Can infant feeding choices modulate later obesity risk?. Am J Clin Nutr. 2009;89(5):1502S-1508S. [pmid: 19321574].
Kral TV, Moore RH, Berkowitz RI, et al. Willing to work for fruits and vegetables: role of youth's obesity predisposition in a behavioral choice paradigm. Obesity. 2011;19:S104.
Lambourne K, Donnelly JE. The role of physical activity in pediatric obesity. Pediatr Clin North Am. 2011;58(6):1481-91. [pmid: 22093864].
Lanier WA, Wagstaff RS, DeMill JH, et al. Teacher awareness and implementation of food and physical activity policies in Utah elementary schools, 2010. Prev Chronic Dis. 2012;9:E18. [pmid: 22172185].
Lau N, Fuller N, Conigrave A, Caterson I. The effects of weight loss arising from a diet and exercise program on fasting serum levels of adiponectin, total ghrelin, glucagon-like-peptide 1, insulin and leptin in overweight and obese subjects. Obes Facts. 2012;5:130.
Laure P, Mangin G. Advising parents on physical activity for children between 0 and 5 years. J Sports Med Phys Fitness. 2011;51(3):467-72. [pmid: 21904286].
Lawrence HP, Romanetz M, Rutherford L, Cappel L, Binguis D, Rogers JB. Effects of a community-based prenatal nutrition program on the oral health of Aboriginal preschool children in northern Ontario. Probe(08341494). 2004;38(4):172.
Ludwig DS. Weight loss strategies for adolescents: a 14-year-old struggling to lose weight. JAMA. 2012;307(5):498-508. [pmid: 22215761].
Markert J, Alff F, Gausche R, et al. T.A.F.F.-Telephone-based adiposity prevention for families: socio-demographic description of participants and barriers to participation. Horm Res Paediatr. 2011;76:188-9.
McFarlin BK, Johnston CJ, Carpenter KC, et al. A one-year school-based diet/exercise intervention improves non-traditional disease biomarkers in Mexican-American children. Matern Child Nutr. 2012. [Epub ahead of print].
McKinnon R, Reedy J, Berrigan D. NCCOR's measures registry: a new tool to spur innovation in childhood obesity research. Obesity. 2011;19:S144.
Mehta NM, Bechard LJ, Cahill N, et al. Nutritional practices and their relationship to clinical outcomes in critically ill children-an international multicenter cohort study. Crit Care Med. 2012;40(7):2204-11. [pmid: 22564954].
Melino Borden V, Labiner-Wolfe J, Blake SM, et al. BodyWorks: a parent-focused program to promote healthful eating and physical activity for children and adolescents. J Nutr Educ Behav. 2012;44(2):192-3. [pmid: 22245164].
Milne E, Simpson JA, Johnston R, et al. Time spent outdoors at midday and children's body mass index. Am J Public Health. 2007;97(2):306-10. [pmid: 17194858].
Miyazaki T, Kurokawa J, Arai S. AIMing at metabolic syndrome -Towards the development of novel therapies for metabolic diseases via apoptosis inhibitor of macrophage (AIM). Circ J. 2011;75(11):2522-31. [pmid: 21970839].
Moodie M, Haby MM, Swinburn B, et al. Assessing cost-effectiveness in obesity: active transport program for primary school children: TravelSMART Schools Curriculum program. (Provisional abstract). J Phys Act Health. 2011;8(4):503-15. [pmid: 21597123].
Motl RW, Dishman RK, Felton G, et al. Self-motivation and physical activity among black and white adolescent girls. Med. Sci. Sports Exerc. 2003;35(1):128-136. [pmid: 12544646].
Munn Z, Yifan X, Moola S, et al. Children's views about obesity body size shape and weight; Inequalities and the mental health of young people: a systematic review of secondary school-based cognitive behavioural interventions; Intervention strategies that support self-care activities: an integrative study across disease/impairment groupings; Advocacy interventions to reduce or eliminate violence and promote the physical and psychosocial well-being of women who experience intimate partner abuse. JAN. 2011;67(5):954-960.
Murashima M, Hoerr SL, Hughes SO, et al. Feeding behaviors of low-income mothers: directive control relates to a lower BMI in children, and a nondirective control relates to a healthier diet in preschoolers. Am J Clin Nutr. 2012;95(5):1031-7. [pmid: 22456658].
Nakahara S, Poudel KC, Lopchan M, Poudel, et al. Differential effects of out-of-home day care in improving child nutrition and augmenting maternal income among those with and without childcare support: A prospective before-after comparison study in Pokhara Nepal. Health Policy. 2010;97(1):16-25. [pmid: 20236723].
Navarro-Cruz RA, Navarro-Cruz AR, Vera-Lopez O, et al. Development of a child animation for the promotion of good eating habits. Obes Rev. 2011;12:71.
Nguyen B, Shrewsbury V, O'Connor J, et al. Two-year outcomes of an extended adolescent weight-loss maintenance intervention involving novel additional therapeutic contact: The Loozit^®^ randomised controlled trial. Obes Facts. 2012;5:188-9.
Niinikoski H, Viikari J, Ronnemaa T, et al. Regulation of growth of 7- to 36-month-old children by energy and fat intake in the prospective randomized STRIP baby trial. Pediatrics. 1997;100(5):810-6. [pmid: 9346980].
Noonan K, Corman H, Schwartz-Soicher O, et al. Effects of prenatal care on child health at age 5. Matern Child Health J. 2012. [Epub ahead of print].
Novak D. Meals made by mom. Nurs Spectr. 2011;24(18):8.
Novotny R, Vijayadeva V, Ramirez V, et al. Development and implementation of a food system intervention to prevent childhood obesity in rural Hawai'i. Hawaii Med J. 2011;70(7 Suppl 1):42-6. [pmid: 21886293].
Noyes FR, Barber-Westin SD, Smith ST, et al. A training program to improve neuromuscular indices in female high school volleyball players. J Strength Cond Res. 2011;25(8):2151-60. [pmid: 21659890].
Noyes FR, Barber-Westin SD, Smith ST, et al. A training program to improve neuromuscular and performance indices in female high school basketball players. J Strength Cond Res. 2012;26(3):709-19. [pmid: 22289699].
O'Hara BJ, Phongsavan P, Venugopal K, et al. Characteristics of participants in Australia's Get Healthy telephone-based lifestyle information and coaching service: reaching disadvantaged communities and those most at need. Health Educ Res. 2011;26(6):1097-106. [pmid: 21987479].
Olson G. The relationship of birth weight to body mass index and blood pressure at ages 3-5 years. Am J Obstet Gynecol. 2012;206(1):S190.
O'Neil ME, Fragala-Pinkham M, Ideishi RI, et al. Community-based programs for children and youth: our experiences in design, implementation, and evaluation. Phys Occup Ther Pediatr. 2012;32(2):111-9. [pmid: 22483374].
Pal S, Khossousi A, Binns C, et al. The effects of 12-week psyllium fibre supplementation or healthy diet on blood pressure and arterial stiffness in overweight and obese individuals. Br J Nutr. 2012;107(5):725-34. [pmid: 21787454].
Perez-Morales ME, Bacardi-Gascon M, Jimenez-Cruz A. Long-term randomized school-based intervention: effect on obesity and lifestyles in Mexico. Obes Rev. 2011;12:74.
Pierce JP, Yong CS, Dwyer T, et al. A survey of health promotion priorities in the community. Community Health Stud. 1985;9(3):263-9. [pmid: 4085203].
Pietrobelli A, Tosi C, Malavolti M, et al. A child is not a small adult: Development of pediatric obesity intervention in Italy. Obes Facts. 2012;5:10.
Pinard CA, Davy BM, Estabrooks PA. Beverage intake in low-income parent-child dyads. Eating Behaviors. 2011;12(4):313-16. [pmid: 22051366].
Potdevin FJ, Alberty ME, Chevutschi A, et al. Effects of a 6-week plyometric training program on performances in pubescent swimmers. J Strength Cond Res. 2011;25(1):80-6. [pmid: 21157388].
Powell LM, Chriqui J, Chaloupka FJ. Associations between State-level Soda Taxes and Adolescent Body Mass Index. J Adolesc Health. 2009;45(3 Suppl):S57-S63. [pmid: 19699437].
Puder JJ, Marques-Vidal P, Schindler C, et al. Effect of multidimensional lifestyle intervention on fitness and adiposity in predominantly migrant preschool children (Ballabeina): Cluster randomised controlled trial. BMJ (Online). 2011;343(7830).
Quigg R, Reeder AI, Gray A, et al. The effectiveness of a community playground intervention. J Urban Health. 2012;89(1):171-84. [pmid: 21959697].
Rahmani K, Djazayery A, Habibi MI, et al. Effects of daily milk supplementation on improving the physical and mental function as well as school performance among children: Results from a school feeding program. J Res Med Sci. 2011;16(4):469-476. [pmid: 22091261].
Ramos-Goni JM, Valcarcel-Nazco C, Castilla-Rodriguez I. Cost-effectiveness of interventions against childhood obesity. Value Health. 2011;14(7):A402.
Rankin J, Spear BA, Bouler R, et al. Using indirect calorimetry (RMR) to establish energy requirements in adolescents participating in a summer weight loss camp. J Adolesc Health. 2012;50(2):S58-9.
Reilly JJ, Kelly L, Montgomery C, et al. Physical activity to prevent obesity in young children: cluster randomised controlled trial. BMJ. 2006;333(7577):1041. [pmid: 17028105].
Reis CEG, Vasconcelos IAL, de Barros JF. Politicas puoblicas de nutricao para o controle da obesidade infantile. Policies on nutrition for controlling childhood obesity. Rev Paul Pediatr. 2011;29(4):625-33.
Ribaya-Mercado JD, Maramag CC, Tengco LW, et al. Relationships of body mass index with serum carotenoids tocopherols and retinol at steady-state and in response to a carotenoid-rich vegetable diet intervention in Filipino schoolchildren. Biosci Rep. 2008;28(2):97-106. [pmid: 18384277].
Rona RJ. Genetic and environmental factors in the control of growth in childhood. Br Med Bull. 1981;37(3):265-72. [pmid: 7034851].
Rossini R, Moscatiello S, Tarrini G, et al. Effects of cognitive behavioral treatment for weight loss in family members. J Am Diet Assoc. 2011;111(11):1712-19. [pmid: 22027054].
Ruble K, Hayat M, Stewart KJ, et al. Body composition after bone marrow transplantation in childhood. Oncol Nurs Forum. 2012;39(2):186-92. [pmid: 22374492].
Sanchis-Moysi J, Dorado C, Arteaga-Ortiz R, et al. Effects of training frequency on physical fitness in male prepubertal tennis players. J Sports Med Phys Fitness. 2011;51(3):409-16. [pmid: 21904279].
Sandoval A, Turner L, Nicholson L, et al. The relationship among state laws, district policies, and elementary school-based measurement of children's body mass index. J Sch Health. 2012;82(5):239-45. [pmid: 22494095].
Sigman-Grant M, Christiansen E, Fernandez G, et al. Child care provider training and a supportive feeding environment in child care settings in 4 states, 2003. Prev Chronic Dis. 2011;8(5):A113. [pmid: 21843416].
Singh A. ENERGY-project. Obes Rev. 2011;12:5-6.
Siqueira-Catania A, Cezaretto A, Barros CR, et al. Effectiveness of lifestyle interventions in public health system of developing country in reducing inflammation and insulin resistance of individuals at high-risk for type 2 diabetes. J Diabetes. 2011;3:89.
Smiciklas-Wright H, D'Augelli AR. Primary prevention for overweight: Preschool Eating Patterns(PEP) Program. J Am Diet Assoc. 1978;72(6):626-9. [pmid: 670616].
Stewart D, Anne C, Jacqueline C, et al. Modification of eating attitudes and behavior in adolescent girls: A controlled study. Int J Eat Disord. 2001;29(2):107-118. [pmid: 11429973].
Storfer-Isser A, Patel SR, Babineau DC, et al. Relation between sleep duration and BMI varies by age and sex in youth age 8-19. Pediatr Obes. 2012;7(1):53-64. [pmid: 22434739].
Strutz KL, Richardson LJ, Hussey JM. Preconception health trajectories and birth weight in a national prospective cohort. J Adolesc Health. 2012. [Epub ahead of print].
Stunkard AJ. Adherence to medical treatment: overview and lessons from behavioral weight control. J Psychosom Res. 1981;25(3):187-97. [pmid: 7265022].
Stunkard AJ. Obesity: risk factors consequences and control. Med J Aust. 1988;148(Suppl):S21-8. [pmid: 3340057].
Sturm R, Datar A. Food prices and weight gain during elementary school:5-year update. Public Health. 2008;122(11):1140-1143. [pmid: 18539306].
Sweet M. Childhood obesity can be prevented, says Cochrane. BMJ. 2011;343(7836):1231.
Tandon PS, Garrison MM, Christakis DA. Physical activity and beverages in home and center based child care programs. J Nutr Educ Behav. 2012;44(4):355-9. [pmid: 22564855].
Tang MB. The effect of lifestyle modification for the metabolic syndrome. J Hypertens. 2011;29:e48.
Taveras EM, Blackburn K, Gillman MW, et al. First steps for mommy and me: a pilot intervention to improve nutrition and physical activity behaviors of postpartum mothers and their infants. Matern Child Health J. 2011;15(8):1217-27. [pmid: 20957514].
Taylor BJ, Heath AL, Galland BC, et al. Prevention of Overweight in Infancy (POI.nz) study: a randomised controlled trial of sleep, food and activity interventions for preventing overweight from birth. BMC Public Health. 2011;1:942. [pmid: 22182309].
Taylor JP, MacLellan D, Caiger JM, et al. Implementing elementary school nutrition policy: prinicipal's perspectives. Can J Diet Pract Res. 2011;72(4):176. [pmid: 22146114].
Tolfrey K, Campbell IG, Batterham AM. Exercise training induced alterations in prepubertal children's lipid-lipoprotein profile. Med Sci Sports Exerc. 1998;30(12):1684-92. [pmid: 9861600].
Townsend N, Murphy S, Moore L. The more schools do to promote healthy eating, the healthier the dietary choices by students. J Epidemiol Community Health. 2011;65(10):889-95. [pmid: 21118953].
Triay J, Mundi M, Klein S, et al. Does rimonabant independently affect free fatty acid and glucose metabolism?. J Clin Endocrinol Metab. 2012;97(3):819-27. [pmid: 22170727].
Ulrich DA, Burghardt AR, Lloyd M, et al. Physical activity benefits of learning to ride a two-wheel bicycle for children with down syndrome: a randomized trial. Phys Ther. 2011;91(10):1463-77. [pmid: 21852519].
Van Dorsten B, Lindley EM. Cognitive and behavioral approaches in the treatment of obesity. Med Clin North Am. 2011;95(5):971-88. [pmid: 21855703].
Vance DE, Wright MA, McKie PR, et al. Evaluating the impact of an interactive telephone technology and incentives when combined with a behavioral intervention for weight loss. Obesity. 2011;19:S115.
Vargo K, Kennedy E, Fisher J, et al. Sustaining change: Long term maintenance of weight loss following completion of a weight management program for children and adolescents. J Adolesc Health. 2012;50(2):S34-S35.
Vasickova L, Stavek P, Suchanek P. Possible effect of DHA intake on body weight reduction and lipid metabolism in obese children. Neuro Endocrinol Lett. 2011;32(Suppl 2):64-7. [pmid: 22101886].
Vasquez-Garibay EM, Gonzalez-Rico JL, Cabrera-Pivaral C, et al. Differences in the score of areas of family dynamic between obese vs. non obese school children. FASEB J. 2011;25:781.15.
Villiard H, Moreno M. An analysis of fitness behaviors promoted on facebook for adolescents. Pediatr Res. 2011;70(4):440.
Virtanen SM, Barlun S, Salonen M, et al. Feasibility and compliance in a nutritional primary prevention trial in infants at increased risk for type 1 diabetes. Acta Paediatr Int J Paediatr. 2011;100(4):557-64.
Viskic-Stalec N, Stalec J, Katic R, Podvorac D, Katovic D. The impact of dance-aerobics training on the morpho-motor status in female high-schoolers. Coll Antropol. 2007;31(1):259-66. [pmid: 17598411].
Voigt K. Tackling childhood obesity through the education system: opportunities and ethical challenges. Obes Rev. 2011;12:21.
Vos M, Barlow SE. Update in childhood and adolescent obesity. Pediatr Clin North Am. 2011;58(6):xv-xvii. [pmid: 22093868].
Wake M, Turner MJ, Price A, et al. How confident are general paediatricians at assessing and managing obesity in childhood?. Arch Dis Child. 2011;96:A63-A64.
Walker SE, Smolkin ME, O'Leary MLL, et al. Predictors of retention and BMI loss or stabilization in obese youth enrolled in a weight loss intervention. Obes Res Clin Pract. 2011:e1-e10.
Walter HJ, Hofman A, Connelly PA, et al. Coronary heart disease prevention in childhood: one-year results of a randomized intervention study. Am J Prev Med. 1986;2(4):239-45. [pmid: 3453186].
Wang LY, Gutin B, Barbeau P, et al. Cost-effectiveness of a school-based obesity prevention program. J Sch Health. 2008;78(12):619-24. [pmid: 19000237].
Werner D, Teufel J, Brown S. Exploring the experiences of older adults volunteering with an intergenerational program to prevent childhood obesity. Californian J Health Promot. 2011;9(1):1-8.
Wilksch S. Role of schools in prevention of obesity and eating disorders. Obes Res Clin Pract. 2011;5:S10.
Williams CL, Squillace MM, Bollella MC, Brotanek, et al. Healthy Start: a comprehensive health education program for preschool children. Prev Med. 1998;27(2):216-23. [pmid: 9578999].
Williams G, Nicholls S, Voigt K, et al. Ethical and political aspects of obesity interventions in children. Int J Obes. 2011;35:S148.
Wong Oi Ling. Gendered power in eating habits: insight into childhood obesity in a Chinese family context. J Fam Ther. 2011;33(3):332-52.
Ye S, Muntner P, Shimbo D, et al. Do behavioral risk factors explain the association between depressive symptoms and cardiovascular risk in individuals with coronary heart disease? Report from the reasons for geographic and racial differences in stroke (REGARDS) study. J Am Coll Cardiol. 2012;59(13):E1375.
Zhang Y, Wang S. Prevalent change in overweight and obesity in children and adolescents from 1995 to 2005 in Shandong, China. Asia Pac J Public Health. 2011;23(6):904-16. [pmid: 20460297].

## Other

Graf C, Dordel S. The CHILT I project(Children's Health Interventional Trial): A multicomponent intervention to prevent physical inactivity and overweight in primary schools. Bundesgesundheitsblatt Gesundheitsforschung Gesundheitsschutz. 2011;54(3):313-21. [pmid: 21347764].
Marcus C. Positive weight trend among 4-year old children. High risk of setback--vigorous prevention measures against childhood obesity are still required. Lakartidningen. 2009;106(43):2748-9. [pmid: 19960900].
Moya Martinez P, Lopez MS, Bastida JL, Sotos FE, Pacheco BN, Aguilar FS, Vizcaino VM. Cost-effectiveness of an intervention to reduce overweight and obesity in 9-10-year-olds. The Cuenca study. Gac Sanit. 2011;25(3):198-204. [pmid: 21324563].
Muckelbauer R, Libuda L, Clausen K, Kersting M. Approaches for the prevention of overweight through modified beverage consumption in the elementary school setting. The “trinkfit” study. Bundesgesundheitsblatt Gesundheitsforschung Gesundheitsschutz. 2011;54(3):339-48. [pmid: 21347767].
Plachta-Danielzik S, Landsberg B, Lange D, et al. 15 years of the Kiel Obesity Prevention Study(KOPS): Results and its importance for obesity prevention in children and adolescents. Bundesgesundheitsblatt Gesundheitsforschung Gesundheitsschutz. 2011;54(3):304-12. [pmid: 21347763].
Strauss A, Herbert B, Mitschek C, et al. TigerKids. Successful health promotion in preschool settings. Bundesgesundheitsblatt Gesundheitsforschung Gesundheitsschutz. 2011;54(3):322-9. [pmid: 21347765].
Strumeyer C, Cheymol J. Treatment and prevention networks in pediatric obesity. Soins Pediatr Pueric. 2007;(239):38. [pmid: 18179016].
Treppoz S. RePOP a network for prevention and management of obesity in children in Lyon area. Arch Pediatr. 2006;13(6):641-3. [pmid: 16697168].

## Non-English language

Bosch-Marin JDe LA, Camara JP, Navas L. Prevention of estival weight loss in children of preschool age. Acta Pediatr Esp. 1955;13(153):677-90. [pmid: 13282708].
Bougle D, Zunquin G, Sesboue B, Sabatier J-P, Daireaux A. Treatment of pediatric obesity: effects on body composition and physical fitness: Prise en charge ambulatoire de l'obesite : effets sur la composition corporelle et la capacite aerobie. Arch Pediatr. 2007;14(5):439-443. [pmid: 17395440].
Jung F. Appetite behavior of preschool children during experimental control. Prax Kinderpsychol Kinderpsychiatr. 1973;22(5):167-71. [pmid: 4731720].
Korsten-Reck U, Bauer S, Keul J. Sports and nutrition--an ambulatory care program for obese children(long-term experiences). Padiatr Padol. 1993;28(6):145-52. [pmid: 8302620].
Lichtenstein S, Teufel U, Weiland C, et al. Prevention of obesity in primary school. A school-based prevention program reduces the risk for obesity in school children. Adipositaspravention in Grundschulen. Nachhaltige Senkung des Adipositasrisikos bei Grundschulern mittels schulbasiertem. Praventionsprogramm Monatsschr Kinderheilkd. 2011:1-6.
Ortega Porcel FB, Chillon Garzon P, Ruiz Ruiz J, et al. A six-month program of nutritional intervention and physical activity produces positive effects on the body composition of school adolescent. Un programa de intervencion nutricional y actividad fisica de seis meses produce efectos positivos sobre la composicion corporal de adolescentes escolarizados. Rev Esp Pediatr. 2004;60(4):283-290.
Pott W, Frohlich G, Albayrak O, Hebebrand J, Pauli-Pott U. Conditions for success in a lifestyle intervention weight-reduction programme for overweight or obese children and adolescents. Bedingungen fur den erfolg ubergewichtiger und adiposer kinder in einem ambulanten programm zur gewichtsreduktion durch veranderungen des lebensstils. Z. Kinder- Jugendpsychiatr. Psychother. 2010;38(5):351-360. [pmid: 20809471].
Sybilski AJ, Tolak K, Wolniewicz A, et al. Overweight obesity and above average physical activity in a grammar school population. Nadwaga otylosc a aktywnosc fizyczna powyzej przecietnej uczniow klas gimnazjalnych. Pediatr Pol. 2007;82(11):864-867.
Temboury Molina MC, Sacristan Martin A, San Frutos Fernandez MA, Rodriguez Alfaro F, Llorente Gonzalez R. Preliminary results of a therapeutic program for childhood obesity in primary health care. An Esp Pediatr. 1993;38(5):413-6. [pmid: 8503583].
Tiedjen U, Stachow R, Haring J, et al. Multimodal treatment for children with obesity: Verhaltenstraining mit adiposen grundschulkindern. Pravent Rehabil. 2004;16(2):49-58.

## No human subjects

Becker CB, McDaniel L, Bull S, et al. Can we reduce eating disorder risk factors in female college athletes? A randomized exploratory investigation of two peer-led interventions. Body Image. 2012;9(1):31-42. [pmid: 22019502].
Finni T, Saakslahti A, Laukkanen A, et al. A family based tailored counselling to increase non-exercise physical activity in adults with a sedentary job and physical activity in their young children: design and methods of a year-long randomized controlled trial. BMC Public Health. 2011;11:944. [pmid: 22185647].
Krukowski RA, Philyaw Perez AG, Bursac Z, et al. Development and evaluation of the school cafeteria nutrition assessment measures. J Sch Health. 2011;81(8):431-6. [pmid: 21740427].
Manios Y, Grammatikaki E, Androutsos O, et al. A systematic approach for the development of a kindergarten-based intervention for the prevention of obesity in preschool age children: the ToyBox-study. Obes Rev. 2012;13(Suppl 1):3-12. [pmid: 22309061].
Suarez C, Ferreira Monteiro A, Macri E, et al. High-fat diets and body composition over two generations. An experimental study. Endocrinol Nutr. 2012;59(4):232-8. [pmid: 22406127].
Wijesuriya M, Gulliford M, Vasantharajah L, et al. DIABRISK-SL prevention of cardio-metabolic disease with life style modification in young urban Sri Lankan's - study protocol for a randomized controlled trial. Trials. 2011;12:209. [pmid: 21943067].
Williams MA. Translating a G3 community-based, childhood obesity prevention intervention from Europe to Australia - EPODE to OPAL. Obes Res Clin Pract. 2011;5:S74-5.