# Screening and Data Abstraction Forms

There are 33 pages of standardized forms for data extraction. The forms asked reviewers to determine whether article titles, abstracts, and text applied to any of the Key Questions and to provide other details about relevant articles.