# Detailed Search Strategies

PubMed

Search ((“body weight”[mh] OR “body weight”[tiab] OR “normal weight”[tiab] OR “healthy weight”[tiab] OR obese[tiab] OR obesity[tiab] OR overweight[tiab] OR “over weight”[tiab] OR “body mass index”[mh] OR “body mass index”[tiab] OR BMI[tiab] OR “Waist circumference”[mh] OR “Waist circumference”[tiab] OR “skinfold thickness”[mh] OR “skinfold thickness”[tiab] OR (“body fat”[tiab] AND percent*[tiab]) OR “body composition”[mh] OR “body composition”[tiab] OR Adiposity[tiab]) AND (maintenance[tiab] OR maintain[tiab] OR management[tiab] OR manage[tiab] OR (“weight gain”[tiab] AND (prevent*[tiab] OR reduce[tiab] OR reduction[tiab])) OR Prevention[tiab] OR Intervention[tiab] OR Preventative[tiab] OR Promote[tiab] OR Promotion[tiab] OR weight control[tiab] OR control[tiab]) AND (“educational setting”[tiab] OR Academic[tiab] OR Kindergarten[tiab] OR School[tiab] OR Schools[tiab] OR Schools[mh] OR “after-school”[tiab] AND “after school”[tiab] OR Caregiver[tiab] OR Caregivers[mh] OR Caregivers[tiab] OR Cooking[mh] OR Cooking[tiab] OR Family[mh] OR Family[tiab] OR Families[tiab] AND Father[tiab] OR Fathers[tiab] OR Home[tiab] OR House[tiab] OR Meal[tiab] OR Meals[tiab] OR Mother[tiab] OR Mothers[tiab] OR Parent[tiab] OR Parents[tiab] OR Parental[tiab] OR Parenting[tiab] OR Purchasing[tiab] OR Shopping[tiab] OR “adolescent medicine”[mh] OR “family physician”[tiab] OR “physicians, family”[mh] OR “primary care”[tiab] OR “primary health care”[mh] OR “primary health care”[tiab] OR Clinic[tiab] OR Clinical[tiab] OR Clinics[tiab] OR Medical[tiab] OR Medicine[tiab] OR Office[tiab] OR Pediatrician[tiab] OR Paediatrician[tiab] OR Pediatricians[tiab] OR Pediatrics[mh] OR “after care”[tiab] OR “child day care centers”[mh] OR “day care”[tiab] OR “preschool”[tiab] OR “pre-school”[tiab] OR “boy scout”[tiab] OR “boy scouts”[tiab] OR “Girl scouts”[tiab] OR Campfire[tiab] OR Church[tiab] OR Community[tiab] OR Communities[tiab] OR Faith[tiab] OR Garden[tiab] OR Gardening[mh] OR Mosque[tiab] OR Neighborhood[tiab] OR Neighborhoods[tiab] OR Recreation[mh] OR Recreation[tiab] OR Synagogue[tiab] OR YMCA[tiab] OR YWCA[tiab] OR “calorie information”[tiab] OR “calorie labeling”[tiab] OR “food label”[tiab] OR “food labeling”[mh] OR “food labeling”[tiab] OR “health Policy”[mh] OR “policy”[tiab] OR “income inequality”[tiab] OR “social-ecological”[tiab] OR “socioeconomic factors”[mh] OR campaign[tiab] OR Environment[mh] OR Environment[tiab] OR Environmental[tiab] OR Infrastructure[tiab] OR Tax*[tiab] OR taxes[mh] OR “Consumer Health Information”[Mesh] OR “Informatics”[Mesh] OR “internet”[MeSH Terms] OR “Medical Informatics Applications”[Mesh] OR “medical informatics”[mh] OR “Support systems”[tiab] OR “computer communication networks”[mh] OR “electronic mail”[mh] OR “electronic media”[tiab] OR informatics[tiab] OR Internet[tiab] OR Facebook[tiab] OR Cell phone[tiab] OR Telephone[tiab] OR telemedicine[mh] OR regulation[tiab])) NOT (Cure[tiab] OR Medication[tiab] OR Drug[tiab] OR Drugs[tiab] OR Pharmacy[tiab] OR Pharmaceutical[tiab] OR Surgical[tiab] OR Surgery[tiab] OR Orlistat[Supplementary Concept] OR Orlistat[tiab] OR Phentermine[mh] OR Phentermine[tiab] OR Sibutramine[Supplementary Concept] OR Sibutramine[tiab] OR “bariatric surgery”[mh]) NOT ((adult[tiab] OR adults[tiab] OR men[mh] OR men[tiab] OR women[mh] OR women[tiab] OR infant[mh] OR infant[tiab]) NOT (child[mh] OR child[tiab] OR children[tiab] OR adolescent[mh] OR adolescent[tiab] OR “teen-age”[tiab] OR pediatric[tiab] OR paediatric[tiab])) NOT (animal[mh] NOT human[mh]) | 16997

EMBASE

school OR schools OR caregiver OR caregivers OR ‘cooking’/exp OR cooking OR ‘family’/exp OR family OR families OR father OR fathers OR home OR house OR meal OR meals OR mother OR mothers OR parent OR parents OR parental OR parenting OR purchasing OR shopping OR ‘adolescent medicine’ OR ‘family physician’ OR ‘primary health care’/exp OR ‘primary health care’ OR ‘primary care’ OR clinic OR clinical OR clinics OR medical OR medicine OR office OR pediatrics OR pediatrician OR paediatrician OR pediatricians OR ‘day care’ OR ‘after care’ OR preschool OR ‘pre-school’ OR ‘boy scout’ OR ‘boy scouts’ OR ‘girl scout’ OR ‘girl scouts’ OR campfire OR church OR community OR communities OR faith OR garden OR ‘gardening’/exp OR mosque OR neighborhood OR neighborhoods OR recreation OR synagogue OR ymca OR ywca OR ‘calorie information’ OR ‘calorie labeling’ OR ‘food label’ OR ‘food labeling’ OR policy OR ‘income inequality’ OR ‘social-ecological’ OR ‘socioeconomic factors’ OR ‘socioeconomics’/exp OR campaign OR environment OR environmental OR infrastructure OR tax* OR ‘consumer health information’/exp OR informatics OR internet OR ‘support systems’ OR ‘e-mail’ OR ‘electronic mail’ OR facebook OR ‘cell phone’ OR cellphone OR telephone OR telemedicine OR regulation OR academic OR kindergarten AND (control OR maintenance OR maintain OR management OR manage OR (‘weight gain’ AND (prevent* OR reduce OR reduction)) OR prevention OR preventative OR promote OR intervention OR promotion) AND (‘body weight’ OR ‘normal weight’ OR ‘healthy weight’ OR obese OR obesity OR overweight OR ‘body mass’/exp OR ‘body mass index’ OR bmi OR ‘waist circumference’ OR ‘skinfold thickness’ OR (‘body fat’ AND percent) OR ‘body composition’/exp OR ‘body composition’ OR adiposity) NOT (orlistat OR tetrahydrolipstatin OR phentermine OR sibutramine OR ‘bariatric surgery’/exp OR cure OR medication OR drug OR drugs OR pharmacy OR pharmaceutical OR surgery OR surgical) AND ([article]/lim OR [article in press]/lim OR [conference abstract]/lim OR [conference paper]/lim OR [conference review]/lim OR [erratum]/lim OR [review]/lim) AND ([preschool]/lim OR [school]/lim OR [child]/lim OR [adolescent]/lim) AND [humans]/lim AND [embase]/lim AND [<1966-2010]/py OR (school OR schools OR caregiver OR caregivers OR ‘cooking’/exp OR cooking OR ‘family’/exp OR family OR families OR father OR fathers OR home OR house OR meal OR meals OR mother OR mothers OR parent OR parents OR parental OR parenting OR purchasing OR shopping OR ‘adolescent medicine’ OR ‘family physician’ OR ‘primary health care’/exp OR ‘primary health care’ OR ‘primary care’ OR clinic OR clinical OR clinics OR medical OR medicine OR office OR pediatrics OR pediatrician OR paediatrician OR pediatricians OR ‘day care’ OR ‘after care’ OR preschool OR ‘pre-school’ OR ‘boy scout’ OR ‘boy scouts’ OR ‘girl scout’ OR ‘girl scouts’ OR campfire OR church OR community OR communities OR faith OR garden OR ‘gardening’/exp OR mosque OR neighborhood OR neighborhoods OR recreation OR synagogue OR ymca OR ywca OR ‘calorie information’ OR ‘calorie labeling’ OR ‘food label’ OR ‘food labeling’ OR policy OR ‘income inequality’ OR ‘social-ecological’ OR ‘socioeconomic factors’ OR ‘socioeconomics’/exp OR campaign OR environment OR environmental OR infrastructure OR tax* OR ‘consumer health information’/exp OR informatics OR internet OR ‘support systems’ OR ‘e-mail’ OR ‘electronic mail’ OR facebook OR ‘cell phone’ OR cellphone OR telephone OR telemedicine OR regulation OR academic OR kindergarten AND (control OR maintenance OR maintain OR management OR manage OR (‘weight gain’ AND (prevent* OR reduce OR reduction)) OR prevention OR preventative OR promote OR intervention OR promotion) AND (‘body weight’ OR ‘normal weight’ OR ‘healthy weight’ OR obese OR obesity OR overweight OR ‘body mass’/exp OR ‘body mass index’ OR bmi OR ‘waist circumference’ OR ‘skinfold thickness’ OR (‘body fat’ AND percent) OR ‘body composition’/exp OR ‘body composition’ OR adiposity) NOT (orlistat OR tetrahydrolipstatin OR phentermine OR sibutramine OR ‘bariatric surgery’/exp OR cure OR medication OR drug OR drugs OR pharmacy OR pharmaceutical OR surgery OR surgical) NOT (adult OR adults OR men OR women OR infant NOT (child OR children OR adolescent OR adolescents OR ‘teen age’ OR ‘teen-age’ OR ‘teenage’ OR pediatric OR paediatric)) NOT (animal NOT human) AND ([article]/lim OR [article in press]/lim OR [conference abstract]/lim OR [conference paper]/lim OR [conference review]/lim OR [erratum]/lim) AND [embase]/lim AND [2011-2012]/py) | 7521

Cochrane

| 2461
#1 “educational setting”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=1) 20 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=1&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #2 (academic):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=2) 3157 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=2&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #3 (kindergarten):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=3) 193 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=3&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #4 (shcool):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=4) 2 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=4&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #5 MeSH descriptor Schools explode tree 1 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=5) 761 edit (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=editquery&qnum=5&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636) delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=5&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #6 “after-school”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=6) 83 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=6&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #7 “after school”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=7) 83 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=7&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #8 (caregiver):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=8) 1069 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=8&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #9 (caregivers):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=9) 1829 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=9&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #10 (cooking):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=10) 535 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=10&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #11 MeSH descriptor Family, this term only (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=11) 828 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=11&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #12 (family):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=12) 11572 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=12&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #13 (father):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=13) 373 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=13&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #14 (home):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=14) 12623 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=14&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #15 (house):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=15) 1967 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=15&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #16 (meal):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=16) 6951 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=16&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #17 (mother):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=17) 5384 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=17&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #18 (parent):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=18) 7453 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=18&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #19 (parental):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=19) 1954 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=19&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #20 (purchasing):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=20) 387 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=20&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #21 (shopping):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=21) 137 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=21&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #22 “adolescent medicine”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=22) 26 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=22&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #23 “family physician”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=23) 128 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=23&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #24 “primary health care”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=24) 2876 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=24&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #25 (clinic):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=25) 12937 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=25&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #26 (clinical):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=26) 215567 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=26&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #27 (medical):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=27) 34560 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=27&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #28 (medicine):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=28) 14448 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=28&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #29 (office):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=29) 2614 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=29&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #30 MeSH descriptor Pediatrics, this term only (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=30) 414 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=30&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #31 (pediatrician):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=31) 387 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=31&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #32 “after care”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=32) 60 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=32&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #33 “day care”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=33) 749 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=33&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #34 (preschool):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=34) 23599 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=34&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #35 “pre-school”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=35) 245 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=35&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #36 “boy scout”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=36) 5 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=36&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #37 “boy scouts”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=37) 4 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=37&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #38 “girl scout”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=38) 6 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=38&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #39 “girl scouts”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=39) 5 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=39&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #40 (church):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=40) 118 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=40&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #41 (community):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=41) 13442 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=41&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #42 (faith):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=42) 65 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=42&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #43 (garden):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=43) 67 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=43&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #44 (mosque):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=44) 1 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=44&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #45 (neighborhood):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=45) 319 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=45&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #46 MeSH descriptor Recreation explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=46) 7703 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=46&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #47 (recreation):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=47) 207 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=47&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #48 (YMCA):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=48) 13 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=48&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #49 “food labeling”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=49) 29 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=49&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #50 “food label”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=50) 10 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=50&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #51 MeSH descriptor Health Policy explode tree 3 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=51) 402 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=51&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #52 (policy):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=52) 3400 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=52&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #53 “social-ecological”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=53) 20 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=53&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #54 MeSH descriptor Socioeconomic Factors explode tree 2 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=54) 5321 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=54&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #55 (campaign):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=55) 641 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=55&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #56 (environment):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=56) 5030 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=56&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #57 (environmental):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=57) 2876 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=57&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #58 (infrastructure):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=58) 223 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=58&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #59 (tax*):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=59) 1658 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=59&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #60 MeSH descriptor Consumer Health Information explode tree 1 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=60) 76 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=60&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #61 (informatics):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=61) 176 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=61&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #62 (internet):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=62) 2492 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=62&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #63 MeSH descriptor Medical Informatics Applications explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=63) 7344 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=63&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #64 “support systems”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=64) 328 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=64&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #65 MeSH descriptor Computer Communication Networks explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=65) 1248 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=65&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #66 “electronic mail”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=66) 171 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=66&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #67 “e-mail”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=67) 310 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=67&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #68 “electronic media”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=68) 16 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=68&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #69 “cell phone”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=69) 46 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=69&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #70 (telephone):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=70) 4811 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=70&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #71 (telemedicine):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=71) 830 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=71&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #72 (regulation):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=72) 6616 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=72&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #73 ( (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #1 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #2 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #3 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #4 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #5 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #6 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #7 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #8 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #9 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #10 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #11 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #12 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #13 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #14 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #15 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #16 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #17 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #18 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #19 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #20 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #21 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #22 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #23 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #24 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #25 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #26 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #27 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #28 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #29 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #30 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #31 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #32 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #33 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73); #34 OR; #35 OR; #36 OR; #37 OR; #38 OR; #39 OR; #40 OR; #41 OR; #42 OR; #43 OR; #44 OR; #45 OR; #46 OR; #47 OR; #48 OR; #49 OR; #50 OR; #51 OR; #52 OR; #53 OR; #54 OR; #55 OR; #56 OR; #57 OR; #58 OR; #59 OR; #60 OR; #61 OR; #62 OR; #63 OR; #64 OR; #65 OR; #66 OR; #67 OR; #68 OR; #69 OR; #70 OR; #71 OR; #72 314499 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=73&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #74 (maintenance):ti,ab,kw or (maintain):ti,ab,kw or (management):ti,ab,kw or (manage):ti,ab,kw or (prevention):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=74) 143775 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=74&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #75 (promote) or (promotion):ti or (control):au or (intervention):pt or (preventative):kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=75) 10501 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=75&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #76 (weight gain):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=76) 4659 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=76&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #77 (prevent*):ti,ab,kw or (reduce):ti,ab,kw or (reduction):au (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=77) 175751 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=77&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #78 ( (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=78); #76 AND (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=78); #77 1688 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=78) edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=78&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #79 ( (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=79); #74 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=79); #75 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=79); #78 151220 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=79) edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=79&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #80 ( (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=80); #73 AND (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=80); #79 81196 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=80) edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=80&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #81 “body weight”:ti,ab,kw or “normal weight”:ti,ab,kw or “healthy weight”:ti,ab,kw or (obesity):ti,ab,kw or (obese):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=81) 21417 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=81&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #82 (overweight):ti,ab,kw or “over weight”:ti,ab,kw or “body mass index”:ti,ab,kw or (BMI):ti,ab,kw or “waist circumference”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=82) 12787 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=82&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #83 “skinfold thickness”:ti,ab,kw or (adiposity):ti,ab,kw or “body composition”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=83) 4045 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=83&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #84 “body fat”:ti,ab,kw and (percent*):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=84) 734 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=84&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #85 MeSH descriptor Body Mass Index explode tree 3 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=85) 4762 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=85&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #86 ( (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=86); #81 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=86); #82 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=86); #83 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=86); #84 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=86); #85 29578 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=86) edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=86&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #87 ( (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=87); #73 AND (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=87); #79 AND (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=87); #86 5113 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=87) edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=87&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #88 (cure):ti,ab,kw or (medication):ti,ab,kw or (drug):ti,ab,kw or (pharmacy):ti,ab,kw or (pharmaceutical):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=88) 296948 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=88&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #89 (surgical):ti,ab,kw or (surgery):ti,ab,kw or (Orlistat):ti,ab,kw or (Phentermine):ti,ab,kw and (Sibutramine):ti,ab,kw in Cochrane Reviews (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=89) 1331 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=89&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #90 ( (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=90); #88 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=90); #89 351275 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=90) edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=90&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #91 MeSH descriptor Phentermine, this term only (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=91) 46 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=91&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #92 MeSH descriptor Bariatric Surgery explode tree 1 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=92) 544 edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=92&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #93 ( (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=93); #90 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=93); #91 351278 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=93) edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=93&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #94 ( (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=94); #90 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=94); #91 OR (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=94); #92 351329 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=94) edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=94&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636); #95 ( (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=95); #87 AND NOT (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=95); #94 2761 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=95) edit delete (http://onlinelibrary.wiley.com/search-web/cochrane/searchHistory?mode=deletequery&qnum=95&uuid=f5956cd7-a75c-49bb-9e05-d4adc4337636&searchKey=f5956cd7-a75c-49bb-9e05-d4adc4337636)

Cinahl

S338 | S333 NOT S337
S337 | S334 or S335 or S336
S336 | TX cure OR TX medication OR TX drug OR TX drugs OR TX pharmacy OR TX pharmaceutical OR TX surgery OR TX surgical
S335 | TX orlistat
S334 | TX sibutramine
S333 | S281 and S332
S332 | S282 or S283 or S284 or S285 or S286 or S287 or S288 or S289 or S290 or S291 or S292 or S293 or S294 or S295 or S296 or S297 or S298 or S299 or S300 or S301 or S302 or S303 or S304 or S305 or S306 or S307 or S308 or S309 or S310 or S311 or S312 or S313 or S314 or S315 or S316 or S317 or S318 or S319 or S320 or S321 or S322 or S323 or S324 or S325 or S326 or S327 or S328 or S329 or S330 or S331
S331 | TX internet OR TX facebook OR TX “cell phone” OR TX regulation
S330 | TX “support systems”
S329 | TX “electronic media”
S328 | TX telemedicine
S327 | TX “consumer health information”
S326 | TX informatics
S325 | TX “Computer communication networks”
S324 | TX “electronic mail” OR TX “e-mail”
S332 | S282 or S283 or S284 or S285 or S286 or S287 or S288 or S289 or S290 or S291 or S292 or S293 or S294 or S295 or S296 or S297 or S298 or S299 or S300 or S301 or S302 or S303 or S304 or S305 or S306 or S307 or S308 or S309 or S310 or S311 or S312 or S313 or S314 or S315 or S316 or S317 or S318 or S319 or S320 or S321 or S322 or S323 or S324 or S325 or S326 or S327 or S328 or S329 or S330 or S331
S331 | TX internet OR TX facebook OR TX “cell phone” OR TX regulation
S330 | TX “support systems”
S33 | TX cooking
S329 | TX “electronic media”
S328 | TX telemedicine
S327 | TX “consumer health information”
S326 | TX informatics
S325 | TX “Computer communication networks”
S324 | TX “electronic mail” OR TX “e-mail”
S323 | TX tax*
S322 | TX infrastructure
S321 | TX environmental
S320 | TX campaign
S319 | TX environment
S318 | TX “income inequality”
S317 | TX “social-ecological”
S316 | TX socioeconomic
S315 | TX policy
S314 | TX clinic OR TX clinical OR TX clinics OR TX medical OR TX medicine OR TX office
S313 | TX “primary care”
S312 | TX “Primary Health Care”
S311 | TX “adolescent medicine”
S310 | TX “family physician” OR TX pediatrician
S309 | (MM “Physicians, Family”) OR (MM “Pediatricians”)
S308 | TX garden OR TX gardening
S307 | TX faith
S306 | TX community OR TX communities OR TX neighborhood OR TX neighborhoods
S305 | TX church OR TX Synagogue OR TX Mosque
S304 | TX recreation
S303 | TX ywca
S302 | TX ymca
S301 | TX campfire
S300 | TX “girl scouts”
S299 | TX “girl scout”
S298 | TX “boy scouts”
S297 | TX “boy scout”
S296 | TX “food label”
S295 | TX “food labeling”
S294 | TX meal OR TX meals OR TX purchasing OR TX shopping OR TX calorie
S293 | TX house OR TX home
S292 | TX preschool OR TX “pre-school”
S291 | TX “day care”
S290 | TX father OR TX fathers OR TX mother OR TX mothers OR TX parent OR TX parents OR TX parental OR TX parenting
S289 | TX “educational setting” OR TX academic OR TX kindergarten OR TX “after-school” OR TX “after school” OR TX families
S288 | TX school
S287 | TX caregivers
S286 | TX “care giver”
S285 | TX caregiver
S284 | TX cooking
S283 | TX schools
S282 | TX family
S281 | S275 and S280
S280 | S276 or S279
S279 | S277 and S278
S278 | TX “weight gain”
S277 | TX prevent* OR TX reduce OR TX reduction
S276 | TX maintenance OR TX maintain OR TX manage OR TX prevention OR TX intervention OR TX preventative OR TX promote OR TX promotion OR TX control
S275 | S264 or S265 or S266 or S267 or S268 or S269 or S270 or S271 or S272 or S273 or S274
S274 | TX “body fat” AND TX percent*
S273 | TX “Waist circumference” OR TX adiposity
S272 | TX obese OR TX obesity OR TX overweight OR TX “over weight”
S271 | TX “normal weight” OR TX “healthy weight”
S270 | TX “body composition”
S27 | TX “weight gain”
S269 | “skinfold thickness”
S268 | TX obese
S267 | TX obesity
S266 | TX BMI
S265 | TX “body mass index”
S264 | TX “body weight”
S263 | S252 or S253 or S254 or S255 or S256 or S257 or S258 or S259 or S260 or S261 or S262
S262 | TX “body fat” AND TX percent*
S261 | TX “Waist circumference” OR TX adiposity
S260 | TX obese OR TX obesity OR TX overweight OR TX “over weight”
S26 | TX prevent* OR TX reduce OR TX reduction
S259 | TX “normal weight” OR TX “healthy weight”
S258 | TX “body composition”
S257 | “skinfold thickness”
S256 | TX obese
S255 | TX obesity
S254 | TX BMI
S253 | TX “body mass index”
S252 | TX “body weight”
S251 | S199 and S250
S250 | S200 or S201 or S202 or S203 or S204 or S205 or S206 or S207 or S208 or S209 or S210 or S211 or S212 or S213 or S214 or S215 or S216 or S217 or S218 or S219 or S220 or S221 or S222 or S223 or S224 or S225 or S226 or S227 or S228 or S229 or S230 or S231 or S232 or S233 or S234 or S235 or S236 or S237 or S238 or S239 or S240 or S241 or S242 or S243 or S244 or S245 or S246 or S247 or S248 or S249
S249 | TX internet OR TX facebook OR TX “cell phone” OR TX regulation
S248 | TX “support systems”
S247 | TX “electronic media”
S246 | TX telemedicine
S245 | TX “consumer health information”
S244 | TX informatics
S243 | TX “Computer communication networks”
S242 | TX “electronic mail” OR TX “e-mail”
S241 | TX tax*
S240 | TX infrastructure
S24 | S13 or S14 or S15 or S16 or S17 or S18 or S19 or S20 or S21 or S22 or S23
S239 | TX environmental
S238 | TX campaign
S237 | TX environment
S236 | TX “income inequality”
S235 | TX “social-ecological”
S234 | TX socioeconomic
S233 | TX policy
S232 | TX clinic OR TX clinical OR TX clinics OR TX medical OR TX medicine OR TX office
S231 | TX “primary care”
S230 | TX “Primary Health Care”
S229 | TX “adolescent medicine”
S228 | TX “family physician” OR TX pediatrician
S227 | (MM “Physicians, Family”) OR (MM “Pediatricians”)
S226 | TX garden OR TX gardening
S225 | TX faith
S224 | TX community OR TX communities OR TX neighborhood OR TX neighborhoods
S223 | TX church OR TX Synagogue OR TX Mosque
S222 | TX recreation
S221 | TX ywca
S220 | TX ymca
S219 | TX campfire
S218 | TX “girl scouts”
S217 | TX “girl scout”
S216 | TX “boy scouts”
S215 | TX “boy scout”
S214 | TX “food label”
S213 | TX “food labeling”
S212 | TX meal OR TX meals OR TX purchasing OR TX shopping OR TX calorie
S211 | TX house OR TX home
S210 | TX preschool OR TX “pre-school”
S209 | TX “day care”
S208 | TX father OR TX fathers OR TX mother OR TX mothers OR TX parent OR TX parents OR TX parental OR TX parenting
S207 | TX “educational setting” OR TX academic OR TX kindergarten OR TX “after-school” OR TX “after school” OR TX families
S206 | TX school
S205 | TX caregivers
S204 | TX “care giver”
S203 | TX caregiver
S202 | TX cooking
S201 | TX schools
S200 | TX family
S199 | S193 and S198
S198 | S194 or S197
S197 | S195 and S196
S196 | TX “weight gain”
S195 | TX prevent* OR TX reduce OR TX reduction
S194 | TX maintenance OR TX maintain OR TX manage OR TX prevention OR TX intervention OR TX preventative OR TX promote OR TX promotion OR TX control
S193 | S182 or S183 or S184 or S185 or S186 or S187 or S188 or S189 or S190 or S191 or S192
S192 | TX “body fat” AND TX percent*
S191 | TX “Waist circumference” OR TX adiposity
S190 | TX obese OR TX obesity OR TX overweight OR TX “over weight”
S189 | TX “normal weight” OR TX “healthy weight”
S188 | TX “body composition”
S187 | “skinfold thickness”
S186 | TX obese
S185 | TX obesity
S184 | TX BMI
S183 | TX “body mass index”
S182 | TX “body weight”
S181 | S170 or S171 or S172 or S173 or S174 or S175 or S176 or S177 or S178 or S179 or S180
S180 | TX “body fat” AND TX percent*
S179 | TX “Waist circumference” OR TX adiposity
S178 | TX obese OR TX obesity OR TX overweight OR TX “over weight”
S177 | TX “normal weight” OR TX “healthy weight”
S176 | TX “body composition”
S175 | “skinfold thickness”
S174 | TX obese
S173 | TX obesity
S172 | TX BMI
S171 | TX “body mass index”
S170 | TX “body weight”
S169 | S164 NOT S168
S168 | S165 or S166 or S167
S167 | TX cure OR TX medication OR TX drug OR TX drugs OR TX pharmacy OR TX pharmaceutical OR TX surgery OR TX surgical
S166 | TX orlistat
S165 | TX sibutramine
S164 | S112 and S163
S163 | S113 or S114 or S115 or S116 or S117 or S118 or S119 or S120 or S121 or S122 or S123 or S124 or S125 or S126 or S127 or S128 or S129 or S130 or S131 or S132 or S133 or S134 or S135 or S136 or S137 or S138 or S139 or S140 or S141 or S142 or S143 or S144 or S145 or S146 or S147 or S148 or S149 or S150 or S151 or S152 or S153 or S154 or S155 or S156 or S157 or S158 or S159 or S160 or S161 or S162
S162 | TX internet OR TX facebook OR TX “cell phone” OR TX regulation
S161 | TX “support systems”
S160 | TX “electronic media”
S159 | TX telemedicine
S158 | TX “consumer health information”
S157 | TX informatics
S156 | TX “Computer communication networks”
S155 | TX “electronic mail” OR TX “e-mail”
S154 | TX tax*
S153 | TX infrastructure
S152 | TX environmental
S151 | TX campaign
S150 | TX environment
S149 | TX “income inequality”
S148 | TX “social-ecological”
S147 | TX socioeconomic
S146 | TX policy
S145 | TX clinic OR TX clinical OR TX clinics OR TX medical OR TX medicine OR TX office
S144 | TX “primary care”
S143 | TX “Primary Health Care”
S142 | TX “adolescent medicine”
S141 | TX “family physician” OR TX pediatrician
S140 | (MM “Physicians, Family”) OR (MM “Pediatricians”)
S139 | TX garden OR TX gardening
S138 | TX faith
S137 | TX community OR TX communities OR TX neighborhood OR TX neighborhoods
S136 | TX church OR TX Synagogue OR TX Mosque
S135 | TX recreation
S134 | TX ywca
S133 | TX ymca
S132 | TX campfire
S131 | TX “girl scouts”
S130 | TX “girl scout”
S129 | TX “boy scouts”
S128 | TX “boy scout”
S127 | TX “food label”
S126 | TX “food labeling”
S125 | TX meal OR TX meals OR TX purchasing OR TX shopping OR TX calorie
S124 | TX house OR TX home
S123 | TX preschool OR TX “pre-school”
S122 | TX “day care”
S121 | TX father OR TX fathers OR TX mother OR TX mothers OR TX parent OR TX parents OR TX parental OR TX parenting
S120 | TX “educational setting” OR TX academic OR TX kindergarten OR TX “after-school” OR TX “after school” OR TX families
S119 | TX school
S118 | TX caregivers
S117 | TX “care giver”
S116 | TX caregiver
S115 | TX cooking
S114 | TX schools
S113 | TX family
S112 | S106 and S111
S111 | S107 or S110
S110 | S108 and S109
S109 | TX “weight gain”
S108 | TX prevent* OR TX reduce OR TX reduction
S107 | TX maintenance OR TX maintain OR TX manage OR TX prevention OR TX intervention OR TX preventative OR TX promote OR TX promotion OR TX control
S106 | S95 or S96 or S97 or S98 or S99 or S100 or S101 or S102 or S103 or S104 or S105
S105 | TX “body fat” AND TX percent*
S104 | TX “Waist circumference” OR TX adiposity
S103 | TX obese OR TX obesity OR TX overweight OR TX “over weight”
S102 | TX “normal weight” OR TX “healthy weight”
S101 | TX “body composition”
S100 | “skinfold thickness”
S99 | TX obese
S98 | TX obesity
S97 | TX BMI
S96 | TX “body mass index”
S95 | TX “body weight”
S94 | S83 or S84 or S85 or S86 or S87 or S88 or S89 or S90 or S91 or S92 or S93
S93 | TX “body fat” AND TX percent*
S92 | TX “Waist circumference” OR TX adiposity
S91 | TX obese OR TX obesity OR TX overweight OR TX “over weight”
S90 | TX “normal weight” OR TX “healthy weight”
S89 | TX “body composition”
S88 | “skinfold thickness”
S87 | TX obese
S86 | TX obesity
S85 | TX BMI
S84 | TX “body mass index”
S83 | TX “body weight”
S82 | S30 and S81
S81 | S31 or S32 or S33 or S34 or S35 or S36 or S37 or S38 or S39 or S40 or S41 or S42 or S43 or S44 or S45 or S46 or S47 or S48 or S49 or S50 or S51 or S52 or S53 or S54 or S55 or S56 or S57 or S58 or S59 or S60 or S61 or S62 or S63 or S64 or S65 or S66 or S67 or S68 or S69 or S70 or S71 or S72 or S73 or S74 or S75 or S76 or S77 or S78 or S79 or S80
S80 | TX internet OR TX facebook OR TX “cell phone” OR TX regulation
S79 | TX “support systems”
S78 | TX “electronic media”
S77 | TX telemedicine
S76 | TX “consumer health information”
S75 | TX informatics
S74 | TX “Computer communication networks”
S73 | TX “electronic mail” OR TX “e-mail”
S72 | TX tax*
S71 | TX infrastructure
S70 | TX environmental
S69 | TX campaign
S68 | TX environment
S67 | TX “income inequality”
S66 | TX “social-ecological”
S65 | TX socioeconomic
S64 | TX policy
S63 | TX clinic OR TX clinical OR TX clinics OR TX medical OR TX medicine OR TX office
S62 | TX “primary care”
S61 | TX “Primary Health Care”
S60 | TX “adolescent medicine”
S59 | TX “family physician” OR TX pediatrician
S58 | (MM “Physicians, Family”) OR (MM “Pediatricians”)
S57 | TX garden OR TX gardening
S56 | TX faith
S55 | TX community OR TX communities OR TX neighborhood OR TX neighborhoods
S54 | TX church OR TX Synagogue OR TX Mosque
S53 | TX recreation
S52 | TX ywca
S51 | TX ymca
S50 | TX campfire
S49 | TX “girl scouts”
S48 | TX “girl scout”
S47 | TX “boy scouts”
S46 | TX “boy scout”
S45 | TX “food label”
S44 | TX “food labeling”
S43 | TX meal OR TX meals OR TX purchasing OR TX shopping OR TX calorie
S42 | TX house OR TX home
S41 | TX preschool OR TX “pre-school”
S40 | TX “day care”
S39 | TX father OR TX fathers OR TX mother OR TX mothers OR TX parent OR TX parents OR TX parental OR TX parenting
S38 | TX “educational setting” OR TX academic OR TX kindergarten OR TX “after-school” OR TX “after school” OR TX families
S37 | TX school
S36 | TX caregivers
S35 | TX “care giver”
S34 | TX caregiver
S33 | TX cooking
S32 | TX schools
S31 | TX family
S30 | S24 and S29
S29 | S25 or S28
S28 | S26 and S27
S27 | TX “weight gain”
S26 | TX prevent* OR TX reduce OR TX reduction
S25 | TX maintenance OR TX maintain OR TX manage OR TX prevention OR TX intervention OR TX preventative OR TX promote OR TX promotion OR TX control
S24 | S13 or S14 or S15 or S16 or S17 or S18 or S19 or S20 or S21 or S22 or S23
S23 | TX “body fat” AND TX percent*
S22 | TX “Waist circumference” OR TX adiposity
S21 | TX obese OR TX obesity OR TX overweight OR TX “over weight”
S20 | TX “normal weight” OR TX “healthy weight”
S19 | TX “body composition”
S18 | “skinfold thickness”
S17 | TX obese
S16 | TX obesity
S15 | TX BMI
S14 | TX “body mass index”
S13 | TX “body weight”
S12 | S1 or S2 or S3 or S4 or S5 or S6 or S7 or S8 or S9 or S10 or S11
S11 | TX “body fat” AND TX percent*
S10 | TX “Waist circumference” OR TX adiposity
S9 | TX obese OR TX obesity OR TX overweight OR TX “over weight”
S8 | TX “normal weight” OR TX “healthy weight”
S7 | TX “body composition”
S6 | “skinfold thickness”
S5 | TX obese
S4 | TX obesity
S3 | TX BMI
S2 | TX “body mass index”
S1 | TX “body weight”

ClinicalTrials.gov

Clinicaltrials.gov 23July2012 Childhood AND obesity: 213 Childhood AND weight: 364 Child AND obesity: 970 Child AND weight: 2906 Teen and obesity: 301 Teen AND weight: 526 Adolescent AND obesity: 301 Adolescent and weight: 526
6107 unduplicated De-duplicated: 3168