# List of Acronyms

AHRQ: Agency for Healthcare Research and Quality
API: Asian Pacific Islanders
BMC: Bone Mineral Content
BMD: Bone Mineral Density
BMI: Body Mass Index
BNH: Black Non-Hispanic
BP: Blood Pressure
CDC: Centers for Disease Control
CER: Comparative Effectiveness Review
CNMI: Commonwealth of the Northern Marina Islands
CVD: Cardiovascular Disease
DXA: Dual-Emission X-Ray Absorptiometry
Edu: Education
HDL: High-Density Lipids
HRQOL: Health-Related Quality Of Life
KQ: Key Question
LDL: Low-Density Lipids
Maint: Maintenance
MeSH: Medical Subject Headings
N: No
NR: Not Relevant
oth: Other
Phy: Physical or Environmental
PICOTS: Population/Intervention/Comparison/Outcome/Timeframe/Setting
PRISMA: Preferred Reporting Items For Systematic Reviews And Meta-Analyses
RCT: Randomized Controlled Trials
SD: Standard Deviation
SES: Social-Economic Status
SM: Self-Management
TEP: Technical Expert Panel
WHO: World Health Organization
WNH: White Non-Hispanic
Y: Yes