# Results

## Introduction

In this chapter, we present the results of our systematic review of the literature and synthesis of the extracted data on outcomes on the effectiveness and comparative effectiveness of local hepatic therapies for unresectable HCC. The Key Questions for this review are: effectiveness (KQ1) and harms (KQ2) of local hepatic therapies in patients with HCC who are not otherwise candidates for surgical resection or transplantation; and comparative effectiveness of local hepatic therapies in subgroups of patients with HCC who are not otherwise candidates for surgical resection or transplantation, stratified by specific patient and tumor characteristics, such as age, sex, disease etiology, and Child-Pugh score (KQ3).

We first describe the results of our literature searches, followed by results for KQ1 and KQ2, which include a list of key points, an overview of the included literature and detailed synthesis of the data. Results for KQ3 are presented in a similar fashion. We identified 1,713 nonduplicate titles or abstracts with potential relevance, with 732 proceeding to full-text review (Figure 2). Forty-eight articles were included in the review, including six hand-searched articles, representing 48 distinct studies: six randomized controlled trials (RCTs), one prospective cohort study, four retrospective cohort studies, one prospective case control study, one retrospective case control study, 14 prospective case series, 16 retrospective case series, two case series of unknown temporal frame, and three case reports. All 48 studies pertain to KQ1 and KQ2, and three studies pertain to KQ3.

Figure 2 PRISMA diagram for identified studies

Figure 2 is a PRISMA diagram illustrating the review of articles identified via literature search for this systematic review. 1,707records were identified through the literature search. 316 records were excluded due to a publication date prior to the year 2000. 1,391 titles were screened and 469 were excluded. 922 abstracts were screened and 196 abstracts were excluded. The remaining 726 records were retrieved and the full-text articles were assessed for eligibility. An additional 684 articles were excluded with reasons given in Appendix F. 42 articles were included in this report from the literature search and six additional records were found through hand searching for a total of 48 articles included in this review.

## Results of Literature Search

Of the 1,707 articles identified through the literature search, 1,665 were excluded at various stages of screening and 42 articles were included. Six hand-searched articles were also included for a total of 48 articles in this systematic review. The Preferred Reporting Items for Systematic Reviews and Meta-Analysis (PRISMA) diagram (Figure 2) depicts the flow of search screening and study selection.

Our searches of various grey literature sources did not yield any additional published studies meeting our inclusion criteria.

We evaluated the results of the grey literature search as follows:

- Regulatory information: The search yielded 33 results but no new studies were identified from this source.
- Clinical trial registries (ClinicalTrials.gov, controlled-trials.com, who.int): The search yielded 207 clinical trials; we excluded 136 trials during the title and abstract screen. All 71 remaining trials were excluded. Of these 71 trials, three had been terminated, 42 were ongoing or recruiting, 23 were of unknown status, and three had been completed. We found no publications for the three completed trials (NCT00867750, NCT00739167, and ISRCTN54481540). There were no ongoing or completed trials that were relevant to this systematic review.
- Abstracts and conference papers (American Society of Clinical Oncology, Gastrointestinal Cancers Symposium, Society of Surgical Oncology, The Radiosurgery Society, American Association for the Study of Liver Diseases): The search yielded 134 citations, and we excluded all 134 during the title and abstract screen.
- Manufacturer database: Scientific information packets (SIPs) were received from Accuray (manufacturers of the CyberKnife^®^ stereotactic body radiation therapy [SBRT] system), Biocompatibles (DC Bead^®^), SIRTEX (manufacturers of the yttrium-90–infused SIR-Spheres microspheres), and Nordion (manufacturers of TheraSphere^®^). There were 150 published studies in the submission, and all 150 were excluded during full-text screen.

## Description of Included Studies

Forty-eight studies met our inclusion criteria and addressed local hepatic therapies for unresectable HCC (Table 9 and Table 10). Eleven studies were conducted in China, seven in Italy, nine in Japan, seven in the United States, three in Taiwan, three in South Korea, two in Canada, and one each in France, Egypt, Greece, Austria, Thailand, and Australia. The number of participants ranged from 10 to 320 patients (not including case reports).

Table 9 Characteristics of studies included in this review by intervention: monotherapies

Characteristic | Cryoablation | RFA | MWA | PEI/PAI | TAE | TACE^*^ | RE | DEB | 3D-CRT | IMRT | SBRT | HPBT | Intraluminal brachytherapy | Total^†^
Total | 3 | 9 | 1 | 3 | 3 | 19 | 4 | 5 | 2 | 0 | 3 | 0 | 0 | 52
Study Design
RCT | 0 | 4 | 0 | 3 | 1 | 1 | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 11
Prospective Cohort | 0 | 1 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 3
Retrospective Cohort | 1 | 1 | 0 | 0 | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 5
Prospective Case Control | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 2
Retrospective Case Control | 0 | 0 | 0 | 0 | 1 | 1 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 3
Prospective Case Series | 0 | 1 | 1 | 0 | 0 | 4^‡^ | 3^§^ | 1 | 1 | 0 | 0 | 0 | 0 | 10
Retrospective Case Series | 2 | 0 | 0 | 0 | 1 | 5 | 1 | 1 | 0 | 0 | 3 | 0 | 0 | 13
Case Series – Unknown Temporal Frame | 0 | 1 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2
Case Report | 0 | 1 | 0 | 0 | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 3
Outcomes Reported
Overall Survival | 3 | 8 | 1 | 3 | 3 | 14 | 4 | 5 | 2 | 0 | 3 | 0 | 0 | 41
Quality of Life | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Time to Progression | 0 | 5 | 1 | 2 | 2 | 6 | 0 | 4 | 0 | 0 | 3 | 0 | 0 | 23
Length of Stay | 1 | 2 | 0 | 2 | 0 | 4 | 1 | 3 | 0 | 0 | 0 | 0 | 0 | 13
Local Recurrence | 2 | 7 | 1 | 3 | 1 | 0 | 0 | 1 | 2 | 0 | 1 | 0 | 0 | 18
Adverse Events | 3 | 8 | 0 | 3 | 2 | 15 | 3 | 5 | 2 | 0 | 3 | 0 | 0 | 44
Study population
United States/Canada | 0 | 1 | 0 | 0 | 0 | 4 | 3 | 1 | 0 | 0 | 1 | 0 | 0 | 10
Europe | 0 | 1 | 0 | 1 | 2 | 6 | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 12
Australia | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1
Asia | 3 | 7 | 1 | 2 | 1 | 9 | 0 | 1 | 2 | 0 | 2 | 0 | 0 | 28
Africa | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Total N participants | 238 | 320 | 60 | 299 | 76 | 1,876 | 187 | 362 | 55 | 0 | 91 | 0 | 0 | 3,564

* Transarterial embolization (bland, without any chemotherapeutic agent) was performed every time epirubicin was contraindicated in Pietrosi et al. 2009.^49^

† This number reflects the total number of study arms.

‡ Includes one RCT extracted as case series.

§ Includes one prospective cohort study extracted as case series.

Abbreviations: 3D-CRT = Three dimensional conformal radiotherapy; DEB = Drug-eluting beads; HPBT = Hypofractionated proton beam therapy; IMRT = Intensity modulated radiation therapy; MWA = Microwave ablation; N = Number; PAI = Percutaneous acetic acid injection; PEI = Percutaneous ethanol injection; RCT = Randomized controlled trial; RE = Radioembolization; RFA = Radiofrequency ablation; SBRT = Stereotactic body radiotherapy; TACE = Transarterial chemoembolization; TAE = Transarterial embolization; N = number.

Table 10 Characteristics of studies included in this review by intervention: combination therapies

Characteristic | RFA With TACE | RFA With TAE | RFA With DEB | TACE With PEI | TACE With Cryoablation | Total
Total | 2 | 1 | 1 | 1 | 1 | 6
Study Design
RCT | 1 | 0 | 0 | 0 | 0 | 1
Prospective Cohort | 0 | 0 | 0 | 0 | 0 | 0
Retrospective Cohort | 0 | 0 | 0 | 0 | 1 | 1
Retrospective Case Control | 0 | 0 | 0 | 0 | 0 | 0
Prospective Case Series | 0 | 1 | 1 | 1 | 0 | 3
Retrospective Case Series | 1 | 0 | 0 | 0 | 0 | 1
Case Report | 0 | 0 | 0 | 0 | 0 | 0
Outcomes Reported
Overall Survival | 2 | 1 | 0 | 1 | 1 | 5
Quality of Life | 0 | 0 | 0 | 0 | 0 | 0
Time to Progression | 2 | 0 | 0 | 0 | 0 | 2
Length of Stay | 0 | 0 | 1 | 0 | 0 | 1
Local Recurrence | 1 | 0 | 0 | 0 | 1 | 2
Adverse Events | 1 | 1 | 1 | 1 | 1 | 5
Study population
United States | 0 | 0 | 0 | 0 | 0 | 0
Europe | 0 | 0 | 1 | 0 | 0 | 1
Australia | 0 | 0 | 0 | 0 | 0 | 0
Asia | 2 | 1 | 0 | 1 | 1 | 5
Total N participants | 141 | 36 | 20 | 63 | 290 | 550

Abbreviations: DEB = Drug-eluting beads; N = Number; PEI = Percutaneous ethanol injection; RCT = Randomized controlled trial; RFA = Radiofrequency ablation; TACE = Transarterial chemoembolization; TAE = Transarterial embolization.

Appendix D presents the quality ratings for all 48 articles included in this evidence review.

All six RCTs assembled and maintained comparable groups, had minimal loss to followup, clearly defined the interventions, and included important outcomes of interest. The outcome measurements were not equal, valid, and reliable in all six studies, largely due to the lack of blinding of the outcomes assessor. All but two studies performed an intent-to-treat analysis, and three studies acknowledged the funding source. Overall, one study was rated as good quality, three studies were of fair quality, and two were rated as poor quality according to The United States Preventive Services Task Force rating.45

Using the same rating system as for the RCTs, the four nonrandomized comparative studies were rated as poor. The studies did not report blinding and did not use appropriate statistical analysis. They had representative samples; valid, reliable, and equal measurements; and adequate length of followup; however, none attempted to balance groups by design, allocate participants to treatment groups to minimize bias, or adjust for confounders in statistical analysis. One study did not report followup loss.

All 35 case series studies had clearly defined questions and well-described interventions, used validated outcome measures, and had conclusions that were supported by the data. Studies varied on how well they described the study population and their results. Twenty studies did not have well-described patient populations and five lacked well-described results. Twelve studies were of good quality, 20 studies of fair quality, and three were rated as poor quality. Quality rating was not applied to the single case report in this review.

## Key Questions 1 and 2 Effectiveness and Harms of Local Hepatic Therapy

Key questions 1 and 2 focus on the comparative effectiveness (KQ1) and harms (KQ2) of the various local hepatic therapies in patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and have no evidence of extrahepatic disease.

Data for ablative, transarterial, radiotherapy, and combinations of local therapies are presented in four separate sections.

### Key Points

- RFA compared with PEI/PAI: There is moderate strength of evidence to support better overall survival at 3 years for RFA compared with PEI/PAI, with a low risk of bias.
  ○ Three RCTs compared the ablative treatments RFA and PEI/PAI. No nonrandomized comparative studies examined this comparison. In addition to the comparative evidence, three case series of RFA are included in this report. There are no observational studies on PEI/PAI that met inclusion criteria.
- The body of evidence for RFA compared with PEI/PAI was rated low strength to support increased TTP, improved local control and a longer LOS for RFA compared with PEI/PAI, with a high risk of bias.
- Of the 13 interventions included in this report, only one comparison had sufficient evidence to receive a rating above insufficient. For all other comparisons, the body of evidence on overall survival, quality of life, disease progression, local control, LOS, days of missed work, and adverse events for local hepatic therapy for the treatment of HCC is insufficient to support the effectiveness of one local hepatic therapy over another, due to the lack of comparative studies.

## Ablative Therapies

### Description of Included Studies

A total of 11 studies met the inclusion criteria to address KQ1 and KQ2 for ablative therapies, including three RCTs,50-52 one nonrandomized comparative study,53 six series studies,54-59 and one case report.60 The nonrandomized comparative study was retrospective.53 Of the six case series studies, two were retrospective54,59 and three were prospective.55-57 The prospective or retrospective nature of one study could not be determined.58 The total number of patients for whom data were extracted from the 11 studies was 809. There were 483 patients from RCTs, 91 from nonrandomized comparative studies, 234 from case series, and one from a case report. All 11 studies had patient samples that were restricted to unresectable HCC patients (i.e., not including patients with liver tumors of other primary origins). All studies initiated treatment in patients after January 1, 2000.

One RCT compared RFA to PEI alone,50 one RCT compared RFA to conventional and high-dose PEI,51 and the third RCT compared RFA to PEI and PAI.52 Table 11 and Table 12 present a summary of study and patient characteristics from the RCTs, including the number of patients enrolled, intervention period, intervention, and baseline characteristics. Patients ranged in age from 59 to 70.3 years with the majority in their sixties and seventies. The patients' baseline Child-Pugh liver cirrhosis classes were A or B, and there were no patients in class C cirrhosis. ECOG scores were 0 to 1 in all studies. No study reported BCLC stage. No RCTs reported prior treatment history or presence of portal vein thrombosis. Studies varied in terms of proportions of patients with hepatitis B virus (HBV) and hepatitis C virus (HCV) infection.

Table 11 Summary of ablative therapy study characteristics: RCTs

Study N Rating | Intervention | Intervention Period | Mean Age (Range) | CP A%; B% | BCLC A%; B% | Previous LDT %
Brunello et al. 2008^50^ 139 Good | RFA under US guidance with either cool tip or multitined electrodes for 12 min or 15–25 min, respectively | 01/2001 - 09/2004 | 69.0 (NR) | A: 55.7; B: 44.3 | NR | NR
Brunello et al. 2008^50^ 139 Good | PEI with sterile ethanol (95%, 2–20 mL) injected into each lesion with a single needle (1–4 sessions) | 01/2001 - 09/2004 | 70.3 (NR) | A: 56.5; B: 43.5 | NR | NR
Lin et al. 2004^51^ 157 Fair | Percutaneous RFA with 15-gauge electrode under US guidance repeated 2 weeks later for up to 2 courses per tumor | 04/2000 - 04/2002 | 62 (NR) | A: 79; B: 21 | NR | NR
Lin et al. 2004^51^ 157 Fair | PEI with 99.5% ethanol (volume per session mean: 4.5 mL, SD: 1.6 mL, range: 2–10 mL) using a single transhepatic cholangiography needle twice weekly for up to 6 sessions per tumor per course and 12 sessions of the maximal treatment per tumor | 04/2000 - 04/2002 | 59 (NR) | A: 75; B: 25 | NR | NR
Lin et al. 2004^51^ 157 Fair | PEI with 99.5% ethanol (volume per session mean: 8.5 mL, SD: 2.8 mL, range: 6–18 mL) using two transhepatic cholangiography needles and a third needle if needed twice weekly for up to 3 sessions per tumor per course and 6 sessions of the maximal treatment per tumor | 04/2000 - 04/2002 | 61 (NR) | A: 74; B: 26 | NR | NR
Lin et al. 2005^52^ 187 Fair | Percutaneous RFA with 15-gauge electrode under US guidance repeated 2 weeks later for up to 2 courses per tumor | 04/2000 - 06/2002 | 61 (NR) | A: 74.2; B: 25.8 | NR | NR
Lin et al. 2005^52^ 187 Fair | PEI with 99.5% ethanol (volume per session mean: 4.8 mL, SD: 1.4 mL, range: 2–10.4 mL) twice weekly for up to 6 sessions per tumor per course and 12 sessions of the maximal treatment per tumor | 04/2000 - 06/2002 | 60 (NR) | A: 75.8; B: 24.2 | NR | NR
Lin et al. 2005^52^ 187 Fair | PAI with 50% acetic acid (volume per session mean: 2.2 mL, SD: 1.1 mL, range: 1–3.5 mL) twice weekly for up to 6 sessions per tumor per course and 12 sessions of the maximal treatment per tumor | 04/2000 - 06/2002 | 63 (NR) | A: 71.4; B: 28.6 | NR | NR

Abbreviations: BCLC = Barcelona Clinic Liver Center hepatocellular carcinoma stage; CP = Child-Pugh liver cirrhosis class; LDT = liver-directed therapy; N = number of patients; NR = not reported; PAI = percutaneous acetic acid injection; PEI = percutaneous ethanol injection; RFA = radiofrequency ablation; SD = standard deviation; US = ultrasound.

Table 12 Summary of ablative therapy underlying liver disease characteristics: RCTs

Study Rating | Group N | Cirrhosis% | HBV% | HCV% | Alcohol%
Brunello et al. 2008^50^ Good | RFA 70 | NR | 8.6 | 62.9 | 15.7
Brunello et al. 2008^50^ Good | PEI 69 | NR | 0 | 68.1 | 11.6
Lin et al. 2004^51^ Fair | RFA 52 | NR | 67 | 31 | NR
Lin et al. 2004^51^ Fair | Conventional PEI 52 | NR | 71 | 27 | NR
Lin et al. 2004^51^ Fair | High dose PEI 53 | NR | 69 | 30 | NR
Lin et al. 2005^52^ Fair | RFA 62 | NR | 66.1 | 32.3 | NR
Lin et al. 2005^52^ Fair | PEI 62 | NR | 67.7 | 30.6 | NR
Lin et al. 2005^52^ Fair | PAI 63 | NR | 65.1 | 33.3 | NR

Abbreviations: HBV = hepatitis B virus; HCV = hepatitis C virus; N = number of patients; NR = not reported; PAI = percutaneous acetic acid injection; PEI = percutaneous ethanol injection; RFA = radiofrequency ablation.

As displayed in Table 13, the three RCTs were similar in which tumor characteristics were reported and how these characteristics were reported. None of these studies reported lesion size, or bilobar disease status. The majority of patients presented with solitary tumors which ranged from 73 to 79 percent.

Table 13 Summary of ablative therapy tumor characteristics: RCTs

Study Rating | Group N | Bilobar % | Number of Lesions | Lesion Size Range (cm) | Other Lesion Characteristics
Brunello et al. 2008^50^ Good | RFA 70 | NR | Mean:1.3 Solitary: 77.1 | NR | NR
Brunello et al. 2008^50^ Good | PEI 69 | NR | Mean:1.3 Solitary: 78.7 | NR | NR
Lin et al. 2004^51^ Fair | RFA 52 | NR | 1: 73%, 2: 21%, 3: 6% | NR | NR
Lin et al. 2004^51^ Fair | ConventionalPEI 52 | NR | 1: 77%, 2: 17%, 3: 6% | NR | NR
Lin et al. 2004^51^ Fair | High-dose PEI 53 | NR | 1: 77%, 2: 19%, 3: 4% | NR | NR
Lin et al. 2005^52^ Fair | RFA 62 | NR | Solitary: 79.0% | NR | NR
Lin et al. 2005^52^ Fair | PEI 62 | NR | Solitary: 79.0% | NR | NR
Lin et al. 2005^52^ Fair | PAI 63 | NR | Solitary: 76.2% | NR | NR

Abbreviations: N = number; NR = not reported; PAI = percutaneous acetic acid injection; PEI = percutaneous ethanol injection; RFA = radiofrequency ablation.

Of the eight observational studies (1 nonrandomized comparative study, 6 case series studies, and 1 case report), one study included patients treated with TACE,53 five studies included patients treated with RFA,53,56-58,60 two studies treated patients with cryoablation,54,59 and one study treated patients with MWA.55 The nonrandomized comparative study treated patients with RFA or TACE and was included in this section because all patients were eligible for ablative therapy due to a small tumor size.53 Table 14 and Table 15 present a summary of study and patient characteristics from the nonrandomized comparative studies and case series, including number of patients enrolled, intervention period, intervention, and baseline characteristics. Median age ranged from 46 to 67.7 years. The patients' baseline Child-Pugh liver cirrhosis classes were largely A or B, with a very small minority (≤10 percent) in class C. ECOG scores were reported in only one study with all patients having 0 to 1.^55^ One study reported BCLC stage A (early) or B (intermediate) of the enrolled patients with all patients classified in the intermediate category.59 One study reported that no patients had PVT.55 No studies reported previous liver directed therapies. Two studies reported on the proportion of patients with cirrhosis, ranging from 84.6 percent to 100 percent.54,58 Studies varied in terms of proportions of patients with HBV and HCV infection.50-55,57,60 Overall, studies were inconsistent in reporting— and often did not report— these patient and tumor characteristics at baseline (e.g., ECOG score, Child-Pugh class, PVT, HCC stage) which are important prognostic factors to consider when comparing patient populations across studies.

Table 14 Summary of ablative therapy study and patient characteristics: nonrandomized comparative studies

Study N Rating | Study Design | Intervention Period | Intervention | Age, Mean or Median (Range) | ECOG Score | CP A%; B%; C% | BCLC A%; B% | Previous LDT %
Chok et al. 2006^53^ 91 Poor | Retrospective cohort | 02/2001 - 03/2004 | TACE with cisplatin (1 mg/mL), lipiodol (volume ration 1:1), gelatin sponge mixed with gentamicin sulfate (40 mg) via superselective arteries repeated 8 to 12 weeks | Median: 66 (47–85) | NR | A: 78; B: 20; C: 2 | NR | NR
Chok et al. 2006^53^ 91 Poor | Retrospective cohort | 02/2001 - 03/2004 | Percutaneous (45%), laparoscopic (2%) or open (53%) RFA with cool-tip electrodes | Median: 62 (42–77) | NR | A: 76; B: 22; C: 2 | NR | NR

Abbreviations: BCLC = Barcelona Clinic Liver Center hepatocellular carcinoma stage; CP = Child-Pugh liver cirrhosis class; ECOG = Eastern Cooperative Oncology Group; LDT = liver-directed therapy; N = number of patients; NR = not reported; RFA = radiofrequency ablation.

Table 15 Summary of ablative therapy study and patient characteristics: case series studies

Study N Rating | Study Design | Intervention Period | Intervention | Age, Mean or Median (Range) | ECOG Score | CP A%; B%; C% | BCLC A%; B% | Previous LDT %
Chen et al. 2011^54^ 40 Fair | Retrospective case series | 01/2006 - 06/2009 | US-guided percutaneous cryotherapy | Mean: 59.3 (NR) | NR | A: 30; B: 60; C: 10 | NR | NR
Chen et al. 2011^54^ 26 Fair | Retrospective case series | 01/2006 - 06/2009 | US-guided percutaneous cryotherapy | Mean: 57.4 (NR) | NR | A: 23.1; B: 69.2; C: 7.7 | NR | NR
Itoh et al. 2011^55^ 60 Good | Prospective case series | 05/2003 - 12/2010 | Surgical microwave therapy administered for 60 s at a power setting of 65 W per pulse using a microwave electrode 1.6mm in diameter and 25cm in length | Mean: 67.7 (47–83) | ≤1: 100 | A: 68.3; B: 31.6; C: 0 | NR | NR
Minami et al. 2007^56^ 30 Poor | Prospective case series | 05/2000 - 09/2003 | Open RFA with cooled-tip needle guided by intraoperative sonography | Mean: 63 (44–76) | NR | NR | NR | NR
Shen et al. 2005^57^ 16 Poor | Prospective cohort^*^ | 09/2001 - 06/2004 | Percutaneous RFA with retractable curved electrodes (90W peak power) under US guidance | Median: 56.1 (36–75) | NR | A: 37.5; B: 62.5; C: 0 | NR | NR
Singh et al. 2011 60 1 Poor | Case report | | RFA under US guidance using cool-tip RFA probe | 46 | NR | A | NR | NR
Tanaka et al. 2009^58^ 20 Poor | Case series (uncertain if prospective or retrospective) | 07/2000 - 12/2002 | Open RFA via laparotomy (17) or thoracotomy (3) | Median: 66 (NR) | NR | A: 50.0; B: 45.0; C: 5.0 | NR | NR
Zhou et al. 2009^59^ 42 Fair | Retrospective case series | 12/2003 - 12/2006 | Surgical cryoablation with argon (drop to -140°C for 15–20 min) and helium (raise to 20°C-40°C for 3–5 min) for 2–3 freezing-thawing cycles | Median: 55.8 (NR) | NR | A: 66.7; B: 33.3; C: 0 | A: 0; B: 100 | NR

* Only a single arm of the two comparative arms was included in this evidence review.

Abbreviations: BCLC = Barcelona Clinic Liver Center hepatocellular carcinoma stage; CP = Child-Pugh liver cirrhosis class; ECOG = Eastern Cooperative Oncology Group; LDT = liver directed therapy; N = number of patients; NR = not reported; RFA = radiofrequency ablation; US = ultrasound.

Table 16 and Table 17 present data on underlying liver disease characteristics from the nonrandomized comparative studies and case series. Table 18 presents data on the nonrandomized comparative study tumor characteristics. In Table 19, the seven observational studies varied in which tumor characteristics were reported and how these characteristics were reported. The proportion of patients with a bilobar disease was reported by three studies and ranged from 25 to 69.2 percent.54,57,60 The number of lesions was reported in four studies55,57,58,60 and lesion size was reported in five studies.55,57-60

Table 16 Summary of ablative therapy underlying liver disease characteristics: nonrandomized comparative studies

Study Rating | Group N | Cirrhosis% | HBV% | HCV% | NAFLD% | Alcohol%
Chok et al. 2006^53^ Poor | TACE 40 | NR | 78 | NR | NR | NR
Chok et al. 2006^53^ Poor | RFA 51 | NR | 82 | NR | NR | NR

Abbreviations: HBV = hepatitis B virus; HCV = hepatitis C virus; N = number of patients; NAFLD = nonalcoholic fatty liver disease; NR = not reported; RFA = radiofrequency ablation; TACE = transarterial chemoembolization

Table 17 Summary of ablative therapy underlying liver disease characteristics: case series studies

Study Rating | Group N | Cirrhosis% | HBV% | HCV% | NAFLD% | Alcohol%
Chen et al. 2011^54^ Fair | Cryotherapy 40 | 85 | 95 | 5 | NR | NR
Chen et al. 2011^54^ Fair | Cryotherapy (recurrent HCC) 26 | 84.6 | 96.2 | 3.8 | NR | NR
Itoh et al. 2011^55^ Good | MWA 60 | NR | 13.3 | 78.3 | NR | NR
Minami et al. 2007^56^ Poor | RFA 30 | NR | NR | NR | NR | NR
Shen et al. 2005^57^ Poor | RFA 16 | NR | 56.2 | NR | NR | NR
Singh et al. 2011^60^ Poor | RFA 1 | NR | 100 | NR | NR | 100
Tanaka et al. 2009^58^ Poor | RFA 20 | 100 | NR | NR | NR | NR
Zhou et al. 2009^59^ Fair | Cryoablation 42 | NR | NR | NR | NR | NR

Abbreviations: HBV = hepatitis B virus; HCC = hepatocellular carcinoma; HCV = hepatitis C virus; MWA = microwave ablation; N = number of patients; NAFLD = nonalcoholic fatty liver disease; NR = not reported; RFA = radiofrequency ablation; RFTA = radiofrequency thermal ablation.

Table 18 Summary of ablative therapy tumor characteristics: nonrandomized comparative studies

Study Rating | Group N | Bilobar % | Number of Lesions | Lesion Size (cm) | Other Lesion Characteristics
Chok - 2006^53^ Poor | TACE 40 | 28 | NR | NR | NR
Chok - 2006^53^ Poor | RFA 51 | 12 | NR | NR | NR

Abbreviations: N = number of patients; NR = not reported; RFA = radiofrequency ablation; TACE = transarterial chemoembolization.

Table 19 Summary of ablative therapy tumor characteristics: case series studies

Study Rating | Group N | Bilobar % | Number of Lesions | Lesion Size (cm) | Other Lesion Characteristics
Chen et al. 2011^54^ Fair | Cryotherapy 40 | 25 | NR | NR | NR
Chen et al. 2011^54^ Fair | Cryotherapy (Recurrent HCC) 26 | 69.2 | NR | NR | NR
Itoh et al. 2011^55^ Good | MWA 60 | NR | Median: 2 Range: 1–9 Solitary: 45% | Median: 2.0 Range: 0.8–3.3 | NR
Minami et al. 2007^56^ Poor | RFA 30 | NR | NR | Range: 1.0–10 | NR
Shen et al. 2005^57^ Poor | RFA 16 | 37.5 | Solitary: 18.8% | Range: 2.3–12.3 | NR
Singh et al. 2011^60^ Poor | RFA 1 | 100 | 2 | 1.5 | NR
Tanaka et al. 2009^58^ Poor | RFA 20 | NR | Median: 2 IQR: 1-3 | IQR: 1.5-2.8 | NR
Zhou et al. 2009^59^ Fair | Cryoablation 42 | NR | NR | Median: 6.2 | NR

Abbreviations: HCC = hepatocellular carcinoma; IQR = interquartile range; N = number of patients; NR = not reported; RFA = radiofrequency ablation; SBRT = stereotactic body radiation therapy.

### Detailed Synthesis

Table 20 displays the outcomes reported in the three RCTs. All RCTs reported overall survival and survival by year.50-52 Outcomes related to progression were reported in two trials.51,52 All RCTs reported local recurrence or local tumor progression as a measure of treatment failure.50-52 Studies varied in the use of terms and definitions of those outcomes related to disease progression and local recurrence, and we describe them in this report as they are reported in the studies. LOS was reported in two trials.51,52 Quality of life was not reported in any of the RCTs. All three trials reported adverse events.50-52

Table 20 Ablative therapy outcomes reported for Key Questions 1 and 2: RCTs

Study N Rating | OS | Survival by Year | Outcomes Related to Progression | LR/Local Tumor Progression | LOS | QOL | AE
Brunello et al. 2008^50^ 139 Good | ● | ● | NR | ● | NR | NR | ●
Lin et al. 2004^51^ 157 Fair | ● | ● | ● | ● | ● | NR | ●
Lin et al. 2005^52^ 187 Fair | ● | ● | ● | ● | ● | NR | ●

“●” Indicates that this outcome was reported in the article.

Abbreviations: AE = adverse events; LOS = length of stay; LR = local recurrence; N = number of patients; NR = not reported; OS = overall survival; QOL = quality of life.

Study outcomes data were synthesized by intervention comparisons found in the 11 included articles.

Table 21 displays the outcomes reported in the nonrandomized comparative study. Overall survival, survival by year, outcomes related to progression, and adverse events were reported. Recurrence was reported only for the RFA group.53

Table 21 Ablative therapy outcomes reported for Key Questions 1 and 2: nonrandomized comparative studies

Study N Rating | OS | Survival by Year | Outcomes Related to Progression | LR/Local Tumor Progression | LOS | QOL | AE
Chok et al. 2006^53^ 91 Poor | ● | ● | ● | ●* | NR | NR | ●

Chok et al. 2006 reported local recurrence in the RFA group only.

Abbreviations: AE = adverse events; LOS = length of stay; LR = local recurrence; N = number of patients; NR = not reported; OS = overall survival; QOL = quality of life.

Table 22 displays the outcomes reported in the seven case series and case report studies. All studies, with the exception of the case report,60 reported overall survival or survival by year. Survival by year presents the duration of survival for the included patients and reporting ranges from 1 to 5 years for the case series. Outcomes related to progression were reported in two studies.55,58 Local recurrence or local tumor progression were reported in four studies.54,55,57,58 LOS was reported by one study.54 Adverse events were reported in all but one study,55 and no observational studies reported on quality of life.

Table 22 Outcomes reported for Key Questions 1 and 2: case series studies

Study N Rating | OS | Survival by Year | Outcomes Related to Progression | LR/Local Tumor Progression | LOS | QOL | AE
Chen et al. 2011^54^ 66 Fair | ● | ● | NR | ● | ●^*^ | NR | ●
Itoh et al. 2011^55^ 60 Good | ● | ● | ● | ● | NR | NR | NR
Shen et al. 2005^57^ 16 Poor | ● | ● | NR | ● | NR | NR | ●
Singh et al. 2011^60^ 1 Poor | NR | NR | NR | NR | NR | NR | ●
Tanaka et al. 2009^58^ 20 Poor | ● | ● | ● | ● | NR | NR | ●
Zhou et al. 2009^59^ 42 Fair | ● | ● | NR | NR | NR | NR | ●

* LOS reported for unresectable HCC group only (not reported for recurrent unresectable HCC group).

“●” Indicates that this outcome was reported in the article.

Abbreviations: AE = adverse events; HCC = hepatocellular carcinoma; LOS = length of stay; LR = local recurrence; N = number of patients; NR = not reported; OS = overall survival; QOL = quality of life.

### RFA Compared With PEI/PAI

Three RCTs compared the ablative treatments RFA and PEI/PAI.50-52 Brunello et al.50 compared RFA and PEI. Lin et al. compared RFA, conventional PEI, and higher-dose PEI in one study51 and RFA, PEI, and PAI in another study.52 Quantitative pooling (meta-analysis) of these results was conducted for the outcome of overall survival at 3 years. As described earlier, PEI and PAI are the same intervention with different drug regimens. Since comparison across regimen is outside the scope of the review, PEI and PAI were treated as one intervention.

No nonrandomized comparative studies examined this comparison. In addition to the comparative evidence, three case series of RFA56-58 and one case report 60 are included in this report. There are no observational studies on PEI/PAI that met inclusion criteria.

Tables 23–27 give information on RFA compared with PEI/PAI.

Table 23 Strength of evidence for studies comparing RFA to PEI/PAI

Outcome | No of Studies Type of Study | Risk of Bias | Consistency | Directness | Precision | Overall Grade
Overall Survival | 3; Brunello et al. 2008^50^ RCT; Lin et al. 2004^51^ RCT; Lin et al. 2005^52^ RCT | Low | Inconsistent | Direct | Precise | Moderate
Quality of Life | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Time to Progression | 2; Lin et al. 2004^51^ RCT; Lin et al. 2005^52^ RCT | High | Consistent | Indirect | Precise | Low
Local Recurrence | 2; Lin et al. 2004^51^ RCT; Lin et al. 2005^52^ RCT | High | Consistent | Indirect | Precise | Low
Length of Stay | 2;Lin et al. 2004^51^ RCT; Lin et al. 2005^52^ RCT | High | Consistent | Indirect | Precise | Low
Days of Work Missed | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Gastric bleeding | 1 Lin et al. 2005^52^ RCT | Low | Unknown | Direct | Imprecise | Insufficient
Hemoperitoneum | 1 Brunello et al. 2008^50^ RCT | Low | Unknown | Direct | Imprecise | Insufficient
Hemothorax | 2 Brunello et al. 2008^50^ RCT; Lin et al. 2005^52^ RCT | Low | Unknown | Direct | Imprecise | Insufficient
Thrombosis | 1 Brunello et al. 2008^50^ RCT | Low | Unknown | Direct | Imprecise | Insufficient

Abbreviation: RCT = randomized controlled trial.

Table 24 Survival outcomes: RFA compared with PEI or PAI

Study Rating Design | Treatment Group N | Intervention | Survival Time From | Median OS | % Survival Year 1 | % Survival Year 2 | % Survival Year 3 | Statistical Comparison
Brunello et al. 2008^50^ Good RCT | RFA 70 | RFA under US guidance with either cool tip or multitined electrodes for 12 min or 15–25 min, respectively | Study Treatment | 40^*^ | NR | NR | 58.9 | NS, Adjusted hazard ratio=0.88, 95% CI, 0.50 to1.53
Brunello et al. 2008^50^ Good RCT | PEI 69 | PEI with sterile ethanol (95%, 2–20 mL) injected into each lesions with a single needle (1–4 sessions) | Study Treatment | 37^*^ | NR | NR | 56.7 | NS, Adjusted hazard ratio=0.88, 95% CI, 0.50 to1.53
Lin et al. 2004^51^ Fair RCT | RFA 52 | Percutaneous RFA with 15-gauge electrode under US guidance repeated 2 weeks later for up to 2 courses per tumor | Study Treatment | Not reached^*^ | 90 | 82 | 74 | -
Lin et al. 2004^51^ Fair RCT | PEI-conventional 52 | PEI with 99.5% ethanol (volume per session mean: 4.5 mL, SD: 1.6mL, range: 2–10 mL) using a single transhepatic cholangiography needle twice weekly for up to 6 sessions per tumor per course and 12 sessions of the maximal treatment per tumor | Study Treatment | 36^†^ | 85 | 61 | 50 | RFA vs. conventional PEI: risk ratio=0.34, 95% CI, 0.11 to 0.79, p=0.014
Lin et al. 2004^51^ Fair RCT | PEI-higher dose 53 | PEI with 99.5% ethanol (volume per session mean: 8.5 mL, SD: 2.8 mL, range: 6–18 mL) using two transhepatic cholangiography needles and a third needle if needed twice weekly for up to 3 sessions per tumor per course and 6 sessions of the maximal treatment per tumor | Study Treatment | 41^*^ | 88 | 63 | 55 | RFA vs. higher-dose PEI: risk ratio, 0.39, 95% CI, 0.21 to 0.85, p=0.023
Lin et al. 2005^52^ Fair RCT | RFA 62 | Percutaneous RFTA with 15-gauge electrode under US guidance repeated 2 weeks later for up to 2 courses per tumor | Not reported | Not reached^*^ | 93 | 81 | 74 | -
Lin et al. 2005^52^ Fair RCT | PEI 62 | PEI with 99.5% ethanol (volume per session mean: 4.8 mL, SD: 1.4 mL, range: 2–10.4 mL) twice weekly for up to 6 sessions per tumor per course and 12 sessions of the maximal treatment per tumor | Not reported | 32^*^ | 88 | 66 | 51 | RFA vs. PEI: risk ratio=0.42, 95% CI, 0.21 to 0.98, p=0.031
Lin et al. 2005^52^ Fair RCT | PAI 63 | PAI with 50% acetic acid (volume per session mean: 2.2 mL, SD: 1.1 mL, range: 1–3.5 mL) twice weekly for up to 6 sessions per tumor per course and 12 sessions of the maximal treatment per tumor | Not reported | 37^*^ | 90 | 67 | 53 | RFA vs. PAI: risk ratio=0.45, 95% CI, 0.06 to 0.58, p=0.038

* Extrapolated from Kaplan-Meier graphs.

Abbreviations: CI = confidence interval; N = number of patients; NS = nonsignificant; NR = not reported; OS = overall survival; PAI = percutaneous acetic acid injection; PEI = percutaneous ethanol injection; RCT = randomized controlled trial; RFA = radiofrequency ablation; RFTA = radiofrequency thermal ablation; SD = standard deviation; US = ultrasound.

Table 25 Survival outcomes: RFA compared with PEI/PAI, case series studies

Study Rating | Group N | Intervention | Survival Time From | Median OS (95% CI) | % Survival Year 1 | % Survival Year 2 | % Survival Year 3 | % Survival Year 4 | % Survival Year 5
Minami et al. 2007^56^ Poor | RFA 30 | Open RFA with cooled-tip needle guided by intraoperative sonography | Study Treatment | Not yet reached | NR | NR | NR | NR | NR
Shen et al. 2005^57^ Poor | RFA 16 | Percutaneous RFA with retractable curved electrodes (90W peak power) under US guidance | Study Treatment | 16^*^ | 52.2 | NR | 20.4 | NR | NR
Singh et al. 2011 Poor | RFA 1 | RFA under US-guidance using cool-tip RFA probe | NR | NR | NR | NR | NR | NR | NR
Tanaka et al. 2009^58^ Poor | RFA 20 | Open RFA via laparotomy (17) or thoracotomy (3) | Study Treatment | Not yet reached | 100 | 90^†^ | 90^†^ | NR | NR

* Extrapolated from Kaplan-Meier graphs.

Abbreviations: CI = confidence interval; N = number of patients; NR = not reported; OS = overall survival; RFA = radiofrequency ablation; US = ultrasound.

Table 26 Adverse events associated with local hepatic therapies: RFA compared with PEI/PAI

Study Rating Design | Treatment Group N | Intervention | Liver Failure % | Hepatic Hemorrhage % | Hepatic Abscess % | Rare AE, N (%)
Brunello et al. 2008^50^ Good RCT | RFA 70 | RFA under US guidance with either cool tip or multitined electrodes for 12 min or 15–25 min, respectively | NR | NR | NR | 1 (1.4) hemoperitoneum and 1 (1.4) hemothorax that needed urgent thoracotomy
Brunello et al. 2008^50^ Good RCT | PEI 69 | PEI with sterile ethanol (95%, 2–20 mL) injected into each lesions with a single needle (1–4 sessions) | NR | NR | NR | 1 (1.4) hemoperitoneum and 1 (1.4) death from thrombosis and possible bowel infarction 10 days after PEI
Lin et al. 2004^51^ Fair RCT | RFA^*^ 52 | Percutaneous RFA with 15-gauge electrode under US guidance repeated 2 weeks later for up to 2 courses per tumor | NR | NR | NR | NR
Lin et al. 2004^51^ Fair RCT | PEI-conventional^*^ 52 | PEI with 99.5% ethanol (volume per session mean: 4.5 mL, SD: 1.6 mL, range: 2–10 mL) using a single transhepatic cholangiography needle twice weekly for up to 6 sessions per tumor per course and 12 sessions of the maximal treatment per tumor | NR | NR | NR | NR
Lin et al. 2004^51^ Fair RCT | PEI-higher dose^*^ 53 | PEI with 99.5% ethanol (volume per session mean: 8.5 mL, SD: 2.8 mL, range: 6–18 mL) using two transhepatic cholangiography needles and a third needle if needed twice weekly for up to 3 sessions per tumor per course and 6 sessions of the maximal treatment per tumor | NR | NR | NR | NR
Lin et al. 2005^52^ Fair RCT | RFA 62 | Percutaneous RFTA with 15-gauge electrode under US guidance repeated 2 weeks later for up to 2 courses per tumor | NR | NR | NR | 2 (3.2) had hemothorax requiring chest tube drainage and 1 (1.6) had gastric bleeding and perforation and underwent gastric repair during operation.
Lin et al. 2005^52^ Fair RCT | PEI^*^ 62 | PEI with 99.5% ethanol (volume per session mean: 4.8 mL, SD: 1.4 mL, range: 2–10.4 mL) twice weekly for up to 6 sessions per tumor per course and 12 sessions of the maximal treatment per tumor | NR | NR | NR | NR
Lin et al. 2005^52^ Fair RCT | PAI^*^ 63 | PAI with 50% acetic acid (volume per session mean: 2.2 mL, SD: 1.1 mL, range: 1–3.5 mL) twice weekly for up to 6 sessions per tumor per course and 12 sessions of the maximal treatment per tumor | NR | NR | NR | NR

* No grade 3 or 4 adverse events of interest were observed for these treatment groups.

Abbreviations: AE = adverse event; N = number of patients; NR = not reported; PAI = percutaneous acetic acid injection; PEI = percutaneous ethanol injection; RCT = randomized controlled trial; RFA = radiofrequency ablation; RFTA = radiofrequency thermal ablation; SD = standard deviation; US = ultrasound.

Table 27 Adverse events associated with local hepatic therapies: RFA compared with PEI/PAI, case series studies

Study Rating | Group N | Liver Failure % | Hepatic Hemorrhage % | Hepatic Abscess % | Rare AE, N (%)
Minami et al. 2007^56^ Poor | RFA 30 | NR | NR | 0 | 1 operative death due to GI bleeding after surgery.
Shen et al. 2005^57^ Poor | RFA 16 | 0 | NR | NR | The only complication was 1 (6.3%) case of right pleural effusion.
Singh et al 2011^60^ Poor | RFA 1 | NR | NR | NR | Iatrogenic diaphragmatic hernia following RFA treated by urgent laparoscopic repair. There were no postoperative complications and the patient was discharged 6 days after the procedure.
Tanaka et al. 2009^58^ Poor | RFA^*^ 20 | NR | NR | NR | NR

* No grade 3 or 4 adverse events of interest were observed for these treatment groups.

Abbreviations: AE = adverse events; GI = gastrointestinal; N = number of patients; NR = not reported; RFA = radiofrequency ablation.

#### Overall Survival

Outcomes related to overall survival are summarized in Table 24.

In comparing RFA and PEI by intent-to-treat analysis, Brunello et al.50 reported a 3-year overall survival from the time of study treatment of 58.9 percent and 56.7 percent, respectively. No significant difference was observed between groups (adjusted hazard ratio=0.88; 95% CI, 0.50 to 1.53). In a study by Lin et al.,51 the 3-year overall survival rates were 74 percent, 50 percent, and 55 percent in the RFA, conventional PEI, and higher-dose PEI groups, respectively. The RFA group had a significantly higher overall survival rate from the time of study treatment compared with the two PEI groups (RFA vs. conventional PEI: risk ratio=0.34; 95% CI, 0.11 to 0.79, p=0.014; RFA vs. higher-dose PEI: risk ratio, 0.39; 95% CI, 0.21 to 0.85, p=0.023). Another study by the same investigators,52 the 3-year overall survival rates were 74 percent, 51 percent, and 53 percent in the RFA, PEI, and PAI groups, respectively. The RFA group achieved a significantly higher overall survival than PEI and PAI groups (RFA vs. PEI: RR=0.42; 95% CI, 0.21 to 0.98, p=0.031; RFA vs. PAI: RR=0.45; 95% CI, 0.06 to 0.58, p=0.038).

These trials50-52 were pooled in a meta-analysis (Figure 3). Risk differences were calculated for the three studies. The pooled estimate was 0.16 (95% CI, 0.03 to 0.28), a statistically significant result that favored RFA and was consistent with the direction of effect reported by the individual trials. The degree of statistical heterogeneity in this pool of studies was moderate (I^2^=48 percent).

Figure 3 RFA compared with PEI/PAI: meta-analysis of three trials for the outcome of overall survival

Abbreviations: -C = Conventional; -HD = High-dose; CI: Confidence interval; IV = Independent variable; PAI = Percutaneous acetic acid injection; PEI = Percutaneous ethanol injection; RFA = Radiofrequency ablation.

Figure 3 depicts the results of a meta-analysis for the comparison of RFA with PEI/PAI. Three trials reported on the outcome of 3 year overall survival. A random effects model using inverse variance weighting was used. Risk differences are reported for individual trials and for the overall pooled effect. In the first trial, Brunello, 2008, there were 41 events in the RFA group and 39 in the PEI/PAI group. The risk difference was 0.02 favoring RFA with a 95 percent confidence interval of -0.14 to 0.18. The weight of this trial was 30.7 percent. In the second trial, Lin, 2004 there were 38 events in the RFA group and 55 in the PEI/PAI group. The risk difference was 0.21 favoring RFA with a 95 percent confidence interval of -0.05 to 0.36. The weight of this trial was 33 percent. In the third trial, Lin, 2005, there were 46 events in the RFA group and 65 events in the PEI/PAI group. The mean difference was 0.22 favoring RFA with a 95 percent confidence interval of 0.08 to 0.36. The weight of this trial was 36.3 percent. The figure shows a forest plot of these results. The x-axis spans minus 1 at the left favoring PEI/PAI to positive 1 at the right favoring RFA. There is a vertical line at zero that that extends up from the x-axis. The risk difference for each trial is represented by a blue box sized according to the weight of the trial. The confidence interval is represented by a horizontal black line centered on the box. The overall pooled result is represented by a black diamond, the ends of which represent the confidence interval for the pooled result. The blue boxes for all trials and the black diamond fall to the right of the vertical line. Tests for heterogeneity are Tau squared of 0.01, chi squared of 3.88 with 2 degrees of freedom and a p-value of 0.14, and I squared of fourty-eight percent. The Z test for overall effect was 2.48 with a p-value equal to 0.01.

Three case-series56-58 reported overall survival after treatment with RFA and are summarized in Table 25. The 3-year survival following RFA was 20.4 percent and 90 percent in the studies by Shen et al.57 and Tanaka et al.,58 respectively. Minami et al.56did not report 3-year survival. Lack of a direct comparison in these studies limits the application of these data to inform conclusions on overall survival. There were no case series on PEI/PAI included in this report.

##### Strength of Evidence

There is moderate strength of evidence that overall survival is better for RFA compared with PEI/PAI for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease. The three trials50-52 all lacked blinding and were rated good50 or fair.51,52 While the lack of blinding is particularly worrisome, it does not affect the measurement of overall survival. Therefore, the risk of bias for the assessment of overall survival was graded as low. Overall survival is a direct health outcome and the meta-analysis produced a precise estimate. The direction of effect was consistent across the three studies, but there was a very large range of effect (.02 to .22). Combined with the moderate heterogeneity (I^2^=48 percent), we considered these results inconsistent. Based on this inconsistency, the strength of evidence was graded as moderate.

#### Quality of Life

Quality of life was not reported in any of the included studies.

##### Strength of Evidence

No studies addressed this outcome. Therefore, the strength of evidence to evaluate quality of life for RFA compared with PEI/PAI for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation with no evidence of extrahepatic disease was judged to be insufficient due to the lack of evidence.

#### Outcomes Related to Progression

In a 2004 study, Lin et al.51 reported cancer-free survival, defined as the time from study treatment to local tumor progression, extrahepatic metastasis, additional new HCC recurrence, or death. Followup occurred every 2 months and included a computed tomography (CT) scan. The 3-year cancer-free survival rate was 37 percent, 17 percent, and 20 percent in the RFA, conventional PEI, and higher-dose PEI groups, respectively. The RFA group had a significantly higher rate than in the two PEI groups (RF vs. conventional PEI: risk ratio=0.38; 95% CI, 0.14 to 0.88, p=0.019; RF vs. higher-dose PEI: risk ratio=0.41; 95% CI, 0.22 to 0.89, p=0.024). In another study by the same investigators,52 the 3-year cancer-free survival rate was 43 percent, 21 percent, and 23 percent in the RFA, PEI, and PAI groups, respectively. Similar to the previous study, the RFA group achieved a significantly higher cancer-free survival than the PEI group (risk ratio=0.31; 95% CI, 0.18 to 0.85, p=0.038) and the PAI group (risk ratio=0.26, 95% CI, 0.13 to 0.81, p=0.041).

One case series56 reported a 2-year disease-free survival rate of 39 percent following open RFA. In another study of open RFA by Tanaka et al.,58 the median disease-free survival was not reached.

##### Strength of Evidence

There is a low strength of evidence to evaluate TTP for RFA compared with PEI/PAI for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease. Both trials51,52 lacked blinding and were rated as fair quality studies. Lack of blinding can lead to detection bias. This is particularly true when outcomes are based on interpretation. (i.e., not a hard outcome, like death) Therefore, the risk of bias for the assessment of outcomes related to progression was graded as high. In addition, the results of the two trials were consistent, and progression outcomes are indirect health outcomes. The estimates were precise.

#### Local Recurrence/Local Tumor Progression

In a 2004 study, Lin et al.51 reported local tumor progression, defined as the presence of an enhanced tumor on CT, corresponding to the initial target tumor. The cumulative local tumor progression rate at the end of 3 years was 18 percent, 45 percent, and 33 percent in the RFA, conventional PEI, and higher dose PEI groups, respectively. The RFA group had a significantly lower rate than in the PEI groups (RFA vs. conventional PEI: risk ratio=0.37; 95% CI, 0.12 to 0.76, p=0.012; RFA vs. higher-dose PEI: risk ratio=0.49; 95% CI, 0.23 to 0.92, p=0.037). In another study by the same investigators,52 the cumulative local recurrence rate at the end of 3 years was 14 percent, 34 percent, and 31 percent in the RFA, PEI, and PAI groups, respectively. The local recurrence rate was significantly lower in the RFA group compared with the PEI (risk ratio=0.35; 95% CI, 0.21 to 0.89, p=0.012) and PAI (risk ratio=0.41; 95% CI, 0.23 to 0.91, p=0.017) groups. In the latter study, the authors assessed local recurrence only among the subset of patients achieving complete tumor necrosis following treatment, whereas they assessed it in all randomized patients in the former study.

Local recurrence was reported in two case series on RFA.57,58 In a study by Tanaka et al.,58 local recurrence (recurrence within the liver) was observed in one of 20 patients (5 percent) following open RFA. Shen et al.57 reported local recurrence (tumor recurrence within or at the periphery of the ablated lesion in the subsequent CT scans after complete ablation) in 5 (31.3 percent) patients following percutaneous RFA.

##### Strength of Evidence

There is a low strength of evidence to evaluate local recurrence for RFA compared with PEI/PAI for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease. Both trials51,52 lacked blinding and were rated as fair quality studies. Lack of blinding can lead to detection bias. This is particularly true when outcomes are based on interpretation, (i.e., not a hard outcome like death), which local recurrence is. Therefore, the risk of bias for the assessment of local recurrence was graded as high. In addition, the results of the two trials were consistent. Local recurrence is an indirect health outcome, and the comparison in Lin 2004^51^ was direct. Finally, the estimates are precise.

#### Length of Stay

In a 2004 study by Lin et al.,51 LOS was reported among the subset of those patients that achieved complete tumor necrosis (50 out of 52, 46 out of 52, and 50 out of 53 in RFA, conventional PEI, and higher dose PEI groups, respectively). The RFA group had a significantly longer mean LOS than in the conventional PEI group (4.4 days ± 1.8 vs. 1.6 days ± 0.3, p<0.01). Similarly, in another study by the same investigators,52 the RFA group had a significantly longer LOS than either the PEI group or the PAI group (4.2 days ± 1.9, 1.7 days ± 0.4, 2.2 days ± 0.6, respectively, all p<0.01). Likewise, the LOS data were assessed only for the subset of those patients achieving complete tumor necrosis.

None of the single-arm studies of RFA reported LOS.

##### Strength of Evidence

There is a low strength of evidence to evaluate LOS for RFA compared with PEI/PAI for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease. Both trials51,52 lacked blinding and were rated as fair quality studies. Lack of blinding can lead to detection bias. This is particularly true when outcomes are based on interpretation (i.e., not a hard outcome like death). LOS may be determined by the physician and is subject to bias based on knowledge of the treatment received. In addition, both studies assessed LOS for only a subset of patients. Therefore, the risk of bias for the assessment of LOS was graded as high. In addition, the results of the two trials were consistent. Finally, the estimates are precise.

#### Days of Missed Work

Days of missed work was not reported in any of the included studies.

##### Strength of Evidence

No studies addressed this outcome. Due to the lack of data for this outcome, the strength of evidence to evaluate days of work missed for RFA compared with PEI/PAI for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Adverse Events

None of the 3 RCTs comparing RFA and PEI/PAI reported the following AEs: hepatic abscess, hepatic hemorrhage, biloma, steatohepatitis, injury to adjacent organs, liver failure, and infection.

Table 26 presents a summary of AEs reported in the 3 RCTs comparing RFA and PEI/PAI. Lin et al.51 observed transient increases transaminases in most patients regardless of treatment but no occurrences of sustained levels of clinical concern.

Of the single-arm studies of RFA Shen et al.57 reported one (6.3 percent) case of right pleural effusion after treatment. One case report60 reported a rare AE of iatrogenic diaphragmatic hernia following RFA treated by urgent laparoscopic repair. No other adverse events of interest were reported in the single-arm studies (Table 27).57

##### Strength of Evidence

The three RCTs50-52 reported very limited adverse events. The adverse event of elevated transaminases reported in the RCT is not subject to interpretation (i.e., objective outcome based on liver function test results); therefore, the risk of bias for the assessment of adverse events was rated as low. The consistency is unknown, and adverse events are direct health outcomes, but the estimates are imprecise. Due to the limited amount of data, the strength of evidence is insufficient to evaluate adverse events for RFA compared with PEI/PAI for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation with no evidence of extrahepatic disease (Table 23).

#### Overall GRADE for RFA Compared With PEI/PAI

The strength of evidence ratings for studies comparing RFA to PEI/PAI are displayed in Table 23.

### RFA Compared With TACE

No RCT examined this comparison. One retrospective cohort study by Chok et al.53 compared ablative treatment with RFA to TACE. Patients included in this study were all eligible to receive ablative therapy.

Tables 28-30 give information on RFA compared with TACE.

Table 28 Strength of evidence for studies comparing RFA to TACE

Outcome | No. of Studies Type of Study | Risk of Bias | Consistency | Directness | Precision | Overall Grade
Overall Survival | 1; Chok et al. 2006^53^ Retrospective cohort | High | Unknown | Direct | Imprecise | Insufficient
Quality of Life | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Time to Progression | 1; Chok et al. 2006^53^ Retrospective cohort | High | Unknown | Indirect | Imprecise | Insufficient
Local Control | 1; Chok et al. 2006^53^ Retrospective cohort | High | Unknown | Indirect | Imprecise | Insufficient
Length of Stay | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Days of Work Missed | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Adverse Events | 1; Chok et al. 2006^53^ Retrospective cohort | High | Unknown | Direct | Imprecise | Insufficient

Table 29 Survival outcomes: RFA compared with TACE

Study Rating Design | Treatment Group N | Intervention | Survival Time From | Median OS (95% CI) | % Survival Year 1 | % Survival Year 2 | % Survival Year 3 | % Survival Year 4 | % Survival Year 5 | Statistical Comparison
Chok et al. 2006^53^ Poor Retrospective cohort | RFA 51 | Percutaneous (45%), laparoscopic (2%) or open (53%) RFA with cool-tip electrodes | Study Treatment | Not yet reached | 82 | 72 | NR | NR | NR | 2 year survival: NS, p=0.21
Chok et al. 2006^53^ Poor Retrospective cohort | TACE 40 | TACE with cisplatin (1 mg/mL), lipiodol (volume ration 1:1), gelatin sponge mixed with gentamicin sulfate (40 mg) via superselective arteries repeated 8 to 12 weeks | Study Treatment | 25^*^ | 80 | 58 | NR | NR | NR | 2 year survival: NS, p=0.21

* Extrapolated from Kaplan-Meier graphs.

Abbreviations: CI = confidence interval; N = number of patients; NR = not reported; NS = nonsignificant; OS = overall survival; RFA = radiofrequency ablation; TACE = transarterial chemoembolization.

Table 30 Adverse events associated with local hepatic therapies: RFA compared with TACE

Study Rating Design | Treatment Group N | Intervention | Liver Failure % | Hepatic Hemorrhage % | Hepatic Abscess % | Rare AE, N (%)
Chok et al. 2006^53^ Poor Retrospective cohort | RFA 51 | Percutaneous (45%), laparoscopic (2%) or open (53%) RFA with cool-tip electrodes | NR | NR | 0 | 1 operative death due to GI bleeding after surgery.
Chok et al. 2006^53^ Poor Retrospective cohort | TACE 40 | TACE with cisplatin (1 mg/mL), lipiodol (volume ratio 1:1), gelatin sponge mixed with gentamicin sulfate (40 mg) via superselective arteries repeated 8 to 12 weeks | NR | NR | NR | 1 case (1%) of bowel perforation (grade 5), 2 cases (1%) of severe sepsis without leucopenia (grade 5)

Abbreviations: AE = adverse event; GI = gastrointestinal; N = number of patients; NR = not reported; RFA = radiofrequency ablation; TACE = transarterial chemoembolization.

#### Overall Survival

Outcomes related to overall survival are summarized in Table 29. Two-year survival for RFA compared with TACE was 72 percent and 58 percent, respectively, which was not found to be statistically different (p=0.21) when analyzed with Cox proportional hazards model.

##### Strength of Evidence

The strength of evidence to evaluate overall survival for RFA compared to TACE for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation with no evidence of extrahepatic disease is rated insufficient. Evidence to evaluate this outcome comes from one poor quality study. Chok et al.53 is a retrospective cohort study which began with a low strength of evidence due to the nature of the study design (e.g., lack of blinding and no randomization) and was further reduced to insufficient SOE due to a high risk of bias. For an observational study to overcome the limitations of a non-randomized design adequate control of confounders must be considered in the analysis. The authors did not attempt to adjust for confounders in their analysis. Therefore, the risk of bias for the assessment of overall survival was graded as high. There is unknown consistency as there is only one trial, overall survival is a direct health outcome, and the estimate is imprecise.

#### Quality of Life

Quality of life was not reported in any of the included studies.

##### Strength of Evidence

No studies addressed this outcome. Due to the lack of data for this outcome, the strength of evidence to evaluate quality of life for RFA compared with TACE for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Outcomes Related to Progression

In the study by Chok et al.,53 time to disease progression was calculated from the date of disease response to treatment to the date of disease progression. Disease progression occurred in 35 patients (88 percent) in the TACE group and 36 patients (71 percent) in the RFA group. The median time to disease progression was 9.5 months (range: 1.0 to 47.3 months) in patients treated with TACE and 10.4 months (range: 1.0 to 42.7 months) in patients treated with RFA (p=0.95).

##### Strength of Evidence

The strength of evidence to evaluate outcomes related to progression for RFA compared to TACE for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation with no evidence of extrahepatic disease is rated insufficient. Evidence to evaluate this outcome comes from one poor quality study. Chok et al.53 is a retrospective cohort study which began with a low strength of evidence due to the nature of the study design (e.g., lack of blinding and no randomization) and was further reduced to insufficient SOE due to a serious risk of bias. For an observational study to overcome the limitations of a non-randomized design adequate control of confounders must be considered in the analysis. The authors did not attempt to adjust for confounders in their analysis. Lack of blinding can lead to detection bias. Even though blinding would be difficult, not doing so remains a major threat to validity. This is particularly true when outcomes are based on interpretation (i.e., not a hard outcome like death). Therefore, the risk of bias for the assessment of outcomes related to progression was graded as high. In addition, with only one study, consistency is unknown, progression is an indirect measure of a health outcome, and the estimates are imprecise.

#### Local Recurrence/Local Tumor Progression

In the study by Chok et al.,53 during a median followup period of 19 months, the local recurrence rate was 14 percent (n=7) in the RFA group. The authors did not report local recurrence rate in the TACE group.

##### Strength of Evidence

The strength of evidence to local recurrence or local tumor progression for RFA compared to TACE for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation with no evidence of extrahepatic disease is rated insufficient. Evidence to evaluate this outcome comes from one poor quality study. Chok et al.53 is a retrospective cohort study which began with a low strength of evidence due to the nature of the study design (e.g., lack of blinding and no randomization) and was further reduced to insufficient SOE due to a serious risk of bias. For an observational study to overcome the limitations of a non-randomized design adequate control of confounders must be considered in the analysis. The authors did not attempt to adjust for confounders in their analysis. This is particularly true when outcomes are based on interpretation (i.e., not a hard outcome like death). Therefore, the risk of bias for the assessment of outcomes related to local recurrence as high. In addition, with only one study, consistency is unknown, progression is an indirect measure of a health outcome, and the estimates are imprecise.

#### Length of Stay

LOS was not a reported outcome in the study by Chok et al.53

##### Strength of Evidence

No studies addressed this outcome. Due to the lack of data for this outcome, the strength of evidence to evaluate LOS for RFA compared with TACE for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Days of Missed Work

Days of missed work was not reported in any of the included studies.

##### Strength of Evidence

No studies addressed this outcome. Due to the lack of data for this outcome, the strength of evidence to evaluate days of work missed for RFA compared with TACE for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient (Table 28).

#### Adverse Events

Table 30 presents a summary of AEs reported in the study comparing RFA to TACE. In the study by Chok et al.,53 liver failure was observed in 1 (2 percent) and 2 (5 percent) patients in the RFA and TACE groups, respectively. The study did not report on the following AEs: hepatic abscess, hepatic hemorrhage, biloma, steatohepatitis, injury to adjacent organs, infection, increased liver enzymes (transaminases, bilirubin, alkaline phosphatase), and rare adverse events.

##### Strength of Evidence

The strength of evidence to evaluate adverse events for RFA compared with TACE is rated as insufficient because only a single poor quality study assessed this outcome. The lack of blinding affected the risk of bias in the assessment of adverse events. The majority of adverse events of interest, such as hepatic hemorrhage, leave little room for interpretation, but other adverse events, such as liver failure, involve some interpretation; therefore, the risk of bias for the assessment of adverse events was rated as high. The consistency is unknown, adverse events are direct health outcomes, but the estimates are imprecise.

#### Overall GRADE for RFA Compared With TACE

The strength of evidence ratings for studies comparing RFA to TACE are displayed in Table 28.

### Interventions With No Comparative Evidence

Three case series were included in this report for which no comparative evidence exists. Two focused on cryotherapy and one on microwave ablation.54,55,59

#### Strength of Evidence

No comparative studies met inclusion criteria for this review. Therefore strength of evidence is insufficient to evaluate all outcomes of interest: overall survival, quality of life, TTP, local recurrence, LOS, days of work missed, and adverse events for all interventions without comparative studies for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease.

#### Overall Survival

A case series study by Chen et al.54 on cryoablation reported a 1-year survival of 81.4 percent in the nonrecurrent HCC group and 70.2 percent in the recurrent HCC group. Zhou et al.59 reported a 1-year survival of 61.9 percent following cryoablation. One study of MWA reported a 3-year survival of approximately 54 percent.55 Survival outcomes for the combination treatments are summarized in Table 31. Lack of a direct comparison in these studies limits the application of these data to inform conclusions on overall survival.

Table 31 Outcomes related to overall survival, studies with no comparative data

Study Rating | Group N | Intervention | Survival Time From | Median OS (95% CI) | % Survival Year 1 | % Survival Year 2 | % Survival Year 3 | % Survival Year 4 | % Survival Year 5
Chen et al. 2011^54^ Fair | Cryoablation 40 | US-guided percutaneous cryotherapy | Study Treatment | Not yet reached | 81.4 | NR | 60.3 | NR | NR
Chen et al. 2011^54^ Fair | Cryotherapy, Recurrent HCC 26 | US-guided percutaneous cryotherapy | Study Treatment | 24^*^ | 70.2 | NR | 28.8 | NR | NR
Itoh et al. 2011^55^ Good | MWA 60 | Surgical microwave therapy administered for 60 s at a power setting of 65 W per pulse using a microwave electrode 1.6 mm in diameter and 25 cm in length | Study Treatment | 42^*^ | 93.9 | NR | 53.8 | NR | 43.1
Zhou et al. 2009^59^ Fair | Cryoablation 42 | Surgical cryoablation with argon (drop to -140C for 15-20 min) and helium (raise to 20-40C for 3-5 min) for 2-3 freezing-thawing cycles | Study Treatment | 17.4^*^ | 61.9 | 22.9 | 5.7 | NR | NR

* Extrapolated from Kaplan-Meier graphs.

Abbreviations: CI = confidence interval; CP = Child-Pugh liver cirrhosis class; MWA = microwave ablation; N = number of patients; NS = nonsignificant; NR = not reported; OS = overall survival; US = ultrasound.

#### Quality of Life

Quality of life was not reported in any of the included studies.

#### Outcomes Related to Progression

Itoh et al. reported a median progression-free survival of approximately 12 months in patients treated with MWA.55

#### Local Recurrence/Local Tumor Progression

One cryoablation study,54 local tumor progression (recurrence of the treated tumor) was observed in 12 (30 percent) of the unresectable HCC patients and 6 (23 percent) of the recurrent HCC patients. In the study by Itoh et al., local recurrence was observed in 11.7% of the patients treated with MWA.55

#### Length of Stay

LOS was not reported in any of the included studies.

#### Days of Missed Work

Days of missed work was not reported in any of the included studies.

#### Adverse Events

For the studies lacking comparative data, no liver failure or hepatic abscess was reported. An incidence of hepatic hemorrhage of 3.8 percent was reported by Chen et al. in the recurrent HCC arm.54 Other rare adverse events are listed in Table 32, including fatal and nonfatal events.

Table 32 Adverse events associated with local hepatic therapies: studies with no comparative data

Study Rating | Group N | Liver Failure % | Hepatic Hemorrhage % | Hepatic Abscess % | Rare AE, N (%)
Chen et al. 2011^54^ Fair | Cryoablation 40 | 0 | 0 | NR | Infection, 1 (2.5%)
Chen et al. 2011^54^ Fair | Cryotherapy, Recurrent HCC 26 | 0 | 3.8 | NR | Post-operative hemorrhage, 1 (3.8%); Infection, 1 (3.8%)
Zhou et al. 2009^59^ Fair | Cryoablation 42 | NR | NR | 0 | Abdominal Infection, 2 (4.8%); Wound Infection, 2 (4.8%)
Itoh et al. 2011^55^ Good | MWA 60 | NR | NR | NR | NR

* No grade 3 or 4 adverse events of interest were observed for these treatment groups.

Abbreviations: AE = adverse event; CP = Child-Pugh liver cirrhosis class; MWA = microwave ablation; N = number of patients.

## Embolization Therapies

### Description of Included Studies

A total of 26 studies met the inclusion criteria to address KQ1 and KQ2, including two RCTs,61,62 two nonrandomized comparative studies,31,63 20 case series studies,49,64-82 and two case reports.83,84 Two nonrandomized comparative studies were included, one retrospective63 and one prospective.31 Of the 19 case series studies,10 were retrospective65,68-70,72,74,76,79-81 and eight were prospective.64,66,67,71,73,77,78,82 The prospective or retrospective nature of one study could not be determined.49 One RCT was abstracted as a case-series because the comparator was not of interest for this report.75 The total number of patients for whom data were extracted from the 26 studies was 2,461. There were 151 patients from RCTs, 165 from nonrandomized comparative studies, 2,142 from case series, and three from case reports. All studies had patient samples that were restricted to unresectable HCC patients (i.e., not including patients with liver tumors of other primary origins). All studies initiated treatment in patients after January 1, 2000.

One RCT compared DEB to TACE,62 and another compared DEB to TAE.61

Table 33 and Table 34 present a summary of study and patient characteristics from the RCTs, including the number of patients enrolled, intervention period, intervention, and baseline characteristics. Patients ranged in mean age from 68.7 to 71.3 years. The patients' baseline Child-Pugh liver cirrhosis classes were A or B, and there were no patients in class C cirrhosis. ECOG scores were 0 to 1 in all studies. One study reported BCLC HCC stage A (early) or B (intermediate) of the enrolled patients.62 No RCTs reported prior treatment history or presence of PVT. One study reported that 100 percent of the patients were cirrhotic.61 One RCT reported the proportion of patients with HBV and HCV infection.62

Table 33 Summary of embolization treatment study characteristics: RCTs

Study N Rating | Intervention | Intervention Period | Mean Age (Range) | CP A%; B% | BCLC A%; B% | Previous LDT %
Malagari et al. 2010^61^ 84 Poor | Transarterial DEB with DC beads^®^ loaded with doxorubicin (37.5 mg/mL of bead suspension) every 2 months with a maximum of 3 procedures | 2005 | 70.7 (NR) | A: 56.1; B: 43.9 | NR | NR
Malagari et al. 2010^61^ 84 Poor | Bland embolization with nonloaded particles of the same diameter and mechanics as DEB (BeadBlock) every 2 months with a maximum of 3 procedures | 2005 | 70.0 (NR) | A: 60.5; B: 39.5 | NR | NR
Sacco et al. 2011^62^ 67 Fair | TACE with iodized oil (mean: 16.6 mL, range: 10–25 mL), doxorubicin (mean: 57.0 mg, range: 50–75 mg) and gelatin sponge particles via hepatic arteries | 01/2006 - 03/2009 | 68.7 (NR) | A: 73.5; B: 26.5 | A: 64.7; B: 35.3 | NR
Sacco et al. 2011^62^ 67 Fair | DEB chemoembolization with DC Bead^®^ (2-4 mL, 100–300 μm) loaded with doxorubicin (50 mg/vial, mean: 55 mg, range: 25–150 mg) mixed with nonionic contrast medium at a 1:3 ratio via superselective injection | 01/2006 - 03/2009 | 71.3 (NR) | A: 87.9; B: 12.1 | A: 66.7; B: 33.3 | NR

Abbreviations: BCLC = Barcelona Clinic Liver Center hepatocellular carcinoma stage; CP = Child-Pugh liver cirrhosis class; DEB = drug-eluting bead; LDT = liver-directed therapy; N = number of patients; NR = not reported; TACE = transarterial chemoembolization.

Table 34 Summary of embolization treatment underlying liver disease characteristics: RCTs

Study Rating | Group N | Cirrhosis% | HBV% | HCV% | Alcohol%
Malagari et al. 2010^61^ Poor | DEB 41 | 100 | NR | NR | NR
Malagari et al. 2010^61^ Poor | TAE 43 | 100 | NR | NR | NR
Sacco et al. 2011^62^ Fair | TACE 34 | NR | 11.8 | 73.5 | NR
Sacco et al. 2011^62^ Fair | DEB 33 | NR | 12.1 | 66.7 | NR

Abbreviations: DEB = drug-eluting bead; HBV = hepatitis B virus; HCV = hepatitis C virus; N = number of patients; NR = not reported; TACE = transarterial chemoembolization; TAE = transarterial embolization.

As displayed in Table 35, the two RCTs varied in which tumor characteristics were reported and how these characteristics were reported. The proportion of patients with a bilobar disease was reported in one study and consisted of 17.6 percent in the TACE group and 24.2 percent in the DEB group.62 The mean number of lesions ranged from 1 (solitary tumor) to 1.5. Only one study reported the lesion size, which ranged from 1.0 cm to 13.0 cm.62 Malagari et al. reported the sum of tumor diameters, which had a mean value of 8.35 cm in the DEB group and 8.1 cm in the TAE group.61

Table 35 Summary of embolization treatment tumor characteristics: RCTs

Study Rating | Group N | Bilobar % | Number of Lesions | Lesion Size Range (cm) | Other Lesion Characteristics
Malagari et al. 2010^61^ Poor | DEB 41 | NR | 1: 29.2%, >1: 26.8%, | Sum of tumor diameters, mean (SD): 8.35 (2.75) | Multinodular: 43.9%
Malagari et al. 2010^61^ Poor | TAE 43 | NR | 1: 34.9%, >1: 32.6%; | Sum of tumor diameters, mean (SD): 8.1 (2.8) | Multinodular: 32.6%
Sacco et al. 2011^62^ Fair | TACE 34 | 17.6 | Mean:1.5 Range: 1–3 | Range: 1.3–8.8 | NR
Sacco et al. 2011^62^ Fair | DEB 33 | 24.2 | Mean:1.3 | Range: 1.0–13.0 | NR

Abbreviations: DEB = drug-eluting bead; N = number; NR = not reported; SD = standard deviation; TACE = transarterial chemoembolization; TAE = transarterial embolization.

Of the observational studies (two nonrandomized comparative studies, 20 case series studies, and two case reports), 16 studies included patients treated with TACE,49,64,65,68-70,72,73,75,76,78,80-82,84 four studies included patients treated with RE,66,67,71,74 one study included patients treated with TAE,79 and one study included patients treated with DEB.31,77 One article reported on either TACE or TAE but did not report outcomes separately for each procedure.49 Table 36 and Table 37 present a summary of study and patient characteristics from the nonrandomized comparative studies and case series, including number of patients enrolled, intervention period, intervention, and baseline characteristics. Median age ranged from 48 to 73 years. The patients' baseline Child-Pugh liver cirrhosis classes were largely A or B, with a very small minority (≤10 percent) in class C. Similarly, the ECOG scores were 0 to 1 in the vast majority of patients, with few scoring 2. Two studies reported BCLC HCC stage A (early) or B (intermediate) of the enrolled patients; in one study, most patients (88.1 percent) were in stage A and 0 in stage B.64 In one study, 100 percent of the patients were in stage B.82 Eight studies reported the HCC stage using the Okuda staging system, and the vast majority of the patients were in Okuda stage I or II, which are equivalent to BCLC stages A and B, respectively.31,66,74-77,79,81 Liu et al.74 included patients in Okuda stage III that exceeded 10 percent of the sample (36 percent); because the study reported Okuda stage II patients separately, we extracted data for this subset of patients only. Six studies reported the proportion of patients with PVT,63,66,67,70,72,81 which ranged from 0 to 28 percent. Eleven studies described patients' prior treatment history, including local hepatic therapies such as resection.70,74,78,80,81,83 Twelve studies reported on the proportion of patients with cirrhosis, ranging from 45 percent to 100 percent.49,66,67,69-71,74-77,79,81 Studies varied in terms of proportions of patients with HBV and HCV infection.49,64-67,69-72,74-82 Overall, studies were inconsistent in reporting—and often did not report— these patient and tumor characteristics at baseline (e.g., ECOG score, Child-Pugh class, PVT, HCC stage) which are important prognostic factors to consider when comparing patient populations across studies.

Table 36 Summary of embolization treatment study and patient characteristics: nonrandomized comparative studies

Study N Rating | Study Design | Intervention Period | Intervention | Age, Mean or Median (Range) | ECOG Score | CP A%; B%; C% | BCLC A%; B% | Previous LDT %
Recchia et al. 2012^31^ 105 Poor | Prospective case control | 01/2008 – 01/2010 | DEB with DC beads^®^ loaded with doxorubicin (50 mg/m^2^). For tumors >5 cm the size was between 500 and 700 μm, for tumors between 5 and 3 cm, the size was 300-500 μm, while for tumors <3 cm the size was 300 μm. | Median: 72 (53–80) | ≤1: 100 | A: 34; B: 66; C: 0 | NR | NR
Recchia et al. 2012^31^ 105 Poor | Prospective case control | 01/2008 – 01/2010 | TACE | Median: 70 (47–80) | ≤1: 100 | A: 40; B: 60; C: 0 | NR | NR
Yu et al. 2009^63^ 60 Poor | Retrospective case control | 03/2002 - 12/2002 | TEA with lipiodol-ethanol mixture (mean: 14.5 mL, SD: 17.6 mL) via tumor feeder vessel(s) for a median of 2 treatments | Mean: 64.4 (NR) | ≤1: 100; 2: 0 | A: 93.3; B: 6.7; C: 0 | NR | NR
Yu et al. 2009^63^ 60 Poor | Retrospective case control | 01/2005 - 12/2005 | TACE with lipiodol (20 mL) - cisplatin (10 mg) emulsion and gelatin sponge particle embolization via hepatic artery for a median of 3 treatments | Mean: 62.7 (NR) | ≤1:96.7; 2: 3.3 | A: 93.3; B: 6.7; C: 0 | NR | NR

Abbreviations: BCLC = Barcelona Clinic Liver Center hepatocellular carcinoma stage; CP = Child-Pugh liver cirrhosis class; DEB = drug-eluting bead; ECOG = Eastern Cooperative Oncology Group; LDT = liver-directed therapy; N = number of patients; NR = not reported; SD = standard deviation; TACE = transarterial chemoembolization; TEA = transarterial ethanol ablation.

Table 37 Summary of embolization treatment study and patient characteristics: case series studies

Study N Rating | Study Design | Intervention Period | Intervention | Age, Mean or Median (Range) | ECOG Score | CP A%; B%; C% | BCLC A%; B% | Previous LDT %
Bargellini et al. 2011^64^ 67 Fair | Prospective case series | 01/2006 - 03/2009 | TACE with lipiodol (mean: 16.1 mL, range: 10–25 mL), epirubicin hydrochloride (mean: 57 mg, range: 40–75 mg), and gelatin sponge particles via hepatic artery | Mean: 70 (NR) | NR | A: 79.1; B: 20.9; C: 0 | 0: 13.6; A: 88.1; B: 0 | NR
Buijs et al. 2008^65^ 190 Fair | Retrospective case series | 01/2002 - 01/2007 | TACE with cisplatin (100 mg), doxorubicin (50 mg), mitomycin C (10 mg) in a 1:1 mixture with iodized oil, and either polyvinyl alcohol particles or gelatin-coated trisacryl microspheres via femoral artery | Mean: 65 (18–84) | NR | A: 66; B: 34; C: 0 | NR | NR
Carr et al. 2004^66^ 65 Poor | Prospective case series | 08/2000 - 08/2003 | RE with Y90 (dose delivered mean: 145.7 Gy, median: 134.3 Gy, range: 61.1–280.9Gy) via hepatic artery | Median: 69 (NR) | NR | NR | NR | NR
Carr et al. 2010^67^ 99 Fair | Prospective cohort^*^ | 2000 - 2005 | RE with Y90 (deliver 135–150 Gy) via hepatic artery over 1–5 min | NR | NR | NR | NR | NR
Giannini et al. 2010^68^ 128 Poor | Retrospective cohort^*^ | 2003 - 2006 | TACE with an emulsion of lipiodol and chemotherapeutic agent (doxorubicin, epirubicin, mitoxantrone) | Median: 66 (NR) | NR | A: 64.8; B: 35.2; C: 0 | NR | NR
Guiu et al. 2009^69^ 43 Fair | Retrospective case series | 09/2000 - 12/2006 | TACE with pirarubicin (50 mg) diluted in 5% glucose (20 mL), lipiodol (20 mL), particles of gelatin sponge (2- to 3-mm diameter), and amiodarone (150 mg) via femoral artery once every 6–8 weeks | Median: 64.9 (47–86) | NR | A: 85; B: 12.5; C: 2.5 | NR | NR
Imai et al. 2011^70^ 122 Poor | Retrospective case series | 12/2007 - 12/2010 | TACE with miriplatin (median 80 mg, range 20–120 mg) and lipiodol (median 3 mL, range 1–6 mL) via hepatic artery | Median: 72 (48–87) | NR | A: 75.4; B: 24.6; C: 0 | NR | TACE: 80
Kanhere et al. 2008^71^ 12 Poor | Prospective case series | 08/2000 - 02/2005 | RE with radiolabelled lipiodol (average dose 1.7GBq (1.4–2.2 GBq) diluted in unlabeled lipiodol (2–10 mL) via hepatic artery | Mean: 63.4 (34–83) | NR | A: 75; B: 25; C: 0 | NR | NR
Kawaoka et al. 2009^72^ 107 Poor | Retrospective case series | 06/2000 - 12/2007 | TACE with lipiodol and cisplatin (total per case median: 60 mg, range 10–390 mg) with or without embolization via femoral artery | Median: 73 (42–92) | NR | A: 72.1; B: 27.9; C: 2.8 | NR | NR
Kim et al. 2012^83^ 2 Poor | Case Report | | TACE for 6 sessions in one case, unknown schedule in the other case | NR | NR | NR | NR | TACE: 50^†^
Leelawat et al. 2008^73^ 15 Poor | Prospective cohort | 01/2007 - 12/2007 | TACE with doxorubicin (25–50 mg) plus mitomycin C (5–10 mg) in a mixture of ionized oil contrast medium and Ivalon particles | Median: 59 (37–65) | NR | NR | NR | NR
Leelawat et al. 2008^73^ 15 Poor | Prospective cohort | 01/2007 - 12/2007 | TACE with mitomycin C (5–10 mg) in a mixture of ionized oil contrast medium and Ivalon particles | Median: 52 (40–65) | NR | NR | NR | NR
Liu et al. 2004^74^ 11 Fair | Retrospective case series | 01/2002 - 08/2003 | RE with Y90 TheraSphere (prescribed dose 100–150 Gy) via hepatic artery | Median: 67 (51–73) | NR | NR | NR | TACE: 36, TACE and resection: 18, TACE and RFA: 9, RFA 9
Mabed et al. 2009^75^ 50 Fair | RCT^*^ | 09/2003 - 06/2005 | TACE using lipiodol (10 mg), doxorubicin (50 mg) and cisplatin (50 mg) via hepatic artery every 4 weeks as long as the condition permits and total dose of 500 mg/m^2^ not exceeded | Median: 52 (36–60) | 0:26; 1-2:74 | A: 68; B: 32; C: 0 | NR | NR
Maeda et al. 2008^76^ 33 Fair | Retrospective case series | 01/2000 - 03/2006 | TACE with iodized oil, epirubicin (accumulated dose average 16.1 mg, range 0–72.5 mg) and gelatin sponge via hepatic artery for an average of 2.3 sessions (range 1–7 sessions) | Mean: 69.6 (38–85) | NR | A: 79; B: 21; C: 0 | NR | NR
Martin et al. 2011^77^ 118 Poor | Prospective case series | 01/2007 - 10/2009 | DEB with doxorubicin (75 mg per 2 mL, minimum recommended volume of 10 mL) in 2 bead vials via hepatic artery every 3–8 weeks for 2–4 treatment cycles | Median: 68 (35–88) | 0 or 1: 91 | A: 72; B: 28; C: 0 | NR | NR
Molinari et al.78 2006 47 Poor | Prospective case series | 11/2001 - 05/2004 | TACE with doxorubicin (75 mg/m^2^) with lipiodol (10 mL) followed in some patients with polyvinyl alcohol particles via hepatic artery or superselectively in some cases | Mean: 63.4 (NR) | NR | NR | NR | RFA: 4.3
Pietrosi et al. 2009^49^ 320 Poor | Case series (uncertain if prospective or retrospective) | 01/2000 - 12/2004 | TACE with epirubicin (50 mg/m^2^) with or without iodized oil and/or Gelfoam via hepatic artery or transarterial embolization with iodized oil and/or Gelfoam via superselective artery supplying a single lesion or hepatic artery | Median: 63 (35–81) | NR | A: 61.9; B: 30.6; C: 2.8 | NR | NR
Rand et al. 2005^79^ 46 Good | Retrospective case series | 01/2000 - 09/2002 | TAE with tirsacryl gelatin microspheres (size 100–700 μ) followed by cyanoacrylate (0.3–1 mL) and lipiodol via hepatic arteries | NR | NR | A: 45.7; B: 23.9; C: 8.7 | NR | NR
Reso et al. 2009^84^ 1 Poor | Case report | | TACE with cisplatin (50 mg), adriamycin (50 mg) and lipidol (20 mL) | NR | NR | NR | NR | NR
Seki et al. 2011^80^ 135 Poor | Retrospective case series | 05/2007 - 06/2009 | TACE with epirubicin-loaded (25–30 mg) superabsorbent polymer microspheres via hepatic artery | Mean: 72 (31–87) | NR | A: 60.0; B: 39.3; C: 0.7 | NR | Interventional radiology: 86.7; TACE: 48.2
Wu et al. 2010^81^ 110 Poor | Retrospective cohort | 04/2008 - 04/2009 | TACE with I-metuximab-131 (median 1720 MBq, 95% CI, 1654–1804 MBq), epirubicin, lipiodol, and/or gelfoam sponge via transhepatic artery for 5–10 min | Median: 48 (25–84) | 0:100 | A: 69; B: 31; C: 0 | NR | None: 72; RFA: 16
Wu et al. 2010^81^ 132 Poor | Retrospective cohort | 06/2008 - 12/2008 | TACE with epirubicin and lipiodol and/or gelfoam sponge | Median: 52 (24–89) | 0:100 | A: NR; B: 35; C: NR | NR | NR
Zhang et al. 2011^82^ 277 Good | Prospective case series | 12/2003 - 11/2005 | TACE with 5-fluorouracil (1 g), cis-dichlorodiamine platinum (80 mg), mitomycin (10 mg) mixed with lipiodol (5–30 mL) and, for some patients, gelatin sponge, via hepatic artery repeated every 8–12 weeks until stabilization of the tumor | Median: 54 (12–85) | NR | A: 89.2; B: 10.8; C: 0 | A: 0; B: 100 | NR

* Only a single arm of the two comparative arms was included in this evidence review.

Abbreviations: BCLC = Barcelona Clinic Liver Center hepatocellular carcinoma stage; CI = confidence interval; CT = computed tomography; CP = Child-Pugh liver cirrhosis class; DEB = drug-eluting bead; ECOG = Eastern Cooperative Oncology Group; GBq = gigabecquerel; Gy = Gray; LDT = liver directed therapy; N = number of patients; NR = not reported; RCT = randomized controlled trial; RE = radioembolization; SD = standard deviation; TACE = transarterial chemoembolization; TAE = transarterial embolization; US = ultrasound; Y90 = yittrium-90.

Table 38 and Table 39 present data on underlying liver disease characteristics from the nonrandomized comparative studies and case series. As displayed in Table 40, the two nonrandomized comparative studies varied in which tumor characteristics were reported and how these characteristics were reported. No nonrandomized comparative study reported the proportion of patients with a bilobar disease. The number of lesions and lesion size was reported by one study.31 As displayed in Table 41, the 22 observational studies varied in which tumor characteristics were reported and how these characteristics were reported. The proportion of patients with a bilobar disease was reported by five studies and ranged from 17.9 to 58 percent.64,66,67,78,81 The number of lesions was reported in 12 studies64,65,67,70-72,76-78,80,82,84 and lesion size was reported in 10 studies.64,68-72,77,80-82

Table 38 Summary of embolization treatment underlying liver disease characteristics: nonrandomized comparative studies

Study Rating | Group N | Cirrhosis% | HBV% | HCV% | NAFLD% | Alcohol%
Recchia et al. 2012^31^ Poor | DEB 35 | NR | NR | NR | NR | NR
Recchia et al. 2012^31^ Poor | TACE 70 | NR | NR | NR | NR | NR
Yu et al. 2009^63^ Poor | TEA 30 | NR | NR | NR | NR | NR
Yu et al. 2009^63^ Poor | TACE 30 | NR | NR | NR | NR | NR

Abbreviations: DEB = drug-eluting bead; HBV = hepatitis B virus; HCV = hepatitis C virus; N = number of patients; NAFLD = nonalcoholic fatty liver disease; NR = not reported; TACE = transarterial chemoembolization; TEA = transarterial ethanol ablation.

Table 39 Summary of embolization treatment underlying liver disease characteristics: case series studies

Study Rating | Group N | Cirrhosis% | HBV% | HCV% | NAFLD% | Alcohol%
Bargellini et al. 2011^64^ Fair | TACE 67 | NR | 11.9 | 74.6 | NR | NR
Buijs et al. 2008^65^ Fair | TACE 190 | NR | 21 | 40 | NR | NR
Carr et al. 2004^66^ Poor | RE 65 | 75.0 | 26.8 | 45.0 | NR | 47.5
Carr et al. 2010^67^ Fair | RE 99 | 80 | 9 | 30 | NR | NR
Giannini et al. 2010^69^ 128 Poor | TACE 128 | NR | NR | NR | NR | NR
Guiu et al. 2009^69^ Fair | TACE 43 | 93 | 5 | 10 | 7.5 | 67.5
Imai et al. 2011^70^ Poor | TACE 122 | 100 | 9.0 | 84.4 | NR | NR
Kanhere et al. 2008^71^ Poor | RE 12 | 66.7 | 25.0 | 16.7 | 0 | 8.3
Kawaoka et al. 2009^72^ Poor | TACE 107 | NR | 6.7 | 78.8 | NR | NR
Kim et al. 2012^83^ Poor | TACE 2 | NR | NR | NR | NR | NR
Leelawat et al. 2008^73^ Poor | TACE-Doxorubicin 15 | NR | NR | NR | NR | NR
Leelawat et al. 2008^73^ Poor | TACE 15 | NR | NR | NR | NR | NR
Liu et al. 2004^74^ Fair | RE 11 | 45 | 18 | 45 | NR | NR
Mabed et al. 2009^75^ Fair | TACE 50 | 90 | 12 | 74 | NR | NR
Maeda et al. 2008^76^ Fair | TACE 33 | 100 | 24 | 58 | NR | 3
Martin et al. 2011^77^ Poor | DEB 118 | 100 | 12 | 16 | NR | 5
Molinari et al.78 2006 Poor | TACE 47 | NR | 49 | 28 | NR | 15
Pietrosi et al. 2009^49^ Poor | TACE or TAE 320 | 95.3 | 13.1 | 77.8 | NR | 0.9
Rand et al. 2005^79^ Good | TAE 46 | 78.3 | NR | 17.4 | NR | NR
Reso et al. 2009^84^ Poor | TACE 1 | NR | NR | NR | NR | NR
Seki et al. 2011^80^ Poor | DEB 135 | NR | 7.4 | 81.4 | NR | NR
Wu et al. 2010^81^ Poor | TACE with iodine 131-metuximab 110 | 98 | 95 | 3 | NR | NR
Wu et al. 2010^81^ Poor | Conventional TACE 132 | 97 | 95 | NR | NR | NR
Zhang et al. 2011^82^ Good | TACE 277 | NR | 86.7 | 1.1 | NR | NR
Zhou et al. 2009^59^ Fair | Cryoablation 42 | NR | NR | NR | NR | NR

Abbreviations: DEB = drug-eluting bead; HBV = hepatitis B virus; HCC = hepatocellular carcinoma; HCV = hepatitis C virus; N = number of patients; NAFLD = nonalcoholic fatty liver disease; NR = not reported; TACE = transarterial chemoembolization; TAE = transarterial embolization; RE = radioembolization.

Table 40 Summary of embolization treatment tumor characteristics: nonrandomized comparative studies

Study Rating | Group N | Bilobar % | Number of lesions | Lesion size (cm) | Other lesion characteristics
Recchia et al. 2012^31^ Poor | DEB 35 | NR | Range: 1–3 | Median: 4.12 Range:1–9 | NR
Recchia et al. 2012^31^ Poor | TACE 70 | NR | Range: 1–3 | Median: 5.3 Range: 2–9 | NR
Yu et al. 2009^63^ Poor | TEA 30 | NR | NR | NR | NR
Yu et al. 2009^63^ Poor | TACE 30 | NR | NR | NR | NR

Abbreviations: DEB = drug-eluting bead; N = number of patients; NR = not reported; TACE = transarterial chemoembolization; TEA = transarterial ethanol ablation.

Table 41 Summary of embolization treatment tumor characteristics: case series studies

Study Rating | Group N | Bilobar % | Number of Lesions | Lesion Size (cm) | Other Lesion Characteristics
Bargellini et al. 2011^64^ Fair | TACE 67 | 17.9 | Mean:1.5 Range: 1–3 1: 62.7%, 2: 28.5%, 3: 8.9 % | Range: 1.0–6.5 | NR
Buijs et al. 2008^65^ Fair | TACE 190 | NR | 1: 26%; multiple lesions: 74% | NR | NR
Carr et al. 2004^66^ Poor | RE 65 | 50.8 | NR | NR | Liver involvement >50 percent: 15.4%
Carr et al. 2010^67^ Fair | RE 99 | 43 | ≥5: 26% | NR | NR
Giannini et al. 2010^68^ Poor | TACE 128 | NR | NR | Median: 3 95% CI: 3.0–3.5 | NR
Guiu et al. 2009^69^ Fair | TACE 43 | NR | NR | Range: 1–20 | Unifocal: 14%, multifocal: 53%, diffuse: 33%
Imai et al. 2011^70^ Poor | TACE 122 | NR | Mean:4 Range: 1–100 Solitary: 18%; | Range: 1.0–10.0 | Portal vein invasion: 2% (also noted in PVT)
Kanhere et al. 2008^71^ Poor | RE 12 | NR | Solitary: 50% | Range: 5.0–18.5 | NR
Kawaoka et al. 2009^72^ Poor | TACE 107 | NR | 1: 40%, 2–3: 33%, >3: 27% | Range: 0.6–13.0 | NR
Kim et al. 2012^83^ Poor | TACE 2 | NR | NR | NR | NR
Leelawat et al. 2008^73^ Poor | TACE-Doxorubicin 15 | NR | NR | NR | NR
Leelawat et al. 2008^73^ Poor | TACE 15 | NR | NR | NR | NR
Liu et al. 2004^74^ Fair | RE 11 | NR | NR | NR | NR
Mabed et al. 2009^75^ Fair | TACE 50 | NR | NR | NR | NR
Maeda et al. 2008^76^ Fair | TACE 33 | NR | Solitary: 21% | NR | NR
Martin et al. 2011^77^ Poor | DEB 118 | NR | Median: 2 Range: 1–25 Solitary: 45% | Range: 1.0–16.9 | NR
Molinari et al.78 2006 Poor | TACE 47 | 53 | Solitary: 17% | NR | NR
Pietrosi et al. 2009^49^ Poor | TACE or TAE 320 | NR | NR | NR | NR
Rand et al. 2005^79^ Good | TAE 46 | NR | NR | NR | NR
Reso et al. 2009^84^ Poor | TACE 1 | NR | 1 | NR | NR
Seki et al. 2011^80^ Poor | DEB 135 | NR | 1: 22.9%, 2–5: 27.4%, 6–10: 12.6%, >10: 37.0% | Range: 1.0–12.0 | NR
Wu et al. 2010^81^ Poor | TACE with 131 I-metuximab 110 | 58 | NR | ≤5 cm: 72%, > 5 cm: 28% | NR
Wu et al. 2010^81^ Poor | Conventional TACE 132 | 58 | NR | NR | NR
Zhang et al. 2011^82^ Good | TACE 277 | NR | Solitary: 60.6% | Range: 1–20 ≤7 cm: 50.5%, >7 cm: 49.5% | NR

Abbreviations: CI = confidence interval; DEB = drug-eluting beads; HCC = hepatocellular carcinoma; IQR = interquartile range; N = number of patients; NR = not reported; PVT = portal vein thrombosis; RE = radioembolization; RFA = radiofrequency ablation; TACE = transarterial chemoembolization; TAE = transarterial embolization.

### Detailed Synthesis

Table 42 displays the outcomes reported in the two RCTs. One RCT reported overall survival,61 and both trials reported survival rate by year.61,62 Survival by year presents the duration of survival for the included patients and ranges from 1 to 3 years in the RCTs. Outcomes related to progression were reported in both trials.61,62 One RCT reported local recurrence or local tumor progression as a measure of treatment failure.61 LOS was reported in one trial.62 Quality of life was not reported in any of the RCTs. Both trials reported adverse events.

Table 42 Embolization treatment outcomes reported for Key Questions 1 and 2: RCTs

Study N Rating | OS | Survival by Year | Outcomes Related to Progression | LR/Local Tumor Progression | LOS | QOL | AE
Malagari et al. 2010^61^ 84 Poor | NR | ● | ● | ● | NR | NR | ●
Sacco et al. 2011^62^ 67 Fair | ● | ● | ● | NR | ● | NR | ●

“●” Indicates that this outcome was reported in the article.

Abbreviations: AE = adverse events; LOS = length of stay; LR = local recurrence; N = number of patients; NR = not reported; OS = overall survival; QOL = quality of life.

Study outcomes data were synthesized by intervention comparisons found in the 26 included articles.

Table 43 displays the outcomes reported in the two nonrandomized comparative studies. Both studies reported overall survival or survival by year.31,63 Survival by year presents the duration of survival for the included patients and reporting ranges from 1 to 5 years for the nonrandomized comparative studies. Outcomes related to progression were reported by two studies.31,63 Local recurrence or local tumor progression and adverse events were not reported by these studies. None of the studies reported on LOS or quality of life outcomes. Adverse events were reported by one nonrandomized comparative study.31

Table 43 Embolization treatment outcomes reported for Key Questions 1 and 2: nonrandomized comparative studies

Study N Rating | OS | Survival by Year | Outcomes Related to Progression | LR/Local Tumor Progression | LOS | QOL | AE
Recchia et al. 2012^31^ 105 Poor | ● | NR | ● | NR | ● | NR | ●
Yu et al. 2009^63^ 60 Poor | NR | ● | ● | NR | NR | NR | NR

Abbreviations: AE = adverse events; LOS = length of stay; LR = local recurrence; N = number of patients; NR = not reported; OS = overall survival; QOL = quality of life.

Table 44 displays the outcomes reported in the 22 case series and case report studies. All but four studies reported overall survival or survival by year.49,70,83,84 Survival by year presents the duration of survival for the included patients and reporting ranges from 1 to 5 years for the case series. Outcomes related to progression were reported in four studies.64,69,75,77 Local recurrence or local tumor progression were reported in one study.64 LOS was reported by four studies.64,71,77,78 Adverse events were reported in all but three studies,67,68,73 and no observational studies reported on quality of life.

Table 44 Embolization treatment outcomes reported for Key Questions 1 and 2: case series studies

Study N Rating | OS | Survival by Year | Outcomes Related to Progression | LR/Local Tumor Progression | LOS | QOL | AE
Bargellini et al. 2011^64^ 67 Fair | ● | ● | ● | ● | ● | NR | ●
Buijs et al. 2008^65^ 190 Fair | ● | ● | NR | NR | NR | NR | ●
Carr et al. 2004^66^ 65 Poor | ● | NR | NR | NR | NR | NR | ●
Carr et al. 2010^67^ 99 Fair | ● | NR | NR | NR | NR | NR | NR
Giannini et al. 2010^68^ 128 Poor | ● | NR | NR | NR | NR | NR | NR
Guiu et al. 2009^69^ 43 Fair | ● | ● | ● | NR | NR | NR | ●
Imai et al. 2011^70^ 122 Poor | NR | NR | NR | NR | NR | NR | ●
Kanhere et al. 2008^71^ 12 Poor | ● | ● | NR | NR | ● | NR | ●
Kawaoka et al. 2009^72^ 107 Poor | ● | ● | NR | NR | NR | NR | ●
Kim et al. 2012^83^ 2 Poor | NR | NR | NR | NR | NR | NR | ●
Leelawat et al. 2008^73^ 30 Poor | ● | ● | NR | NR | NR | NR | NR
Liu et al. 2004^74^ 11 Fair | ●^†^ | NR | NR | NR | NR | NR | ●
Mabed et al. 2009^75^ 50 Fair | ● | NR | ● | NR | NR | NR | ●
Maeda et al. 2008^76^ 33 Fair | ● | ● | NR | NR | NR | NR | ●
Martin et al. 2011^77^ 118 Poor | ● | ● | ● | NR | ● | NR | ●
Molinari et al. 2006^78^ 47 Poor | ● | ● | NR | NR | ● | NR | ●
Pietrosi et al. 2009^49^ 320 Poor | NR | ● | NR | NR | NR | NR | ●
Rand et al. 2005^79^ 46 Good | ● | ● | NR | NR | NR | NR | ●
Reso et al. 2009^84^ 1 Poor | NR | NR | NR | NR | NR | NR | ●
Seki et al. 2011^80^ 135 Poor | ● | ● | NR | NR | NR | NR | ●
Wu et al. 2010^81^ 242 Poor | ● | ●^*^ | NR | NR | NR | NR | ●
Zhang et al. 2011^82^ 277 Good | ● | ● | NR | NR | NR | NR | ●

* Survival by year only reported for the TACE with 131I-metuximab arm only (not reported for the conventional TACE arm).

“●” Indicates that this outcome was reported in the article.

Abbreviations: AE = adverse events; HCC = hepatocellular carcinoma; LOS = length of stay; LR = local recurrence; N = number of patients; NR = not reported; OS = overall survival; QOL = quality of life.

### DEB Compared With TAE

One RCT by Malagari et al. compared DEB with doxorubicin-loaded beads and TAE with nonleaded particles.61 Two case series80,85 reported relevant outcomes for treatment with DEB and one79 reported outcomes after TAE. No nonrandomized comparative studies examined this comparison, and there were two included case series on DEB80,85 and one for TAE.79

Tables 45-49 give information on DEB compared with TAE.

Table 45 Strength of evidence for studies comparing DEB to TAE

Outcome | No. of Studies Type of Study | Risk of Bias | Consistency | Directness | Precision | Overall Grade
Overall Survival | 1; Malagari et al. 2010^61^ RCT | Medium | Unknown | Direct | Imprecise | Insufficient
Quality of Life | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Time to Progression | 1; Malagari et al. 2010^61^ RCT | High | Unknown | Indirect | Precise | Insufficient
Local Control | 1; Malagari et al. 2010^61^ RCT | High | Unknown | Indirect | Imprecise | Insufficient
Length of Stay | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Days of Work Missed | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Adverse Events | 1; Malagari et al. 2010^61^ RCT | Medium | Unknown | Direct | Precise | Insufficient

Abbreviation: RCT = randomized controlled trial.

Table 46 Survival outcomes: DEB compared with TAE

Study Rating Design | Treatment Group N | Intervention | Survival Time From | Median OS | % Survival Year 1 | % Survival Year 2 | % Survival Year 3 | Statistical Comparison
Malagari et al. 2010^61^ Poor RCT | DEB 41 | Transarterial DEB with DC beads^®^ loaded with doxorubicin (37.5 mg/mL) of bead suspension every 2 months with a maximum of 3 procedures | Study treatment | NR | 85.3 | NR | NR | NS, No statistical test of significance reported
Malagari et al. 2010^61^ Poor RCT | TAE 43 | Bland embolization with nonloaded particles of the same diameter and mechanics as DEB (BeadBlock) every 2 months with a maximum of 3 procedures | Study treatment | NR | 86.0 | NR | NR | NS, No statistical test of significance reported

Abbreviations: DEB = drug-eluting bead; N = number of patients; NR = not reported; NS = nonsignificant; OS = overall survival; RCT = randomized controlled trial; TAE = transarterial embolization.

Table 47 Survival outcomes: DEB compared with TAE, case series studies

Study Rating | Group N | Intervention | Survival Time From | Median OS (95% CI) | % Survival Year 1 | % Survival Year 2 | % Survival Year 3 | % Survival Year 4 | % Survival Year 5
Martin et al. 2011^85^ Poor | DEB 118 | DEB with doxorubicin (75 mg per 2 mL, minimum recommended volume of 10 mL) in 2 bead vials via hepatic artery every 3–8 weeks for 2–4 treatment cycles | Not reported | 14.2 | 75 | NR | NR | NR | NR
Seki et al. 2011^80^ Poor | DEB 135 | TACE with epirubicin-loaded (25–30 mg) superabsorbent polymer microspheres via hepatic artery | Study treatment | 26 | 73.7 | 59.0 | NR | NR | NR
Rand et al. 2005^79^ Good | TAE 46 | TAE with tirsacryl gelatin microspheres (size 100–700 μ) followed by cyanoacrylate (0.3–1 mL) and lipiodol via hepatic arteries | HCC diagnosis | 22.2 | 70.7 | NR | NR | NR | NR

Abbreviations: CI = confidence interval; DEB = drug-eluting beads; HCC = hepatocellular carcinoma; N = number of patients; NR = not reported; NS = nonsignificant; OS = overall survival; TACE = transarterial chemoembolization; TAE = transarterial alcohol embolization.

Table 48 Adverse events associated with local hepatic therapies: DEB compared with TAE

Study Rating Design | Treatment Group N | Intervention | Liver Failure % | Hepatic Hemorrhage % | Hepatic Abscess % | Rare AE, N (%)
Malagari et al. 2010^61^ Poor RCT | DEB 41 | Transarterial DEB with DC beads^®^ loaded with doxorubicin (37.5 mg/mL) of bead suspension every 2 months with a maximum of 3 procedures | 4.8 | NR | 4.8 | NR
Malagari et al. 2010^61^ Poor RCT | TAE 43 | Bland embolization with nonloaded particles of the same diameter and mechanics as DEB (BeadBlock) every 2 months with a maximum of 3 procedures | 4.6 | NR | 2.3 | NR

Abbreviations: AE = adverse event; N = number of patients; NR = not reported; DEB = drug-eluting bead; TAE = transarterial embolization; RCT = randomized controlled trial.

Table 49 Adverse events associated with local hepatic therapies: DEB compared with TAE, case series studies

Study Rating | Group N | Liver Failure % | Hepatic Hemorrhage % | Hepatic Abscess % | Rare AE, N (%)
Martin et al. 2011^85^ Poor | DEB 118 | NR | NR | NR | Grade 3+ AE: Bleeding 4 (9%), hematological 2 (5%), pancreatitis 1 (2%), liver dysfunction/failure 2 (5%), hypertension 1 (2%)
Seki et al. 2011^80^ Poor | DEB 135 | 0 | NR | 0 | 1 (0.7%) patient with grade 3 hematologic toxicity (anemia)
Rand et al. 2005^79^ Good | TAE 46 | 2.2 | NR | 2.2 | NR

Abbreviations: AE = adverse events; DEB = drug-eluting beads; N = number of patients; NR = not reported; TAE = transarterial alcohol embolization.

#### Overall Survival

Outcomes related to overall survival are summarized in Table 46. Malagari et al.61 reported that there was no statistically significant difference in 1-year overall survival between the groups (85.3 percent and 86 percent, respectively, p-value not reported). The authors stated that the reported survival is affected by the introduction of further treatment after the three planned procedures and for those with recurrence or disease progression.

The case series reported that 1-year survival following DEB was 75 percent in the Martin85 study and 73.7 percent in the Seki study.80 The study by Rand et al.79 reported a 1-year survival of 70.7 percent. Lack of a direct comparison in these studies limits the application of these data to inform conclusions on overall survival.

##### Strength of Evidence

The strength of evidence to evaluate overall survival for DEB compared with TAE is rated insufficient for patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease. Evidence to evaluate this outcome comes from one poor quality study. Malagari et al. 61 is an RCT and was rated as a poor quality due to the lack of blinding, participant drop out, and lack of appropriate, controlled analysis. While the lack of blinding is particularly worrisome, it does not affect the measurement of overall survival. Therefore, the risk of bias for the assessment of overall survival was graded as medium. There is unknown consistency as there is only one trial, overall survival is a direct health outcome, and the estimate is imprecise (Table 45).

#### Quality of Life

Quality of life was not reported in any of the included studies.

##### Strength of Evidence

No studies addressed this outcome. Due to the lack of data for this outcome, the strength of evidence to evaluate quality of life for DEB compared with TAE for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Outcomes Related to Progression

Malagari et al.61 reported time-to-progression (TTP), defined as the time from the first treatment until progression which consisted of as local recurrence, new lesions, or a combination of both (overall recurrence). Progression was assessed at the followup visits 1 month after each procedure and then at 9 and 12 months with CT or magnetic resonance imaging (MRI).

The mean TTP was longer in the DEB group (10.6 ± 2.4 months) than the TAE group (9.1 ± 2.3 months; p=0.008).

One case series by Martin et al.85 reported a median progression-free survival of 13 months (range: 6 to 32 months) following DEB.

##### Strength of Evidence

The strength of evidence to evaluate outcomes related to progression for DEB compared with TAE is rated insufficient for patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease. Evidence to evaluate this outcome comes from one study of poor quality. Malagari et al.61 is an RCT and was rated as poor quality due to the lack of blinding and participant drop out. Lack of blinding can lead to detection bias. This is particularly true when the outcomes are based on interpretation (i.e., not a hard outcome like death). Therefore, the risk of bias for the assessment of outcomes related to progression was graded as high. In addition, with only one study consistency is unknown, progression is an indirect measure of a health outcome, and the estimates are precise.

#### Local Recurrence/Local Tumor Progression

Malagari et al.61 reported local recurrence as the number of patients with local recurrence out of the total number of patients evaluated at 6, 9, and 12 months. In the DEB and TAE groups local recurrence at 6 months was observed in 1/41 patients and 4/43 patients (2.4 percent and 9.3 percent, p=0.17), at 9 months in 6/40 and 19/41 (15 percent and 46.3 percent, p=0.002), and at 12 months in 11/35 and 19/41 patients (31.4 percent and 56.8 percent, p=0.03) respectively.

Local recurrence was not reported in case series on DEB80,85 or TAE.79

##### Strength of Evidence

The strength of evidence to evaluate local recurrence or local tumor progression for DEB compared with TAE is rated insufficient for patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease. Evidence to evaluate this outcome comes from one study of poor quality. Malagari et al.61 is an RCT and was rated as poor quality due to the lack of blinding and participant drop out. Lack of blinding can lead to detection bias. This is particularly true when the outcomes are based on interpretation (i.e., not a hard outcome like death). Therefore, the risk of bias for the assessment of local recurrence was graded as high. In addition, with only one study consistency is unknown, local recurrence is an indirect measure of a health outcome, and the estimates are precise at six and twelve months. The authors calculated local recurrence out of those who returned for followup, which decreased over time.

#### Length of Stay

LOS was not a reported outcome in the study by Malagari et al.61

##### Strength of Evidence

No studies addressed this outcome. Due to the lack of data for this outcome, the strength of evidence to evaluate LOS for DEB compared with TAE for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Days of Missed Work

Days of missed work was not reported in any of the included studies.

##### Strength of Evidence

No studies addressed this outcome. Due to the lack of data for this outcome, the strength of evidence to evaluate days of work missed for DEB compared with TAE for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Adverse Events

Table 48 presents a summary of AEs reported in the RCT comparing DEB and TAE. Malagari et al61 reported hepatic abscess in 2 (4.8 percent) and 1 (2.3 percent) patients in the DEB and TAE groups, respectively, and liver failure in 2 patients in each group. The study authors did not report on the following AEs: hepatic hemorrhage, biloma, steatohepatitis, injury to adjacent organs, infection, increased liver enzymes (transaminases, bilirubin, alkaline phosphatase), and rare adverse events.

In the case series, Seki et al. reported none of 135 patients experienced liver failure, hepatic abscess, or biloma after DEB (Table 49).80 One patient (0.7 percent) had a grade 3 hematologic toxicity (anemia). In a study by Rand et al.,79 approximately 2 percent of 46 patients who underwent treatment with TAE experienced liver failure while another 2 percent developed hepatic abscess.

##### Strength of Evidence

The strength of evidence to evaluate adverse events for DEB compared with TAE is rated as insufficient. Evidence to evaluate this outcome comes from a single poor quality RCT and three observational studies. Malagari et al.61 is an RCT and was rated as poor quality due to the lack of blinding and participant drop out. The lack of blinding in the trial affected the risk of bias in the assessment of adverse events. The majority of adverse events of interest leave little room for interpretation, such as hepatic hemorrhage, but some such as liver failure involve some interpretation; therefore, the risk of bias for the assessment of adverse events was rated as medium. The consistency is unknown, and adverse events are direct health outcomes, but the estimates are imprecise.

#### Overall GRADE for DEB Compared With TAE

The strength of evidence ratings for studies comparing DEB to TAE are displayed in Table 45.

### DEB Compared With TACE

One RCT by Sacco et al. compared DEB with doxorubicin-loaded beads and conventional TACE with doxorubicin.62 One prospective case control study also investigated this comparison.31 There were 14 studies with 16 extracted single-treatment arms for TACE.64,65,68-70,72,73,75,76,78,81-84 Two of these studies were cohort studies that were extracted as two single arms with varied TACE regimens. As mentioned previously, there were two included case series on DEB.80,85

Tables 50-54 give information on DEB compared with TACE.

Table 50 Strength of evidence for studies comparing DEB to TACE

Outcome | No. of Studies Type of Study | Risk of Bias | Consistency | Directness | Precision | Overall Grade
Overall Survival | 2; Sacco et al. 2011^62^ 67 RCT; Recchia et al. 2012^31^ 105 Prospective Case Control | Medium | Consistent | Direct | Imprecise | Insufficient
Quality of Life | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Time to Progression | 2; Sacco et al. 2011^62^ 67 RCT Recchia et al. 2012^31^ 105 Prospective Case Control | High | Consistent | Indirect | Imprecise | Insufficient
Local Control | 1; Sacco et al. 2011^62^ 67 RCT | High | Unknown | Indirect | Imprecise | Insufficient
Length of Stay | 2; Sacco et al. 2011^62^ 67 RCT Recchia et al. 2012^31^ 105 Prospective Case Control | High | Inconsistent | Indirect | Imprecise | Insufficient
Days of Work Missed | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Adverse Events | 1; Sacco et al. 2011^62^ 67 RCT | Medium | Unknown | Direct | Imprecise | Insufficient

Abbreviation: RCT = randomized controlled trial.

Table 51 Survival outcomes: DEB compared with TACE

Study Rating Design | Treatment Group N | Intervention | Survival Time From | Median OS | % Survival Year 1 | % Survival Year 2 | % Survival Year 3 | Statistical Comparison
Sacco et al. 2011^62^ 67 Fair RCT | DEB 33 | DEB with DC Bead^®^ (2–4 mL, 100–300 μm) loaded with doxorubicin (50 mg/vial, mean: 55mg, range: 25–150 mg) mixed with nonionic contrast medium at a 1:3 ratio via superselective injection | Study treatment | Not reached | NR | 86.8 | NR | NS, p=0.96
Sacco et al. 2011^62^ 67 Fair RCT | TACE 34 | TACE with iodized oil (mean: 16.6 mL, range: 10–25 mL), doxorubicin (mean: 57.0, range: 50–75 mg) and gelatin sponge particles via hepatic arteries | Study treatment | Not reached | NR | 83.6 | NR | NS, p=0.96
Recchia et al. 2012^31^ 105 Poor | DEB 35 | DEB with DC beads^®^ loaded with doxorubicin (50mg/m2). For tumors >5 cm the size was between 500 and 700 μm, for tumors between 5 and 3 cm, the size was 300-500 μm, while for tumors <3 cm the size was 300 μm. | Study enrollment | 18.4 | NR | NR | NR | NS
Prospective Case Control | TACE 70 | TACE | Study enrollment | 11.4 | NR | NR | NR | NS

Abbreviations: DEB = drug-eluting bead; N = number of patients; NR = not reported; NS = nonsignificant; OS = overall survival; RCT = randomized controlled trial; TACE = transarterial chemoembolization.

Table 52 Survival outcomes: DEB compared with TACE, case series studies

Study Rating | Group N | Intervention | Survival Time From | Median OS (95% CI) | % Survival Year 1 | % Survival Year 2 | % Survival Year 3 | % Survival Year 4 | % Survival Year 5
Martin et al. 2011^85^ Poor | DEB 118 | DEB with doxorubicin (75 mg per 2 mL, minimum recommended volume of 10 mL) in 2 bead vials via hepatic artery every 3–8 weeks for 2–4 treatment cycles | Not reported | 14.2 | 75 | NR | NR | NR | NR
Seki et al. 2011^80^ Poor | DEB 135 | TACE with epirubicin-loaded (25–30 mg) superabsorbent polymer microspheres via hepatic artery | Study Treatment | 26 | 73.7 | 59.0 | NR | NR | NR
Bargellini et al. 2011^64^ Fair | TACE 67 | TACE with lipiodol (mean: 16.1 mL, range: 10–25 mL), epirubicin hydrochloride (mean:57mg, range: 40–75 mg), and gelatin sponge particles via hepatic artery | Study Treatment | Not reached | 90.9 | 86.1 | 80.5 | NR | NR
Buijs et al. 2008^65^ Fair | TACE 190 | TACE with cisplatin (100 mg), doxorubicin (50 mg), mitomycin C (10 mg) in a 1:1 mixture with iodized oil, and either polyvinyl alcohol particles or gelatin-coated trisacryl microspheres via femoral artery | From time of HCC diagnosis | 16 | 58 | 39 | 29 | NR | NR
Giannini et al. 2010^68^ Poor | TACE 128 | TACE with an emulsion of lipiodol and chemotherapeutic agent (doxorubicin, epirubicin, mitoxantrone) | From time of HCC diagnosis | 38^*^ | NR | NR | NR | NR | NR
Guiu et al. 2009^69^ Fair | TACE 43 | TACE with pirarubicin (50 mg) diluted in 5% glucose (20 mL), lipiodol (20 mL), particles of gelatin sponge (2–3mm diameter), and amiodarone (150mg) via femoral artery once every 6–8 weeks | HCC diagnosis | 29 (13.8 to 45) | 68 | 55 | 47 | 27 | NR
Imai et al. 2011^70^ Poor | TACE 122 | TACE with miriplatin (median 80 mg, range 20–120mg) and lipiodol (median 3 mL, range 1–6 mL) via hepatic artery | NR | NR | NR | NR | NR | NR | NR
Kawaoka et al. 2009^72^ Poor | TACE 107 | TACE with lipiodol and cisplatin (total per case median: 60 mg, range 10–390 mg) with or without embolization via femoral artery | Study treatment | 25^*^ | 86 | NR | 40 | NR | 20
Kim et al. 2012^83^ Poor | TACE 1 | TACE for 6 sessions in one case, unknown schedule in the other case | NR | NR | NR | NR | NR | NR | NR
Leelawat et al. 2008^73^ Poor | TACE 15 | TACE with mitomycin C (5–10 mg) in a mixture of ionized oil contrast medium and Ivalon particles | Study treatment | 15^*^ | NR | 40 | NR | NR | NR
Mabed et al. 2009^75^ Fair | TACE 50 | TACE using lipiodol (10 mg), doxorubicin (50 mg) and cisplatin (50 mg) via hepatic artery every 4 weeks as long as the condition permits and total dose of 500 mg/m^2^ not exceeded | Study treatment | 9.5 | NR | NR | NR | NR | NR
Maeda et al. 2008^76^ Fair | TACE 33 | TACE with iodized oil, epirubicin (accumulated dose average 16.1 mg, range 0–72.5mg), and gelatin sponge via hepatic artery for an average of 2.3 sessions (range 1–7) | Study treatment | Not yet reached | 93.5 | 85.2 | 77.4 | NR | NR
Molinari et al.78 2006 Poor | TACE 47 | TACE with doxorubicin (75 mg/m^2^) with lipiodol (10 mL) followed in some patients with polyvinyl alcohol particles via hepatic artery or superselectively in some cases | Study treatment | Not yet reached | 76.6 | 55.5 | 50.0 | NR | NR
Reso et al. 2009^49^ Poor | TACE 1 | TACE with cisplatin (50 mg), adriamycin (50 mg) and lipidol (20 mL) | NR | NR | NR | NR | NR | NR | NR
Wu et al. 2010^81^ Poor | TACE 110 | TACE with epirubicin and lipiodol and/or gelfoam sponge | Study treatment | 17.7 (14.6 to 19.4) | NR | NR | NR | NR | NR
Zhang et al. 2011^82^ Good | TACE 277 | TACE with 5-fluorouracil (1 g), cis-dichlorodiamine platinum (80 mg), mitomycin (10 mg) mixed with lipiodol (5–30 mL) and, for some patients, gelatin sponge, via hepatic artery repeated every 8–12 weeks until stabilization of the tumor | Study treatment | 16.7 | 52.1 | 31.8 | 20.2 | NR | 11.3
Wu et al. 2010^81^ Poor | TACE with 131-I–metuximab 132 | TACE with 131-I–metuximab (median 1720 MBq, 95% CI, 1654 to1804 MBq), epirubicin, lipiodol and/or gelfoam sponge via transhepatic artery for 5–10 min | Study treatment | 21.2 (18.6 to 23.4) | 79.1 | NR | NR | NR | NR
Leelawat et al. 2008^73^ Poor | TACE-Doxorubicin 15 | TACE with doxorubicin (25–50 mg) plus mitomycin C (5–10 mg) in a mixture of ionized oil contrast medium and Ivalon particles | Study treatment | 25^*^ | NR | 38 | NR | NR | NR

* Extrapolated from Kaplan-Meier graphs.

Abbreviations: CI = confidence interval; DEB = drug-eluting beads; HCC = hepatocellular carcinoma; N = number of patients; NR = not reported; OS = overall survival; TACE = transarterial chemoembolization.

Table 53 Adverse events associated with local hepatic therapies: DEB compared with TACE

Study Rating Design | Treatment Group N | Intervention | Liver Failure % | Hepatic Hemorrhage % | Hepatic Abscess % | Rare AE, N (%)
Sacco et al. 2011^62^ Fair RCT | DEB 33 | DEB with DC Bead^®^ (2–4 mL, 100–300 μm) loaded with doxorubicin (50mg/vial, mean: 55 mg, range: 25–150 mg) mixed with nonionic contrast medium at a 1:3 ratio via superselective injection | 0 | NR | NR | NR
Sacco et al. 2011^62^ Fair RCT | TACE 34 | TACE with iodized oil (mean: 16.6 mL, range: 10–25 mL), doxorubicin (mean: 57.0, range: 50–75mg) and gelatin sponge particles via hepatic arteries | 3.0 | NR | NR | NR
Recchia et al. 2012^31^ 105 Poor Prospective Case Control | DEB 35 | DEB with DC beads® loaded with doxorubicin (50mg/m2). For tumors >5 cm the size was between 500 and 700 μm, for tumors between 5 and 3 cm, the size was 300-500 μm, while for tumors <3 cm the size was 300 μm. | NR | NR | NR | NR
Recchia et al. 2012^31^ 105 Poor Prospective Case Control | TACE 70 | TACE | NR | NR | NR | NR

Abbreviations: AE = adverse event; DEB = drug-eluting bead; N = number of patients; NR = not reported; TACE = transarterial chemoembolization; RCT = randomized controlled trial.

Table 54 Adverse events associated with local hepatic therapies: DEB compared with TACE, case series studies

Study Rating | Group N | Liver Failure % | Hepatic Hemorrhage % | Hepatic Abscess % | Rare AE, N (%)
Martin et al. 2011^85^ Poor | DEB 118 | NR | NR | NR | Grade 3+ AE: bleeding 4 (9%), hematological 2 (5%), pancreatitis 1 (2%), liver dysfunction/failure 2 (5%), hypertension 1 (2%)
Seki et al. 2011^80^ Poor | DEB 135 | 0 | NR | 0 | 1 (0.7%) patient with grade 3 hematologic toxicity (anemia)
Bargellini et al. 2011^64^ Fair | TACE 67 | 3 | NR | NR | 1 patient died from liver failure
Buijs et al. 2008^65^ Fair | TACE 190 | 2.6 | NR | 0.5 | Fatal variceal bleeding in 1 patient 4 weeks after TACE; MI in 1 patient 2 days after TACE
Giannini et al. 2010^68^ Poor | TACE 128 | NR | NR | NR | NR
Guiu et al. 2009^69^ Fair | TACE 43 | NR | NR | NR | 1 case (1%) of bowel perforation (grade 5), 2 cases (1%) of severe sepsis without leucopenia (grade 5), ischemic cholecystitis 2 (1%), gastric ulcer 1 (1%), 2 (1%) cardiac toxicity, 2 (1%), 3 (7%) treatment related deaths
Imai et al. 2011^70^ Poor | TACE 122 | NR | NR | NR | Grade 4 decrease in neutrophil count 1 (1%), increased AST 4 (3%), increase ALT 1 (1%), all resolved in two weeks
Kawaoka et al. 2009^72^ Poor | TACE^*^ 107 | NR | NR | 0 | NR
Kim et al. 2012^83^ Poor | TACE 2 | NR | NR | NR | Reactivated tuberculosis in both cases
Leelawat et al. 2008^73^ Poor | TACE 15 | NR | NR | NR | NR
Mabed et al. 2009^75^ Fair | TACE 50 | 22 | NR | 2 | Puncture site bleeding and subsequent hematoma occurred in 3 patients (6%). Hypotension and bradycardia in 1 patient (2%). Two patients (4%) suffered GI bleeds due to ruptured esophageal varices. 1 (2%) patient developed cholecystitis.
Maeda et al. 2008^76^ Fair | TACE 33 | NR | NR | NR | Grade 3 hepatic arterial disease (15%)
Molinari et al. 2006^78^ Poor | TACE 40 | NR | NR | NR | Major adverse events: partial PVT 3 (3.7%), upper GI bleeding 3 (3.7%), dehydration and cachexia requiring readmission 3 (3.7%), flare of hepatitis B virus hepatitis 1 (1.2%), neutropenic fever requiring parenteral antibiotics 1 (1.2%), femoral artery pseudo aneurysm 1 (1.2%), paraduodenal chemotherapy extravasation 1 (1.2%), Psoas muscle abscess 1 (1.2%) Mortality within 30 days posttreatment: Myocardial infarction at 3 weeks 1 (1.2%), neutropenic pneumonia complicated by sepsis 1 (1.2%)
Reso et al. 2009^84^ Poor | TACE 1 | NR | NR | NR | Tumor rupture resulting in intraperitoneal bleeding 1 (100%); developed post-embolization syndrome 1 (100%); patient died of respiratory failure 16 days following TACE.
Wu et al. 2010^81^ Poor | TACE 110 | NR | NR | NR | Grade 3 or 4: bilirubin toxicity 18 (13.6%), alanine aminotransferase toxicity 17 (12.8%), aspartate aminotransferase toxicity 25 (18.9%), white blood cell toxicity 3 (2.3%), platelet toxicity 1 (0.8%) Death possibly related to treatment, arm not reported 1 (0.75%)
Zhang et al. 2011^82^ Good | TACE 277 | 0.4 | NR | NR | Tumor rupture in 1 (0.4%), GI bleeding in 2 (0.7%), refractory ascites 1 (0.7%), 1 patient died of liver failure 1 month post treatment
Wu et al. 2010^81^ Poor | TACE with 131 I-metuximab 132 | NR | NR | NR | Grade 3 or 4: bilirubin toxicity 13 (11.8%), alanine aminotransferase toxicity 17 (15.5%), aspartate aminotransferase toxicity 22 (20%), white blood cell toxicity 6 (5.5%), platelet toxicity 8 (7.2%) Death possibly related to treatment, arm not reported 1 (0.75%)
Leelawat et al. 2008^73^ Poor | TACE-Doxorubicin 15 | NR | NR | NR | NR

* No grade 3 or 4 adverse events of interest were observed for these treatment groups.

Abbreviations: AE = adverse events; ALT = alanine aminotransferase; AST = aspartate transaminase; DEB = drug-eluting beads; GI = gastrointestinal; HCC = hepatocellular carcinoma; IV = intravenous; MI = myocardial infarction; N = number of patients; NR = not reported; PVT = portal vein thrombosis; TACE = transarterial chemoembolization.

#### Overall Survival

Outcomes related to overall survival are summarized in Table 51. In the trial by Sacco et al.62 the 2-year overall survival rates were not significantly different between the groups (83.6 percent in the conventional TACE group and 86.8 percent in the DEB group, p=0.96).

In the study by Recchia et al.31 the reported median overall survival was 18.4 months and 11.4 months in the DEB and TACE groups, respectively, with no statistically significant difference.

Two case series report 1-year survival following DEB: 75 percent in the Martin study85 and 73.7 percent in the Seki study.80 Following TACE, 1-year survival is reported in 8 case series studies64,65,69,72,76,78,81,82 and ranged from 52.1 percent to 90.9 percent (Table 52). Lack of a direct comparison in these studies limits the application of these data to inform conclusions on overall survival.

##### Strength of Evidence

The strength of evidence to evaluate overall survival for DEB compared with TACE is rated as insufficient for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease based on evidence from one poor and one fair quality study. Sacco et al.62 is an RCT and was rated as fair quality due to the lack of blinding. Recchia et al.31 is a prospective cohort study which was rated as poor quality study due to the lack of control for relevant confounders during statistical analyses. The overall strength of evidence began with a moderate strength of evidence and was further reduced to insufficient SOE due to a serious risk of bias in the study by Recchia et al. and imprecision in the estimates. For an observational study to overcome the limitation of a non-randomized design, adequate control of confounders must be considered in the analysis. The authors did not control for these confounders and in addition do not discuss loss to follow up, have non-equal measurements between groups and poorly defined interventions. The lack of blinding in the study by Sacco et al is particularly worrisome, however it does not affect the measurement of overall survival. Therefore, the risk of bias for the assessment of overall survival was graded as medium. There is consistency between the RCT and prospective cohort study, overall survival is a direct health outcome, the comparison was direct, and the estimate is imprecise (Table 50).

#### Quality of Life

Quality of life was not reported in any of the included studies.

##### Strength of Evidence

No studies addressed this outcome. Due to the lack of data for this outcome, the strength of evidence to evaluate quality of life for DEB compared with TACE for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Outcomes Related to Progression

Sacco et al.62 reported time-to-radiologic-progression, defined as the time from study treatment to disease progression identified at followup 1 month after chemoembolization and every 3 months thereafter with CT or MRI. Radiologic progression was observed in 12 patients (17.9 percent), who then subsequently received repeated DEB or TACE. While the median time to progression had not been reached, the mean expected time-to-radiographic-progression was not significantly different between the groups (24.2 months after TACE vs. 15.6 months after DEB, p=0.64).

Recchia et al.31 reported relapse-free survival (RFS) defined as the time between the study treatment to any relapse and the appearance of a second primary cancer or death. The median RFS was 13.1 months and 8.4 months in the DEB and TACE groups, respectively (not statistically significant). One case series by Martin et al.85 reported a median progression-free survival of 13 months (range: 6 to 32 months) following DEB. Three case series studies on TACE reported on disease progression-related outcomes.64,69,75 Bargellini et al.64 reported a radiological disease progression following TACE in 12 patients (17.9 percent). Guiu et al.69 reported a median progression-free survival of 15 months (95% CI, 11.5 to 20.8) following TACE. In the study by Mabed et al.,75 the authors reported the median progression-free survival of 8 months (range: 4 to 17.5) among the subset of patients with partial response and stable disease following TACE (29 out of 50).

##### Strength of Evidence

The strength of evidence to evaluate outcomes related to progression for DEB compared with TACE is rated as insufficient for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease. Evidence to evaluate this outcome comes from two studies; one fair quality RCT and one poor quality observational study. Sacco et al.62 is an RCT and was rated as fair quality due to the lack of blinding. Recchia et al.31 is a prospective cohort study which was rated as poor quality study due to the lack of control for relevant confounders during statistical analyses. Lack of blinding can lead to detection bias. This is particularly true when outcomes are based on interpretation (i.e., not a hard outcome like death). Therefore, the risk of bias for the assessment of outcomes related to progression was graded as high. Evidence is consistent, and progression is an indirect measure of a health outcome. The estimates are imprecise.

#### Local Recurrence/Local Tumor Progression

Sacco et al.62 assessed the median expected time to local recurrence within the initial target lesions and found the difference is nonsignificant (12.8 months after TACE and 8.9 months after DEB, p=0.46). Recchia et al. did not report local recurrence.31

Local recurrence was not reported in case series on DEB.80,85 Of the 15 extracted single-treatment arms for TACE,64,65,68-70,72,73,75,76,78,81,82,84 local recurrence was only reported in one study by Bargellini et al.64 The authors reported no local recurrence or 100 percent technical success of treatment with TACE.

##### Strength of Evidence

The strength of evidence to evaluate local control for DEB compared with TACE is rated as insufficient for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease. Evidence to evaluate this outcome comes from one fair quality study. Sacco et al.62 is an RCT and was rated as fair quality due to the lack of blinding. Lack of blinding can lead to detection bias. This is particularly true when outcomes are based on interpretation (i.e., not a hard outcome like death). Therefore, the risk of bias for the assessment of local recurrence was graded as high. In addition, with only one study, consistency is unknown, local recurrence is an indirect measure of a health outcome, and the estimates are imprecise. Based on the high risk of bias, unknown consistency, and lack of precision, the strength of evidence is insufficient to evaluate local control for DEB compared with TACE for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease.

#### Length of Stay

Sacco et al.62 reported no significant difference between the conventional TACE and DEB groups in terms of mean LOS (6.8 days vs. 5.9 days, p=0.26).

In the study by Recchia et al., the mean LOS was 4.7 and 2.3 days in the DEB and TACE groups, respectively (p<0.0001).31

##### Strength of Evidence

The strength of evidence to evaluate length of stay for DEB compared with TACE is rated as insufficient for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease. Evidence to evaluate this outcome comes from two studies; one fair quality RCT and one poor quality observational study. Sacco et al.62 is an RCT and was rated as fair quality due to the lack of blinding. Recchia et al. is a prospective cohort study which was rated as poor quality study due to the lack of control for relevant confounders during statistical analyses.31 Lack of blinding can lead to assessment bias. This is particularly true when outcomes are based on interpretation, (i.e., not a hard outcome like death). LOS may be determined by the physician and is subject to bias based on knowledge of the treatment received. Therefore, the risk of bias for the assessment of LOS was graded as high. The studies are inconsistent regarding the superiority of one treatment over another for the outcome length of stay, and LOS is an indirect health outcome. Finally, the estimates are imprecise.

#### Days of Missed Work

Days of missed work was not reported in any of the included studies.

##### Strength of Evidence

No studies addressed this outcome. Therefore, the strength of evidence to evaluate days of work missed for DEB compared with TACE for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Adverse Events

Table 53 presents a summary of AEs reported in the RCT comparing DEB and TACE. Sacco et al.62 reported liver failure in 1 patient (3 percent) receiving TACE and none in the DEB group. Sacco et al.62 reported significant (p<0.0001) increases in ALT and bilirubin levels compared with baseline. Increase of ALT was significantly higher in the TACE group than in the DEB group (p=0.007). Increased bilirubin was not different between groups. Transaminases are intermediate outcomes. Implications are therefore unclear with respect to morbidity, mortality or more terminal health outcomes. The study did not report on the following AEs: hepatic abscess, hepatic hemorrhage, biloma, steatohepatitis, injury to adjacent organs, infection, and rare adverse events.

The study by Recchia et al. did not report any AEs.31

In the case series, Seki et al. reported none of 135 patients experienced liver failure, hepatic abscess, or biloma after DEB.80 One patient (0.7 percent) had a grade 3 hematologic toxicity (anemia). No adverse events of interest were reported in the other DEB study.85 There were instances of liver failure reported in six single arms, ranging from 0.4 82 to 22 75 percent, and two studies reported the incidence of hepatic abscess as 0.5 percent 65 and 2 percent.75 In a case report by Reso et al,84 a rare AE of tumor rupture resulting in intraperitoneal bleeding was reported in a patient treated with TACE. In another case report, Kim reported a rare AE of reactivated tuberculosis in two patients treated with TACE.83 Other rare adverse events are listed in Table 54 and include fatal and nonfatal events.

##### Strength of Evidence

The strength of evidence to evaluate local control for DEB compared with TACE is rated as insufficient for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease. Evidence to evaluate this outcome comes from one fair quality study. Sacco et al.62 is an RCT and was rated as fair quality due to the lack of blinding. The lack of blinding in the trial affected the risk of bias in the assessment of adverse events. The majority of adverse events of interest, such as hepatic hemorrhage, leave little room for interpretation, but some, such as liver failure, involve some interpretation; therefore, the risk of bias for the assessment of adverse events was rated as medium. The consistency is unknown, and adverse events are direct health outcomes but the estimates are imprecise.

#### Overall GRADE for DEB Compared With TACE

The strength of evidence ratings for studies comparing DEB to TACE are displayed in Table 50.

### TACE Compared With TEA (TAE)

No RCT examined this comparison. One retrospective case control study by Yu et al.63 compared TACE to transarterial ethanol ablation (TEA), a type of TAE. In addition to the comparative evidence, there were two49,79 single-arm studies reporting outcomes after TAE, and 14 studies with 16 extracted single-treatment arms for TACE 64,65,68-70,72,73,75,76,78,81-84 that met inclusion criteria. Two cohort studies73,81 were extracted as two single arms with varied TACE regimens, and the study by Pietrosi et al.49 treated patients with both TAE and TACE but did not specify how many patients were treated with each.

Tables 55–59 give information on TACE compared with TEA (TAE).

Table 55 Strength of evidence for studies: TACE compared with TEA

Outcome | No of Studies Type of Study | Risk of Bias | Consistency | Directness | Precision | Overall Grade
Overall Survival | 1; Yu et al. 2009^63^ Retrospective case control | High | Unknown | Direct | Precise | Insufficient
Quality of Life | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Time to Progression | 1; Yu et al. 2009^63^ Retrospective case control | High | Unknown | Indirect | Precise | Insufficient
Local Control | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Length of Stay | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Days of Work Missed | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Adverse Events | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient

Table 56 Survival outcomes: TACE compared with TEA (TAE)

Study Rating Design | Treatment Group N | Intervention | Survival Time From | Median OS (95% CI) | % Survival Year 1 | % Survival Year 2 | % Survival Year 3 | % Survival Year 4 | % Survival Year 5 | Statistical Comparison
Yu et al. 2009^63^ Poor Retrospective case control | TACE 30 | TACE with lipiodol (20 mL) - cisplatin (10 mg) emulsion and gelatin sponge particle embolization via hepatic artery for a median of 3 treatments | Study treatment | NR | 73.3 | 43.3 | NR | NR | NR | 2 year survival: p=0.053
Yu et al. 2009^63^ Poor Retrospective case control | TEA 30 | Transarterial ethanol ablation with lipiodol-ethanol mixture (mean: 14.5 mL, SD: 17.6 mL) via tumor feeder vessel(s) for a median of 2 treatments | Study treatment | NR | 93.3 | 80.0 | NR | NR | NR | 2 year survival: p=0.053

Abbreviations: CI = confidence interval; N = number of patients; NR = not reported; OS = overall survival; SD = standard deviation; TACE = transarterial chemoembolization; TEA = transarterial ethanol ablation.

Table 57 Survival outcomes: TACE compared with TEA (TAE) case series studies

Study Rating | Group N | Intervention | Survival Time From | Median OS (95% CI) | % Survival Year 1 | % Survival Year 2 | % Survival Year 3 | % Survival Year 4 | % Survival Year 5
Bargellini et al. 2011^64^ Fair | TACE 67 | TACE with lipiodol (mean: 16.1 mL, range: 10–25 mL), epirubicin hydrochloride (mean: 57 mg, range: 40–75 mg), and gelatin sponge particles via hepatic artery | Study treatment | Not reached | 90.9 | 86.1 | 80.5 | NR | NR
Buijs et al. 2008^65^ Fair | TACE 190 | TACE with cisplatin (100 mg), doxorubicin (50 mg), mitomycin C (10 mg) in a 1:1 mixture with iodized oil, and either polyvinyl alcohol particles or gelatin-coated trisacryl microspheres via femoral artery | HCC diagnosis | 16 | 58 | 39 | 29 | NR | NR
Giannini et al. 2010^68^ Poor | TACE 128 | TACE with an emulsion of Lipiodol and chemotherapeutic agent (doxorubicin, epirubicin, mitoxantrone) | HCC diagnosis | 38^*^ | NR | NR | NR | NR | NR
Guiu et al. 2009^69^ Fair | TACE 43 | TACE with pirarubicin (50 mg) diluted in 5% glucose (20 mL), Lipiodol (20 mL), particles of gelatin sponge (2–3 mm diameter), and amiodarone (150 mg) via femoral artery once every 6-8 weeks | HCC diagnosis | 29 (13.8 to 45) | 68 | 55 | 47 | 27 | NR
Imai et al. 2011^70^ Poor | TACE 122 | TACE with miriplatin (median 80 mg, range 20–120 mg) and lipiodol (median 3 mL, range 1–6 mL) via hepatic artery | NR | NR | NR | NR | NR | NR | NR
Kawaoka et al. 2009^72^ Poor | TACE 107 | TACE with lipiodol and cisplatin (total per case median: 60 mg, range 10–390 mg) with or without embolization via femoral artery | Study treatment | 25^*^ | 86 | NR | 40 | NR | 20
Kim et al. 2012^83^ Poor | TACE 1 | TACE for 6 sessions in one case, unknown schedule in the other case | NR | NR | NR | NR | NR | NR | NR
Leelawat et al. 2008^73^ Poor | TACE 15 | TACE with mitomycin C (5–10 mg) in a mixture of ionized oil contrast medium and Ivalon particles | Study treatment | 15^*^ | NR | 40 | NR | NR | NR
Mabed et al. 2009^75^ Fair | TACE 50 | TACE using lipiodol (10 mg), doxorubicin (50 mg) and cisplatin (50 mg) via hepatic artery every 4 weeks as long as the condition permits and total dose of 500 mg/m^2^ not exceeded | Study treatment | 9.5 | NR | NR | NR | NR | NR
Maeda et al. 2008^76^ Fair | TACE 33 | TACE with iodized oil, epirubicin (accumulated dose average 16.1 mg, range 0–72.5 mg) and gelatin sponge via hepatic artery for an average of 2.3 sessions (range 1–7 sessions) | Study treatment | Not yet reached | 93.5 | 85.2 | 77.4 | NR | NR
Molinari et al. 2006^78^ Poor | TACE 47 | TACE with doxorubicin (75 mg/m^2^) with lipiodol (10 mL) followed in some patients with polyvinyl alcohol particles via hepatic artery or superselectively in some cases | Study treatment | Not yet reached | 76.6 | 55.5 | 50.0 | NR | NR
Reso et al. 2009^84^ Poor | TACE 1 | TACE with cisplatin (50 mg), adriamycin (50 mg) and lipidol (20 mL) | NR | NR | NR | NR | NR | NR | NR
Wu et al. 2010^81^ Poor | TACE 110 | TACE with epirubicin and lipiodol and/or gelfoam sponge | Study treatment | 17.7 (14.6 to 19.4) | NR | NR | NR | NR | NR
Zhang et al. 2011^82^ Good | TACE 277 | TACE with 5-fluorouracil (1 g), cis-dichlorodiamine platinum (80 mg), mitomycin (10 mg) mixed with lipiodol (5–30 mL) and, for some patients, gelatin sponge, via hepatic artery repeated every 8–12 weeks until stabilization of the tumor | Study treatment | 16.7 | 52.1 | 31.8 | 20.2 | NR | 11.3
Wu et al. 2010^81^ Poor | TACE with 131 I-metuximab 132 | TACE with I-metuximab131 (median 1720 MBq, 95% CI, 1654 to1804 MBq), epirubicin, lipiodol and/or gelfoam sponge via trans-hepatic artery for 5-10 min | Study treatment | 21.2 (18.6 to 23.4) | 79.1 | NR | NR | NR | NR
Leelawat et al. 2008^73^ Poor | TACE-Doxorubicin 15 | TACE with doxorubicin (25–50 mg) plus mitomycin C (5–10 mg) in a mixture of ionized oil contrast medium and Ivalon particles | Study treatment | 25^*^ | NR | 38 | NR | NR | NR
Pietrosi et al. 2009^49^ Poor | TACE or TAE 320 | Transarterial chemoembolization with epirubicin (50 mg/m^2^) with or without iodized oil and/or Gelfoam via hepatic artery or transarterial embolization with iodized oil and/or Gelfoam via superselective artery supplying a single lesion or hepatic artery | Study treatment | NR | 73.8 | 53.9 | 44.7 | NR | NR
Rand et al. 2005^79^ Good | TAE 46 | TAE with tirsacryl gelatin microspheres (size 100–700 μ) followed by cyanoacrylate (0.3–1 mL) and lipiodol via hepatic arteries | HCC diagnosis | 22.2 | 70.7 | NR | NR | NR | NR

* Extrapolated from Kaplan-Meier graphs.

Abbreviations: CI = confidence interval; HCC = hepatocellular carcinoma; N = number of patients; NR = not reported; NS = nonsignificant; OS = overall survival; TACE = transarterial chemoembolization; TAE = transarterial embolization.

Table 58 Adverse events associated with local hepatic therapies: TACE compared with TEA (TAE)

Study Rating Design | Treatment Group N | Intervention | Liver Failure % | Hepatic Hemorrhage % | Hepatic Abscess % | Rare AE, N (%)
Yu et al. 2009^63^ Poor Retrospective case control | TACE 30 | TACE with lipiodol (20mL) - cisplatin (10mg) emulsion and gelatin sponge particle embolization via hepatic artery for a median of 3 treatments | NR | NR | NR | NR
Yu et al. 2009^63^ Poor Retrospective case control | TEA 30 | TEA with lipiodol-ethanol mixture (mean: 14.5mL, SD: 17.6mL) via tumor feeder vessel(s) for a median of 2 treatments | NR | NR | NR | NR

Abbreviations: AE = adverse event; N = number of patients; NR = not reported; SD = standard deviation; TACE = transarterial chemoembolization; TEA = transarterial ethanol ablation.

Table 59 Adverse events associated with local hepatic therapies: TACE compared with TEA (TAE), case series studies

Study Rating | Group N | Liver Failure % | Hepatic Hemorrhage % | Hepatic Abscess % | Rare AE, N (%)
Bargellini et al. 2011^64^ Fair | TACE 67 | 3 | NR | NR | NR
Buijs et al. 2008^65^ Fair | TACE 190 | 2.6 | NR | 0.5 | Fatal variceal bleeding in 1 patient 4 weeks after TACE; MI in 1 patient 2 days after TACE;
Giannini et al.2010^68^ Poor | TACE 128 | NR | NR | NR | NR
Guiu et al. 2009^69^ Fair | TACE 43 | NR | NR | NR | 1 case (1%) of bowel perforation (grade 5), 2 cases (1%) of severe sepsis without leucopenia (grade 5), ischemic cholecystitis 2 (1%), gastric ulcer 1 (1%), 2 (1%) cardiac toxicity, 2 (1%), 3 (7%) treatment related deaths
Imai et al. 2011^70^ Poor | TACE 122 | NR | NR | NR | Grade 4 decrease in neutrophil count 1 (1%), increased AST 4 (3%), increase ALT 1 (1%), all resolved in two weeks
Kawaoka et al. 2009^72^ Poor | TACE^*^ 107 | NR | NR | 0 | NR
Kim et al. 2012^83^ Poor | TACE 2 | NR | NR | NR | Reactivated tuberculosis in both cases
Leelawat et al. 2008^73^ Poor | TACE 15 | NR | NR | NR | NR
Mabed et al. 2009^75^ Fair | TACE 50 | 22 | NR | 2 | Puncture site bleeding and subsequent hematoma occurred in 3 patients (6%). Hypotension and bradycardia in 1 patient (2%). Two patients (4%) suffered GI bleeds due to ruptured esophageal varices. 1 (2%) patient developed cholecystitis.
Maeda et al. 2008^76^ Fair | TACE 33 | NR | NR | NR | Grade 3 hepatic arterial disease (15%)
Molinari et al. 2006^78^ Poor | TACE 40 | NR | NR | NR | Major adverse events: Partial PVT 3 (3.7%), Upper GI bleeding 3 (3.7%), Dehydration and cachexia requiring readmission 3 (3.7%), Flare of hepatitis B virus hepatitis 1 (1.2%), Neutropenic fever requiring parenteral antibiotics 1 (1.2%), Femoral artery pseudo aneurysm 1 (1.2%), Paraduodenal chemotherapy extravasation 1 (1.2%), Psoas muscle abscess 1 (1.2%) Mortality within 30 days post treatment: Myocardial infarction at 3 weeks 1 (1.2%), Neutropenic pneumonia complicated by sepsis 1 (1.2%)
Reso et al. 2009^84^ Poor | TACE 1 | NR | NR | NR | Tumor rupture resulting in intraperitoneal bleeding 1 (100%); developed post-embolization syndrome 1 (100%); Patient died of respiratory failure 16 days following TACE.
Wu et al. 2010^81^ Poor | TACE 110 | NR | NR | NR | Grade 3 or 4: bilirubin toxicity 18 (13.6%), alanine aminotransferase toxicity 17 (12.8%), aspartate aminotransferase toxicity 25 (18.9%), white blood cell toxicity 3 (2.3%), platelet toxicity 1 (0.8%) Death possibly related to treatment, arm not reported 1 (0.75%)
Zhang et al. 2011^82^ Good | TACE 277 | 0.4 | NR | NR | Tumor rupture in 1 (0.4%), GI bleeding in 2 (0.7%)
Wu et al. 2010^81^ Poor | TACE with 131 I-metuximab 132 | NR | NR | NR | Grade 3 or 4: bilirubin toxicity 13 (11.8%), alanine aminotransferase toxicity 17 (15.5%), aspartate aminotransferase toxicity 22 (20%), white blood cell toxicity 6 (5.5%), platelet toxicity 8 (7.2%) Death possibly related to treatment, arm not reported 1 (0.75%)
Leelawat et al. 2008^73^ Poor | TACE-Doxorubicin 15 | NR | NR | NR | NR
Pietrosi et al. 2009^49^ Poor | TACE or TAE 320 | 0.3 | NR | NR | 2(1%) ischemic cholecystitis, 1 (1%)gastric ulcer, 1 (1%)bowel perforation, 4 (3%) edemo-ascitic decompensation, 1 (1%) gastrointestinal hemorrhage, 2 (1%) cardiac toxicity, 2 (1%) severe sepsis, 3 (7%) treatment related deaths
Rand et al. 2005^79^ Good | TAE 46 | 2.2 | NR | 2.2 | NR

* No grade 3 or 4 adverse events of interest were observed for these treatment groups.

Abbreviations: AE = adverse events; ALT = alanine aminotransferase; AST = aspartate transaminase; GI = gastrointestinal; HCC = hepatocellular carcinoma; MI = myocardial infarction; N = number of patients; NR = not reported; PVT = portal vein thrombosis; TACE = transarterial chemoembolization; TAE = transarterial alcohol embolization.

#### Overall Survival

Outcomes related to overall survival are summarized in Table 56. There was a significant difference in the 2-year survival rates (measured from the date of first study treatment) of 43.3 percent and 80 percent between the TACE and TEA groups, respectively (p=0.0053). The authors did not report the median overall survival.

Following TACE, 1-year survival is reported in eight case series studies64,65,69,72,76,78,81,82 and ranged from 52.1 percent to 90.9 percent (Table 57). Following TAE, 1-year survival was 73.8 percent in the Pietrosi study49 and 70.7 percent in the Rand study.79 Lack of a direct comparison in these studies limits the application of these data to inform conclusions on overall survival.

##### Strength of Evidence

The strength of evidence to evaluate overall survival for TACE compared with TEA is rated as insufficient for patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease. Evidence to evaluate this outcome comes from one poor quality study. Yu et al.63 is a retrospective cohort study which began with a low strength of evidence due to the nature of the study design (e.g., lack of blinding and no randomization) and was further reduced to insufficient due to a serious risk of bias. For an observational study to overcome the limitation of a non-randomized design, adequate control of confounders must be considered in the analysis. The authors did not attempt to adjust for confounders in their analysis. Therefore, the risk of bias for the assessment of outcomes related to progression was graded as high. There is only one study so consistency is unknown. Overall survival is a direct health outcome and the estimate is precise (Table 55).

#### Quality of Life

Quality of life was not reported in any of the included studies.

##### Strength of Evidence

No studies addressed this outcome. Due to the lack of data for this outcome, the strength of evidence to evaluate quality of life for TACE compared with TEA (TAE) for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Outcomes Related to Progression

Yu et al.63 assessed progression-free survival, measured from the date of first study treatment to the date of death or last followup, and reported a nonsignificant difference between the TACE and TEA groups (46 percent at 1 year and 42.5 percent at 2 years for TACE and 69.8 percent at 1 year and 58.8 percent at 2 years for TEA, p=0.0588).

Three case series studies on TACE reported on disease progression-related outcomes.64,69,75 Bargellini et al.64 reported a radiological disease progression following TACE in 12 patients (17.9 percent). Guiu et al.69 reported a median progression-free survival of 15 months (95% CI, 11.5 to 20.8) following TACE. In the study by Mabed et al.,75 the authors reported the median progression-free survival of 8 months (range: 4 to 17.5) among the subset of patients with partial response and stable disease following TACE (29 out of 50).

Two case series on TAE did not report on outcomes related to progression.49,79

##### Strength of Evidence

The strength of evidence to evaluate outcomes related to progression for TACE compared with TEA is rated as insufficient for patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease. Evidence to evaluate this outcome comes from one poor quality study. Yu et al.63 is a retrospective cohort study which began with a low strength of evidence due to the nature of the study design (e.g., lack of blinding and no randomization) and was further reduced to insufficient quality due to a serious risk of bias. . For an observational study to overcome the limitation of a non-randomized design, adequate control of confounders must be considered in the analysis. The authors did not attempt to adjust for confounders in their analysis. Lack of blinding can lead to assessment bias. This is particularly true when outcomes are based on interpretation, (i.e., not a hard outcome like death). This is particularly true when outcomes are based on interpretation (i.e., not a hard outcome like death). Therefore, the risk of bias for the assessment of outcomes related to progression was graded as high. In addition, with only one study, consistency is unknown, progression is an indirect measure of a health outcome, and the estimates are precise.

#### Local Recurrence/Local Tumor Progression

Local recurrence/local tumor progression was not a reported outcome in the study by Yu et al.63

Of the 16 extracted single-treatment arms for TACE, including the study by Pietrosi et al.,49 local recurrence was only reported in one study by Bargellini et al.64 The authors reported no local recurrence, or 100 percent technical success of treatment with TACE.

Local recurrence was not reported in the case series of TAE.49,79

##### Strength of Evidence

No comparative studies addressed this outcome. Due to the lack of data for this outcome, the strength of evidence to evaluate local recurrence for TACE compared with TEA (TAE) for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Length of Stay

LOS was not a reported outcome in the study by Yu et al.63

##### Strength of Evidence

No comparative studies addressed this outcome. Due to the lack of data for this outcome, the strength of evidence to evaluate LOS for TACE compared with TEA (TAE) for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Days of Missed Work

Days of missed work was not reported in any of the included studies.

##### Strength of Evidence

No comparative studies addressed this outcome. Due to the lack of data for this outcome, the strength of evidence to evaluate days of work missed for TACE compared with TEA (TAE) for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Adverse Events

Yu et al.63 did not report any adverse events (Table 58).

In the case series, there were instances in liver failure reported in six single arms ranging from 0.4^82^ to 22^75^ percent and two studies reported incidences of hepatic abscess of 0.5 percent65 and 2 percent.75 Rand et al.79 reported 2 percent of 46 patients who underwent treatment with TAE experienced liver failure while another 2 percent developed hepatic abscess.

In a case report by Reso et al.,84 a rare AE of tumor rupture resulting in intraperitoneal bleeding was reported in a patient treated with TACE. In another case report, Kim et al.83 reported a rare AE of reactivated tuberculosis in two patients treated with TACE. Other rare adverse events including fatal and nonfatal events are listed in Table 59.

##### Strength of Evidence

No comparative studies addressed this outcome. Due to the lack of data for this outcome, the strength of evidence to evaluate adverse events for TACE compared with TEA (TAE) for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Overall GRADE for TACE Compared With TEA

The strength of evidence ratings for studies comparing TACE to TEA are displayed in Table 23.

### Interventions With No Comparative Evidence

Four case series were included in this report for which no comparative evidence exists.66,67,71,74 All four studies performed radioembolization.66,67,71,74

#### Strength of Evidence

No comparative studies met inclusion criteria for this review. Therefore strength of evidence is insufficient to evaluate all outcomes of interest: overall survival, quality of life, TTP, local recurrence, LOS, days of work missed, and adverse events for all interventions without comparative studies for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease.

#### Overall Survival

One of four studies on RE reported 1-year survival of 75 percent,71 while three studies reported a median survival ranging from 11 months74 to 15 months (Table 60).71

Table 60 Outcomes related to overall survival, studies with no comparative data

Study Rating | Group N | Intervention | Survival Time From | Median OS (95% CI) | % Survival Year 1 | % Survival Year 2 | % Survival Year 3 | % Survival Year 4 | % Survival Year 5
Carr et al. 2004^66^ Poor | RE 65 | RE with Y90 (dose delivered mean: 145.7 Gy, median: 134.3 Gy, range: 61.1–280.9Gy) via hepatic artery | NR | NR | NR | NR | NR | NR | NR
Carr et al. 2010^67^ Fair | RE 99 | RE with Y90 (deliver 135–150 Gy) via hepatic artery over 1–5 min | Study treatment | 11.5 | NR | NR | NR | NR | NR
Kanhere et al. 2008^71^ Poor | RE 12 | RE with radiolabelled lipiodol (average dose 1.7 GBq (1.4–2.2 GBq) diluted in unlabeled lipiodol (2–10 mL) via hepatic artery | Study treatment | 15 | 75 | 25 | NR | NR | NR
Liu et al. 2004^74^ Fair | RE 11 | RE with Y90 TheraSphere (prescribed dose 100–150 Gy) via hepatic artery | Study treatment | 11 | NR | NR | NR | NR | NR

Abbreviations: CI = confidence interval; CT = computed tomography; CP = Child-Pugh liver cirrhosis class; GBq = gigabecquerel; Gy = Gray; N = number of patients; NR = not reported; OS = overall survival; RE = radioembolization; Y90 = yittrium-90.

#### Quality of Life

Quality of life was not reported in any of the included studies.

#### Outcomes Related to Progression

Four RE studies66,67,71,74 did not report on outcomes related to progression.

#### Local Recurrence/Local Tumor Progression

Case series on RE,66,67,71,74 did not report on local recurrence.

#### Length of Stay

LOS was reported in two studies. One radioembolization study by Kanhere et al.71 reported a mean LOS of 7 days.

#### Days of Missed Work

Days of missed work was not reported in any of the included studies.

#### Adverse Events

For the studies lacking comparative data, no liver failure or hepatic abscess was reported. Other rare adverse events are listed in Table 61, including fatal and nonfatal events.

Table 61 Adverse events associated with local hepatic therapies: studies with no comparative data

Study Rating | Group N | Liver Failure % | Hepatic Hemorrhage % | Hepatic Abscess % | Rare AE, N (%)
Carr et al. 2004^66^ Poor | RE 65 | NR | NR | NR | Acute cholecystectomy (2%)
Carr et al. 2010^67^ Fair | RE 99 | NR | NR | NR | NR
Kanhere et al. 2008^71^ Poor | RE 12 | NR | NR | NR | Severe thrombocytopenia (8.3%); radiation pneumonitis (8.3%); radiation-induced hepatitis with pneumonia (8.3%)
Liu et al. 2004^74^ Fair | RE^*^ 11 | NR | NR | NR | NR

* No grade 3 or 4 adverse events of interest were observed for these treatment groups.

Abbreviations: AE = adverse event; CP = Child-Pugh liver cirrhosis class; N = number of patients; NR = not reported; RE = radioembolization.

## Radiation Therapies

### Description of Included Studies

A total of five case series met the inclusion criteria to address KQ1 and KQ2.^86-90^ Of these, four case series were retrospective86,87,89,90 and one was prospective.88 The total number of patients for whom data were extracted from the five studies was 146. All five studies had patient samples that were restricted to unresectable HCC patients (i.e., not including patients with liver tumors of other primary origins). All studies initiated treatment in patients after January 1, 2000.

Three studies were of SBRT, one reviewed 3D-CRT, and one presented data on real-time tumor tracking radiotherapy. No studies of IMRT, HPBT, or intraluminal brachytherapy met the inclusion criteria for this evidence review.

Table 62 and Table 63 present a summary of study and patient characteristics, including number of patients enrolled, intervention period, intervention, and baseline characteristics. Median age ranged from 57 to 63 years. The patients' baseline Child-Pugh liver cirrhosis classes were A or B. One study reported Eastern Cooperative Oncology Group (ECOG) scores of 0 to 1 in 97.5 present of enrolled patients.88 No studies reported BCLC HCC stage. One study by Taguchi et al.,90 reported Okuda stage, and less than 10 percent of the patients were in Okuda stage III (6.5 percent). Two studies described patients' prior treatment history.88,89 In both studies, 100 percent of the patients had prior treatment with TACE. Three studies reported on the proportion of patients with cirrhosis, ranging from 29 percent to 100 percent.86,88,89 Studies varied in terms of proportions of patients with HBV and HCV infection. Overall, studies were inconsistent in reporting—and often did not report—these patient and tumor characteristics at baseline (e.g., ECOG score, PVT, HCC stage) which are important prognostic factors to consider when comparing patient populations across studies.

Table 62 Summary of study and patient characteristics: case series studies

Study N Rating | Study Design | Intervention Period | Intervention | Age, Mean or Median (Range) | ECOG Score | CP A%; B%; C% | BCLC A%; B% | Previous LDT %
Andolino et al. 2011^86^ 37 Poor | Retrospective case series | 2005 - 2009 | SBRT with a total dose of 48 Gy in 3 fractions for CP A cirrhosis patients and a total dose of 40 Gy in 5 fractions for CP B cirrhosis patients | Median: 63 (24–85) | NR | A: 64.9; B: 35.1; C: 0 | NR | NR
Chan et al. 2011^87^ 16 Fair | Retrospective case series | 05/2000 - 11/2004 | SBRT (4.5 Gy) for 10 daily fractions, 2.5 Gy for 18–20 fractions where planned target volume encompassed hepatic portal area or gallbladder, or 1.8 Gy for 28–30 fractions where planned target volume included the bowel | Mean: 55.2 Median: 57.5 (23–69) | NR | A: 75; B: 25; C: 0 | NR | NR
Oh et al. 2010^88^ 40 Good | Prospective case series | 01/2006 - 02/2007 | 3D-CRT (median delivered 54 Gy, range 30–54 Gy) in 2.5–5 Gy per fraction | Median: 59.5 (36–92) | 0–1: 97.5; 2:2.5 | A: 90; B: 10; C: 0 | NR | TACE: 100
Seo et al. 2010^89^ 38 Fair | Retrospective case series | 03/2003 - 04/2008 | SBRT with escalating doses(33–57 Gy in 3 or 4fractions) | Median: 61 (37–81) | NR | A: 89.5; B: 10.5; C: 0 | NR | TACE: 100
Taguchi et al. 2007^90^ 15 Fair | Retrospective case series | 2001 - 2004 | Real-time tumor-tracking radiotherapy (RTRT) on a hypofractionated schedule (most common dose: 48 Gy in 8 fractions) | Median: 57 (54–73) | NR | A: 80; B: 20; C: 0 | NR | NR

Abbreviations: 3D-CRT = Three dimensional conformal radiotherapy; BCLC = Barcelona Clinic Liver Center hepatocellular carcinoma stage; CI = Confidence interval; CP = Child-Pugh liver cirrhosis class; ECOG = Eastern Cooperative Oncology Group; GBq = gigabecquerel; Gy = Gray; LDT = liver directed therapy; N = number of patients; NR = not reported; SBRT = stereotactic body radiotherapy.

Table 63 Summary of underlying liver disease characteristics: case series studies

Study Rating | Group N | Cirrhosis% | HBV% | HCV% | NAFLD% | Alcohol%
Andolino et al. 2011^86^ Poor | SBRT 37 | 100 | 8.1 | 43.2 | NR | NR
Chan et al. 2011^87^ Fair | SBRT 16 | NR | 81.3 | 6.3 | NR | NR
Oh et al. 2010^88^ Good | 3D-CRT 40 | 97.5 | NR | NR | NR | NR
Seo et al. 2010^89^ Fair | SBRT 38 | 28.9 | NR | NR | NR | NR
Taguchi et al. 2007^90^ Fair | 3D-CRT with real-time tumor tracking 15 | NR | 33.3 | 60.0 | NR | 6.7

Abbreviations: 3D-CRT = three dimensional conformal radiotherapy; HBV = hepatitis B virus; HCC = hepatocellular carcinoma; HCV = hepatitis C virus; N = number of patients; NAFLD = nonalcoholic fatty liver disease; NR = not reported; SBRT = stereotactic body radiotherapy.

Table 64 presents data on tumor characteristics from the included studies. No studies presented the proportion of patients with a bilobar disease, and one study86 reported number of lesions, with 94.6 and 5.4 percent having one and two lesion(s), respectively. Lesion size ranged between 1 and 7 cm across three studies.86,87,90 Oh and colleagues88 reported a dichotomized range of 45 and 55 percent of patients having lesions of <5 cm and ≥ 5 cm, respectively.

Table 64 Summary of tumor characteristics: case series studies

Study Rating | Group N | Bilobar % | Number of Lesions | Lesion Size (cm) | Other Lesion Characteristics
Andolino et al. 2011^86^ Poor | SBRT 37 | NR | 1: 94.6%, 2: 5.4%, 3: 0%; Range: 1–2 | Range: 1–6.5 | NR
Chan et al. 2011^87^ Fair | SBRT 16 | NR | NR | Range: 1-7 | NR
Oh et al. 2010^88^ Good | 3D-CRT 40 | NR | NR | <5 cm: 45%; ≥5 cm: 55% | NR
Seo et al. 2010^89^ Fair | SBRT 38 | NR | NR | NR | NR
Taguchi et al. 2007^90^ Fair | 3D-CRT with real-time target tracking 15 | NR | NR | Range:1.5–5.2 | NR

Abbreviations: 3D-CRT = three dimensional conformal radiation therapy; HCC = hepatocellular carcinoma; N = number of patients; NR = not reported; PVT = portal vein thrombosis; SBRT = stereotactic body radiation therapy.

### Detailed Synthesis

Table 65 displays the outcomes reported in the five case series. All studies reported overall survival and survival by year.86-90 Survival by year presents the duration of survival for the included patients and reporting ranges from 1 to 3 years. Outcomes related to progression were reported in two studies,86,89 and local recurrence or local tumor progression were reported in three studies.86,88,90 Adverse events were reported in all five of the studies. No studies reported on LOS and quality of life.

Table 65 Outcomes reported for Key Questions 1 and 2: case series studies

Study N Rating | OS | Survival by Year | Outcomes Related to Progression | LR/Local Tumor Progression | LOS | QOL | AE
Andolino et al. 2011^86^ 37 Poor | ● | ● | ● | ● | NR | NR | ●
Chan et al. 2011^87^ 16 Fair | ● | ● | NR | NR | NR | NR | ●
Oh et al. 2010^88^ 40 Good | ● | ● | NR | ● | NR | NR | ●
Seo et al. 2010^89^ 38 Fair | ● | ● | ● | NR | NR | NR | ●
Taguchi et al. 2007^90^ 15 Fair | ● | ● | NR | ● | NR | NR | ●

“●” Indicates that this outcome was reported in the article.

Abbreviations: AE = adverse events; HCC = hepatocellular carcinoma; LOS = length of stay; LR = local recurrence; N = number of patients; NR = not reported; OS = overall survival; QOL = quality of life.

### Radiotherapy Interventions With No Comparative Evidence

Five case series, for which no comparative evidence exists, reported on treatment with radiotherapy and were included in this report. Two studies of 3D-CRT, one of which reported on real-time target tracking88,90 and three SBRT studies86,87,89 met inclusion criteria.

#### Strength of Evidence

No comparative studies of radiotherapy met inclusion criteria for this review. Therefore, strength of evidence is insufficient to evaluate all outcomes of interest: overall survival, quality of life, TTP, local recurrence, LOS, days of work missed, and adverse events for all interventions without comparative studies for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease.

#### Overall Survival

Two case series on 3D-CRT reported 1-year survival rates of 72 percent88 and 79 percent (Table 66).90

Table 66 Outcomes related to overall survival, studies with no comparative data

Study Rating | Group N | Intervention | Survival Time From | Median OS (95% CI) | % Survival Year 1 | % Survival Year 2 | % Survival Year 3 | % Survival Year 4 | % Survival Year 5
Oh et al. 2010^88^ Good | 3D-CRT 40 | 3D-CRT (median delivered 54 Gy, range 30–54 Gy) in 2.5 to 5 Gy per fraction | Study treatment | 19 | 72.0 | 45.6 | NR | NR | NR
Taguchi et al. 2007^90^ Fair | 3D-CRT with real-time target tracking 15 | Real-time tumor-tracking radiotherapy (RTRT) on a hypofractionated schedule (most common dose: 48 Gy in 8 fractions) | Study treatment | 21^*^ | 79 | 44 | NR | NR | NR
Andolino et al. 2011^86^ Poor | SBRT 37 | SBRT with a total dose of 48 Gy in 3 fractions for CP A cirrhosis patients and a total dose of 40 Gy in 5 fractions for CP B cirrhosis patients | Study treatment | 20.4 | NR | 47 | NR | NR | NR
Chan et al. 2011^87^ Fair | SBRT 16 | SBRT (4.5 Gy) for 10 daily fractions, 2.5 Gy for 18–-20 fractions where planned target volume encompassed hepatic portal area or gall bladder, or 1.8 Gy for 28–-30 fractions where planned target volume included the bowel | Study treatment | 23 | 62 | NR | 28 | NR | NR
Seo et al. 2010^89^ Fair | SBRT 38 | SBRT with escalating doses(33–57 Gy in 3 or 4 fractions) | Study treatment | 32 | 68.4 | 61.4 | 42.1 | NR | NR

* Extrapolated from Kaplan-Meier graphs.

Abbreviations: 3D-CRT = three dimensional conformal radiation therapy; CI = confidence interval; CP = Child-Pugh liver cirrhosis class; Gy = Gray; N = number of patients; NS = nonsignificant; NR = not reported; OS = overall survival; SBRT = stereotactic body radiation therapy.

All three SBRT studies reported median survival from study treatment with a range of 23 to 32 months.86,87,89 Lack of a direct comparison in these studies limits the application of these data to inform conclusions on overall survival.

#### Quality of Life

Quality of life was not reported in any of the included radiotherapy studies.

#### Outcomes Related to Progression

The case series on 3D-CRT,88,90 did not report on outcomes related to progression.

Of the 3 studies on SBRT, two reported on outcomes related to progression.86,89 In a study by Andolino et al.,86 the median progression-free survival and 2-year progression-free survival rate following the first treatment with SBRT were 14.1 months and 33 percent, respectively. In another study of SBRT by Seo et al.,89 the median time to disease progression and 2-year disease progression-free survival rate were 10 months and 37.5 percent, respectively. Chan et al.87 did not report on outcomes related to progression.

#### Local Recurrence/Local Tumor Progression

Both 3D-CRT studies reported local recurrence with rates of 13.3 percent (2 out of 15 patients)90 to 22.5 percent (9 out of 40 patients)88. One SBRT study reported a local recurrence rate of 5.4 percent.91 In another study of SBRT,86 the local control rate (lack of recurrence within the treated planned target volume) at 2 years was 87 percent.

#### Length of Stay

LOS was not reported in any of the included radiotherapy studies.

#### Days of Missed Work

Days of missed work was not reported in any of the included radiotherapy studies.

#### Adverse Events

There were no instances of liver failure or hepatic abscess was reported in the included radiotherapy studies. Three cases of radiation induced liver disease were reported by Chan et al. 2010,^87^ and one was fatal. Other rare adverse events are listed in Table 67, including fatal and nonfatal events.

Table 67 Adverse events associated with local hepatic therapies: studies with no comparative data

Study Rating | Group N | Liver Failure % | Hepatic Hemorrhage % | Hepatic Abscess % | Rare AE, N (%)
Oh et al. 2010^88^ Good | 3D-CRT 40 | NR | NR | NR | NR
Taguchi et al. 2007^90^ Fair | 3D-CRT with real-time target tracking 15 | NR | NR | NR | Grade 3 transient gastric ulcer, 1 (6.6%); Grade 3 increase of amino transaminase, 2 (13.2%)
Andolino et al. 2011^86^ Poor | SBRT 37 | NR | NR | NR | Grade 3 liver enzymes and/or hyper bilirubinemia, 9 (24%); grade 3 thrombocytopenia, 9 (24%); elevated international normalized ratio of prothrombin, 2 (5.4%); grade 3 hypoalbuminemia, 7 (19%); grade 3 hematologic/hepatic toxicity, 21 (57%); Grade 4 thrombocytopenia and hyperbilirubinemia developed, 1 (2.7%)
Chan et al. 2011^87^ Fair | SBRT 16 | NR | NR | NR | Radiation-induced liver disease, 2 (12.5%); fatal radiation-induced liver disease, 1 (6.3%)
Seo et al. 2010^89^ Fair | SBRT 38 | NR | NR | NR | Acute radiation dermatitis leading to Grade 3 soft tissue toxicity,1 (2.6%). No grade 4 toxicity or treatment related death was observed.

Abbreviations: 3D-CRT = three dimensional conformal radiation therapy; AE = adverse event; CP = Child-Pugh liver cirrhosis class; N = number of patients; SBRT = stereotactic body radiation therapy.

## Combination Therapies

Key questions 1 and 2 focus on the comparative effectiveness (KQ1) and harms (KQ2) of the various combined local hepatic therapies in patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and have no evidence of extrahepatic disease.

### Description of Included Studies

A total of six combination therapy studies met the inclusion criteria to address KQ1 and KQ2, including one RCT,92 one nonrandomized comparative study,93 and four series studies33,91,94-97 The nonrandomized comparative study was retrospective.93 Of the six case series studies, two were retrospective33,94 and four were prospective.91,95-97 The total number of patients for whom data were extracted from the six studies was 698. There were 37 patients from the RCT, 420 from the nonrandomized comparative study, and 241from case series. All six studies had patient samples that were restricted to unresectable HCC patients (i.e., not including patients with liver tumors of other primary origins). All studies initiated treatment in patients after January 1, 2000.

The RCT compared RFA to a combination of TACE-RFA.92

Table 68 and Table 69 present a summary of study and patient characteristics from the RCT, including the number of patients enrolled, intervention period, intervention, and baseline characteristics. Patients ranged in age from 48 to 84 years with the mean age per group in the seventies. The patients' baseline Child-Pugh liver cirrhosis classes were A or B, and there were no patients in class C cirrhosis. ECOG scores were 0 to 1. The RCT did not report prior treatment history or presence of PVT. The study reported 89 percent of the patients with HCV infection.

Table 68 Summary of combination therapy study characteristics: RCTs

Study N Rating | Intervention | Intervention Period | Mean Age (Range) | CP A%; B% | BCLC A%; B% | Previous LDT %
Morimoto et al. 2010^92^ 37 Poor | TACE with epirubicin (30–50 mg per body surface), lipiodol, and gelatin sponge particles via hepatic artery followed by percutaneous RFA with multitined expandable electrode or internally cooled electrode | 08/2005 - 04/2009 | 70 (57–78) | A: 95; B: 5 | NR | NR
Morimoto et al. 2010^92^ 37 Poor | Percutaneous RFA with multitined expandable electrode or internally cooled electrode | 08/2005 - 04/2009 | 73 (48–84) | A: 89; B: 11 | NR | NR

Abbreviations: BCLC = Barcelona Clinic Liver Center hepatocellular carcinoma stage; CP = Child-Pugh liver cirrhosis class; LDT = liver-directed therapy; N = number of patients; NR = not reported; RFA = radiofrequency ablation; TACE = transarterial chemoembolization.

Table 69 Summary of combination therapy underlying liver disease characteristics: RCTs

Study Rating | Group N | Cirrhosis% | HBV% | HCV% | Alcohol%
Morimoto et al. 2010^92^ Poor | TACE-RFA 19 | NR | 0 | 89 | 11
Morimoto et al. 2010^92^ Poor | RFA 18 | NR | 0 | 89 | 0

Abbreviations: HBV = hepatitis B virus; HCV = hepatitis C virus; N = number of patients; NR = not reported; RFA = radiofrequency ablation; TACE = transarterial chemoembolization.

As displayed in Table 70, the RCT did not report the proportion of patients with a bilobar disease, mean number of lesions, lesion size, or other lesion characteristics.

Table 70 Summary of combination therapy tumor characteristics: RCTs

Study Rating | Group N | Bilobar % | Number of Lesions | Lesion Size Range (cm) | Other Lesion Characteristics
Morimoto et al. 2010^92^ Poor | TACE-RFA 19 | NR | NR | NR | NR
Morimoto et al. 2010^92^ Poor | RFA 18 | NR | NR | NR | NR

Abbreviations: N = number; NR = not reported; RFA = radiofrequency ablation; TACE = transarterial chemoembolization.

Of the five observational studies (one nonrandomized comparative studies and four case series studies), one study included patients treated with each of the following; TACE,93 TACE and cryoablation,93 TACE and PEA,94 RFA and DEB,91 TAE and RFA,95 and TACE and RFA.33 TACE and systemic chemotherapy,96 and RE and systemic chemotherapy.97 Table 71 and Table 72 present a summary of study and patient characteristics from the nonrandomized comparative study and case series, including number of patients enrolled, intervention period, intervention, and baseline characteristics. Mean age ranged from 53 to 70 years. The patients' baseline Child-Pugh liver cirrhosis classes were A or B. The ECOG scores and BCLC HCC stage were not reported in the included studies. One study included both intermediate and advanced stage patients.33 Results were reported separately by stage and extracted for the intermediate stage patients. One study reported the HCC stage using the Okuda staging system, and all the patients were in Okuda stage I or II, which are equivalent to BCLC stages A and B, respectively.94 One study reported the proportion of patients with PVT, which was 19 percent.94 One study described patients' prior treatment history, including local hepatic therapies such as PEI and TAE.95 Two studies reported on the proportion of patients with cirrhosis, which was100 percent for both.91,95 Studies varied in terms of proportions of patients with HBV and HCV infection.33,91,94,95 Overall, studies were inconsistent in reporting—and often did not report— these patient and tumor characteristics at baseline (e.g., ECOG score, Child-Pugh class, PVT, HCC stage) which are important prognostic factors to consider when comparing patient populations across studies.

Table 71 Summary of combination therapy study and patient characteristics: nonrandomized comparative studies

Study N Rating | Study Design | Intervention Period | Intervention | Age, Mean or Median (Range) | ECOG Score | CP A%; B%; C% | BCLC A%; B% | Previous LDT %
Xu et al. 2009^93^ 420 Poor | Retrospective cohort | 03/2001 - 12/2006 | TACE with doxorubicin (50 mg), mitomycin (10 mg) and lipiodol (4–15 mL) via arterial branches followed by percutaneous cryoablation via right lateral intercostal access | Median: 46 (NR) | NR | A: 31.4; B: 68.6; C: 0 | NR | NR
Xu et al. 2009^93^ 420 Poor | Retrospective cohort | 03/2001 - 12/2006 | Percutaneous cryoablation via right lateral intercostal access | Median: 41 (NR) | NR | A: 32.3; B: 67.7; C: 0 | NR | NR

Abbreviations: BCLC = Barcelona Clinic Liver Center hepatocellular carcinoma stage; CP = Child-Pugh liver cirrhosis class; ECOG = Eastern Cooperative Oncology Group; LDT = liver-directed therapy; N = number of patients; NR = not reported; TACE = transarterial chemoembolization.

Table 72 Summary of combination therapy study and patient characteristics: case series studies

Study N Rating | Study design | Intervention Period | Intervention | Age, Mean or Median (Range) | ECOG Score | CP A%; B%; C% | BCLC A%; B% | Previous LDT %
Gao et al. 2011^94^ 63 Fair | Retrospective case series | 11/2001 - 09/2009 | TACE with lipiodol, perarubicin (50 mg/m^2^), DDP (80 mg/m^2^) via hepatic artery 1–2 times followed by CT-guided percutaneous ethanol ablation with ethanol (99% concentration) mixed with lipiodol (9:1 volume ratio, mean 30.5 mL per patient) via hepatic artery | Mean: 57.2 (NR) | NR | A: 60.3; B: 39.7; C: 0 | NR | NR
Lencioni et al. 2008^91^ 20 Poor | Prospective case series | 09/2005 - 11/2006 | Percutaneous, US-guided RFA (target temp 105°C) followed within 24 hours with DEB of doxorubicin (range 50–125 mg; mean 60.2 mg; SD 21.8 mg) via arterial branches feeding the tumor | Mean: 70 (63–83) | NR | NR | NR | NR
Liao et al. 2008^95^ 36 Poor | Prospective case series | 01/2000 - 12/2005 | TAE with lipiodol followed by RFA between the 7th and 14th days after TAE | Mean: 56.4 (43–81) | NR | A: 75; B: 25 C: 0 | NR | TAE and/or PEI: 17.1
Zhao et al. 2012^33^ 122^*^ Fair | Retrospective case series | 01/2000 – 12/2009 | TACE with lipiodol (10–30 ml), epirubicin (6–12 mg), mitomycin C (6–12 mg) and normal saline solution (3 ml) via femoral artery using the Seldinger technique followed by RFA 3–4 weeks later with multitined expandable electrodes (01/00-12/03) or monopolar electrode system (01/04-12/09) | Mean: 53 (18–86) | NR | A: 79; B: 21; C: 0 | NR | NR

* Patient characteristics are reported for combined intermediate and advanced stage groups (n=122). Results are reported for the intermediate stage group separately (n=72).

Abbreviations: BCLC = Barcelona Clinic Liver Center hepatocellular carcinoma stage; CT = computed tomography; CP = Child-Pugh liver cirrhosis class; DEB = drug-eluting bead; ECOG = Eastern Cooperative Oncology Group; LDT = liver-directed therapy; N = number of patients; NR = not reported; RFA = radiofrequency ablation; SD = standard deviation; TACE = transarterial chemoembolization; TAE = transarterial embolization; US = ultrasound.

Table 73 and Table 74 present data on underlying liver disease characteristics from the nonrandomized comparative study and case series. As displayed in Table 75, the nonrandomized comparative study reported number of lesions and lesion size per group. The proportion of patients with a bilobar disease was not reported. As displayed in Table 76, the four case series studies varied in which tumor characteristics were reported and how these characteristics were reported. The proportion of patients with a bilobar disease was reported by two studies and ranged from 27 to 28 percent.94,95 The number of lesions was reported in three studies33,94,95 and lesion size was reported in two studies.91,95

Table 73 Summary of combination therapy underlying liver disease characteristics: nonrandomized comparative studies

Study Rating | Group N | Cirrhosis% | HBV% | HCV% | NAFLD% | Alcohol%
Xu et al. 2009^93^ Poor | TACE and Cryoablation 290 | NR | NR | NR | NR | NR
Xu et al. 2009^93^ Poor | Cryoablation 130 | NR | NR | NR | NR | NR

Abbreviations: HBV = hepatitis B virus; HCV = hepatitis C virus; N = number of patients; NAFLD = nonalcoholic fatty liver disease; NR = not reported; TACE = transarterial chemoembolization.

Table 74 Summary of combination therapy underlying liver disease characteristics: case series studies

Study Rating | Group N | Cirrhosis% | HBV% | HCV% | NAFLD% | Alcohol%
Gao et al. 2011^94^ Fair | TACE+PEA 63 | NR | 96.8 | 0 | NR | NR
Lencioni et al. 2008^91^ Poor | RFA+DEB 20 | 100 | 10 | 55 | NR | 5
Liao et al. 2008^95^ Poor | TAE+RFA 36 | 100 | 75.0 | 16.7 | NR | NR
Zhao et al. 2012^33^ Fair | TACE+RFA 122^*^ | NR | 74 | 3 | NR | NR

* Patient characteristics are reported for combined intermediate and advanced stage groups (n=122). Results are reported for the intermediate stage group separately (n=72).

Abbreviations: DEB = drug-eluting bead; HBV = hepatitis B virus; HCC = hepatocellular carcinoma; HCV = hepatitis C virus; N = number of patients; NAFLD = nonalcoholic fatty liver disease; NR = not reported; RFA = radiofrequency ablation; TACE = transarterial chemoembolization; TAE = transarterial embolization.

Table 75 Summary of combination therapy tumor characteristics: nonrandomized comparative studies

Study Rating | Group N | Bilobar % | Number of Lesions | Lesion Size (cm) | Other Lesion Characteristics
Xu - 2009^93^ Poor | TACE and Cryoablation 290 | NR | 1, 45.5%; 2, 28.9%; 3, 11.0%; >3, 14.5% | Range: 4.5–15.0; >10 cm: 23.8% | NR
Xu - 2009^93^ Poor | Cryoablation 130 | NR | 1, 57.7%; 2, 25.4%; 3, 10.0%; >3, 6.9% | Range: 3.1–7.0; >10 cm: 0% | mean size difference p=0.04;

Abbreviations: N = number of patients; NR = not reported; TACE = transarterial chemoembolization.

Table 76 Summary of combination therapy tumor characteristics: case series studies

Study Rating | Group N | Bilobar % | Number of Lesions | Lesion Size (cm) | Other Lesion Characteristics
Gao et al. 2011^94^ Fair | TACE+PEA 63 | 27.0 | Solitary: 68.3% | NR | NR
Lencioni et al. 2008^91^ Poor | RFA+DEB 20 | NR | NR | Range: 3.3–7.0 | NR
Liao et al. 2008^95^ Poor | TAE+RFA 36 | 28 | Mean:1.1 Solitary: 61% | Range: 3.0–12.0 | NR
Zhao et al. 2012^33^ Fair | TACE+RFA 122^*^ | NR | Solitary: 44% | NR | NR

* Patient characteristics are reported for combined intermediate and advanced stage groups (n=122). Results are reported for the intermediate stage group separately (n=72).

Abbreviations: DEB = drug-eluting beads; HCC = hepatocellular carcinoma; N = number of patients; NR = not reported; PEA = percutaneous ethanol ablation; RFA = radiofrequency ablation; TACE = transarterial chemoembolization; TAE = transarterial embolization.

### Detailed Synthesis

Table 77 displays the outcomes reported in the RCT. The RCT reported survival rate by year, local recurrence, and adverse events.92 Survival by year presents the duration of survival for the included patients and ranges from 1–3 years in the RCT. Studies varied in the use of terms and definitions of those outcomes related to disease progression and local recurrence, and we describe them in this report as they are reported in the studies. Overall survival, outcomes related to progression, LOS, and quality of life were not reported in the RCTs.

Table 77 Outcomes reported for Key Questions 1 and 2: RCTs

Study N Rating | OS | Survival by Year | Outcomes Related to Progression | LR/Local Tumor Progression | LOS | QOL | AE
Morimoto et al. 2010^92^ 37 Poor | NR | ● | NR | ● | NR | NR | ●

“●” Indicates that this outcome was reported in the article.

Abbreviations: AE = adverse events; LOS = length of stay; LR = local recurrence; N = number of patients; NR = not reported; OS = overall survival; QOL = quality of life.

Study outcomes data were synthesized by intervention comparisons found in the six included articles.

Table 78 displays the outcomes reported in the nonrandomized comparative studies. The study reported survival by year, local recurrence, and adverse events.93 Survival by year presents the duration of survival for the included patients and reporting ranges from 1 to 5 years for the nonrandomized comparative study. The study did not report on overall survival, outcomes related to progression, LOS, or quality of life outcomes.

Table 78 Outcomes reported for Key Questions 1 and 2: nonrandomized comparative studies

Study N Rating | OS | Survival by Year | Outcomes Related to Progression | LR/Local Tumor Progression | LOS | QOL | AE
Xu et al. 2009^93^ 420 Poor | NR | ● | NR | ● | NR | NR | ●

Abbreviations: AE = adverse events; LOS = length of stay; LR = local recurrence; N = number of patients; NR = not reported; OS = overall survival; QOL = quality of life.

Table 79 displays the outcomes reported in the four case series studies. All but one study reported overall survival or survival by year.91 Survival by year presents the duration of survival for the included patients and reporting ranges from 1 to 5 years for the case series. Outcomes related to progression were reported in one study.33 LOS was reported by one study.91 Adverse events were reported in all but one study,33 and no observational studies reported on local recurrence or quality of life.

Table 79 Outcomes reported for Key Questions 1 and 2: case series studies

Study N Rating | OS | Survival by Year | Outcomes Related to Progression | LR/Local Tumor Progression | LOS | QOL | AE
Gao et al. 2011^94^ 63 Fair | ● | ● | NR | NR | NR | NR | ●
Lencioni et al. 2008^91^ 20 Poor | NR | NR | NR | NR | ● | NR | ●
Liao et al. 2008^95^ 36 Poor | ● | ● | NR | NR | NR | NR | ●
Zhao et al. 2012^33^ 122^*^ Fair | ● | ● | ● | NR | NR | NR | NR

* Patient characteristics are reported for combined intermediate and advanced stage groups (n=122). Results are reported for the intermediate stage group separately (n=72).

“●” Indicates that this outcome was reported in the article.

Abbreviations: AE = adverse events; HCC = hepatocellular carcinoma; LOS = length of stay; LR = local recurrence; N = number of patients; NR = not reported; OS = overall survival; QOL = quality of life.

### RFA Compared With TACE-RFA

One RCT by Morimoto et al.92 compared RFA monotherapy to TACE-RFA combination therapy. No nonrandomized comparative studies examined this comparison. One case series using TACE-RFA met inclusion criteria.33

Tables 80–84 give information on RFA compared with TACE-RFA.

Table 80 Strength of evidence for studies comparing RFA to TACE-RFA

Outcome | No of Studies Type of Study | Risk of Bias | Consistency | Directness | Precision | Overall Grade
Overall Survival | 1; Morimoto et al. 2010^92^ RCT | High | Unknown | Direct | Imprecise | Insufficient
Quality of Life | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Time to Progression | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Local Control | 1; Morimoto et al. 2010^92^ RCT | High | Unknown | Indirect | Precise | Insufficient
Length of Stay | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Days of Work Missed | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Adverse Events | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient

Abbreviation: RCT = randomized controlled trial.

Table 81 Survival outcomes: RFA compared with TACE-RFA, randomized controlled trial

Study Rating Design | Treatment Group N | Intervention | Survival Time From | Median OS (95% CI) | % Survival Year 1 | % Survival Year 2 | % Survival Year 3 | % Survival Year 4 | % Survival Year 5 | Statistical Comparison
Morimoto et al. 2010^92^ 37 Poor RCT | TACE-RFA 19 | TACE with epirubicin (30–50 mg per body surface), lipiodol, and gelatin sponge particles via hepatic artery followed by percutaneous RFA with multitined expandable electrode or internally cooled electrode followed | Randomization | NR | 100 | 93 | 93 | NR | NR | NS, p=0.369
Morimoto et al. 2010^92^ 37 Poor RCT | RFA 18 | Percutaneous RFA with multitined expandable electrode or internally cooled electrode | Randomization | NR | 89 | 89 | 80 | NR | NR | NS, p=0.369

Abbreviations: CI = confidence interval; N = number of patients; NR = not reported; NS = nonsignificant; OS = overall survival; RCT = randomized controlled trial; RFA = radiofrequency ablation; TACE = transarterial chemoembolization.

Table 82 Survival outcomes: RFA compared with TACE-RFA, case series studies

Study Rating | Group N | Intervention | Survival Time From | Median OS (95% CI) | % Survival Year 1 | % Survival Year 2 | % Survival Year 3 | % Survival Year 4 | % Survival Year 5
Zhao et al. 2012^33^ Fair | TACE-RFA 122^†^ | TACE with lipiodol (10–30 ml), epirubicin (6–12 mg), mitomycin C (6–12 mg) and normal saline solution (3 ml) via femoral artery using the Seldinger technique followed by RFA 3–4 weeks later with multitined expandable electrodes (01/00-12/03) or monopolar electrode system (01/04-12/09) | Study Treatment | 32^*^ | 88.9 | NR | 58.3 | NR | 13.9

* Extrapolated from Kaplan-Meier graphs.

† Patient characteristics are reported for combined intermediate and advanced stage groups (n=122). Results are reported for the intermediate stage group separately (n=72).

Abbreviations: CI = confidence interval; N = number of patients; NR = not reported; OS = overall survival; RFA = radiofrequency ablation; TACE = transarterial chemoembolization.

Table 83 Adverse events associated with local hepatic therapies: RFA compared with TACE-RFA

Study Rating Design | Treatment Group N | Intervention | Liver Failure % | Hepatic Hemorrhage % | Hepatic Abscess % | Rare AE, N (%)
Morimoto et al. 2010^92^ 37 Poor RCT | TACE-RFA 19 | TACE with epirubicin (30–50 mg per body surface), lipiodol, and gelatin sponge particles via hepatic artery followed by percutaneous RFA with multitined expandable electrode or internally cooled electrode followed | NR | NR | NR | NR
Morimoto et al. 2010^92^ 37 Poor RCT | RFA 18 | Percutaneous RFA with multitined expandable electrode or internally cooled electrode | NR | NR | NR | NR

Abbreviations: AE = adverse event; N = number of patients; NR = not reported; RCT = randomized controlled trial; RFA = radiofrequency ablation; TACE = transarterial chemoembolization.

Table 84 Adverse events associated with local hepatic therapies: RFA compared with TACE-RFA, case series studies

Study Rating | Group N | Liver Failure % | Hepatic Hemorrhage % | Hepatic Abscess % | Rare AE, N (%)
Zhao et al. 2012^33^ Fair | TACE-RFA 122^†^ | NR | NR | NR | NR

† Patient characteristics are reported for combined intermediate and advanced stage groups (n=122). Results are reported for the intermediate stage group separately (n=72).

Abbreviations: AE = adverse events; N = number of patients; NR = not reported; RFA = radiofrequency ablation; TACE = transarterial chemoembolization.

#### Overall Survival

Outcomes for the RCT related to overall survival are summarized in Table 81. There was no statistically significant difference in the 1-, 2-, and 3-year survival rates between the two groups (p=0.369).

One case series by Zhao et al., reported overall survival after treatment with TACE-RFA combination (Table 82).33 Zhao et al., reported a 3-year survival of 58 months. Lack of a direct comparison in these studies limits the application of these data to inform conclusions on overall survival.

##### Strength of Evidence

The strength of evidence to evaluate overall survival for RFA compared with TACE-RFA is rated as insufficient for patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease. Evidence to evaluate this outcome comes one poor quality study. Morimoto et al. is an RCT and was rated as a poor quality study due to the lack of blinding and insufficient power to confirm the superiority of one group to another.92 The low sample size of 37 is below the calculated 40 participants required to establish the specified 80 percent power calculation provided by the authors. Therefore, the risk of bias for the assessment of overall survival was graded as high. There is unknown consistency as there is only one study, overall survival is a direct health outcome, and the estimate is imprecise (Table 80).

#### Quality of Life

Quality of life was not reported in any of the included studies.

##### Strength of Evidence

No comparative studies addressed this outcome. Due to the lack of data for this outcome, the strength of evidence to evaluate quality of life for RFA compared with TACE-RFA for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Outcomes Related to Progression

Outcomes related to progression were not reported in the study by Morimoto et al.92

Zhao et al., defined TTP as the interval from the date of treatment to the date of progressive disease (sum of the diameters of the target lesions had increased >20% or any new intrahepatic or extrahepatic lesions), death or the last followup visit.33 Mean TTP was 8.8 months (range 1.5–69 months).

##### Strength of Evidence

No comparative studies addressed this outcome. Due to the lack of data for this outcome, the strength of evidence to evaluate TTP for RFA compared with TACE-RFA for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Local Recurrence/Local Tumor Progression

Morimoto et al. reported a significant difference in local tumor progression rate (undefined) at the end of 1, 2, and 3 years between the TACE-RFA combination therapy group and the RFA monotherapy group (6 percent vs. 39 percent, respectively, p=0.012).92

##### Strength of Evidence

The strength of evidence to evaluate local control for RFA compared with TACE-RFA is rated as insufficient for patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease. Evidence to evaluate this outcome comes from one poor quality study Morimoto et al. is an RCT and was rated as poor quality due to the lack of blinding and insufficient power. Lack of blinding can lead to detection bias.92 This is particularly true when outcomes are based on interpretation (i.e., not a hard outcome like death). Therefore, the risk of bias for the assessment of outcomes related to local recurrence as high. In addition, with only one study consistency is unknown, progression is an indirect measure of a health outcome, and the estimates are precise.

#### Length of Stay

LOS was not a reported outcome in the study by Morimoto et al.92

##### Strength of Evidence

No comparative studies addressed this outcome. Due to the lack of data for this outcome, the strength of evidence to evaluate LOS for RFA compared with TACE-RFA for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Days of Missed Work

Days of missed work not a reported outcome in the study by Morimoto et al.92

##### Strength of Evidence

No comparative studies addressed this outcome. Due to the lack of data for this outcome, the strength of evidence to evaluate days of work missed for RFA compared with TACE-RFA for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Adverse Events

No major complications were observed in the TACE-RFA combination and RFA monotherapy groups (Table 84).92 The study did not report on the following AEs: hepatic abscess, hepatic hemorrhage, biloma, steatohepatitis, injury to adjacent organs, liver failure, infection, increased liver enzymes (transaminases, bilirubin, alkaline phosphatase), and rare adverse events (Table 83).

##### Strength of Evidence

No comparative studies addressed this outcome. Due to the limited amount of data, the strength of evidence is insufficient to evaluate adverse events for RFA compared with TACE-RFA for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease.

#### Overall GRADE for RFA Compared With TACE-RFA

The strength of evidence ratings for studies comparing RFA to TACE-RFA are displayed in Table 80.

### Cryoablation Compared With TACE-Cryoablation

One retrospective cohort study by Xu et al.93 compared cryoablation to sequential TACE and cryoablation for the treatment of HCC.

Tables 85-87 give information on cryoablation compared with TACE-cryoablation.

Table 85 Strength of evidence for studies comparing cryoablation to TACE-cryoablation

Outcome | No of Studies Type of Study | Risk of Bias | Consistency | Directness | Precision | Overall Grade
Overall Survival | 1; Xu et al. 2009^93^ Retrospective cohort | High | Unknown | Direct | Precise | Insufficient
Quality of Life | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Time to Progression | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Local Control | 1; Xu et al. 2009^93^ Retrospective cohort | High | Unknown | Indirect | Precise | Insufficient
Length of Stay | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Days of Work Missed | 0 | Unknown | Unknown | Unknown | Unknown | Insufficient
Adverse Events | 1; Xu et al. 2009^93^ Retrospective cohort | Medium | Unknown | Direct | Imprecise | Insufficient

Table 86 Survival outcomes: cryoablation compared with TACE with sequential cryoablation

Study Rating Design | Treatment Group N | Intervention | Survival Time From | Median OS (95% CI) | % Survival Year 1 | % Survival Year 2 | % Survival Year 3 | % Survival Year 4 | % Survival Year 5 | Statistical Comparison
Xu et al. 2009^93^ Poor Retrospective cohort | Cryoablation 130 | Percutaneous cryoablation via right lateral intercostal access | Study treatment | NR | 73 | 54 | 42 | 29 | 23 | 1-year: p=0.668M 2-year: p=0.147 3-year: p=0.064 4-year: p=0.001 5-year: p=0.001
Xu et al. 2009^93^ Poor Retrospective cohort | TACE and Cryoablation 290 | TACE with doxorubicin (50 mg), mitomycin (10 mg) and lipiodol (4–15 mL) via arterial branches followed by percutaneous cryoablation via right lateral intercostal access | Study treatment | NR | 71 | 61 | 52 | 49 | 39 | 1-year: p=0.668M 2-year: p=0.147 3-year: p=0.064 4-year: p=0.001 5-year: p=0.001

Abbreviations: CI = confidence interval; N = number of patients; NR = not reported; OS = overall survival; TACE = transarterial chemoembolization.

Table 87 Adverse events associated with local hepatic therapies: cryoablation compared with TACE with sequential cryoablation

Study Rating Design | Treatment Group N | Intervention | Liver Failure % | Hepatic Hemorrhage % | Hepatic Abscess % | Rare AE, N (%)
Xu et al. 2009^93^ Poor Retrospective cohort | Cryoablation 130 | Percutaneous cryoablation via right lateral intercostal access | 0 | 0 | NR | NR
Xu et al. 2009^93^ Poor Retrospective cohort | TACE and Cryoablation 290 | TACE with doxorubicin (50 mg), mitomycin (10 mg) and lipiodol (4–15 mL) via arterial branches followed bypercutaneous cryoablation via right lateral intercostal access | 4.1 | 1.7 | NR | NR

Abbreviations: AE = adverse event; N = number of patients; NR = not reported; TACE = transarterial chemoembolization.

#### Overall Survival

Outcomes related to overall survival for Xu et al.93 are summarized in Table 86. Survival was measured from the time of cryoablation to the time of death or last followup. One- to 3-year survival outcomes were not statistically different between groups, but were in years 4 and 5 (p=0.001), with the combination therapy showing a superior survival outcome. The authors also noted that 18 patients with HCC lesions larger than 5 cm in diameter survived more than 5 years in the sequential treatment group, whereas no patients with large HCC lesions survived for 5 years after cryoablation alone.

Lack of a direct comparison in these studies limits the application of these data to inform conclusions on overall survival.

##### Strength of Evidence

The strength of evidence to evaluate overall survival for cryoablation compared with TACE-Cryoablation is rated as insufficient for patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease. Evidence to evaluate this outcome comes from one poor quality study. Xu et al.93 is a retrospective cohort study which began with a low strength of evidence due to the nature of the study design (e.g., lack of blinding and no randomization) and was further reduced to insufficient quality due to a serious risk of bias. For an observational study to overcome the limitation of a non-randomized design, adequate control of confounders must be considered in the analysis. The authors did not attempt to adjust for confounders in their analysis. Therefore, the risk of bias for the assessment of overall survival was graded as high. There is unknown consistency as there is only one trial, overall survival is a direct health outcome, the comparison was direct, and the estimate is precise (Table 85).

#### Quality of Life

Quality of life was not reported in any of the included studies.

##### Strength of Evidence

No comparative studies addressed this outcome. Therefore, the strength of evidence to evaluate quality of life for cryoablation compared with TACE-cryoablation for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Outcomes Related to Progression

Outcomes related to progression were not reported in the study by Xu et al.93

##### Strength of Evidence

No comparative studies addressed this outcome. Therefore, the strength of evidence to evaluate TTP for cryoablation compared with TACE-cryoablation for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Local Recurrence/Local Tumor Progression

Xu et al.93 assessed local tumor recurrence of the ablated lesions (identified via CT scan) during followup occurring every 2–3 months for 1–2 years. With a mean followup period of 42 ± 17 months (range: 24–70 months), the local recurrence rate at the ablated area was 17 percent for all patients, and 23 percent and 11 percent for the cryoablation and the sequential TACE-cryoablation groups, respectively (p=0.001).

##### Strength of Evidence

The strength of evidence to evaluate local control for cryoablation compared with TACE-cryoablation is rated as insufficient for patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease. Evidence to evaluate this outcome comes from one poor quality study. Xu et al.93 is a retrospective cohort study which began with a low strength of evidence due to the nature of the study design (e.g., lack of blinding and no randomization) and was further reduced to insufficient SOE due to a serious risk of bias. For an observational study to overcome the limitation of a non-randomized design, adequate control of confounders must be considered in the analysis. The authors did not attempt to adjust for confounders in their analysis. Therefore, the risk of bias for the assessment of outcomes related to progression was graded as high. In addition, with only one study, consistency is unknown, progression is an indirect measure of a health outcome, and the estimates are precise.

#### Length of Stay

LOS was not a reported outcome in the study by Xu et al.93

##### Strength of Evidence

No comparative studies addressed this outcome. Therefore, the strength of evidence to evaluate LOS for cryoablation compared with TACE-cryoablation for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Days of Missed Work

Days of missed work was not reported in any of the included studies.

##### Strength of Evidence

No comparative studies addressed this outcome. Therefore, the strength of evidence to evaluate days of work missed for cryoablation compared with TACE-cryoablation for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Adverse Events

Xu et al.93 reported no observed events of hepatic hemorrhage or liver failure as reported in Table 87. Hepatic abscess, biloma, steatohepatitis, injury to adjacent organs, infection, increased liver enzymes (transaminases, bilirubin, alkaline phosphatase), and rare adverse events were not reported.

##### Strength of Evidence

The strength of evidence to evaluate adverse events for cryoablation compared with TACE-cryoablation is rated as insufficient for patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease. Evidence to evaluate this outcome comes from one poor quality study. The lack of blinding affected the risk of bias in the assessment of adverse events. The majority of adverse events of interest, such as hepatic hemorrhage, leave little room for interpretation, but others, such as liver failure, involve some interpretation; therefore, the risk of bias for the assessment of adverse events was rated as medium. The consistency is unknown, and adverse events are direct health outcomes but the estimates are imprecise.

#### Overall GRADE for TACE Compared With TACE-Cryoablation

The strength of evidence ratings for studies comparing TACE to TACE-cryoablation are displayed in Table 85.

### Combination Therapy Interventions With No Comparative Evidence

Three combination therapy case series were included in this report for which no comparative evidence exists: RFA followed by DEB,91 TACE followed by PEA,94 and TAE followed by RFA.95

#### Strength of Evidence

No comparative studies met inclusion criteria for this review. Therefore, strength of evidence is insufficient to evaluate all outcomes of interest: overall survival, quality of life, TTP, local recurrence, LOS, days of work missed, and adverse events for all interventions without comparative studies for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease.

#### Overall Survival

Survival outcomes for the combination treatments are summarized in Table 88. Lack of a direct comparison in these studies limits the application of these data to inform conclusions on overall survival.

Table 88 Outcomes related to overall survival, combination therapy studies with no comparative data

Study Rating | Group N | Intervention | Survival Time From | Median OS (95% CI) | % Survival Year 1 | % Survival Year 2 | % Survival Year 3 | % Survival Year 4 | % Survival year 5
Lencioni et al. 2008^91^ Poor | RFA and DEB 20 | Percutaneous, US-guided RFA (target temp 105°C) followed within 24 hours with DEB of doxorubicin (range 50–125 mg; mean 60.2 mg; SD 21.8 mg) via arterial branches feeding the tumor | NR | NR | NR | NR | NR | NR | NR
Gao et al. 2011^94^ Fair | TACE+PEA 63 | TACE with lipiodol, perarubicin (50 mg/m^2^), DDP (80 mg/m^2^) via hepatic artery 1–2 times followed by CT-guided percutaneous ethanol ablation with ethanol (99% concentration) mixed with lipiodol (9:1 volume ratio, mean 30.5 mL per patient) via hepatic artery | Study Treatment | 27.7 | 54.0 | NR | 31.7 | NR | 17.5
Liao et al. 2008^95^ Poor | TAE+RFA 36 | TAE with Lipiodol followed by RFA between the 7th and 14th days after TAE | Not reported | 34^*^ | 90 | 57 | 40 | NR | NR

* Extrapolated from Kaplan-Meier graphs.

Abbreviations: CI = confidence interval; CT = computed tomography; CP = Child-Pugh liver cirrhosis class; DEB = drug-eluting beads; GBq = gigabecquerel; Gy = Gray; N = number of patients; NS = nonsignificant; NR = not reported; OS = overall survival; PEA = percutaneous ethanol ablation; RFA = radiofrequency ablation; SD = standard deviation; TACE = transarterial chemoembolization; TAE = transarterial embolization; US = ultrasound.

#### Quality of Life

Quality of life was not reported in any of the included studies.

#### Outcomes Related to Progression

Outcomes related to progression were not reported in any of the included studies.

#### Local Recurrence/Local Tumor Progression

Local recurrence or local tumor progression was not reported in any of the included studies.

#### Length of Stay

A study of RFA followed by DEB reported a mean LOS of 2.7 days with a range of 2 to 4 days.

#### Days of Missed Work

Days of missed work was not reported in any of the included studies.

#### Adverse Events

For the studies lacking comparative data, no liver failure or hepatic abscess was reported. Other rare adverse events are listed in Table 89, including fatal and nonfatal events.

Table 89 Adverse events associated with local hepatic therapies: combination therapy studies with no comparative data

Study Rating | Group N | Liver Failure % | Hepatic Hemorrhage % | Hepatic Abscess % | Rare AE, N (%)
Lencioni et al. 2008^91^ Poor | RFA+DEB^*^ 20 | NR | NR | 0 | NR
Gao et al. 2011^94^ Fair | TACE+PEA 63 | NR | NR | NR | Fatal variceal bleeding due to increased portal vein pressure caused by deterioration of liver cirrhosis after repeated TACE-PEA, 2 (3.2%)
Liao et al. 2008^95^ Poor | TAE+RFA^*^ 36 | NR | NR | NR | NR

* No grade 3 or 4 adverse events of interest were observed for these treatment groups.

Abbreviations: AE = adverse event; CP = Child-Pugh liver cirrhosis class; DEB = drug-eluting beads; N = number of patients; PEA = percutaneous ethanol ablation; RFA = radiofrequency ablation; SC = systemic chemotherapy; SD = standard deviation; TACE = transarterial chemoembolization; TAE = transarterial embolization.

## Key Question 3 Comparative Effectiveness by Patient Subgroups

Key question 3 focuses on the assessment of heterogeneity of treatment effects across patient subgroups. Subgroups of interest include age, sex, HCC stage, disease etiology, lesion size, and multifocal disease. All included comparative studies were reviewed for KQ3, whereas case series and the case report were excluded as we were only interested in subgroups within the comparison of two interventions.

### Description of Included Studies

Three RCTs undertook ad hoc subgroup analyses to assess the impact of various patient and tumor factors on treatment outcomes.50-52 The results are described below and organized by the treatment comparison followed by patient subgroup of interest.

### Key Points

- Three RCTs reported subgroup analyses of interest for the comparison of RFA to PEI/PAI. Subgroup analyses in these studies were ad hoc rather than prespecified in the analysis plan, leading to a high risk of bias. Two RCTs by Lin et al.51,52 found that RFA yielded a significantly greater overall survival than PEI/PAI among patients with larger lesions, defined as 2–3 cm in one study and 3.1–4 cm in another study. In contrast, an RCT by Brunello et al.50 found no significant difference in overall survival between RFA and PEI among patients with lesions >2 cm in size. There is a low strength of evidence to support increased overall survival for RFA compared with PEI/PAI in patients with larger lesions with a high risk of bias. The evidence is insufficient to assess the effects lesion size on other outcomes of interest in this report and of other patient subgroups on any outcome of interest in this report.
- In one RCT by Brunello et al.50 no difference in overall survival was found between RFA and PEI among the subgroups of patients in Child-Pugh class A and those with multifocal HCC. The evidence was graded as insufficient due to results of unknown consistency and a high risk of bias.
- No studies presented subgroup analyses on age, sex, disease etiology, and HCC stage. Therefore, the evidence is insufficient to assess the effect of these subgroups for all outcomes of interest in this review.

### Detailed Synthesis

Subgroup analyses were only present in studies comparing RFA to PEI/PAI.

### RFA Compared With PEI/PAI

#### Age

None of the three RCTs reported subgroup analysis by age.

##### Strength of Evidence

No studies evaluated this subgroup. Due to the lack of data, the strength of evidence to evaluate the effect of age on the comparative effectiveness of RFA and PEI/PAI for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient (Table 90).

Table 90 Strength of evidence for studies comparing RFA to PEI/PAI

Patient or tumor characteristic | No. of Studies Type of Study | Risk of Bias | Consistency | Directness | Precision | Overall Grade
Age | 0 | Unknown | Unknown | Direct | Unknown | Insufficient
Sex | 0 | Unknown | Unknown | Direct | Unknown | Insufficient
Disease Etiology | 0 | Unknown | Unknown | Direct | Unknown | Insufficient
HCC Stage | 0 | Unknown | Unknown | Direct | Unknown | Insufficient
Child-Pugh Class | 1; Brunello et al. 2008^50^ RCT | High | Unknown | Direct | Imprecise | Insufficient
Lesion Size | 3; Brunello et al. 2008^50^ RCT; Lin et al. 2004^51^ RCT; Lin et al. 2005^52^ RCT | High | Consistent | Direct | Imprecise | Low
Multifocal HCC | 1; Brunello et al. 2008^50^ RCT | High | Unknown | Direct | Precise | Insufficient

Abbreviation: RCT = randomized controlled trial

#### Sex

None of the three RCTs reported subgroup analysis by sex.

##### Strength of Evidence

No studies evaluated this subgroup. Due to the lack of data, the strength of evidence to evaluate the effect of sex on the comparative effectiveness of RFA and PEI/PAI for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Disease Etiology

None of the three RCTs reported subgroup analysis by disease etiology (e.g., HBV, HCV).

##### Strength of Evidence

No studies evaluated this subgroup. Due to the lack of data, the strength of evidence to evaluate the effect of disease etiology on the comparative effectiveness of RFA and PEI/PAI for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### HCC Stage

None of the three RCTs reported subgroup analysis by HCC stage (e.g., BCLC stage A or B).

##### Strength of Evidence

No studies evaluated this subgroup. Due to the lack of data, the strength of evidence to evaluate the effect of HCC stage on the comparative effectiveness of RFA and PEI/PAI for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Child-Pugh Class

Brunello et al.50 found a nonsignificant difference in overall survival between the RFA and PEI groups among patients in Child-Pugh class A (hazard ratio=0.67; 95% CI, 0.25 to 1.80; p=0.43). In multivariate models, Child-Pugh class B had a positive association with risk of death (hazard ratio=2.94; 95% CI, 1.6-5.42; p=0.001).

##### Strength of Evidence

One RCT presented a post hoc analysis of the impact of Child-Pugh class on overall survival. The risk of bias for this particular analysis is high because it was not a prespecified analysis.. Only one study reported results by Child-Pugh class; therefore, the consistency is unknown, the measurement is direct for a health outcome, and the estimate is imprecise. Thus, the strength of evidence to evaluate the effect of Child-Pugh classification on the comparative effectiveness of RFA and PEI/PAI for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease was judged to be insufficient.

#### Lesion Size

##### Overall Survival

Brunello et al.50 reported a nonsignificant difference in overall survival between the RFA and PEI groups among patients HCC lesions >2 cm in diameter (hazard ratio=0.62; 95% CI, 0.28 to 1.36; p=0.23).

In the stratified subgroup analysis by lesion size (1–2 cm and 2–3 cm), Lin et al.52 found that the overall survival rate was significantly higher in the RFA group compared with the PEI group (p=0.032) and the PAI group (p=0.027) among patients with HCC lesions 2–3 cm in size. Among patients with smaller HCC lesions (1–2 cm), no significant difference between treatment groups was seen.

In a similar study comparing RFA to conventional PEI and higher-dose PEI, Lin et al.51 conducted a stratified subgroup analysis by lesion size (1–2 cm, 2.1–3 cm, and 3.1–4 cm) and found that the overall survival rate was significantly higher in the RFA group compared with the conventional PEI group (p<0.03) and the higher-dose PEI group (p<0.04) among patients with HCC lesions 3.1–4 cm in size. Among patients with smaller HCC lesions (1–2 cm and 2.1–3 cm), no significant difference between treatment groups was seen.

###### Strength of Evidence

Three RCTs presented a post hoc analysis of the impact of lesion size on overall survival. While randomization would prevent selection bias, the risk of bias remains high since these subgroup analyses were not prespecified (i.e., the lesion size cutoffs). In addition, there is no rationale given for the lesion size cutoffs in these papers. It is particularly troubling for the two papers by Lin et al., in which different cutoffs were used. Results are directionally consistent, showing better survival for patients with larger lesions treated with RFA compared with PEI/PAI. The strength of evidence is low to evaluate the effect of lesion size on the comparative effectiveness of RFA and PEI/PAI for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease.

##### Cancer-Free Survival

In addition to overall survival, Lin et al.48 reported subgroup analyses for cancer-free survival, the RFA group had a significantly higher cumulative survival rate than the PEI group (p=0.031) or PAI group (p=0.035) among patients with 2–3 cm HCC lesions, but not among patients with 1–2 cm HCC lesions.

###### Strength of Evidence

One RCT presented a post hoc analysis of the impact of lesion size on cancer-free survival. The risk of bias for this particular analysis is high because it was not a prespecified analysis. Only one study reported results by lesion size; therefore, the consistency is unknown, the measurement is direct for a health outcome, and the estimate is precise. Thus, the strength of evidence is insufficient to evaluate the effect of lesion size on the comparative effectiveness of RFA and PEI/PAI for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease.

##### Local Recurrence

Lin et al.48 also reported subgroup analyses for local recurrence rate. Local recurrence rate was lower in the RFA group compared with the PEI group (p=0.009) and PAI group (p=0.011) among the smaller HCC lesion subgroup, but not in the larger HCC lesion subgroup.

###### Strength of Evidence

One RCT presented a post hoc analysis of the impact of lesion size on local recurrence. The risk of bias for this particular analysis is high because it was not a prespecified analysis. Only one study reported results by lesion size, therefore the consistency is unknown, the measurement is direct for a health outcome, and the estimate is precise. Due to the high risk of bias and unknown consistency the strength of evidence is insufficient to evaluate the effect of multifocal disease classification on the comparative effectiveness of RFA and PEI/PAI for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease.

#### Multifocal HCC

Brunello et al.50 reported a nonsignificant difference in overall survival between the RFA and PEI groups among patients with multifocal HCC (hazard ratio=0.48; 95% CI, 0.16 to 1.43; p=0.19).

##### Strength of Evidence

One RCT presented a post hoc analysis of the impact of multifocal HCC on overall survival. The risk of bias for this particular analysis is high because it was not a prespecified analysis. Only one study reported results by multifocal HCC; therefore, the consistency is unknown, the measurement is direct for a health outcome, and the estimate is imprecise. Thus, the strength of evidence is insufficient to evaluate the effect of multifocal disease classification on the comparative effectiveness of RFA and PEI/PAI for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation and with no evidence of extrahepatic disease.

## Overall Conclusions for Key Questions 1–3

- Six RCTs, four nonrandomized comparative studies, 35 case series, and three case reports comprised the body of literature. One RCT was rated as good,50 three were rated as fair,51,52,62 and two were rated as poor quality.61,92
- The body of evidence for RFA compared with PEI/PAI was rated moderate strength to support better overall survival at 3 years for RFA compared with PEI/PAI with a low risk of bias.
- The body of evidence for RFA compared with PEI/PAI was rated low strength to support increased TTP, improved local control, and a longer LOS for RFA compared with PEI/PAI, with a high risk of bias.
- For all other comparisons, the body of evidence on overall survival, quality of life, disease progression, local control, LOS, days of missed work, and adverse events for local hepatic therapy for the treatment HCC is insufficient to support the effectiveness of one local hepatic therapy over another, due to the lack of comparative studies.
- Studies with subgroup analyses were limited to the three studies50-52 reporting on the comparison of RFA to PEI/PAI. These analyses reviewed Child-Pugh class, lesion size, and multifocal disease for their effects on overall survival, but were not prespecified. Lesion size was also examined by Lin et al 2004^51^ for its effects on cancer-free survival and local recurrence. There is a low strength of evidence to support increased overall survival for RFA compared with PEI/PAI in patients with larger lesions with a high risk of bias. The evidence is insufficient to assess the effects lesion size on other outcomes of interest in this report and of other patient subgroups on any outcome of interest in this report.
- The assessment of applicability of the study findings to clinical practice is limited by the poor characterization of the patient populations (e.g., number and size of metastases, performance status) and variations in the delivery of the interventions (e.g., surgical approach and dose and drugs delivered).