# References

1 McWilliams JP, Yamamoto S, Raman SS, et al. Percutaneous ablation of hepatocellular carcinoma: current status. J Vasc Interv Radiol. 2010;21(8, Suppl1):S204-S13. [pmid: 20656230].
2 Lencioni R. Loco-regional treatment of hepatocellular carcinoma. Hepatology. 2010;52(2):762-73. [pmid: 20564355].
3 Blonski W, Kotlyar DS, Forde K. Non-viral causes of hepatocellular carcinoma. World J Gastroenterol. 2010;16(29):3603-15. [pmid: 20677332].
4 Kim J, Yim H, Lee K, et al. Recurrence rates and factors for recurrence after radiofrequency ablation combined with transarterial chemoembolization for hepatocellular carcinoma: a retrospective cohort study. Hepatol Int. 2011:1-6. [pmid: 21728030].
5 Llovet JM, Di Bisceglie AM, Bruix J, et al. Design and endpoints of clinical trials in hepatocellular carcinoma. J Natl Cancer Inst. 2008;100(10):698-711. [pmid: 18477802].
6 Bruix J, Sherman M. Management of hepatocellular carcinoma: An update. Hepatology. 2011;53(3):1020-2. [pmid: 21374666].
7 Cabibbo G, Latteri F, Antonucci M, et al. Multimodal approaches to the treatment of hepatocellular carcinoma. Nat Clin Pract Gastroenterol Hepatol. 2009;6(3):159-69. [pmid: 19190599].
8 Grieco A, Pompili M, Caminiti G, et al. Prognostic factors for survival in patients with early-intermediate hepatocellular carcinoma undergoing non-surgical therapy: comparison of Okuda, CLIP, and BCLC staging systems in a single Italian centre. Gut. 2005;54(3):411-8. [pmid: 15710992].
9 Llovet JM. Updated treatment approach to hepatocellular carcinoma. J Gastroenterol. 2005;40:225-35. [pmid: 15830281].
10 Marrero JA, Fontana RJ, Barrat A, et al. Prognosis of hepatocellular carcinoma: comparison of 7 staging systems in an American cohort. Hepatology. 2005;41(4):707-15. [pmid: 15795889].
11 Parikh P, Malhotra H, Jelic S. Hepatocellular carcinoma: ESMO clinical recommendations for diagnosis, treatment and follow-up. Ann Oncol. May. Suppl 2. 2008;19:ii27-8. [pmid: 18456757].
12 Mathews S, Allison W, Lin S. Liver transplant considerations for evaluation, CTP, and MELD. Crit Care Nurs Clin North Am. 2010;22(3):403-11. [pmid: 20691390].
13 Kheyfits A. Yttrium-90 Radioembolization. 2010. www.radiologytoday.net/archive/rt0910p20.shtml. October 27, 2012.
14 National Comprehensive Cancer Network. Clinical Practice Guidelines in Oncology. Hepatobiliary Cancers. Version 2. 2010. www.nccn.org/professional/physician_gls/PDF/hepatobiliay.pdf. January 2011.
15 Thomas MB, Jaffe D, Choti MM, et al. Hepatocellular carcinoma: consensus recommendations of the National Cancer Institute Clinical Trials Planning Meeting. J Clin Oncol. Sep. 1. 2010;28(25):3994-4005. [pmid: 20679622].
16 Padma S, Martinie JB, Iannitti DA. Liver tumor ablation: Percutaneous and open approaches. J Surg Oncol. 2009;100(8):619-34. [pmid: 20017157].
17 Nguyen KT, Geller DA. Radiofrequency Ablation of Hepatocellular Carcinoma. Carr BI, editor. Hepatocellular Carcinoma, Diagnosis and Treatment. New York, New York. Humana Press. 2010:421-51.
18 Radiologyinfo. Radiofrequency Abalation (RFA) of Liver Tumors. 2011. www.radiologyinfo.org/en/info.cfm?pg=rfaliver. May, 10 2012.
19 Gueorguiev AL, Mackey R, Kowdley GC, et al. Minimally invasive evaluation and treatment of colorectal liver metastases. Int J Surg Oncol. 2011;2011:686030. [pmid: 22312518].
20 Shiina S, Teratani T, Obi S, et al. Percutaneous ethanol injection therapy for liver tumors. European Journal of Ultrasound. 2001;13(2):95-106. [pmid: 11369522].
21 Gage AA, Baust J. Mechanisms of Tissue Injury in Cryosurgery. Cryobiology. 1998;37(3):171-86. [pmid: 9787063].
22 Gage AA, Guest K, Montes M, et al. Effect of varying freezing and thawing rates in experimental cryosurgery. Cryobiology. 1985;22(2):175-82. [pmid: 3979086].
23 Blazer DG, Anaya DA, Abdalla EK. Destructive Therapies for Colorectal Cancer Metastastes. Vauthey JN, Audisio RA, Hoff PM, Poston G, editors. Liver Metastases. London. Springer-Verlag. 2009:39-49.
24 Rahbari NN, Mehrabi A, Mollberg NM, et al. Hepatocellular carcinoma: current management and perspectives for the future. Ann Surg. 2011;253(3):453-69. [pmid: 21263310].
25 American Cancer Society. Embolization therapy for liver cancer. 2012. www.cancer.org/Cancer/LiverCancer/DetailedGuide/liver-cancer-treating-embolization-therapy. May 10, 2012.
26 Kennedy AS, Nutting C, Coldwell D, et al. Pathologic response and microdosimetry of 90Y microspheres in man: review of four explanted whole livers. Int J Radiat Oncol Biol Phys. 2004;60(5):1552-63. [pmid: 15590187].
27 Campbell AM, Bailey IH, B MA. Tumour dosimetry in human liver following hepatic yttrium-90 microsphere therapy. Phys Med Biol. 2001;46(2):487-98. [pmid: 11229728].
28 Lau WY, Leung T, Ho S, et al. Diagnostic pharmaco-scintigraphy with hepatic intraarterial technetium-99m macroaggregated albumin in the determination of tumour to non-tumour uptake ratio in hepatocellular carcinoma. Br J Radiol. 1994;67(794):136-9. [pmid: 8130973].
29 Coldwell DM, Kennedy AS. Internal Radiation for the Tratment of Liver Metastases. Vauthey JN, Audisio RA, Hoff PM, Poston G, editors. Liver Metastases. London. Springer-Verlag. 2009:98-109.
30 Meza-Junco J, Montano-Loza AJ, Liu DM, et al. Locoregional radiological treatment for hepatocellular carcinoma; Which, when and how?. Cancer Treat Rev. 2011. In Press, Corrected Proof. [pmid: 21726960].
31 Recchia F, Passalacqua G, Filauri P, et al. Chemoembolization of unresectable hepatocellular carcinoma: Decreased toxicity with slow-release doxorubicineluting beads compared with lipiodol. Oncol Rep. May. 2012;27(5):1377-83. [pmid: 22294036].
32 American Cancer Society. Radiation therapy for liver cancer. 2012. www.cancer.org/Cancer/LiverCancer/DetailedGuide/liver-cancer-treating-radiation-therapy. May 10 2012.
33 Zhao M, Wang JP, Pan CC, et al. CT-guided radiofrequency ablation after with transarterial chemoembolization in treating unresectable hepatocellular carcinoma with long overall survival improvement. Eur J Radiol. Oct. 2012;81(10):2717-25. [pmid: 22245655].
34 Vezali E, Aghemo A, Colombo M. A review of the treatment of chronic hepatitis C virus infection in cirrhosis. Clin Ther. Dec. 2010;32(13):2117-38. [pmid: 21316532].
35 Radiologyinfo. Stereotactic Radiosurgery (SRS) and Stereotactic Body Radiotehrapy (SBRT). American College of Radiology and the Radiological Society of North America. 2012. www.radiologyinfo.org/en/info.cfm?pg=stereotactic. May 10, 2012.
36 Radiologyinfo. Proton therapy. American College of Radiology and the Radiological Society of North America. www.radiologyinfo.org/en/info.cfm?pg=protonthera. May 29, 2012.
37 Radiologyinfo. Brachytherapy. American College of Radiology and the Radiological Society of North America. www.radiologyinfo.org/en/info.cfm?pg=brachy. May 29, 2012.
38 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLo S Med. Jul. 21. 2009;6(7):e1000097. [pmid: 19621072].
39 Moher D, Pham B, Lawson ML, et al. The inclusion of reports of randomised trials published in languages other than English in systematic reviews. Health Technol Assess. 2003;7(41):1-90. [pmid: 14670218].
40 Adam R, Wicherts DA, de Haas RJ, et al. Patients with initially unresectable colorectal liver metastases: is there a possibility of cure?. J Clin Oncol. Apr. 10. 2009;27(11):1829-35. [pmid: 19273699].
41 Kern W, Beckert B, Lang N, et al. Phase I and pharmacokinetic study of hepatic arterial infusion with oxaliplatin in combination with folinic acid and 5-fluorouracil in patients with hepatic metastases from colorectal cancer. Ann Oncol. May. 2001;12(5):599-603. [pmid: 11432616].
42 Kemeny N, Gonen M, Sullivan D, et al. Phase I study of hepatic arterial infusion of floxuridine and dexamethasone with systemic irinotecan for unresectable hepatic metastases from colorectal cancer. J Clin Oncol. May. 15. 2001;19(10):2687-95. [pmid: 11352961].
43 Meyers MO, Sasson AR, Sigurdson ER. Locoregional strategies for colorectal hepatic metastases. Clin Colorectal Cancer. May. 2003;3(1):34-44. [pmid: 12777190].
44 AHRQ. Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=318&pageaction=displayproduct. April 5, 2011.
45 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
46 Carey TS, B SD. A critical guide to case series reports. Spine. 2003;28:1631-4. [pmid: 12897483].
47 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. 2010;63:513-23. [pmid: 19595577].
48 Baba Y, Nosho K, Shima K, et al. HIF1A overexpression is associated with poor prognosis in a cohort of 731 colorectal cancers. American Journal of Pathology. May. 2010;176(5):2292-301. [pmid: 20363910].
49 Pietrosi G, Miraglia R, Luca A, et al. Arterial chemoembolization/embolization and early complications after hepatocellular carcinoma treatment: a safe standardized protocol in selected patients with Child class A and B cirrhosis. J Vasc Interv Radiol. Jul. 2009;(7):896-902. [pmid: 19497762].
50 Brunello F, Veltri A, Carucci P, et al. Radiofrequency ablation versus ethanol injection for early hepatocellular carcinoma: A randomized controlled trial. Scandinavian Journal of Gastroenterology. 2008;43(6):727-35. [pmid: 18569991].
51 Lin SM, Lin CJ, Lin CC, et al. Radiofrequency ablation improves prognosis compared with ethanol injection for hepatocellular carcinoma < or =4 cm. Gastroenterology. Dec. 2004;(6):1714-23. [pmid: 15578509].
52 Lin SM, Lin CJ, Lin CC, et al. Randomised controlled trial comparing percutaneous radiofrequency thermal ablation, percutaneous ethanol injection, and percutaneous acetic acid injection to treat hepatocellular carcinoma of 3 cm or less. Gut. Aug. 2005;(8):1151-6. [pmid: 16009687].
53 Chok KS, Ng KK, Poon RT, et al. Comparable survival in patients with unresectable hepatocellular carcinoma treated by radiofrequency ablation or transarterial chemoembolization. Arch Surg. Dec. 2006;(12):1231-6. [pmid: 17178966].
54 Chen HW, Lai EC, Zhen ZJ, et al. Ultrasound-guided percutaneous cryotherapy of hepatocellular carcinoma. Int J Surg. 2011;(2):188-91. [pmid: 21093616].
55 Itoh S, Ikeda Y, Kawanaka H, et al. Efficacy of surgical microwave therapy in patients with unresectable hepatocellular carcinoma. Ann Surg Oncol. Dec. 2011;18(13):3650-6. [pmid: 21674268].
56 Minami Y, Kawasaki T, Kudo M, et al. Treatment of large and/or multiple hepatic malignancies: open surgical approaches of radiofrequency ablation. Hepatogastroenterology. Dec. 2007;(80):2358-60. [pmid: 18265664].
57 Shen SQ, Xiang JJ, Xiong CL, et al. Intraoperative radiofrequency thermal ablation combined with portal vein infusion chemotherapy and transarterial chemoembolization for unresectable HCC. Hepatogastroenterology. Sep-Oct. 2005;(65):1403-7. [pmid: 16201083].
58 Tanaka S, Shimada M, Shirabe K, et al. Surgical radiofrequency ablation for treatment of hepatocellular carcinoma: an endoscopic or open approach. Hepatogastroenterology. Jul-Aug. 2009;(93):1169-73. [pmid: 19760963].
59 Zhou L, Yang YP, Feng YY, et al. Efficacy of argon-helium cryosurgical ablation on primary hepatocellular carcinoma: a pilot clinical study. Ai Zheng. Jan. 2009;(1):45-8. [pmid: 19448416].
60 Singh M, Singh G, Pandey A, et al. Laparoscopic repair of iatrogenic diaphragmatic hernia following radiofrequency ablation for hepatocellular carcinoma. Hepatol Res. Nov. 2011;41(11):1132-6. [pmid: 22032681].
61 Malagari K, Pomoni M, Kelekis A, et al. Prospective Randomized Comparison of Chemoembolization with Doxorubicin-Eluting Beads and Bland Embolization with BeadBlock for Hepatocellular Carcinoma. CardioVascular and Interventional Radiology. 2010;33(3):541-51. [pmid: 19937027].
62 Sacco R, Bargellini I, Bertini M, et al. Conventional versus Doxorubicin-eluting Bead Transarterial Chemoembolization for Hepatocellular Carcinoma. J Vasc Interv Radiol. 2011. Aug. 15.
63 Yu SC, Hui JW, Hui EP, et al. Embolization efficacy and treatment effectiveness of transarterial therapy for unresectable hepatocellular carcinoma: a case-controlled comparison of transarterial ethanol ablation with lipiodol-ethanol mixture versus transcatheter arterial chemoembolization. J Vasc Interv Radiol. Mar. 2009;(3):352-9. [pmid: 19167240].
64 Bargellini I, Sacco R, Bozzi E, et al. Transarterial chemoembolization in very early and early-stage hepatocellular carcinoma patients excluded from curative treatment: A prospective cohort study. Eur J Radiol. 2011. Apr. 3.
65 Buijs M, Vossen JA, Frangakis C, et al. Nonresectable hepatocellular carcinoma: long-term toxicity in patients treated with transarterial chemoembolization--single-center experience. Radiology. Oct. 2008;(1):346-54. [pmid: 18796686].
66 Carr BI. Hepatic arterial 90Yttrium glass microspheres (Therasphere) for unresectable hepatocellular carcinoma: interim safety and survival data on 65 patients. Liver Transpl. Feb. 2004;(2 Suppl 1):S107-10. [pmid: 14762849].
67 Carr BI, Kondragunta V, Buch SC, et al. Therapeutic equivalence in survival for hepatic arterial chemoembolization and yttrium 90 microsphere treatments in unresectable hepatocellular carcinoma: a two-cohort study. Cancer. Mar. 2010;1(5):1305-14. [pmid: 20066715].
68 Giannini EG, Bodini G, Corbo M, et al. Impact of evidence-based medicine on the treatment of patients with unresectable hepatocellular carcinoma. Aliment Pharmacol Ther. Feb. 2010;15(4):493-501. [pmid: 19912152].
69 Guiu B, Colin C, Cercueil JP, et al. Pilot study of transarterial chemoembolization with pirarubicin and amiodarone for unresectable hepatocellular carcinoma. Am J Clin Oncol. Jun. 2009;(3):238-44. [pmid: 19349854].
70 Imai N, Ikeda K, Seko Y, et al. Previous chemoembolization response after transcatheter arterial chemoembolization (TACE) can predict the anti-tumor effect of subsequent TACE with miriplatin in patients with recurrent hepatocellular carcinoma. Oncology. 2011;(3-4):188-94. [pmid: 21709428].
71 Kanhere HA, Leopardi LN, Fischer L, et al. Treatment of unresectable hepatocellular carcinoma with radiolabelled lipiodol. ANZ J Surg. May. 2008;(5):371-6. [pmid: 18380736].
72 Kawaoka T, Aikata H, Takaki S, et al. Transarterial infusion chemotherapy using cisplatin-lipiodol suspension with or without embolization for unresectable hepatocellular carcinoma. Cardiovasc Intervent Radiol. Jul. 2009;(4):687-94. [pmid: 19444503].
73 Leelawat K, Laisupasin P, Kiatdilokrut A, et al. The effect of doxorubicin on the changes of serum vascular endothelial growth factor (VEGF) in patients with hepatocellular carcinoma after transcatheter arterial chemoembolization (TACE). J Med Assoc Thai. Oct. 2008;(10):1539-43. [pmid: 18972897].
74 Liu MD, Uaje MB, Al-Ghazi MS, et al. Use of Yttrium-90 TheraSphere for the treatment of unresectable hepatocellular carcinoma. Am Surg. Nov. 2004;(11):947-53. [pmid: 15586503].
75 Mabed M, Esmaeel M, El-Khodary T, et al. A randomized controlled trial of transcatheter arterial chemoembolization with lipiodol, doxorubicin and cisplatin versus intravenous doxorubicin for patients with unresectable hepatocellular carcinoma. Eur J Cancer Care (Engl). Sep. 2009;(5):492-9. [pmid: 19453695].
76 Maeda N, Osuga K, Mikami K, et al. Angiographic evaluation of hepatic arterial damage after transarterial chemoembolization for hepatocellular carcinoma. Radiat Med. May. 2008;(4):206-12. [pmid: 18509720].
77 Martin RC, Joshi J, Robbins K, et al. Hepatic intra-arterial injection of drug-eluting bead, irinotecan (DEBIRI) in unresectable colorectal liver metastases refractory to systemic chemotherapy: results of multi-institutional study. Ann Surg Oncol. Jan. 2011;18(1):192-8. [pmid: 20740319].
78 Molinari M, Kachura JR, Dixon E, et al. Transarterial chemoembolisation for advanced hepatocellular carcinoma: results from a North American cancer centre. Clin Oncol (R Coll Radiol). Nov. 2006;(9):684-92. [pmid: 17100154].
79 Rand T, Loewe C, Schoder M, et al. Arterial embolization of unresectable hepatocellular carcinoma with use of microspheres, lipiodol, and cyanoacrylate. Cardiovasc Intervent Radiol. May-Jun. 2005;(3):313-8. [pmid: 15886943].
80 Seki A, Hori S, Kobayashi K, et al. Transcatheter arterial chemoembolization with epirubicin-loaded superabsorbent polymer microspheres for 135 hepatocellular carcinoma patients: single-center experience. Cardiovasc Intervent Radiol. Jun. 2011;(3):557-65. [pmid: 20821211].
81 Wu L, Yang YF, Ge NJ, et al. Hepatic arterial iodine-131-labeled metuximab injection combined with chemoembolization for unresectable hepatocellular carcinoma: interim safety and survival data from 110 patients. Cancer Biother Radiopharm. Dec. 2010;(6):657-63. [pmid: 21204759].
82 Zhang JB, Chen Y, Zhang B, et al. Prognostic significance of serum gamma-glutamyl transferase in patients with intermediate hepatocellular carcinoma treated with transcatheter arterial chemoembolization. Eur J Gastroenterol Hepatol. Sep. 2011;(9):787-93. [pmid: 21730869].
83 Kim YJ, Goh PG, Moon HS, et al. Reactivation of tuberculosis in hepatocellular carcinoma treated with transcatheter arterial chemoembolization: A report of 3 cases. World J Radiol. May. 28. 2012;4(5):236-40. [pmid: 22761986].
84 Reso A, Ball CG, Sutherland FR, et al. Rupture and intra-peritoneal bleeding of a hepatocellular carcinoma after a transarterial chemoembolization procedure: a case report. Cases J. 2009;(1):68. [pmid: 19154593].
85 Martin RC nd, Rustein L, et al. Hepatic arterial infusion of Doxorubicin-loaded microsphere for treatment of hepatocellular cancer: a multi-institutional registry. J Am Coll Surg. Oct. 2011;(4):493-500. [pmid: 21856182].
86 Andolino DL, Johnson CS, Maluccio M, et al. Stereotactic body radiotherapy for primary hepatocellular carcinoma. Int J Radiat Oncol Biol Phys. Nov. 2011;15(4):e447-53. [pmid: 21645977].
87 Chan LC, Chiu SK, Chan SL. Stereotactic radiotherapy for hepatocellular carcinoma: report of a local single-centre experience. Hong Kong Med J. Apr. 2011;(2):112-8. [pmid: 21471590].
88 Oh D, do HL, Park HC. Early three-dimensional conformal radiotherapy for patients with unresectable hepatocellular carcinoma after incomplete transcatheter arterial chemoembolization: a prospective evaluation of efficacy and toxicity. Am J Clin Oncol. Aug. 2010;(4):370-5. [pmid: 20142728].
89 Seo YS, Kim MS, Yoo SY, et al. Preliminary result of stereotactic body radiotherapy as a local salvage treatment for inoperable hepatocellular carcinoma. J Surg Oncol. Sep. 2010;1(3):209-14. [pmid: 20740576].
90 Taguchi H, Sakuhara Y, Hige S, et al. Intercepting radiotherapy using a real-time tumor-tracking radiotherapy system for highly selected patients with hepatocellular carcinoma unresectable with other modalities. Int J Radiat Oncol Biol Phys. Oct. 2007;1(2):376-80. [pmid: 17869660].
91 Lencioni R, Crocetti L, Petruzzi P, et al. Doxorubicin-eluting bead-enhanced radiofrequency ablation of hepatocellular carcinoma: a pilot clinical study. J Hepatol. Aug. 2008;(2):217-22. [pmid: 18486261].
92 Morimoto M, Numata K, Kondou M, et al. Midterm outcomes in patients with intermediate-sized hepatocellular carcinoma: a randomized controlled trial for determining the efficacy of radiofrequency ablation combined with transcatheter arterial chemoembolization. Cancer. 2010;116(23):5452-60. [pmid: 20672352].
93 Xu KC, Niu LZ, Zhou Q, et al. Sequential use of transarterial chemoembolization and percutaneous cryosurgery for hepatocellular carcinoma. World J Gastroenterol. Aug. 2009;7(29):3664-9. [pmid: 19653346].
94 Gao F, Gu YK, Fan WJ, et al. Evaluation of transarterial chemoembolization combined with percutaneous ethanol ablation for large hepatocellular carcinoma. World J Gastroenterol. Jul. 2011;14(26):3145-50. [pmid: 21912458].
95 Liao GS, Yu CY, Shih ML, et al. Radiofrequency ablation after transarterial embolization as therapy for patients with unresectable hepatocellular carcinoma. Eur J Surg Oncol. Jan. 2008;(1):61-6. [pmid: 17434711].
96 Park JW, Koh YH, Kim HB, et al. Phase II study of concurrent transarterial chemoembolization and sorafenib in patients with unresectable hepatocellular carcinoma. J Hepatol. Jun. 2012;56(6):1336-42. [pmid: 22314421].
97 Raoul JL, Boucher E, Olivie D, et al. Association of cisplatin and intra-arterial injection of 131I-lipiodol in treatment of hepatocellular carcinoma: results of phase II trial. Int J Radiat Oncol Biol Phys. Mar. 2006;1(3):745-50. [pmid: 16289908].
98 Bouza C, Lopez-Cuadrado T, Alcazar R, et al. Meta-analysis of percutaneous radiofrequency ablation versus ethanol injection in hepatocellular carcinoma. BMC Gastroenterol. 2009;9:31. [pmid: 19432967].
99 Cho YK, Kim JK, Kim MY, et al. Systematic review of randomized trials for hepatocellular carcinoma treated with percutaneous ablation therapies. Hepatology. Feb. 2009;49(2):453-9. [pmid: 19065676].
100 Wang N, Guan Q, Wang K, et al. TACE combined with PEI versus TACE alone in the treatment of HCC: a meta-analysis. Med Oncol. Dec. 2011;28(4):1038-43. [pmid: 20632218].
101 Wang W, Shi J, Xie WF. Transarterial chemoembolization in combination with percutaneous ablation therapy in unresectable hepatocellular carcinoma: a meta-analysis. Liver Int. May. 2010;30(5):741-9. [pmid: 20331507].
102 Yan S, Xu D, Sun B. Combination of Radiofrequency Ablation with Transarterial Chemoembolization for Hepatocellular Carcinoma: A Meta-Analysis. Dig Dis Sci. 2012. May. 15. [pmid: 22585384].
103 Schoppmeyer K, Weis S, Mossner J, et al. Percutaneous ethanol injection or percutaneous acetic acid injection for early hepatocellular carcinoma. Cochrane Database Syst Rev. 2009;(3):CD006745. [pmid: 19588401].
104 Salhab M, Canelo R. An overview of evidence-based management of hepatocellular carcinoma: a meta-analysis. J Cancer Res Ther. Oct-Dec. 2011;7(4):463-75. [pmid: 22269411].
105 Atkins D, Eccles M, Flottorp S, et al. Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. Dec. 22. 2004;4(1):38. [pmid: 15615589].
106 Kennedy A, Nag S, Salem R, et al. Recommendations for radioembolization of hepatic malignancies using Yttrium-90 microsphere brachytherapy: a consensus panel report from the Radioembolization Brachytherapy Oncology Consortium. Int J Radiat Oncol Biol Phys. 2007;68(1):13-23. [pmid: 17448867].