# Introduction

## Background

This comparative effectiveness review (CER) evaluates local hepatic therapies for patients with unresectable primary hepatocellular carcinoma (HCC) who are not candidates for surgical resection or liver transplantation. In the following background section, we describe the epidemiology and staging of HCC as well as currently available treatment strategies. We also discuss the current practice guidelines and the impetus for this review. Finally, the specific Key Questions (KQs) and the analytic framework for this review are presented.

### Condition

Hepatocellular carcinoma (HCC) is the most common primary liver tumor. It is the fifth most common cancer and the third leading cause of cancer death worldwide.1 Overall 5-year survival rates for HCC are less than 10 percent in Europe and the United States.1 The main etiology of HCC is chronic infection with the hepatitis B and hepatitis C viruses. Approximately 4 million individuals in the United States are chronically infected with hepatitis C virus, and the annual incidence rate of HCC among patients with hepatitis C-related cirrhosis is estimated to be between 2 and 8 percent. Unlike most solid tumors, the incidence of and mortality rate due to HCC are projected to increase worldwide in the next 20 years, primarily due to the dissemination of hepatitis C virus infection.2 Other causes include cirrhosis due to any cause (e.g., alcohol), hereditary hemochromatosis and iron overload syndromes, nonalcoholic fatty liver disease, obesity, diabetes, and environmental toxins (e.g., aflatoxin, chewing of betel quid, and contaminated water).3

While there are several causes of HCC, etiology is not an independent prognostic factor for HCC;4,5 rather, the underlying cirrhosis impacts prognosis and treatment decisions. In the United States, most cases of HCC occur in patients with cirrhosis.1 A small proportion, approximately 5 percent, of all HCC cases in Western countries occurs in patients without cirrhosis.6 For patients with early-stage HCC without underlying cirrhosis, surgical resection is the preferred treatment and offers a high probability of a cure. The Barcelona Clinic Liver Cancer (BCLC) guidelines recommend hepatectomy for patients with a single lesion less than 5 cm in size and mild or no underlying cirrhosis.7 In contrast, patients with severe cirrhosis are not considered resectable and receive supportive care instead.7

This report focuses on the approximately 80 percent of patients who are not surgical candidates due to advanced-stage disease at diagnosis, inadequate hepatic reserve to tolerate resection, tumors in unresectable locations, or medical comorbidities that result in a high surgical risk.1

### Classification/Staging of Hepatocellular Carcinoma

Both tumor stage and underlying liver function are key considerations in diagnosis, treatment selection, and prognosis of HCC. The BCLC classification system takes both tumor stage and underlying liver function into account and is widely used as the basis of treatment algorithms in Europe and North America.7 This system considers factors related to tumor stage, liver function, performance status, and cancer-related symptoms. HCC is staged from 0 to D.

Other staging systems are used regionally, such as Okuda staging developed in Japan, American Joint Committee on Cancer (AJCC) TMN staging, Groupe d'Etude et de Traitement du Carcinome Hepatocellulaire (GETCH), Chinese University Prognostic Index (CUPI), Japan Integrated Staging (JIS), and Cancer of the Liver Italian Program (CLIP).8-10 The set of prognostic factors considered in each of these systems varies and includes various measures and combinations of hepatic function, performance status, and tumor characteristics. Given the wide array of prognostic factors across the staging systems, a direct translation from one system to another is inexact. For example, though the BCLC staging system and the Okuda staging system both include a measure of tumor size, the numeric parameters of tumor size differ between the systems. Additionally, the BCLC system takes into account performance status and underlying liver function using Child-Pugh classification, whereas the Okuda system does not and instead includes other factors (presence of ascites and serum levels of albumin and bilirubin). Despite the apparent discrepancies, efforts have been made to designate equivalent stages between the two systems, albeit with some overlap (Table 1).8

Table 1 Comparison of Barcelona Clinic Liver Cancer (BCLC) and Okuda staging systems^*^

BCLC Stage | Performance Status | Tumor Number and Size | Liver Function | Equivalent Okuda Stage
Stage 0: very early | 0 | Single, <2 cm | Child-Pugh A; no portal hypertension and normal bilirubin | I
Stage A: early | NR | NR | NR | NR
A1 | 0 | Single, <5 cm | Child-Pugh A or B; No portal hypertension and normal bilirubin | I
A2 | 0 | Single, <5 cm | Child-Pugh A or B; Portal hypertension and normal bilirubin | I
A3 | 0 | Single, <5 cm | Child-Pugh A or B; Portal hypertension and abnormal bilirubin | I-II
A4 | 0 | 3 tumors, <3 cm | Child-Pugh A or B | I-II
Stage B: intermediate | 0 | Large multinodular | Child-Pugh A or B | I-II
Stage C: advanced | 1-2 | Vascular invasion or extrahepatic spread | Child-Pugh A or B | I-II
Stage D: terminal | 3-4 | Any | Child-Pugh C | III

* Adapted from Grieco et al. 2005.^8^ NR= not reported

### Classification of Underlying Liver Function

The Child-Pugh classification is a commonly used method to assess the prognosis of patients with underlying liver disease. The system employs five clinical factors: total bilirubin, serum albumin, international normalized ratio (INR; measure of clotting tendency of the blood), ascites (accumulation of fluid in the abdomen), and hepatic encephalopathy (declining brain function caused by toxin accumulation in the brain). Each is scored on a scale of 1–3, from lowest to highest severity. Patients are classified as class A, B, or C based on the total score. HCC patients with class A hepatic impairment have the best prognosis and would be candidates for surgical resection, although many would require local hepatic therapies such as ablative, transarterial, and radiotherapies. HCC patients with class B are not candidates for resection and are typically offered transarterial therapy, ablative therapy, radiotherapy, or systemic therapy. Class C patients typically are not candidates for local hepatic therapies, with rare exceptions, and usually receive supportive care. Transplantation can be offered to patients of all Child-Pugh classifications if they meet the listing criteria.7,11

Another scoring system for chronic liver disease is the Model for End-Stage Liver Disease (MELD) score, which is based on serum bilirubin, serum creatinine, and INR. The MELD score ranges from 6 to 40, with a higher score corresponding to a higher severity of hepatic dysfunction. This score serves as a numerical scale for adult liver transplant candidates.12

### Treatment Strategies

Table 2 through Table 4 present the mechanism of action, treatment setting, personnel involved, and specific harms reported for each of the 13 local hepatic therapies (ablative therapies, transarterial embolization therapies, and radiotherapies) included in this review.

Table 2 Local ablative therapies for primary hepatocellular carcinoma reviewed in this report

Treatment Strategy | Mechanism of Cell Death | Setting | Performed By | Specific Harms
Radiofrequency ablation (RFA) | RFA is performed by generating an alternating current between at least two electrodes in the radiofrequency range that generates heat without muscle contraction. The procedure aims to generate tissue temperatures of 90°C–100°C, which produces protein denaturation and coagulative necrosis.16 | The procedure is performed under intravenous (IV) narcotics for the percutaneous, awake approach and does not require a hospital stay. For laparoscopic or open RFA, the procedure is performed under general anesthesia and results in a longer recovery period.17 Each radiofrequency ablation takes approximately 10 to 30 minutes, with additional time required if multiple ablations are performed. The entire procedure is usually completed within 1 to 3 hours.18 | Interventional Radiologist | Possible side effects after RFA therapy include abdominal pain, mild fever, increase in liver enzymes due to damage to the bile ducts, abscess, infection in the liver, skin burns, and bleeding into the chest cavity or abdomen. Serious complications are uncommon, but are possible, including hepatic failure, hydrothorax, bile duct leaks, intraperitoneal bleeding, and tumor seeding (spill of tumor cells and subsequent growth in an adjacent site).18,19
Percutaneous ethanol injection (PEI)/Percutaneous acetic acid injection (PAI) | PEI involves the injection of a high concentration of ethyl alcohol directly into liver tumors with ultrasound guidance.20 Injections into the tissue or into the blood vessel feeding the tissue leads to cell death by destroying cell membranes, modifying the temperature of cellular enzymes, and blocking the blood vessels. PAI is a variation of PEI where the ethyl alcohol solution is approximately 50% acetic acid. Variations in the drug regimen are outside the scope of this review. Therefore, PEI and PAI will be treated as the same intervention. | PEI is performed as either an inpatient (typical in Japan) or an outpatient (e.g., in European countries) procedure. The patient is given IV sedation and analgesia. Each procedure lasts approximately 20–30 minutes and is repeated twice a week until ethanol seems to be injected throughout the lesion.20 | Interventional Radiologist | Common adverse effects include pain, fever, and a feeling of alcohol intoxication. Serious complications are rare and include ascites, right pleural effusion, jaundice, intraperitoneal hemorrhage, hepatic infarction, a transient decrease in blood pressure, seeding of malignant cells in the puncture tracks, hepatic vascular and bile duct injury, liver abscess, and liver necrosis.20
Cryosurgical ablation (Cryoablation) | The mechanism of action is based on the rapid formation of intracellular ice crystals during the freezing process. The procedure uses repetitive freezing and thawing of the tissue to produce necrosis and irreversible tissue damage, which occurs at temperatures between -20°C and -40°C.21,22 | This type of treatment typically does not require a hospital stay if the percutaneous method is used. An open procedure requires an abdominal incision under general anesthesia and results in a longer recovery period. | Interventional Radiologist | Serious complications are uncommon, but are possible, and for cryosurgical ablation include cryoshock phenomenon (acute renal failure, acute respiratory distress syndrome, disseminated intravascular coagulation, and liver failure), myoglobinuria leading to renal failure, bile leakage, hepatic abscess, pleural effusion, consumptive coagulopathy, thrombocytopenia, hepatic iceball fracture, organ failure, and biliary fistula.19,23
Microwave ablation (MWA) | MWA uses high-frequency electromagnetic radiation to create heat through the excitation of water molecules.16 The heat causes thermal damage that leads to coagulation necrosis. | This type of treatment typically does not require a hospital stay if the percutaneous method is used. An open procedure requires an abdominal incision under general anesthesia and results in a longer recovery period. | Interventional Radiologist | Very little has been published about the complications associated with MWA.23 Many patients experience a low-grade fever and pain for a few days following MWA. Major complications include liver abscess, bile duct injury, pleural effusion, intestinal obstruction, infections, bleeding and skin burn, and potential inadvertent injury to adjacent structures.19 23

Table 3 Transarterial embolization therapies for primary hepatocellular carcinoma reviewed in this report

Treatment Strategy | Mechanism of Cell Death | Setting | Performed By | Specific Harms
Transarterial embolization (TAE) | TAE uses selective catheterization and obstruction of the arterial vessel, which supplies blood to the tumor, with an embolizing agent.24 | Most patients can be discharged several hours after treatment with TAE, but if postembolization syndrome occurs, an overnight stay is typically required. | Interventional Radiologist | Side effects differ depending upon the type of embolization used. Common complications reported are postembolization syndrome (fever, pain, extreme fatigue, nausea/vomiting), infection in the liver, hepatic abscess, gallbladder inflammation, and blood clots in the main blood vessels of the liver. Serious complications are uncommon, but they are possible. Embolization also reduces some of the blood supply to the normal liver tissue. This may be dangerous in patients with underlying hepatitis or cirrhosis.25
Transarterial chemo-embolization (TACE) | TACE aims to cause ischemia and involves administering a chemotherapeutic agent directly to the liver tumor. A chemotherapeutic solution (frequently doxorubicin or cisplatin) is suspended in lipiodol (an oily contrast medium retained selectively within the tumor) and is injected via a catheter into the hepatic arteries directly supplying the tumor; simultaneously, the feeding hepatic arteries are obstructed with an embolizing agent. Tumor ischemia raises the drug concentration, extends the retention of the chemotherapeutic agent, and reduces systemic toxicity. | Most patients can be discharged several hours after treatment with TACE, but if postembolization syndrome occurs, an overnight stay is typically required. | Interventional Radiologist | Same as for TAE.
Radioembolization or selective internal radiation therapy (SIRT) | SIRT involves loading radionuclide yttrium-90 into microspheres and placing them within the microvasculature of the liver metastases, thus targeting multiple hepatic metastases in a single procedure.26 The loaded microspheres deliver high, localized doses of β-radiation to the tumor while minimizing radiation exposure to the surrounding tissue.26-28 | Patients are required to undergo a technetium-99m-macro-aggregated albumin (MAA) scan prior to SIRT to assess eligibility.29 The SIRT procedure takes approximately 90 minutes, and patients can typically return home 4 to 6 hours following treatment. | Interventional Radiologist | The side effects will differ depending upon the type of embolization used. The most common complications reported are postembolization syndrome (fever, pain, extreme fatigue, nausea/vomiting), infection in the liver, hepatic abscess, gallbladder inflammation, and blood clots in the main blood vessels of the liver. Serious complications are uncommon, but they are possible.25 Acute toxicity events include gastritis, ulceration, and pancreatitis due to microsphere deposition in vessels serving these organs.29 Radiation-induced liver disease (jaundice, weight gain, painful hepatomegaly, and elevated liver enzymes), thrombocytopenia, encephalopathy, rise in liver function tests, ascites, and hypoalbuminemia.
Drug-eluting beads (DEB) | This novel transarterial embolization system uses a drug-loaded (typically doxorubicin or cisplatin) superabsorbent polymer microsphere to release doxorubicin gradually into the tumor, allowing a longer intratumoral exposure and less systemic exposure to the drug.30 | Most patients can be discharged several hours after treatment, but if postembolization syndrome occurs, an overnight stay is typically required. | Interventional Radiologist | The side effects will differ depending upon the type of embolization used. The most common complications reported are postembolization syndrome (fever, pain, extreme fatigue, nausea/vomiting), infection in the liver, hepatic abscess, gallbladder inflammation, and blood clots in the main blood vessels of the liver. Serious complications are uncommon, but they are possible.25

Table 4 Local radiotherapies for primary hepatocellular carcinoma reviewed in this report^*^

Treatment Strategy | Mechanism of Cell Death | Setting | Performed By | Specific Harms
External-beam three-dimensional conformal radiation therapy (3D-CRT) | This type of radiotherapy uses computer-assisted tomography (CT or CAT) and/or magnetic resonance imaging (MR or MRI), or both to create detailed, 3D representations of the tumor and the surrounding organs. The radiation oncologist uses these computer-generated images to shape radiation beams to the exact size and shape of the tumor, which is intended to spare nearby healthy tissues. | Each treatment lasts only a few minutes, although the setup time usually takes longer. Most often, radiation treatments are given 5 days a week for several weeks. The patient's diagnosis determines the total duration of treatment.31,32 | Radiation oncologist, medical physicist, dosimetrist, radiation therapist, and radiation therapy nurse | Possible side effects of external radiation therapy include: sunburn-like skin problems, nausea, vomiting, and fatigue. These typically diminish posttreatment. Radiation might also make the side effects of chemotherapy worse.25 Radiation-induced liver disease is the major dose limiting toxicity.23
External-beam intensity-modulated radiotherapy (IMRT) | This approach to radiotherapy allows the radiation oncologist to vary both the intensity of a radiation beam and the angle at which it is delivered to the patient. This is intended to deliver a high dose of radiation to a tumor while significantly reducing the dose to surrounding normal tissue. IMRT offers a better defined radiation dose over traditional 3D-CRT. | Same as 3D-CRT, but IMRT requires slightly longer daily treatment times and additional planning and safety checks before the patient can start the treatment.33 | Radiation oncologist, medical physicist, dosimetrist, radiation therapist, and radiation therapy nurse | Same as for 3D-CRT.
Stereotactic body radiation therapy (SBRT) | This type of external-beam radiation therapy delivers a high dose of radiation with high targeting accuracy to an extracranial target within the body in either a single dose or a small number of dose fractions.34 | SBRT typically consists of one to five treatment sessions over the course of 1 to 2 weeks.35 | Radiation oncologist, medical physicist, dosimetrist, radiation therapist, and radiation therapy nurse | Same as above for 3D-CRT and IMRT.
Hypofractionated proton beam therapy | This is a type of external-beam radiation therapy that delivers high doses of radiation to the tumor target while simultaneously reducing the number of photons reaching normal surrounding tissue, delivered in fewer sessions of larger dose fractions than are delivered in standard regimens.34 | Proton beam therapy is performed typically on an outpatient basis. For most tumor sites, the average course of treatment is usually 5 to 7 weeks, with varying length of each treatment depending on the tumor type and stage. The delivery of the proton beam lasts only 1 minute.35 | Radiation oncologist, radiation physicist, dosimetrist, immobilization specialist, radiation therapy nurse | Same as above for 3D-CRT, IMRT, and SBRT.
Intraluminal brachytherapy | This type of radiotherapy places a radiation source within the body, allowing the delivery of higher doses of radiation directly to a specific tumor.20-22 Brachytherapy can be administered as a permanent or temporary treatment. | In permanent brachytherapy, a radioactive “seed” is permanently implanted in the tumor. Seeds may also be implanted at regular intervals. In temporary brachytherapy, treatments may be delivered at a high dose-rate (HDR) in 10 to 20 minutes per session or at a low dose-rate (LDR) in 20 to 50 hours. HDR brachytherapy is usually an outpatient procedure in which the treatment is repeated two times a day for up to 10 separate treatments in 1 or more weeks. LDR brachytherapy, an inpatient procedure, delivers radiation at a continuous rate in 1 to 2 days. Pulsed dose-rate (PDR) brachytherapy delivers radiation in periodic pulses (usually 1 per hour) rather than continuously.36 | Radiation oncologist, medical physicist, dosimetrist, radiation therapist, radiation therapy nurse, and in some cases, a surgeon | Brachytherapy typically causes fewer side effects than does external-beam radiation.37 39Patients may experience tenderness and swelling in the treatment area and other symptoms depending on the site of brachytherapy and can resume normal activities within days or weeks of brachytherapy.

* The radiotherapy presented in this report is focused on focal treatment of the lesion or lesions and not whole liver irradiation.

### Potential Benefits and Drawbacks of Local Hepatic Therapies

Several patient and institutional factors may dictate the choice of local hepatic therapy for particular patients. Patient factors such as vascular anatomy, proportion of liver parenchyma involved with tumor, presence of shunts (e.g., pulmonary shunting), and performance status may influence the decision to use local hepatic therapies such as radioembolization and chemoembolization. For example, in patients with multifocal disease throughout both hepatic lobes, external-beam radiation may not be optimal due to radiation toxicity.

Ablative therapies such as radiofrequency ablation (RFA) and external beam radiation strategies are typically used in patients with unifocal or limited multifocal disease, whereas transarterial strategies such as chemoembolization (TACE) and radioembolization (RE) are typically offered to patients with more advanced, multifocal disease.7,11 When examining the comparative efficacy of local hepatic therapies it is important to establish that patient groups are comparable. In general, patients treated with ablative therapies and those treated with transarterial strategies represent two distinct patient populations, and as a result when considering comparisons for this review we compared only ablative therapies to one another, embolization therapies to one another, and external-beam therapies compared to one another. TACE, RE, and RFA are performed by an interventional radiologist experienced in these techniques, though RFA can also be performed by surgeons. External-beam radiation is widely available at most centers;13 however, it may not be the best treatment option for some patients, such as those who may be candidates for other modalities such as RE.

Discussions in the literature of the potential benefits or harms from any single local hepatic therapy for a given patient group are limited in their usefulness. In this report (KQ3 below), we will review differences in comparative effectiveness of various local hepatic therapies in patients with unresectable HCC for specific patient and tumor characteristics, such as age, sex, disease etiology, and Child-Pugh score.

The National Comprehensive Cancer Network guidelines state that local hepatic therapies should not be used in place of liver resection or transplantation for patients who meet surgical criteria.14 The National Institutes of Health consensus recommendation suggests the use of locoregional therapies for selected patients with HCC confined to the liver and whose disease is not amenable to resection or transplantation.15 The existing guidelines do not provide specific guidance on the comparative effectiveness of the therapies. Providers and patients faced with treatment decisions need comparative evidence on which to base these decisions.

## Scope and Key Questions

### Scope of the Review

The objective of this systematic review is to examine the comparative effectiveness and harms of various local hepatic therapies for unresectable primary HCC in patients who meet all of the following criteria:

- No extrahepatic spread
- No portal invasion
- Child-Pugh class A or B disease
- Eastern Cooperative Oncology Group (ECOG) status ≤1 and/or
- BCLC stage A or B, or equivalent

Candidates for liver resection or transplant, as well as patients with advanced and terminal disease, are outside the scope of this review, as the treatment options for these patients are vastly different. Children are also excluded from this review as their disease presentation and prognosis are quite different from those of adults.

Nonsurgical candidates eligible for local hepatic therapies are a heterogeneous group. Patient selection criteria are critical for attaining optimal outcomes with the most appropriate local hepatic therapy, and patient selection for these procedures depends on how “medically or technically inoperable patients” are defined. We reviewed studies with any length of followup and in both inpatient and outpatient settings.

Table 5 lists the relevant populations, interventions, comparators, outcomes timeframes of assessment, and settings (PICOTS) relevant for this review.

Table 5 PICOTS (population, intervention, comparator, outcome, timing, and setting) for the Key Questions

PICOTS | KQ1 | KQ2 | KQ3
Population | Adults with HCC who are candidates for local hepatic therapies, but not candidates for surgical resection or transplantation, who meet the following criteria:; - No extrahepatic spread; - No portal invasion; - Child-Pugh class A or B disease; - ECOG status ≤1; and/or; - BCLC stage A or B, or equivalent; This includes:; - Patients whose disease is unresectable due to medical comorbidities, such as low hepatic reserve, cardiac insufficiency, or poor performance status; - Patients whose disease is unresectable due to tumor characteristics; - Patients whose disease has recurred after resection | Same as KQ1 | Subgroups of patients in KQ1 stratified by age, gender, disease etiology, and Child-Pugh class
Intervention | Ablation; - Radiofrequency ablation (RFA); - Percutaneous ethanol injection (PEI)/Percutaneous acetic acid injection (PAI); - Cryoablation; - Microwave ablation (MWA); Embolization; - Transarterial embolization (TAE) or transarterial ethanol ablation (TEA); - Transarterial chemoembolization (TACE); - Radioembolization (RE) or Selective internal radiation therapy (SIRT); - Drug-eluting beads (DEBs); Radiotherapy; - External-beam with 3D conformal radiotherapy (3D-CRT) or intensity-modulated radiotherapy (IMRT); - Stereotactic body radiation therapy (SBRT); - Hypofractionated proton beam therapy; - Intraluminal brachytherapy; Combinations of the interventions listed above were also included in the review, such as TACE plus RFA. | Same as KQ1 | Same as KQ1
Comparator | Therapies were compared with other liver directed therapies within the following categories of intervention:; 1. Ablative therapies compared with other ablative therapies; 2. Transarterial therapies compared with other transarterial therapies; 3. Radiotherapies compared with other radiotherapies; 4. Combinations of liver directed therapies including but not limited to TACE plus Cryoablation and TAE plus RFA | Same as KQ1 | Same as KQ1
Outcome | - [underlined: Final health outcomes]: Survival, quality of life; - [underlined: Intermediate outcomes]: Time to progression, local recurrence, length of stay, days of missed work | - [underlined: Adverse outcomes]: hepatic abscess, hepatic hemorrhage, biloma, steatohepatitis, injury to adjacent organ(s), liver failure, infection, increased alkaline phosphatase, increased bilirubin, increased transaminases, and rare adverse events | Same as KQ1
Timing | The relevant periods occur at the time of treatment through followup over months or years. | Same as KQ1 | Same as KQ1
Setting | Inpatient and outpatient | Same as KQ1 | Same as KQ1

Abbreviations: HCC = hepatocellular carcinoma; KQ = Key Question; ECOG = Eastern Cooperative Oncology Group; BCLC = Barcelona Clinic Liver Cancer.

### Key Questions

KQ1. What is the comparative effectiveness of the various local hepatic therapies in patients with HCC who are not otherwise candidates for surgical resection or transplantation with no evidence of extrahepatic disease regarding survival and quality of life?

KQ2. What are the comparative harms of the various local hepatic therapies in patients with HCC who are not otherwise candidates for surgical resection or transplantation with no evidence of extrahepatic disease regarding adverse events?

KQ3. Are there differences in comparative effectiveness of various local hepatic therapies in patients with HCC who are not otherwise candidates for surgical resection or transplantation for specific patient and tumor characteristics, such as age, gender, disease etiology, and Child-Pugh score?

#### Analytic Framework

We developed the analytic framework shown in Figure 1 based on clinical expertise and refined it with input from our Key Informants and Technical Expert Panel (TEP). The diagram is a revised version of those posted with the review protocol; the revisions are intended to make the core elements of our final analyses clearer, given the actual literature available for the review. Figure 1 outlines potential areas where patients who are not eligible for liver resection or transplantation are using local hepatic therapy. These therapies may affect intermediate health outcomes such as TTP, local recurrence, LOS, and days of work missed as well as final health outcomes of overall survival and quality of life (KQ1 and KQ3). In addition, we attempted to assess the occurrence of adverse effects of local hepatic therapies (KQ2).

Figure 1 Analytic framework for comparative effectiveness of local therapies for treatment of unresectable primary hepatocellular carcinoma

Abbreviations: HCC = hepatocellular carcinoma; 3D-CRT = External-beam three-dimensional conformal radiation therapy; IMRT = External-beam intensity-modulated radiotherapy.

Figure 1 depicts the potential impact of using liver-directed therapies on both intermediate outcomes and final health outcomes for key questions one and two. Direct evidence of the impact of the various therapies on health outcomes, including adverse effects, is shown by solid lines. Intermediate outcomes—such as time to progression and local recurrence—may have an association with the final health outcomes (dotted line).

## Organization of This Report

The Methods chapter describes our processes, including our search strategy, inclusion and exclusion criteria, approach to abstract and full text review, methods for extraction of data into evidence tables, and method for compiling evidence. In addition, we describe the procedures for evaluating bias in individual studies and describing the strength of the body of evidence.

The Results chapter presents the findings of the literature search and the review of the evidence by KQ, synthesizing the findings by strategies.

The Discussion chapter presents the key findings and discusses their relationship to other published findings and the applicability of the findings of this report. We also outline challenges for future research in the field.

The report includes a number of appendices to provide further detail on our methods and the studies assessed. The appendixes are as follows:

- Appendix A: Search Strategies
- Appendix B: Contacted Authors
- Appendix C: DistillerSR Screening and Extraction Forms
- Appendix D: Evidence Tables
- Appendix E: Abbreviations and Acronyms
- Appendix F: Excluded Studies

## Uses of This Report

We anticipate this report will be of primary interest to health care providers who care for patients with HCC, particularly those patients who are not candidates for resection or liver transplantation. Treatment is generally provided by medical oncologists or interventional radiologists. This report can bring providers up to date on the current state of the evidence, and it provides a quality assessment of the risk of bias in individual studies as well as the strength of the body of evidence for each of the KQs. It will be of interest to patients with unresectable HCC—as well as their families—who are concerned about their health and facing treatment choices.

This presentation of the evidence is also of value to researchers who can obtain a concise analysis of the current state of knowledge in the field and where there are gaps in knowledge. This report can help prepare them to conduct research in areas that are needed to advance research methods, understand patient selection, and optimize the effectiveness and safety of treatment for unresectable HCC.