# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Anne Covey, M.D.
  Department of Radiology
  Memorial Sloan-Kettering Cancer Center
  New York, NY
- William Harris, M.D.
  Assistant Professor
  University of Washington School of Medicine
  Seattle, WA
- Jin Hyoung Kim, M.D.
  Asan Medical Center
  University of Ulsan College of Medicine
  Seoul, South Korea
- Ravi Murthy, M.D.
  Professor
  MD Anderson Cancer Center
  Houston, TX