# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Michael Choti, M.D., M.B.A.
  Professor of Surgery
  Johns Hopkins University
  Baltimore, MD
- Steven Curley, M.D.
  Professor of Surgical Oncology
  MD Anderson Cancer Center
  Houston, TX
- Jean-Francois Geschwind, M.D.
  Professor of Radiology, Surgery and Oncology
  Director, Vascular and Interventional Radiology
  Director, Interventional Radiology Center
  Johns Hopkins University
  Baltimore, MD
- Ahmed Kaseb, M.D.
  Assistant Professor
  Gastrointestinal Medical Oncology
  MD Anderson Cancer Center
  Houston, TX
- Robert Lewandowski, M.D.
  Assistant Professor of Radiology
  Northwestern University Feinberg School of Medicine
  Chicago, IL
- John Yao, M.D.
  Senior Medical Director
  Blue Shield of California
  Lodi, CA