# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Raymond Chung, M.D.
  Director of Hepatology
  Massachusetts General Hospital
  Boston, MA
- David Geller, M.D.
  Professor of Surgery
  University of Pittsburgh
  Pittsburgh, PA
- Marcia K. Horn, J.D.
  Patient Advocate
  International Cancer Advocacy Network (ICAN)
  Phoenix, AZ
- Alan P. Venook, M.D.
  Professor of Clinical Medicine
  University of California
  San Francisco, CA