# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Claudia Bonnell, R.N., M.L.S.; Stacey C. Chapman Tobin, Ph.D., E.L.S.; Lisa Garofalo, B.A.; Jenna Khan, M.P.H.; Lisa Sarsany, M.A.; and Kathleen Ziegler, Pharm.D.