# Discussion

## Key Findings and Strength of Evidence

This review addressed the comparative effectiveness of local hepatic therapy for the treatment of unresectable HCC in patients who are not otherwise eligible for transplantation and do not have extrahepatic spread. Forty-eight studies met our inclusion criteria and included six RCTs, four nonrandomized comparative studies, 35 observational case series, and three case reports.

We assessed the strength of evidence for our primary health outcomes of overall survival and quality of life; the intermediate outcomes of TTP, local recurrence, LOS, and days of work missed for KQ1; and adverse events for KQ2 (Table 91). In addition, we reviewed the effect of patient subgroups on the comparative effectiveness of the included comparisons for our population of interest for KQ3.

Table 91 Summary GRADE strength of evidence for KQ1 and KQ2

Key Question | Strength of Evidence | Conclusion
Key Question 1. What is the comparative effectiveness of the various liver-directed therapies in patients with HCC who are not otherwise candidates for surgical resection or transplantation with no evidence of extrahepatic disease regarding survival and quality of life?
RFA to PEI/ PAI
Overall Survival | Moderate | One good-quality RCT (n=139), and two fair quality RCTs (n=157 and n=187) assessed 3-year overall survival after treatment with RFA or PEI/PAI. In a meta-analysis, the pooled risk difference of 0.16 (95% CI 0.03 to 0.28) was statistically significant in favor of RFA. The heterogeneity in this pool of studies was moderate (I^2^=48%).
Quality of Life | Insufficient | Quality of life was not reported in any of the comparative studies.
Outcomes Related to Progression | Low | Two fair-quality RCTs reported outcomes related to progression (n=157 and n=187). One study reported cancer-free survival (from time of study treatment to local tumor progression, extrahepatic metastases, additional new HCC recurrence, or death). The 3-year cancer-free survival rate was 37%, 17%, and 20% in the RFA, PEI, and higher-dose PEI groups respectively. The RFA group had a significantly higher rate than the two PEI groups (RFA vs. conventional PEI: risk ratio=0.38; 95%CI, 0.14 to 0.88, p=0.019; RF vs. higher-dose PEI: risk ratio=0.41; 95%CI, 0.22 to 0.89, p=0.024). In the other RCT, 3-year cancer-free survival was 43%, 21%, and 23% in the RFA, PEI and PAI groups respectively (RFA vs. PEI: risk ratio=0.31; 95% CI, 0.18 to 0.85, p=0.038; RFA vs. PAI: risk ratio=0.26, 95% CI, 0.13 to 0.81, p=0.041).
Local Recurrence/Local Tumor Progression | Low | Two fair-quality RCTs (n=157 and n=187) reported local tumor progression (defined as the presence of an enhanced tumor on CT, corresponding to the initial target tumor). In one RCT, the RFA group had a significantly lower rate than in the PEI groups (RFA vs. conventional PEI: risk ratio=0.37; 95% CI, 0.12 to 0.76, p=0.012; RFA vs. higher-dose PEI: risk ratio=0.49; 95% CI, 0.23 to 0.92, p=0.037). This study assessed local recurrence in all randomized patients. In the second RCT, the local recurrence rate was significantly lower in the RFA group compared with the PEI (risk ratio=0.35; 95% CI, 0.21 to 0.89, p=0.012) and PAI (risk ratio=0.41; 95% CI, 0.23 to 0.91, p=0.017) groups. This study assessed local recurrence only for patients achieving complete tumor necrosis following treatment.
Length of Stay | Low | LOS was reported in two fair-quality RCTs (n=157 and n=187). Both studies reported LOS only for a subset of patients who achieved complete tumor necrosis. In the first study, the RFA group had a significantly longer mean LOS than the conventional PEI group (4.4 days ± 1.8 vs. 1.6 days ± 0.3, p<0.01). In the second trial, the RFA group had a significantly longer LOS than either the PEI group or the PAI group (4.2 days ± 1.9, 1.7 days ± 0.4, 2.2 days ± 0.6, respectively, all p<0.01).
Days of Missed Work | Insufficient | Days of missed work was not reported in any of the comparative studies.
DEB to TAE
Overall Survival | Insufficient | One poor-quality RCT (n=84) reported that there was no statistically significant difference in 1-year overall survival between the groups (85.3% and 86%, respectively, p-value not reported).
Quality of Life | Insufficient | Quality of life was not reported in any of the comparative studies.
Outcomes Related to Progression | Insufficient | One poor-quality RCT (n=84), reported TTP, defined as the time from the first treatment until progression which consisted of as local recurrence, new lesions, or a combination of both (overall recurrence). The mean TTP was longer in the DEB group (10.6 ± 2.4 months) than the TAE group (9.1 ± 2.3 months; p=0.008).
Local Recurrence/Local Tumor Progression | Insufficient | One poor-quality RCT (n=84), reported local recurrence as the number of patients with local recurrence out of the total number of patients evaluated at 6, 9, and 12 months: 1/41 (2.4%), 6/40 (15%), and 11/35 (31.4%) in the DEB group and 4/43 (9.3%), 19/41 (46.3%), and 21/37 (56.8%) in the TAE group, respectively.
Length of Stay | Insufficient | LOS was not reported in any of the comparative studies.
Days of Missed Work | Insufficient | Days of missed work was not reported in any of the comparative studies.
DEB to TACE
Overall Survival | Insufficient | One fair-quality RCT (n=67) reported the 2-year overall survival rates were not significantly different between the groups (83.6% in the conventional TACE group and 86.8% in the DEB group, p=0.96). One poor-quality prospective case control study (n=105) reported no significant difference in overall median survival between the groups (11.4 months after enrollment in the TACE group vs. 18.4 months after enrollment in the DEB group).
Quality of Life | Insufficient | Quality of life was not reported in any of the comparative studies.
Outcomes Related to Progression | Insufficient | One fair-quality RCT (n=67) reported time to radiologic progression (defined as the time from study treatment to disease progression). The median time had not been reached, the mean expected time-to-radiographic-progression was not significantly different between the groups (24.2 months after TACE vs. 15.6 months after DEB, p=0.64). One poor-quality prospective case control study (n=105) reported relapse-free survival (defined as the time between the embolization to any relapse and the appearance of a second primary cancer or death). The median relapse-free survival was not significantly different between the groups (8.4 months after TACE vs. 13.1 months after DEB).
Local Recurrence/Local Tumor Progression | Insufficient | One fair-quality RCT (n=67) assessed the median expected time to local recurrence within the initial target lesions and found the difference is nonsignificant (12.8 months after TACE and 8.9 months after DEB, p=0.46).
Length of Stay | Insufficient | One fair-quality RCT (n=67) reported no significant difference between the conventional TACE and DEB groups in terms of mean LOS (6.8 days vs. 5.9 days, p=0.26). One poor-quality prospective case control study reported a significant difference in median LOS between TACE and DEB (2.3 days vs. 4.7 days, p<0.0001).
Days of Missed Work | Insufficient | Days of missed work was not reported in any of the comparative studies.
RFA to TACE
Overall Survival | Insufficient | One poor-quality retrospective cohort study (n=91) reported overall survival. Two-year survival for RFA compared with TACE was 72% and 58%, respectively, which was not found to be statistically different (p=0.21).
Quality of Life | Insufficient | Quality of life was not reported in any of the comparative studies.
Outcomes Related to Progression | Insufficient | One poor-quality retrospective cohort study (n=91) reported time to disease progression. This was calculated from the date of disease response to treatment to the date of disease progression. Disease progression occurred in 35 patients (88%) in the TACE group and 36 patients (71%) in the RFA group. The median time to disease progression was 9.5 months (range: 1.0 to 47.3 months) in patients treated with TACE and 10.4 months (range: 1.0 to 42.7 months) in patients treated with RFA (p=0.95).
Local Recurrence/Local Tumor Progression | Insufficient | One poor-quality retrospective cohort study (n=91) reported the local recurrence rate was 14% (n=7) in the RFA group. The authors did not report local recurrence rate in the TACE group.
Length of Stay | Insufficient | LOS was not reported in any of the comparative studies.
Days of Missed Work | Insufficient | Days of missed work was not reported in any of the comparative studies.
TACE to TEA
Overall Survival | Insufficient | One poor-quality retrospective case control study (n=60) reported there was a significant difference in the 2-year survival rates (measured from the date of first study treatment) of 43.3% and 80% between the TACE and TEA groups, respectively (p=0.0053).
Quality of Life | Insufficient | Quality of life was not reported in any of the comparative studies.
Outcomes Related to Progression | Insufficient | One poor-quality retrospective case control study (n=60) assessed progression-free survival, measured from the date of first study treatment to the date of death or last followup, and reported a nonsignificant difference between the TACE and TEA groups (46% at 1 year and 42.5% at 2 years for TACE and 69.8% at 1 year and 58.8% at 2 years for TEA, p=0.0588).
Local Recurrence/Local Tumor Progression | Insufficient | Local recurrence/local tumor progression was not reported in any of the comparative studies.
Length of Stay | Insufficient | LOS was not reported in any of the comparative studies.
Days of Missed Work | Insufficient | Days of missed work was not reported in any of the comparative studies.
RFA to RFA-TACE
Overall Survival | Insufficient | One low-quality RCT (n=37) reported no statistically significant difference in the 1-, 2-, and 3-year survival rates between the two groups (p=0.369).
Quality of Life | Insufficient | Quality of life was not reported in any of the comparative studies.
Outcomes Related to Progression | Insufficient | Outcomes related to progression were not reported in any of the comparative studies.
Local Recurrence/Local Tumor Progression | Insufficient | One low-quality RCT (n=37) reported a significant difference in local tumor progression rate (undefined) at the end of 1, 2, and 3 years between the TACE-RFA combination therapy group and the RFA monotherapy group (6% vs. 39%, respectively, p=0.012).
Length of Stay | Insufficient | LOS was not reported in any of the comparative studies.
Days of Missed Work | Insufficient | Days of missed work was not reported in any of the comparative studies.
TACE to TACE-Cryoablation
Overall Survival | Insufficient | One poor-quality retrospective cohort study (n=420) reported that 1- to 3-year survival outcomes were not statistically different between groups. However, in years 4 and 5, the combination therapy group showed a superior survival outcome (p=0.001).
Quality of Life | Insufficient | Quality of life was not reported in any of the comparative studies.
Outcomes Related to Progression | Insufficient | Outcomes related to progression were not reported in any of the comparative studies.
Local Recurrence/Local Tumor Progression | Insufficient | One poor-quality retrospective cohort study (n=420) reported the local recurrence rate at the ablated area was 17% for all patients, and 23% and 11% for the cryoablation and the sequential TACE-cryoablation groups, respectively (p=0.001).
Length of Stay | Insufficient | LOS was not reported in any of the comparative studies.
Days of Missed Work | Insufficient | Days of missed work was not reported in any of the comparative studies.
Key Question 2. What are the comparative harms of the various liver-directed therapies in patients with HCC who are not otherwise candidates for surgical resection or transplantation with no evidence of extrahepatic disease regarding adverse events?
RFA to PEI/ PAI | Insufficient | None of the 3 RCTs comparing RFA and PEI/PAI reported the following AEs: hepatic abscess, hepatic hemorrhage, biloma, steatohepatitis, injury to adjacent organs, liver failure, and infection. Due to the limited amount of data, the strength of evidence is insufficient to evaluate adverse events for RFA compared with PEI/PAI for the treatment of patients with unresectable HCC who are not otherwise candidates for surgical resection or transplantation with no evidence of extrahepatic disease
DEB to TAE | Insufficient | In one poor-quality RCT (n=84), the authors reported hepatic abscess in 2 (4.8%) and 1 (2.3%) patients in the DEB and TAE groups, respectively, and liver failure in 2 patients in each group. The study authors did not report on the following AEs: hepatic hemorrhage, biloma, steatohepatitis, injury to adjacent organs, infection, increased liver enzymes (transaminases, bilirubin, alkaline phosphatase), and rare adverse events.
DEB to TACE | Insufficient | One fair-quality RCT (n=67) reported liver failure in 1 patient (3%) receiving TACE and none in the DEB group. This RCT also reported significant (p<0.0001) increases in ALT and bilirubin levels compared with baseline. Increase of ALT was significantly higher in the TACE group than in the DEB group (p=0.007). Increased bilirubin was not different between groups. The study did not report on the following AEs: hepatic abscess, hepatic hemorrhage, biloma, steatohepatitis, injury to adjacent organs, infection, and rare adverse events. One poor-quality prospective case control study (n=105) reported no significant difference in mean baseline AST values between the TACE and DEB groups (109±12 IU vs. 116±31 IU). After the procedures the difference between the mean AST values became statistically significant (805±125 IU for TACE vs. 238±57 IU for DEB, p<0.05). Increases in the ALT and LDH levels were observed for 9 days and at 4 days for the TACE and DEB groups, respectively.
RFA to TACE | Insufficient | One poor-quality retrospective cohort study (n=91) reported that liver failure was observed in 1 (2%) and 2 (5%) patients in the RFA and TACE groups, respectively. The study did not report on the following AEs: hepatic abscess, hepatic hemorrhage, biloma, steatohepatitis, injury to adjacent organs, infection, increased liver enzymes (transaminases, bilirubin, alkaline phosphatase), and rare adverse events.
TACE to TEA | Insufficient | One poor-quality retrospective case series (n=60) did not report adverse events.
RFA to RFA-TACE | Insufficient | No comparative studies reported on adverse events of interest.
TACE to TACE-Cryoablation | Insufficient | One poor-quality retrospective cohort study (n=420) reported no observed events of hepatic hemorrhage or liver failure. Hepatic abscess, biloma, steatohepatitis, injury to adjacent organs, infection, increased liver enzymes (transaminases, bilirubin, alkaline phosphatase), and rare adverse events were not reported.
Key Question 3. Are there differences in comparative effectiveness of various liver-directed therapies in patients with HCC who are not otherwise candidates for surgical resection or transplantation for specific patient and tumor characteristics, such as age, gender, disease etiology, and Child-Pugh score?
RFA to PEI/ PAI: Age | Insufficient | None of the 3 RCTs reported subgroup analysis by age.
RFA to PEI/ PAI: Sex | Insufficient | None of the 3 RCTs reported subgroup analysis by sex.
RFA to PEI/ PAI: Disease Etiology | Insufficient | None of the 3 RCTs reported subgroup analysis by disease etiology (e.g., HBV, HCV).
RFA to PEI/ PAI: HCC Stage | Insufficient | None of the 3 RCTs reported subgroup analysis by HCC stage (e.g., BCLC stage A or B).
RFA to PEI/ PAI: Child-Pugh Class (Overall Survival) | Insufficient | One RCT (n=139) found a nonsignificant difference in overall survival between the RFA and PEI groups among patients in Child-Pugh class A (hazard ratio=0.67; 95% CI, 0.25 to 1.80; p=0.43).
RFA to PEI/ PAI: Lesion Size (Overall Survival) | Low | One RCT (n=139) found a nonsignificant difference in overall survival between the RFA and PEI groups among patients HCC lesions >2 cm in diameter (hazard ratio=0.62; 95% CI, 0.28 to 1.36; p=0.23). One RCT (n=157) found that the overall survival rate was significantly higher in the RFA group compared with the PEI group (p=0.032) and the PAI group (p=0.027) among patients with HCC lesions 2–3 cm in size. Among patients with smaller HCC lesions (1–2 cm), no significant difference between treatment groups was seen. One RCT (n=187) found that the overall survival rate was significantly higher in the RFA group compared with the conventional PEI group (p<0.03) and the higher-dose PEI group (p<0.04) among patients with HCC lesions 3.1–4 cm in size. Among patients with smaller HCC lesions (1–2 cm and 2.1–3 cm), no significant difference between treatment groups was seen.
RFA to PEI/ PAI: Lesion Size (Cancer-free Survival) | Insufficient | One RCT (n=187) found that the 3-year cancer-free survival of the RFA group was significantly higher than both PEI (p=0.031) and PAI (p=0.035) groups when lesions size was between 2 to 3 cm. This difference was not significant at smaller lesion sizes (1 to 2 cm) or earlier cancer-free survival times.
RFA to PEI/ PAI: Lesion Size (Local Recurrence Rate) | Insufficient | One RCT (n=187) found that local recurrence rate was lower in the RFA group compared with the PEI group (p=0.009) and PAI group (p=0.011) among the smaller HCC lesion subgroup, but not in the larger HCC lesion subgroup.
RFA to PEI/ PAI: Multifocal HCC | Insufficient | One RCT (n=139) reported a nonsignificant difference in overall survival between the RFA and PEI groups among patients with multifocal HCC (hazard ratio=0.48; 95% CI, 0.16 to 1.43; p=0.19).

Abbreviations: ALT = alanine aminotransferase; BCLC= Barcelona Clinic Liver Cancer staging classification; CI= confidence interval; DEB = drug-eluting beads; HBV= hepatitis B virus; HCC= hepatocellular carcinoma; HCV= hepatitis C virus; LOS= length of stay; PAI = percutaneous acetic acid infusion; PEI = percutaneous ethanol infusion; RCT= randomized controlled trial; RFA = radiofrequency ablation; TAE = transarterial embolization; TACE = transarterial chemoembolization; TEA = transarterial ethanol ablation; TTP = time to progression.

For the comparison of RFA to PEI/PAI, three RCTs50-52 were pooled in a meta-analysis (Figure 3), and risk differences were calculated. The pooled estimate was 0.16 (95 percent confidence interval [CI], 0.03 to 0.28), a statistically significant result that favored RFA. The wide range of effect across the three trials and a moderate level of statistical heterogeneity in this pool of studies (I^2^=48 percent) led to the classification of the results as inconsistent. We judged the strength of the body of evidence on overall survival in favor of RFA compared with PEI/PAI as moderate. The strength of the body of evidence was downgraded from high, the starting point when multiple RCTs are available, to moderate for the lack of consistency in the results across studies. In addition to overall survival, two RCTs51,52 reported on the outcomes of TTP, local control, and LOS. Due to the lack of blinding, the risk of bias was high, the results were consistent and precise, and all three are indirect measures of a final health outcome. Based on the high risk of bias and indirect measurement, we judged the strength of evidence on TTP and local control in favor of RFA compared with PEI/PAI to be low. Also based on the high risk of bias due to a lack of blinding, the strength of evidence is graded low for a longer LOS following treatment with RFA compared with PEI/PAI. All three RCTs50-52 performed subgroup analyses to determine if overall survival was superior among specific patient subgroups. There is a low strength of evidence to support increased overall survival for RFA compared with PEI/PAI in patients with larger lesions (defined variably as >2cm, 2-3cm, and 3.1-4cm) with a high risk of bias. The evidence is insufficient to assess the effects lesion size on other outcomes of interest in this report and of other patient subgroups on any outcome of interest in this report.

We judged the strength of evidence to be insufficient to draw conclusions for effectiveness outcomes (overall survival, quality of life, disease progression, local recurrence, LOS, and days of work missed) and for adverse events for patients considered for all other comparisons.

Data were judged to be insufficient due to high risk of bias, imprecision of estimates, and lack of comparative data for some outcomes (e.g., quality of life, days of work missed).

Evaluation of comparative effectiveness requires an intervention and a comparator. Case-series do not use comparators. Therefore, comparative effectiveness cannot be assessed using this type of literature. Further, factors that may affect the effectiveness of the interventions within these populations were not controlled for in the included studies. Control may be achieved either though randomized design or statistically though careful adjustment in the analysis. Studies that aim to determine the effectiveness or comparative effectiveness of local treatment for unresectable HCC should use randomized designs. If randomization is not possible, care should be taken to control for covariates such as size and number of hepatic lesions and performance status through regression analysis.

### Findings in Relationship to What Is Already Known

There is a large range of unique comparisons of various local hepatic therapies for HCC. We are not aware of any systematic review that has examined all comparisons. We identified seven previously published comparative systematic reviews, each examining a single comparison of local hepatic therapies. Two systematic reviews compared RFA to PEI,98,99 three compared TACE-percutaneous ablation (PA; either RFA or PEI) to RFA or TACE monotherapy,100-102 and one compared PEI to PAI.103

Consistent with our findings, the three systematic reviews 98,99,104comparing the ablative therapies RFA and PEI found that RFA demonstrated a significantly better overall survival rate than PEI. These reviews included the three RCTs that met the inclusion criteria for our evidence review, in addition to one or more trials that were not included in this review due to differences in inclusion criteria. The review by Bouza et al.98 included three additional trials in which the study intervention was given prior to the year 2000 or the patient sample included those who refused surgical treatment of HCC, both of which are included in our exclusion criteria. The reviews by Cho et al.99 and Salhab et al.104 included patients refusing surgery in one and two trials, respectively. The pooled patient population in these two systematic reviews was similar to the population for this comparison in our review, that is, early stage HCC patients with up to three nodules less than 3 or 4 cm in size.

The three systematic reviews of TACE-PA combination therapy 100-102 included studies of varying patient populations that were collectively broader than that included in our evidence review. For example, the reviews included studies in patients with more advanced disease or those with unclear Child-Pugh status, as well as studies in which the treatment was given prior to 2000. As such, these reviews included studies that reported comparisons not examined in our review (e.g., TACE-PEI vs. TACE). However, given the heterogeneity across studies and the paucity of high-quality comparative data from randomized clinical trials, the overall strength of evidence is insufficient to permit conclusions regarding these comparisons. Comparing RFA-TACE combination therapy to RFA monotherapy in a meta-analysis, Yan et al.102 reported that the combination therapy was associated with higher survival rates. However, the majority of included studies in that review were of low quality with small sample sizes, and, therefore, Yan et al. judged the overall strength of evidence as low, indicating uncertainties around the pooled estimate of effect. Wang et al.100 conducted a meta-analysis of TACE-PEI combination therapy versus TACE monotherapy and found an improved overall survival with the combination therapy. The included trials in this review were of generally poor quality, with unclear baseline patient characteristics (e.g., Child-Pugh class and HCC lesion characteristics) and unclear or inadequate blinding and allocated concealment. As such, the authors of the review acknowledged the limited reliability of their conclusion. In another meta-analysis of TACE-PA combination therapy versus PA monotherapy,101 the combination therapy was shown to improve overall survival compared with the monotherapy. However, in a sensitivity analysis of TACE-RFA versus RFA alone, the authors found that the survival benefit of the combination therapy was not robust, which is in agreement with the inconclusive evidence base identified in our review. This systematic review also included studies in which the treatment was given prior to 2000. The authors noted the limited availability of high-quality data in their pooled analysis; therefore, the findings of this review are limited as well.

A 2009 Cochrane Review103 compared PEI and PAI, two similar ablative techniques with different chemotherapeutic agents for injection, and found no significant difference with regard to overall survival. This finding supports our approach of combining the PEI and PAI groups in our meta-analysis of the RFA versus PEI/PAI comparison.

The strength of the present review is that it addresses all local hepatic therapies for the included indications and includes comparisons not previously examined in published systematic reviews. Table 92 displays the corresponding comparisons between this review and the previously published reviews we identified. In addition, this report also recognizes that distinct patient groups exist within the population receiving local hepatic therapies. Specifically, we addressed a single patient population, those patients who are eligible for local hepatic therapy but are not otherwise eligible for resection or transplantation. Because we focused on a patient group rather than a specific intervention, we were able to present the outcomes for a wide range of local hepatic therapies for the target population.

Table 92 Comparisons made by current report and identified recent systematic reviews

Author, Year | RFA to PEI/PAI | DEB to TAE | DEB to TACE | RFA to TACE | TACE to TEA | TACE-RFA to RFA | TACE to TACE-Cryoablation | Other
Current Report | X | X | X | X | X | X | X
Bouza et al. 2009^98^ | X
Cho et al. 2009^99^ | X
Salhab et al.104 | X
Yan et al. 2012^102^ | | | | | | X
Wang et al. 2010^101^ | | | | | | | | TACE-PA vs. PA alone
Wang, 2011^100^ | | | | | | | | TACE-PEI vs. TACE alone
Schoppnmeyer, 2009^103^ | | | | | | | | PEI vs. PAI

Abbreviations: DEB = drug-eluting beads; PA = percutaneous ablation (either RFA or PEI); PAI = percutaneous acetic acid infusion; PEI = percutaneous ethanol infusion; RFA = radiofrequency ablation; TACE = transarterial chemoembolization; TAE = transarterial embolization; TEA = transarterial ethanol ablation.

### Applicability

We comment below on the relevance of the included intervention studies (i.e., RCTs and nonrandomized comparative studies) for population, intervention, comparator, outcomes, timing, and setting (PICOTS) elements. The PICOTS format provides a practical and useful structure to review applicability in a systematic manner and is employed in the subsections that follow.105

#### Population and Settings

As specified by our inclusion criteria the study population had unresectable HCC with no extrahepatic spread, no portal invasion, Child-Pugh class A or B disease, ECOG status ≤1 and/or BCLA stage A or B, or equivalent. This patient population comprises the patient group typically considered eligible for the therapies discussed in this review.

We have no information on which we can assess the generalizability of these results of the studies included in our review. The setting in which treatment occurs is a potential factor in the outcomes of local hepatic therapy. Simple generalizability of included studies could not be easily made because expertise of both clinicians and centers varies. In many centers, the choice of a local hepatic therapy may be limited by the available clinical expertise and technology. Local hepatic therapies often require high levels of training and familiarity with the procedure, as with radioembolization.106 Lack of experience may not only affect outcomes but also result in adverse effects; patients who are treated by less-experienced clinicians and centers will likely experience poorer outcomes.

The available studies offered insufficient details for us to assess operator-dependent factors or the representativeness of these settings compared with those of clinical practice. Detailed analysis of differences in outcomes by center has important implications for the relevance of the findings in the literature. Unfortunately, the published literature did not provide this information for our systematic review.

#### Interventions/Comparators

Even for a single local hepatic therapy, variation in how the procedure is performed may be substantial. For instance, the variation may be in the approach (open vs. percutaneous), or it may be in the choice of chemotherapy drugs delivered and the schedule of delivery of chemotherapy and radiation therapy. Given the limited evidence base, the present review did not allow for a more rigorous and systematic comparison of the relative performance of local hepatic therapies stratified by these factors. How these factors may alter health outcomes remains unclear.

Additional heterogeneity exists for the context in which the intervention was delivered. Patients often receive more than one local hepatic therapy over time or more than one session of the same therapy. The complex variation in treatment strategies also limits the benefit attributable to any one component of the treatment plan.

#### Outcomes

Little controversy exists as to the most appropriate direct health outcomes to measure in a study of local hepatic therapies for unresectable HCC. Overall survival is the final health outcome; it is reported in all of the studies included in this review. The utility of outcomes such as disease-free survival or local progression-free survival can be debated. Outcomes such as progression-free survival may not accurately predict changes in overall survival. However, these clinical events may mark changes in therapies and treatment that may be important to patients. Few experts would suggest that these outcomes replace the need for data on overall survival, but they may agree that these are important intermediate health outcomes. Additional studies of a comparative design are needed to measure accurately the differences in overall survival that may be attributed to a local hepatic therapy.

#### Timing

The timing of followup assessment was appropriate given the natural history of unresectable HCC and the primary outcome of overall survival. Nearly all studies reported on duration of patient followup with durations typically lasting until median survival time was reached or beyond.

## Implications for Clinical and Policy Decisionmaking

The goal of any local hepatic therapy for unresectable HCC is to prolong life by eliminating the tumor if possible or to palliate symptoms such as pain. This report has reviewed the literature on local hepatic therapies targeting these goals.

For the comparison of RFA to PEI/PAI, our conclusions suggest that for these patients treatment with RFA confers a survival benefit at 3 years compared with PEI/PAI. In addition, TTP and local recurrence may be improved in patients treated with RFA compared with PEI/PAI. Patients treated with RFA also seem to have longer LOS after treatment compared with those treated with PEI/PAI. Beyond this evidence on the comparative effectiveness of these procedures was insufficient. Subsequent comparisons had only one or no comparative studies on a given treatment comparison. For these comparisons, evidence was insufficient for all outcomes; thus, there is no comparative evidence base to support decisionmaking. In cases where comparative evidence existed, data were judged to be insufficient due to high risk of bias and/or imprecision of estimates.

## Limitations of the Comparative Effectiveness Review Process

Determination of the scope of this review was derived from a lengthy process that began in topic development and continued to be refined even as the CER was underway. The topic was initially broader, encompassing other primary tumors metastasizing to the liver and HCC. During the scoping process, this review was narrowed to focus solely on unresectable HCC, and then further by excluding transplant eligible patients and those who were treated in an effort to downstage them for resection. Based on the refined scope, the literature search revealed an evidence base with limited comparative data. When examining the comparative efficacy of local hepatic therapies it is important to establish that patient groups are comparable. In general, patients treated with ablative therapies and those treated with transarterial strategies represent two distinct patient populations, and as a result, when considering comparisons for this review we compared only ablative therapies to one another, embolization therapies to one another, and external-beam therapies to one another. Combinations of therapies were presented together, but none utilized the same interventions and could not be synthesized. Nonetheless, the evaluation of the quality of the body of literature to assess our KQs and the identification of research needs is a valuable contribution to the field.

## Limitations of the Evidence Base

Limitations of the present review are related largely to two factors: (1) the lack of comparative evidence and (2) clinical heterogeneity of patient populations across studies. With the exception of six RCTs, the vast majority of the evidence base included in this review derived from observational—mostly single-arm—studies. The clinical heterogeneity was most evident in the description of patient and tumor characteristics. For example, the size of lesions being treated with RFA ranged from 4 cm or smaller in the trial by Lin51 to up to 10 cm in a study by Minami et al.56 Often, studies failed to report on these patient and tumor characteristics, which potentially impact treatment-related outcomes. For example, only 17 out of 48 (35.4%) included studies reported both the number and size of lesions in the study patient population. Authors varied in how these tumor characteristics were described including: mean number and size of tumors, median number and size of tumors, range of number and size of tumors, percent solitary and nonsolitary tumor, interquartile range of size and number, or other categorizations. Full descriptions of the patient population is important, as those with—for example—higher ECOG score (i.e., worse functioning status), higher HCC stage, higher Child-Pugh class cirrhosis, or multinodular disease, generally experience poorer outcomes than those without. For this reason, it is ideal to stratify the studies by patient groups (e.g., BCLC stage A versus BCLC stage B) and to compare studies of equivalent patient populations. However, the poor patient characterization in the studies precluded stratification by patient groups as well as indirect comparison of interventions across studies. To maintain clinical relevance, comparisons were only made within category of intervention (e.g., ablative therapy vs. ablative therapy). This stratification is because patients with different disease characteristics are candidates for different treatments (e.g., patients with small accessible tumors are candidates for ablation whereas more extensive disease would undergo embolization therapy). Exceptions to this were two cross category comparisons of RFA and TACE and RFA versus TACE+RFA. The patient populations in these studies were patients eligible for ablative therapy. Chok and colleagues compared RFA to TACE in a patient population with tumor diameters less than 5cm with less than four nodules.53 This cross-category comparison was included under the ablative therapies section because Chok et al. assessed the performance of TACE in these patients to determine if selection bias (caused by advanced disease and poor liver functional reserve) contributed to the perceived benefit of RFA compared to TACE.

The comparative data were limited even further in terms of important subgroups such as those based on age, sex, ECOG score, disease etiology, Child-Pugh class, presence of PVT, HCC stage, lesion size, and multifocal versus single-nodule HCC. Overall survival was examined by subgroup in three RCTs; however, none of these analyses were prespecified, thereby limiting their utility beyond hypothesis generation.

Given the limited number of patients and clinical heterogeneity, we did not systematically review the treatment-specific characteristics such as treatment regimens and techniques used. A very large sample size with uniform data collection of these variables would be required to assess whether specific treatment characteristics were associated with survival differences.

None of the studies included in this review used blinded outcome assessment. It can be a challenge to blind participants and outcome assessors in these studies due to the differences in treatment delivery and the appearance of the liver after treatment. This is a particular limitation for the assessment of intermediate outcomes such as progression and local recurrence.

In addition to the RCTs meeting our inclusion criteria, this review included four nonrandomized comparative studies. These studies did not use statistical adjustment to reduce confounding; such adjustment for confounding should be consistently used in nonrandomized studies. Regardless of the study design, we suggest that studies examining the effectiveness or comparative effectiveness of local hepatic therapies address potential confounders and effect measure modification that could obscure the results. This is particularly important for patient characteristics such as size and number of the lesions, Child-Pugh classification, and performance status, which could serve as both modifiers of the effectiveness and factors that are considered when choosing the best local hepatic therapy.

Although RCTs may not be possible for all comparisons in all centers, well done multivariate analyses from existing case series can aid in identifying additional factors that should be documented and potentially controlled for in the comparative analysis of these data. These analyses can enhance the design of future RCTs or observational studies.

## Research Gaps

This systematic review attempted to compare outcomes of local hepatic therapies for patients treated for unresectable HCC without evidence of extrahepatic spread who are not eligible for transplant. Evidence on patient outcomes is limited. There was a moderate strength of evidence to support that RFA improved 3-year overall survival compared with PEI/PAI. There was low strength of evidence to support higher TTP, less local recurrence, and a longer LOS for RFA compared with PEI/PAI. For all other comparisons and outcomes, strength of evidence was judged to be insufficient.

We identified four broad evidence gaps during this review:

- There is no evidence on quality of life. Quality-of-life outcomes are particularly important for a population of patients in which palliation is often the focus of therapy. For all comparisons, collection and reporting of quality-of-life data using standard measurement tools is needed.
- An objective of CER is to understand the comparative effects for different subgroups. RCTs should prespecify subgroup analyses to assess the effects of characteristics such as lesion size, Child-Pugh class, and ECOG score on treatment outcomes. The subgroups of interest must be delineated using systematic definitions of patient subgroups. Further, studies should present data by these subgroups so that evidence can be interpreted accordingly.
- Future studies should employ a standard or uniform set of outcome definitions (e.g., overall survival, local recurrence) as well as patient characteristics to report (e.g., BCLC stage, Child-Pugh class, lesion number and size). Such uniformity would allow for a more accurate and level comparison of patient populations across studies which the current evidence base precludes.
- During the Peer Review process of this CER, we received the following suggested comparisons for future research: (1) RFA versus other ablative therapies (e.g., MWA, cryoablation), (2) RFA versus TACE-RFA combination therapy, (3) RFA versus radiotherapies (e.g., SBRT), and (4) between transarterial therapies (e.g., TACE versus RE or TACE versus DEB). Such comparative evidence, based on well-designed randomized studies in the patient population included in this review, is needed.

## Conclusions

This review included 13 local hepatic therapies and their combinations for unresectable HCC. There was a moderate strength of evidence demonstrating better overall survival at 3 years, a low level of evidence supporting improved overall survival for patients with larger lesion sizes, and a low strength of evidence for improved TTP and local control for RFA compared with PEI/PAI for the treatment of unresectable HCC. A low level of evidence also supports a longer LOS following RFA compared with PEI/PAI. For all other outcomes and comparisons, there is insufficient evidence to permit conclusions on the comparative effectiveness of local hepatic therapies for unresectable HCC. Important direct health outcomes of therapy include overall survival, adverse effects, and quality of life. Progression-free survival is an important intermediate health outcome, as progression often marks a change in therapy. Future RCTs comparing RFA with other ablative therapies and comparisons between transarterial therapies (e.g., TACE versus RE) are needed to close the existing gap in the comparative evidence.