# Abbreviations and Acronyms

Acronym: Definition
3D-CRT: Three dimensional conformal radiotherapy
AES: Adverse events
AHRQ: Agency for Healthcare Research and Quality
AJCC: American Joint Committee on Cancer
ALT: Alanine aminotransferase
AST: Aspartate transaminase
BCLC: Barcelona Clinic Liver Cancer
CAT: Computed axial tomography
CER: Comparative effectiveness review
CLIP: Cancer of the Liver Italian Program
CRT: Conformal Radiation Therapy
CT: Computed tomography
CP: Child-tucotte-Pugh
CUPI: Chinese University Prognostic Index
DEB: Drug-eluting Beads
ECOG: Eastern Cooperative Oncology Group
EPC: Evidence-based Practice Center
GETCH: Groupe d'Etude et de Traitement du Carcinome Hepatocellulaire
GRADE: Grading of Recommendations Assessment, Development and Evaluation
HAI: Hepatic arterial infusion
HBV: Hepatitis B Virus
HCC: Hepatocellular carcinoma
HCV: Hepatitis C Virus
HDR: High-dose rate
IMRT: Intensity Modulated Radiation Therapy
INR: International normalized ratio
IQR: Inter-quartile range
JIS: Japan Integrated Staging
LDR: Low-dose rate
LDT: Liver directed therapy
LOS: Length of stay
MAA: ^99m^Tc-macro-aggregated albumin
MELD: Model for End-Stage Liver Disease
MRI: Magnetic resonance imaging
MWA: Microwave ablation
NAFLD: Non-alcoholic fatty liver disease
NCCN: National Comprehensive Cancer Network
NIH: National Institutes of Health
PAI: Percutaneous alcohol injection
PDR: Pulsed-dose rate
PEA: Percutaneous ethanol ablation
PEI: Percutaneous ethanol infusion
PFS: Progression-free survival
PICOTS: population, intervention, comparator, outcomes, timing, and setting
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analysis
PVT: Portal vein thrombosis
QOL: Quality of life
RCT: Randomized controlled trial
RFA: Radiofrequency ablation
RFTA: Radiofrequency thermal ablation
RTRT: Real-time target tracking
SBRT: Stereotactic body radiation therapy
SCHIP: State Children's Health Insurance Program
SOE: Strength of evidence
SRC: Scientific Resource Center
TACE: Transarterial chemoembolization
TAE: Transarterial embolization
TEA: Transarterial ethanol ablation
TEP: Technical expert panel
TMN: Tumor, Node, Metastases
TTP: Time to progression
US: Ultrasound
Y90: Yittrium-90