# Evidence Tables

Appendix Table D-1 Study quality ratings: RCTs and non-randomized comparative studies

Study | Study Design | Assembled comparable groups | Maintained comparable groups | Minimal follow up loss | Measurements equal, valid and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results | Funding acknowledged | Overall rating
Sacco 2011 | RCT | Yes***** | Yes | Yes | No^*^ | Yes | Yes | Yes | No | Fair
Malagari 2010 | RCT | Yes | Yes | Yes | No^*^ | Yes | Yes | No^**^ | No | Poor
Morimoto 2010 | RCT | Yes | Yes | No | No^*^ | Yes | Yes | Yes | Yes | Poor
Brunello 2008 | RCT | Yes | Yes | Yes | No^****^ | Yes | Yes | Yes | Yes | Good
Lin 2005 | RCT | Yes | Yes | Yes | No^*^ | Yes | Yes | Yes | No | Fair
Lin 2004 | RCT | Yes | Yes | Yes | No^*^ | Yes | Yes | Yes | No | Fair
Recchia 2012 | NRC | Yes | Yes | No****** | No | No | Yes | Yes | No | Poor
Xu 2009 | NRC | No | No | Yes | No^*^ | Yes | Yes | Yes | No | Poor
Chok 2006 | NRC | Yes | Yes | No****** | No^*^ | Yes | Yes | Yes | Yes | Poor
Yu 2009 | NRC | Yes | Yes | Yes | No^*^ | Yes | Yes | Yes | No | Poor

* This response reflects that the authors did not describe blinding to outcome(s) of interest.

** This response reflects that the study did not analyze results according to intent-to-treat analysis.

*** This response reflects that the study did not report overall survival.

**** Outcomes could not be blinded due to different radiological signs produced by the two intervention techniques.

***** Randomization was done in an open fashion but known confounders between groups appear comparable.

****** Authors did not discuss follow up loss.

Abbreviations: RCT: Randomized controlled trial; NRC: Non-randomized comparative study

Appendix Table D-2 Study quality ratings: case series studies

Study | Study Design | Clearly Defined Question | Well-described study population | Well-described intervention | Use of Validated Outcome Measures | Appropriate Statistical Analysis | Well-Described Results | Discussion/Conclusions Supported by Data | Overall Rating
Andolino 2011 | Retrospective case series | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Bargellini 2011 | Prospective case series | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Buijs 2008 | Retrospective case series | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Carr 2004 | Prospective case series | Yes | Yes | Yes | Yes | Yes | No | Yes | Fair
Carr 2010 | Prospective cohort^*^ | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Chan 2011 | Retrospective case series | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Chen 2011 | Retrospective case series | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Gao 2011 | Retrospective case series | Yes | Yes | Yes | Yes | Yes | No | Yes | Fair
Giannini 2010 | Retrospective cohort^*^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Guiu 2009 | Retrospective case series | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Imai 2011 | Retrospective case series | Yes | No | Yes | Yes | Yes | No | Yes | Poor
Itoh 2011 | Prospective case series | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Kanhere 2008 | Prospective case series | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Kawaoka 2009 | Retrospective case series | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Leelawat 2008 | Prospective cohort^*^ | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Lencioni 2008 | Prospective case series | Yes | No | Yes | Yes | Yes | No | Yes | Poor
Liao 2008 | Prospective case series | Yes | No | No | Yes | Yes | Yes | Yes | Poor
Liu 2004 | Retrospective case series | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Mabed 2009 | RCT^*^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Maeda 2008 | Retrospective case series | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Martin 2011 | Prospective case series | Yes | Yes | Yes | Yes | Yes | No | Yes | Fair
Minami 2007 | Prospective case series | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Molinari 2006 | Prospective case series | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Oh 2010 | Prospective case series | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Pietrosi 2009 | Case series (uncertain if prospective or retrospective) | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Rand 2005 | Retrospective case series | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Seki 2011 | Retrospective case series | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Seo 2010 | Retrospective case series | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Shen 2005 | Prospective cohort^*^ | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Taguchi 2007 | Retrospective case series | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Tanaka 2009 | Case series (uncertain if prospective or retrospective) | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Wu 2010 | Retrospective cohort^*^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Zhang 2011 | Prospective case series | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Zhao 2012 | Retrospective case series | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Zhou 2009 | Retrospective case series | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good

* Comparative studies from which only a single comparator arm meeting inclusion criteria in this evidence review