# DistillerSR Screening and Abstraction Forms

Title Screening
- Is the article published in English?
- Does the article report primary data?
- Are the participants in the article human?
- Is unresectable primary hepatocellular carcinoma the primary focus of the article?

Abstract Screening
- Is the article published in English?
- Does the article report primary data?
- Are the participants in the article human?
- Is primary hepatocellular carcinoma the primary focus of the article?

HCC Full-text Screening
- Is article published in English?
- Is treatment date prior to January 1, 2000?
- Is the study of relevant design?
- Are the study participants human?
- Does the article report on the correct patient population?
- Did the study employ a relevant intervention?
- Did the study report a relevant outcome?

STUDY DESCRIPTION
- First Author (Last name):
- Year of Publication:
- Study design:
- What key question(s) does this article address?
  Descriptors of Treatment (e.g., drug(s) used, route, etc)
  Enrollment Start Date (mm/yyyy)
  Enrollment End Date (mm/yyyy)
  Number in Group
- Outcomes
- Setting
- Patient population with HCC (%)
- Previous Treatment
- Previous resection: % yes
- Previous systemic chemotherapy: % yes
- Previous liver-directed therapy: Therapy: %, Therapy2: …
- Previous LDT: select all that apply
- DIAGNOSIS
- Adenocarcinoma
- Mucinous
- Synchronous
- Mean Liver
- Median Liver
- Min Liver
- Max Liver
- Mean N Hepatic
- Median N Hepatic
- Min N Hepatic
- Max N Hepatic
- Other Liver Involvement: Name: %, Name2: …
- AFP mean
- AFP median
- AFP SD, range or 95% CI
- AFP unit
- AFP other
- PATHOLOGY
- Mean Size of Hepatic (cm) Lesion(s)
- Median Size of Hepatic (cm)
- Lesion(s)
- Min Size of Hepatic Lesion(s)
- Max Size of Hepatic Lesion(s)
- % Unilobar Hepatic Lesion(s)
- % Bilobar Hepatic Lesion(s)
- Other noted lesion characteristics

PATIENT CHARACTERISITCS
- Sex (% Male)
- Mean Age
- Median Age
- Min Age
- Max Age
- RACE: White (%)
- RACE: Black (%)
- RACE: Asian (%)
- RACE: Hispanic (%)
- BCLC Stage (A, B)
- Okuda Stage (I, II)
- Other staging system: (stage (%))
- Etiology of HCC: HBV %
- Etiology of HCC: HCV %
- Etiology of HCC NAFLD %
- Etiology of HCC Alcohol %
- Recurrent HCC %
- Portal Vein Thrombosis %
- Child-pugh score: Mean
- Child-pugh score: Median
- Child-pugh score: Min
- Child-pugh score: Max
- Child-pugh class (A, B, or C)
- ECOG Performance Score: Mean
- ECOG Performance Score: Median
- ECOG Performance Score: Min
- ECOG Performance Score: Max
- Karnofsky Score: Mean
- Karnofsky Score: Median
- Karnofsky score: Min
- Karnofsky Score: Max

ABSTRACTOR COMMENTS: If you would like to leave a comment pertaining to the information above indicate your name below:

Outcomes Form
- FOLLOW-UP
  - Follow-up assessed?
  - Length of Follow-up (weeks)
  - N Subjects Lost to Follow-up
- OUTCOMES
  - Survival outcome definition:
  - Median Overall Survival (months)
  - 95% CI: Lower limit
  - 95% CI: Upper limit
  - Mean Overall Survival (months)
  - 95% CI: Lower limit
  - 95% CI: Upper limit
- Survival by Year
  - % survived at year 1
  - % survived at year 2
  - % survived at year 3
  - % survived at year 4
  - % survived at year 5
- Progression Free Survival
  - Progression free survival definition:
  - Liver PFS
  - Median (months)
  - 95% CI: Lower Limit
  - 95% CI: Upper Limit
  - Liver PFS
  - Mean (months)
  - 95% CI: Lower Limit
  - 95% CI: Upper Limit
  - Overall PFS
  - Median (months)
  - 95% CI: Lower Limit
  - 95% CI: Upper Limit
  - Overall PFS
  - Mean (months)
  - 95% CI: Lower Limit
  - 95% CI: Upper Limit
- Outcomes Continued
  - Local Recurrence N
    Local Recurrence %
    Pain, Instrument
    Mean Pain Score
    Min Pain Score
    Max Pain Score
    Pain Score p-value
  - QOL, Instrument
    Min QOL Score
    Max QOL Score
    QOL Score p-value
    Mean LOS (days)
    Min LOS (days)
    Max LOS (days)
    LOS p-value
  - Hepatic Abscess (%)
    Hepatic Hemorrhage (%)
    Biloma (%)
    Steatohepatitis (%)
    Injury to adjacent organ(s) (%)
    Liver failure (%)
    Increased alkaline phosphatase (N)
    Increased alkaline phosphatase (%)
    Increased bilirubin (N)
    Increased bilirubin (%)
    Increased transaminases (N)
    Increased transaminases (%)

Please describe any rare adverse events which do not fit into the categorizations above:

ABSTRACTOR COMMENTS: If you would like to leave a comment pertaining to the information above indicate your name below:

Study Quality
- Comparative Studies Quality Assessment (USPSTF)
  Initial assembly of comparable groups
  Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
  Avoidance of important differential loss to followup or overall high loss to followup.
  Measurements reliable, valid, equal (includes masking of outcome assessment)
  Interventions comparable/ clearly defined
  All important outcomes considered
  Appropriate analysis of results (adjustment for potential confounders and intention-to-treat analysis)
  Funding/ sponsorship source acknowledged
  Overall Rating
- Non-Randomized Comparative-Deeks and colleagues
- Prospective sample definition and selection
  Clearly described inclusion/exclusion criteria
  Representative Sample
  Attempt to balance groups by design
  Comparable groups as baseline, including clearly described prognostic characteristics
  Clearly specified interventions
  Participants in treatment groups recruited within the same time period
  Attempt to allocate particpants to treatment groups to minimize bias
  Concurrent treatment(s) given equally to all treatment groups
  Valid, reliable, and equal outcome measures
  Blinded outcome assessment
  Adequate length of follow-up
  Attrition below an overall high level(<20%)
  Difference in attrition between treatment groups below a high level (<15%)
  Adjusted for confounders in statistical analysis
- Carey and Boden case series quality assessment tool
  Clearly Defined Question
  Well-described study population
  Well-described intervention
  Use of Validated Outcome Measures
  Appropriate Statistical Analysis
  Well-Described Results
  Discussion/Conclusions Supported by Data
  Funding/Sponsorship Source Acknowledged