# Contacted Authors

Appendix Table B-1 Contacted authors, issue and response