# Search Strategy

We searched MEDLINE^®^ for RCTs, nonrandomized comparative studies, and case series by using the following string of search terms:

“Carcinoma, Hepatocellular”[Mesh] OR (hepatocellular AND (neoplasm* OR cancer OR cancers OR carcinoma)) AND Unresectable OR nonresectable OR inoperable OR irresectable AND “Ablation Techniques”[Mesh] OR “Embolization, Therapeutic”[Mesh] OR “Chemoembolization, Therapeutic”[Mesh] OR “Radiotherapy”[Mesh] OR “radiotherapy “[Subheading] OR “drug therapy “[Subheading] OR “Drug Therapy”[Mesh] OR “radiofrequency ablation” OR (radiofrequency AND ablation) OR RFA OR “microwave ablation” OR (microwave AND ablation) OR ((percutaneous OR intralesional) AND (ethanol OR acetic acid)) OR embolization OR embolisation OR embolize* OR embolise* OR “transarterial chemoembolization” OR “transarterial chemoembolisation” OR TACE OR “transarterial embolization” OR “transarterial embolisation” OR TAE OR radioembolization OR radioembolisation OR radiotherapy OR radiation OR “external beam” OR “3D conformal” OR “3-D Conformal” OR “intensity modulated radiotherapy” OR IMRT OR “intraluminal brachytherapy” OR “liver-directed chemotherapy” OR chemotherapy OR “drug-eluting beads”

Limits: Humans, English

We searched EMBASE^®^ for RCTs, nonrandomized comparative studies, and case series by using the following string of search terms:

hepatocellular AND (neoplasm* OR cancer OR cancers OR carcinoma) AND (unresectable OR nonresectable OR inoperable OR irresectable) AND (radiofrequency AND ablation) OR RFA OR “microwave ablation” OR (microwave AND ablation) OR ((percutaneous OR intralesional) AND (ethanol OR acetic acid)) OR embolization OR embolisation OR embolize* OR embolise* OR “transarterial chemoembolization” OR “transarterial chemoembolisation” OR TACE OR “transarterial embolization” OR “transarterial embolisation” OR TAE OR radioembolization OR radioembolisation OR radiotherapy OR radiation OR “external beam” OR “3D conformal” OR “3-D Conformal” OR “intensity modulated radiotherapy” OR IMRT OR “intraluminal brachytherapy” OR “liver-directed chemotherapy” OR “ OR chemotherapy OR “drug-eluting beads”

Limits: Human, English and not MEDLINE.

Regulatory Information
- FDA
  Source: www.FDA.gov
  Date searched: 5/24/2012
  Search strategy: key word “TheraSphere,” “SIR-Spheres,” “EmboSphere,” “QuadraSphere,” “ LC Bead,” “CyberKnife,” “Cool-tip RF ablation system,” “ cryoablation,” “microwave ablation,” “radiofrequency ablation”
  Records: 33

Clinical Trial Registries
- NIH database
  Source: http://clinicaltrials.gov/
  Date searched: 5/17/2012
  Search strategy: hepatocellular carcinoma (Limits: Adult, senior, received from 01/01/2008 to 05/17/2012)
  Records: 164
- Controlled-Trials.com
  Source: www.controlled-trials.com
  Date searched: 5/24/2012
  Search strategy: hepatocellular carcinoma
  Records: 20
- WHO database
  Source: http://apps.who.int/trialsearch/
  Date searched: 5/24/2012
  Search strategy: hepatocellular carcinoma
  Records: 37

Conference Papers and Abstracts
- Specific conferences and association meetings
  Source – number of results returned for search strategy:
  Annual meeting of American Society of Clinical Oncology (ASCO) - 11
  Annual meeting of American Society of Clinical Oncology Gastrointestinal (ASCO GI) - 83
  Annual meeting of Surgery Society of Oncology (SSO) - 21
  Annual meeting of Radiosurgical Society - 3
  Date searched: 05/12/2012
  Search strategy: KW: “hepatocellular”
  Records: 118

Manufacturer Database
- Source: Accuray Incorporated
  Date posted: 5/14/2012
  Date searched: 5/30/2012
  Search strategy: Not applicable
  Records:8
- Source: Biocompatibles
  Date posted: 5/30/2012
  Date searched: 5/30/2012
  Search strategy: Not applicable
  Records: 108
- Source: BioSphere
  Date posted: 5/14/2012
  Date searched: 5/30/2012
  Search strategy: Not applicable
  Records: 8
- Source: Nordion
  Date posted: 5/25/2012
  Date searched: 6/7/2012
  Search strategy: Not applicable
  Records: 26