# Results

## Key Question 1 (KQ1) What are the comparative benefits and harms of erythropoiesis-stimulating agent (ESA) strategies and non-ESA strategies to manage anemia in patients undergoing chemotherapy or radiation for malignancy (excluding myelodysplastic syndrome and acute leukemia)?

Outcomes of interest include overall survival (on-study and longest available followup), progression-free survival, quality of life, hematologic responses, transfusions, tumor response to therapy, thromboembolic complications, and other adverse events. Specific comparisons to be included are:

1. Epoetin alfa or beta versus no ESA;
2. Darbepoetin versus no ESA;
3. Epoetin alfa or beta or darbepoetin versus no ESA; and
4. Epoetin alfa or beta versus darbepoetin.

### Organization of Results for KQ1

First, an overview of results for all outcomes is presented (Table 5 through Table 13). A detailed tabular listing of trials reporting one or more outcomes is then provided (Table 14); the reader is referred there for specific trials included in each pooled result. Next, for each outcome and comparison, characteristics of included trials are summarized and results detailed. Changes in trials included compared to the previous review are outlined (Appendix Table F1). When relevant, sensitivity analyses were performed to account for any trials excluded here, but included in the 2006 review. Quality of life and survival outcomes play central roles in understanding relative benefit and harms, and contain some differences from the prior report; each section accordingly includes discussion of methodologic underpinnings and considerations. In addition to meta-analyses of survival outcomes, relevant published meta-analytical results are appraised and reviewed.

Table 5 Overview: hematologic response

Variable | Darbepoetin vs. Epoetin | Epoetin vs. Control | Darbepoetin vs. Control | Epoetin or Darbepoetin vs. Control
Number of trials | 2 | 17 | 3 | 20
Patients analyzed | 464 | 4,242 | 800 | 5,042
Pooled relative risk | 0.73 | 3.6 | 3.1 | 3.4
(95% confidence interval) | (0.61 to 0.87) | (2.8 to 4.5) | (2.4 to 3.9) | (2.8 to 4.2)
I^2^ | 0% | 78% | 0% | 64%

Table 6 Overview: transfusion risk

Variable | Darbepoetin vs. Epoetin | Epoetin vs. Control | Darbepoetin vs. Control | Epoetin or Darbepoetin vs. Control
Number of trials | 5 | 31 | 7 | 38
Patients analyzed | 2,005 | 8,003 | 2,806 | 10,809
Pooled relative risk | 1.14 | 0.58 | 0.58 | 0.58
(95% confidence interval) | (0.82 to 1.59) | (0.52 to 0.65) | (0.51 to 0.65) | (0.53 to 0.64)
I^2^ | 43% | 60% | 0% | 51%

Table 7 Overview: overall survival

Variable | Epoetin vs. Control | Darbepoetin vs. Control | Epoetin or Darbepoetin vs. Control
Number of trials | 37 | 7 | 44
Patients analyzed | 11,131 | 3,147 | 14,278
Pooled hazard ratio | 1.04^a^ | 1.04 | 1.04^b,c^
(95% confidence interval) | (0.98 to 1.11) | (0.94 to 1.17) | (0.99 to 1.10)
I^2^ | 35% | 51% | 38%

a Including the single trial enrolling pediatric patients 1.04 (0.96 to 1.09).

b Including the single trial enrolling pediatric patients 1.04 (0.99 to 1.10).

c Excluding the 5 trials classified here as radiotherapy or predominantly radiotherapy34,46,81,82,83 yielded a hazard ratio of 1.03 (95% CI: 0.97 to 1.09).

Table 8 Overview: on-study mortality

Variable | Darbepoetin vs. Epoetin | Epoetin vs. Control | Darbepoetin vs. Control | Epoetin or Darbepoetin vs. Control
Number of trials | 2 | 31 | 6 | 37
Patients analyzed | 1,567 | 8,618 | 2,648 | 11,266
Pooled hazard ratio | 0.90 | 1.19^a,b^ | 1.05^c^ | 1.17^d,e,f^
(95% confidence interval) | (0.67 to 1.20) | (1.05 to 1.36) | (0.80 to 1.38) | (1.04 to 1.31)
I^2^ | 72% | 3% | 0% | 0%

a Including the trial enrolling pediatric patients left estimate and confidence interval unchanged.

b Estimate in Bayesian random effects model 1.16 (95% CrI: 1.00 to 1.32).

c Estimate in Bayesian random effects model 1.10 (95% CrI: 0.76 to 1.58).

d Estimate in Bayesian random effects model 1.15 (95% CrI: 1.02 to 1.31).

e Including the trial enrolling pediatric patients left estimate and CI unchanged.

f Excluding the 2 radiotherapy only trials34,81 1.16 (95% CI: 1.03 to 1.31), or the 3 trials classified here as radiotherapy or predominantly radiotherapy34,81,83 1.16 (95% CI: 1.03 to 1.30).

Table 9 Overview: progression-free survival and related outcomes

22 trials reported some outcome related to survival with disease progression; 3 reported significant differences in disease-free or progression-free survival, one trial in favor of epoetin and two in favor of control

Table 10 Overview: thromboembolic events

Variable | Darbepoetin vs. Epoetin | Epoetin vs. Control^a^ | Darbepoetin vs. Control | Epoetin^a^ or Darbepoetin vs. Control
Number of trials | 3 | 31 | 6 | 37
Patients analyzed | 1,873 | 9,585 | 2,869 | 12,570
Pooled relative risk | 0.86 | 1.50 | 1.53 | 1.51
(95% confidence interval) | (0.61 to 1.21) | (1.26 to 1.77) | (1.18 to 2.00) | (1.30 to 1.74)
I^2^ | 0% | 0% | 0% | 0%

a One trial reporting no events in either treatment arm not included in totals or pooled.

Table 11 Overview: health-related quality of life

Variable | Epoetin or Darbepoetin vs. Control
Number of trials | 14
Patients analyzed | 3,643
Mean Difference for Change Fact Fatigue Score | 2.74
(95% confidence interval) | (1.69 to 3.78)
I^2^ | 45%

Table 12 Overview: tumor response and progression

Variable | Epoetin or Darbepoetin vs. Control
Number of trials | 15
Patients | 5,577
Tumor Response or Progression | No evidence of an association with ESAs; results not pooled due to heterogeneous outcome definitions

Table 13 Overview: other adverse events

Adverse Event | Variable | Epoetin vs. Control | Darbepoetin vs. Control | Epoetin or Darbepoetin vs. Control
Hypertension | Number of trials | 13^a^ | 3 | 16
Hypertension | Patients analyzed | 3,021 | 1,297 | 4,318
Hypertension | Pooled relative risk | 1.62 | 1.31 | 1.48
Hypertension | (95% confidence interval) | (1.05 to 2.50) | (0.79 to 2.18) | (1.07 to 2.06)
Hypertension | I^2^ | 0% | 0% | 0%
Thrombocytopenia/Hemorrhage | Number of trials | 10 | 2 | 12
Thrombocytopenia/Hemorrhage | Patients analyzed | 2,403 | 1,311 | 3,714
Thrombocytopenia/Hemorrhage | Pooled relative risk | 1.11 | 1.46 | 1.17
Thrombocytopenia/Hemorrhage | (95% confidence interval) | (0.94 to 1.31) | (1.03 to 2.06) | (1.01 to 1.36)
Thrombocytopenia/Hemorrhage | I^2^ | 0% | 0% | 0%
Rash | Number of trials | 5 | – | 5
Rash | Patients analyzed | 1,467 | – | 1,467
Rash | Pooled relative risk | 2.00 | – | 2.00
Rash | (95% confidence interval) | (0.98 to 4.07) | – | (0.98 to 4.07)
Rash | I^2^ | 0% | – | 0%
Seizures | Number of trials | 3 | 2 | 5
Seizures | Patients analyzed | 604 | 983 | 1,587
Seizures | Pooled relative risk | 1.49 | 0.88 | 0.93
Seizures | (95% confidence interval) | (0.45 to 4.87) | (0.14 to 5.41) | (0.43 to 2.04)
Seizures | I^2^ | 0% | 54% | 0%

a Two other trials not included in pooled result—one with no events in either arm and one outlier (15 trials reported hypertension outcomes).

Table 14 Trials contributing evidence to specific outcomes and comparisons

Medication | Study | Hematologic Response | Transfusion Rates | Overall Survival | On-Study Mortality | Progression Free Survival and Related Outcomes | Tumor Response | Thromboembolic Events | QoL FACT-Fatigue | Adverse Events HTN | Adverse Events Thrombocytopenia | Adverse Events Rash | Adverse Events Seizure | Full Text | Abstract | FDA Documents | Individual Patient Data^a^
Epoetin beta | Aapro 2008^84^ | ● | ● | ● | ● | ● | | ● | | | | | | ○ | | | ○
Epoetin | Antonadou 2001^82^ | | | ● | | ● | | | | | | | | | ○
Epoetin alfa | Bamias 2003^85^ | ● | ● | ● | ● | | | ● | | ● | ● | | | ○
Epoetin alfa | Blohmer 2011^86^ | | ● | ● | | ● | ● | ● | | | | | | ○ | | ○
Epoetin beta | Boogaerts 2003,^87^ Coiffier 2001^88^ | ● | ● | ● | ● | | | | ● | | ● | | | ○ | | | ○
Epoetin alfa | Case 1993^89^ | ● | ● | ● | ● | | | ● | | ● | | | ● | ○ | | ○ | ○
Epoetin alfa | Chang 2005^90^ | ● | ● | ● | ● | | | ● | ● | | | | | ○ | | | ○
Epoetin alfa | Christodoulou 2009,^91^ Janinis92 | | ● | ● | | | | | ● | | | | | ○
Epoetin alfa | Dammacco 2001^93^ | ● | ● | ● | ● | | | ● | | ● | ● | | | ○ | | ○ | ○
Epoetin alfa | Debus 2006^94^ | | | ● | ● | | ● | ● | | | | | | | ○ | ○ | ○
Epoetin alfa | Engert 2009,^95^ Engert 2010^96^ | | | ● | | ● | ● | ● | | | | | | ○
Epoetin alfa | EPO-INT-1^97^ | | | ● | ● | ● | | ● | | | | | | | ○ | ○ | ○
Epoetin alfa | EPO-INT-3^98^ | | ● | ● | ● | | | ● | | | | | | | | ○ | ○
Epoetin beta | Fugisaka 2011^99^ | | ● | ● | ● | ● | | ● | | ● | ● | | | ○
Epoetin alfa | Goss 2005,^100^ EPO-CAN-15^101^ | | ● | ● | ● | ● | ● | ● | | | ● | | | | ○ | ○ | ○
Epoetin alfa | Grote 2005^102^ (N93-004) | | ● | ● | ● | ● | | ● | | | | | | ○ | | ○ | ○
Epoetin beta | Gupta 2009^103^ | | ● | ● | | | ● | ● | | | | ● | | ○
Epoetin beta | Henke 2003^34^ | | | ● | ● | ● | ● | ● | | | | | | ○ | | ○ | ○
Epoetin alfa | Henry 1995^104^ | ● | ● | ● | ● | | | ● | | ● | | ● | ● | ○ | | ○ | ○
Epoetin alfa | Hoskin 2009,^81^ EPO-GBR-7^105^ | | | ● | ● | ● | ● | ● | ● | ● | | | | ○ | | ○ | ○
Epoetin alfa | Iconomou 2003^106^ | ● | ● | | | | | | ● | ● | | | | ○
Epoetin alfa | Leyland-Jones 2005,^35^ L-Jones 2003^47^ | | ● | ● | ● | ● | | ● | | | | | | ○ | | ○ | ○
Epoetin alfa | Littlewood 2001^107^ | ● | ● | ● | ● | | | ● | ● | ● | ● | | | ○ | | ○ | ○
Epoetin alfa | Machtay 2007,^83^ Machtay 2004^108^ | | | ● | ● | ● | ● | ● | | | | | | ○ | | | ○
Epoetin alfa | Milroy 2011^109^ | ● | ● | ● | ● | | | ● | | ● | ● | ● | | ○ | | | ○
Epoetin alfa | Moebus 2007^110^ | | ● | ● | ● | ● | ● | ● | | | | | | ○ | | ○ | ○
Epoetin beta | Shanghai-Roche Pharm 2006,^111^ ML17620 | ● | | ● | ● | | | | | | | | | | ○
Epoetin beta | Oberhoff 1998^112^ | ● | ● | ● | ● | | | | | | | | | ○ | | | ○
Epoetin beta | Osterborg 2002,^113^ Osterborg 2005^114^ | ● | ● | ● | ● | ● | | ● | ● | ● | | ● | | ○ | | | ○
Epoetin alfa | Porter 1996^78^ | | ● | | | | | | | | | | | ○
Epoetin alfa | Pronzato 2010^115^ | | ● | ● | ● | | | ● | | | | | | ○ | | | ○
Epoetin alfa | Ray-Coquard 2009^116^ | | ● | ● | ● | ● | | ● | | | | | | ○ | | | ○
Epoetin alfa (pediatric) | Razzouk 2004,^117^ Razzouk 2006^79^ | ● | ● | c | c | | | ● | | ● | | | | ○
Epoetin alfa | Rose 1994^118^ | ● | ● | ● | ● | | | ● | | ● | | | | | ○ | ○ | ○
Epoetin alfa | Savonije 2005,^119^ Savonije 2006^120^ | ● | ● | ● | ● | | | ● | ● | ● | ● | | ● | ○ | | | ○
Epoetin alfa | Thomas 2002^121^ | | ● | ● | ● | | | | | | | | | | ○ | | ○
Epoetin alfa | Thomas 2008,^51^ GOG-0191^122^ | | | ● | ● | ● | ● | ● | | | | | | ○ | | ○ | ○
Epoetin beta | Tsuboi 2009^123^ | | ● | ● | | | | ● | ● | ● | ● | ● | | ○
Epoetin alfa | Wagner 2004^80^ | | | | | | ● | | | | | | | ○
Epoetin alfa | Wilkinson 2006^124^ | | ● | ● | ● | ● | | ● | | ● | | | | ○ | | | ○
Epoetin alfa | Witzig 2005^125^ | ● | ● | ● | ● | ● | | ● | ● | | ● | ● | | ○ | | ○ | ○
Darbepoetin alfa | Hedenus 2003^126^ | ● | ● | ● | ● | | | ● | ● | | | | | ○ | | ○ | ○
Darbepoetin alfa | Hernandez 2009^127^ | | ● | ● | ● | | | ● | | ● | | | ● | ○ | | | ○
Darbepoetin alfa | Katakami 2008^128^ | ● | ● | | | | | | | | | | | | ○
Darbepoetin alfa | Kotasek 2003^129^ | ● | ● | ● | ● | | | | ● | | | | | ○ | | | ○
Darbepoetin alfa | Overgaard 2009^46^ | | | ● | | ● | ● | ● | | | | | | | ○
Darbepoetin alfa | Pirker 2008^130^ | | ● | ● | ● | ● | | ● | ● | ● | ● | | ● | ○ | | | ○
Darbepoetin alfa | Untch 2011^131^ | | ● | ● | ● | ● | ● | ● | | | ● | | | ○ | | | ○
Darbepoetin alfa | Vansteenkiste 2002^8^ | | ● | ● | ● | ● | | ● | ● | ● | | | | ○ | | ○ | ○
Epoetin/Darbepoetin | Glaspy 2002^132^ | ● | ● | | | | | | | | | | | ○
Epoetin/Darbepoetin | Glaspy 2005,^133^ Glaspy 2006^134^ | b | ● | | ● | | | ● | | | | | | ○
Epoetin/Darbepoetin | Kotsori 2006^135^ | | ● | | | | | | | | | | | | ○
Epoetin/Darbepoetin | Schwartzberg 2004^136^ | b | ● | | | | ● | ● | | | | | | ○
Epoetin/Darbepoetin | Waltzman 2005^137^ | ● | ● | | ● | | ● | ● | | | | | | ○
Totals | 54 | 22 | 43 | 44 | 39 | 22 | 15 | 41 | 14 | 18 | 12 | 6 | 5 | 43 | 11 | 19 | 34

FACT = Functional Assessment of Cancer Therapy; FDA = U.S. Food and Drug Administration; HTN = hypertension; QoL = quality of life

a Data for overall and on-study mortality from Bohlius et al.48

b Used different response definition, but used to supplement analyses for completeness.

c Enrolled pediatric patients and reported overall survival, but not pooled in main result with trials of adult patients.

### Overview of Evidence and Findings for KQ1

Evidence from three groups of trials were summarized and analyzed (for complete study details, refer to Appendix C). Five trials compared darbepoetin to epoetin (N=1,044 to darbepoetin, N=1,214 epoetin); 41 trials compared epoetin to control (N=6,048 epoetin, N=5,509 control); and 8 trials compared darbepoetin to control (N=1,757 darbepoetin, N=1,624 control). Trial characteristics differed with respect to: primary and secondary endpoints, reported outcomes, types of malignancies, baseline hemoglobin, duration, treatment protocols (e.g., frequency of administration and amount, and iron supplementation), publication type, and quality ratings (Table 15). Reported target hemoglobin levels (defined on page 29) ranged from 11 g/dL to 14 g/dL (mean 12.6 g/dL), but was in only two trials lower than 12 g/dL and in two trials higher than 13 g/dL. Three trials comparing epoetin to control (N=286 total) enrolled pediatric patients.78–80

Table 15 Summary characteristics of the 54 trials included in KQ1

Characteristic | Group | Darbepoetin vs. Epoetin | Epoetin vs. Control | Darbepoetin vs. Control | Epoetin or Darbepoetin vs. Control
Trials | N/A | 5 | 41 | 8 | 49
Patients | Treatment | 1,044 | 6,048 | 1,757 | 7,805
Patients | Comparator | 1,214 | 5,509 | 1,624 | 7,133
Mean Age Range^a^ | Treatment | 57.8–63.7 | 3.2–68.3 | 49.0–64.8 | 3.2–68.3
Mean Age Range^a^ | Comparator | 58.7–63.4 | 3.2–68.1 | 48.0–64.6 | 3.2–68.1
Trial Quality n (%) | High | 0 (0) | 16 (39) | 5 (62.5) | 21 (42.9)
Trial Quality n (%) | Low | 5 (100) | 25 (61) | 3 (37.5) | 28 (57.1)
Treatment Modality n (%) | Chemotherapy | 5 (100) | 31 (75.6) | 7 (87.5) | 38 (77.6)
Treatment Modality n (%) | Chemotherapy includes Platinum | 3 (60) | 25 (61) | 5 (62.5) | 30 (61.2)
Treatment Modality n (%) | Radiotherapy | 0 (0) | 4 (9.8) | 1 (12.5) | 5 (10.2)
Treatment Modality n (%) | Chemoradiotherapy | 0 (0) | 6 (14.6) | 0 (0) | 6 (12.2)
Dose Escalation n (%) | Allowed | 0 (0) | 18 (43.9) | 3 (37.5) | 21 (42.9)
Dose Escalation n (%) | Not allowed | 5 (100) | 20 (48.8) | 4 (50) | 24 (49)
Dose Escalation n (%) | Unknown | 0 (0) | 3 (7.3) | 1 (12.5) | 4 (8.2)
Iron n (%) | As necessary | 0 (0) | 28 (68.3) | 5 (62.5) | 33 (67.3)
Iron n (%) | Other including fixed | 1 (20) | 10 (24.4) | 2 (25) | 12 (24.5)
Iron n (%) | Unknown | 4 (80) | 3 (7.3) | 1 (12.5) | 4 (8.2)
Tumor Type n (%) | Solid | 4 (80) | 27 (65.9) | 6 (75) | 33 (67.3)
Tumor Type n (%) | Mixed | 1 (20) | 8 (19.5) | 1 (12.5) | 9 (18.4)
Tumor Type n (%) | Hematologic | 0 (0) | 4 (9.8) | 1 (12.5) | 5 (10.2)
Baseline Hb g/dL | N/A | 9.9–10.4 | 8.8–13.7 | 9.5–13.6 | 8.8–13.7
Therapy Duration (weeks) | N/A | 8–16 | 4–52 | 9–23 | 4–52

Hb g/dL = hemoglobin grams per deciliter; N/A = not applicable

a Average of reported means or medians.

Note: Percentages may not sum to 100 due to unclear trial characteristics.

Major findings are summarized in Table 5 through Table 13.

### KQ1 Hematologic Response

Hematologic response was defined as the proportion of patients demonstrating a hemoglobin increase ≥2 g/dL. In the 20 included trials, baseline hemoglobin levels ranged from 9.0 to 12.8 g/dL (mean 10.1 g/dL). Data from the seven trials using different definitions of hematologic response are reported in Appendix Tables C7–C9, but were not pooled. Table 16 summarizes characteristics of included trials.

Table 16 Summary of characteristics for trials included in analysis of hematologic response

Characteristic | Factor | Darbepoetin vs. Epoetin | Epoetin vs. Control | Darbepoetin vs. Control | Epoetin or Darbepoetin vs. Control
Trials | N/A | 2 | 17 | 3 | 20
Patients | Treatment | 236 | 2,281 | 475 | 2,756
Patients | Comparator | 228 | 1,961 | 325 | 2,286
Mean Age Range^a^ | Treatment | 57.8–62.1 | 12.4–68.3 | 58.3–64.8 | 12.4–68.3
Mean Age Range^a^ | Comparator | 61.9–63.4 | 10.8–68.1 | 56.2–64.6 | 10.8–68.1
Trial Quality n (%) | High | 0 (0) | 8 (47.1) | 2 (66.7) | 10 (50)
Trial Quality n (%) | Low | 2 (100) | 9 (52.9) | 1 (33.3) | 10 (50)
Treatment Modality n (%) | Chemotherapy | 2 (100) | 17 (100) | 3 (100) | 20 (100)
Treatment Modality n (%) | Chemotherapy Includes Platinum | 1 (50) | 10 (58.8) | 2 (66.7) | 12 (60)
Treatment Modality n (%) | Radiotherapy | 0 (0) | 0 (0) | 0 (0) | 0 (0)
Treatment Modality n (%) | Chemoradiotherapy | 0 (0) | 0 (0) | 0 (0) | 0 (0)
Dose Escalation | Allowed | 0 (0) | 8 (47.1) | 2 (66.7) | 10 (50)
Dose Escalation | Not allowed | 2 (100) | 8 (47.1) | 1 (33.3) | 9 (45)
Dose Escalation | Unknown | 0 (0) | 1 (5.9) | 0 (0) | 1 (5)
Iron n (%) | As necessary | 0 (0) | 13 (76.5) | 2 (66.7) | 15 (75)
Iron n (%) | Other including fixed | 1 (50) | 3 (17.6) | 0 (0) | 3 (15)
Iron n (%) | Unknown | 1 (50) | 1 (5.9) | 1 (33.3) | 2 (10)
Tumor Type n (%) | Solid | 2 (100) | 8 (47.1) | 2 (66.7) | 10 (50)
Tumor Type n (%) | Mixed | 0 (0) | 5 (29.4) | 0 (0) | 5 (25)
Tumor Type n (%) | Hematologic | 0 (0) | 3 (17.6) | 1 (33.3) | 4 (20)
Baseline Hb g/dL | N/A | 9.9–10.2 | 9.0–12.8 | 9.5–9.9 | 9.0–12.8
Therapy Duration (weeks) | N/A | 12–14 | 12–28 | 12-12 | 12–28

Hb g/dL = hemoglobin grams per deciliter; N/A = not applicable

a Average of reported means or medians.

Percentages may not sum to 100 due to unclear trial characteristics.

#### Darbepoetin Versus Epoetin

Two trials132,137 compared hematologic response rates as defined in this review between patients randomized to darbepoetin or epoetin (Appendix Table C9). Both trials were unblinded and judged of poor quality. Two trials applying other response definitions, Glaspy et al.134 and Schwartzberg et al.136 employed different dose adjustments in the darbepoetin and epoetin arms. No trial included a control arm. Only Waltzman et al.137 described any supplemental iron administration. Study results for the two trials forming the main result here, and two others employing different response definitions, are summarized in Table 17.

Table 17 Study characteristics and results of trials comparing hematologic response rates for darbepoetin versus epoetin

Trial | Darbepoetin (200 mcg once per 2 weeks) | Epoetin (40,000 IU once weekly) | Response ≥2 g/dL | Response Rate Darbepoetin N (%) | Response Rate Epoetin N (%) | RR (95% CI)
Waltzman 2005^a,b,137^ | 177 | 175 | yes | 74 (41.8) | 101 (57.7) | 0.72 (0.58 to 0.90)
Glaspy 2006^134^ | 606 | 603 | no^c^ | 463 (76.4) | 487 (80.8) | 0.95 (0.89 to 1.00)
Schwartzberg 2004^136^ | 157 | 155 | no^d^ | 109 (69.4) | 112 (72.3) | 0.96 (0.83 to 1.11)
Glaspy 2002A^a,e,132^ | 59 (2.25 mcg/kg QW) | 53 (150 IU/kg TIW) | yes | 31 (52.5) | 38 (71.7) | 0.73 (0.55 to 0.98)

CI = confidence interval; g/dL = grams per deciliter; IU = international unit; kg = kilogram; mcg = micrograms; RR = relative risk; TIW = three times a week

a Arms differed in dose adjustment for inadequate response.

b Waltzman 2005137 patients with <1 g/dL Hb rise from baseline had 1.5-fold dose increase at week 6 if randomized to darbepoetin (from 200 to 300 mcg q2W), but at week 4 if randomized to epoetin (from 40,000 to 60,000 IU/week).

c Glaspy 2006134 defined response as reaching Hb >11 g/dL and remaining between 11 and 13 g/dL, results from Glaspy 2005133 abstract darbepoetin 90.3% (95% CI: 87.5%, 93.1%), epoetin 95.5% (95% CI: 93.6%, 97.4%).

d Schwartzberg 2004136 defined response as reaching Hb >12 g/dL or increasing by 2 g/dL from baseline to end of study.

e Glaspy 2002A132 compared arms given 2.25 mcg/kg darbepoetin QW versus epoetin alfa 150 IU/kg TIW (arm d); dose increase for inadequate Hb response only permitted for epoetin arm. (Results derived from published figure and calculated from percentages reported; randomization of the darbepoetin arms was not clearly stated).

##### Results

Fewer patients randomized to darbepoetin experienced ≥2 g/dL improvement in hemoglobin in the two trials137,138 employing that response definition—pooled RR 0.73 (95% CI: 0.61 to 0.87; I^2^=0%). For all four trials, using response definitions from each trial, the pooled RR of response comparing darbepoetin to epoetin was 0.88 (95% CI: 0.77 to 1.00; I^2^=65%).

Hematologic response of ≥2 g/dL increase, or as variously defined in the trials, was less frequent in the darbepoetin-treated arms. However, the trials and results are accompanied by clinical variability owing to differing doses and dosing adjustment strategies, both between trials and arms. Accounting for any influence of dose-adjustment strategy (a time-varying treatment induced by hemoglobin as a time-varying confounder) requires analytical methods not applied in any trial.139 These results are not consistent with differences between drugs in achieving hematologic response.

##### Changes From 2006 Review

Two trials from the previous review were excluded, three trials included unchanged (two with a different definition of response and therefore not pooled), and one new trial identified (Appendix Table F1). Table 18 compares current results to sensitivity analysis with two excluded trials.

Table 18 Hematologic response results: darbepoetin versus epoetin—current report, current with trials excluded but in 2006 review, and 2006 review

| Trials | Darbepoetin vs. Epoetin N | Control N | RR (95% CI) | I^2^
Current | 2 | 236 | 228 | 0.73 (0.61 to 0.87) | 0%
Current & Excluded | 4 | 999 | 986 | 0.88 (0.77 to 1.00) | 65%
2006 review | NR | NR | NR | NR | NR

NR = not reported; RR = relative risk

#### Epoetin Versus Control

Seventeen trials (Table 14) compared hematologic response rates (≥2 g/dL) between patients randomized to epoetin (N=2,281) or control (N=1,961). Trial characteristics varied as summarized in Table 16, including antineoplastic therapies and dose escalation. Nine trials were judged of low quality due primarily to lack of blinding. Individual trial characteristics are detailed in Appendix Table C7.

##### Results

More patients randomized to epoetin experienced ≥2 g/dL hemoglobin improvement compared with control—pooled RR 3.6 (95% CI: 2.8 to 4.5; I^2^=78%). Heterogeneity (Figure 8) was consistent with the varied trial characteristics. In meta-regressions trial quality, blinding, baseline hemoglobin, or iron use did not meaningfully account for the heterogeneity (e.g., decreasing I^2^ or was a significant covariate). Five additional trials employed different response definitions 34,51,121,123,124

Figure 8 Forest plot—hematologic response: epoetin versus control

CI = confidence interval; ESA = erythropoiesis-stimulating agent; RR = relative risk; W = weight

Figure 8 displays a forest plot of studies reporting the relative risk of hematologic response: epoetin versus control. Data for figure 8 are presented in Appendix C. This figure is described further in section “Epoetin vsersus Control: Results” as follows: “More patients randomized to epoetin experienced ≥2 g/dL Hb improvement compared to control—pooled RR 3.6 (95 percent CI: 2.8, 4.5; I2=78 percent). Heterogeneity was consistent with the varied trial characteristics.”

Hematologic response ≥2 g/dL was more frequent in the epoetin treated than control arms of included trials. While heterogeneity accompanied the pooled estimates, trials consistently demonstrated higher response rates with epoetin. These results are consistent with superiority of epoetin to a transfusion strategy for achieving a ≥2 g/dL hematologic response.

##### Changes From 2006 Review

Two trials from the previous review were excluded, 12 trials were included unchanged, data were updated for one trial, and three new trials were identified (Appendix Table F1). Table 19 compares current results with the 2006 review and sensitivity analysis with the excluded trials.

Table 19 Hematologic response results: epoetin versus control—current report, current with trials excluded but in 2006 review, and 2006 review

Comparison | Trials | Epoetin N | Control N | RR (95% CI) | I^2^
Current | 17 | 2,281 | 1,961 | 3.6 (2.8 to 4.5) | 78%
Current & Excluded | 19 | 2,433 | 2,039 | 3.6 (2.9 to 4.5) | 76%
2006 review | 15 | 1,844 | 1,449 | 3.4 (3.0 to 3.9) | 66%

CI = confidence interval; RR = relative risk

#### Darbepoetin Versus Control

Three trials (Table 14) compared hematologic response rates (≥2 g/dL) between patients randomized to darbepoetin (N=475) or control (N=325). Kotasek et al.129 examined six doses. Except for dosing, characteristics of the three trials were generally similar (Table 16).

##### Results

More patients randomized to darbepoetin experienced ≥2 g/dL improvement in hemoglobin compared to control—pooled RR 3.1 (95% CI: 2.4 to 3.9; I^2^=0%). Outcomes from two other trials127,140 defining response differently (Appendix Table C11) were consistent with a similar clinical effect improving hemoglobin for darbepoetin compared to control.

##### Changes From 2006 Review

One trial from the previous review was excluded, two trials were included unchanged, and no new trials were identified (Appendix Table F1). Table 20 shows similar current results with the 2006 review and sensitivity analysis with the excluded trial.

Table 20 Hematologic response results: darbepoetin versus control—current report, current with trials excluded but in 2006 review, and 2006 review

Comparison | Trials | Darbepoetin N | Control N | RR (95% CI) | I^2^
Current | 3 | 475 | 325 | 3.1 (2.4 to 3.9) | 0%
Current & Excluded | 4 | 530 | 336 | 3.1 (2.4 to 4.0) | 0%
2006 review | 3 | 427 | 232 | 3.4 (2.5 to 4.6) | 0%

CI = confidence interval; RR = relative risk

### KQ1 Risk of Transfusion

Transfusion risk was defined according to the proportion of patients transfused at least once during the trial.

#### Darbepoetin Versus Epoetin

Five trials132,134–137 compared transfusion risk between patients randomized to darbepoetin or epoetin. All trials were unblinded and judged of poor quality. Schwartzberg et al.136 randomized patients with breast, lung, and gynecologic tumors independently; results were reported separately and accordingly pooled. Glaspy et al.132 evaluated multiple darbepoetin doses in a dose-finding study, and results for 2.25 mcg/kg every week were included in the main analysis; sensitivity analyses performed including all results were not different. No trial included a control arm. Trial characteristics are summarized in Table 21 and detailed in Appendix Tables C1–6.

Table 21 Summary of characteristics for trials included in analysis of transfusion risk

Characteristic | Group | Darbepoetin vs. Epoetin | Epoetin vs. Control | Darbepoetin vs. Control | Epoetin or Darbepoetin vs. Control
Trials | N/A | 5 | 31 | 7 | 38
Patients | Treatment | 1,016 | 4,222 | 1,461 | 5,683
Patients | Comparator | 989 | 3,781 | 1,345 | 5,126
Mean Age Range^a^ | Treatment | 57.8–63.7 | 12.4–68.3 | 49–64.8 | 12.4–68.3
Mean Age Range^a^ | Comparator | 58.7–63.4 | 10.8–68.1 | 48–64.6 | 10.8–68.1
Trial Quality n (%) | High | 0 (0) | 13 (41.9) | 5 (71.4) | 18 (47.4)
Trial Quality n (%) | Low | 5 (100) | 18 (58.1) | 2 (28.6) | 20 (52.6)
Treatment Modality n (%) | Chemotherapy | 5 (100) | 27 (87.1) | 7 (100) | 34 (89.5)
Treatment Modality n (%) | Chemotherapy Includes Platinum | 3 (60) | 19 (61.3) | 5 (71.4) | 24 (63.2)
Treatment Modality n (%) | Radiotherapy | 0 (0) | 0 (0) | 0 (0) | 0 (0)
Treatment Modality n (%) | Chemoradiotherapy | 0 (0) | 4 (12.9) | 0 (0) | 4 (10.5)
Dose Escalation | Allowed | 0 (0) | 15 (48.4) | 3 (42.9) | 18 (47.4)
Dose Escalation | Not allowed | 5 (100) | 15 (48.4) | 4 (57.1) | 19 (50)
Dose Escalation | Unknown | 0 (0) | 1 (3.2) | 0 (0) | 1 (2.6)
Iron n (%) | As necessary | 0 (0) | 23 (74.2) | 4 (57.1) | 27 (71.1)
Iron n (%) | Other including fixed | 1 (20) | 7 (22.6) | 2 (28.6) | 9 (23.7)
Iron n (%) | Unknown | 4 (80) | 1 (3.2) | 0 (0) | 1 (2.6)
Tumor Type n (%) | Solid | 4 (80) | 18 (58.1) | 5 (71.4) | 23 (60.5)
Tumor Type n (%) | Mixed | 1 (20) | 8 (25.8) | 1 (14.3) | 9 (23.7)
Tumor Type n (%) | Hematologic | 0 (0) | 5 (16.1) | 1 (14.3) | 6 (15.8)
Baseline Hb g/dL | N/A | 9.9–10.4 | 9.0–13.5 | 9.5–13.6 | 9.0–13.6
Therapy Duration (weeks) | N/A | 8–16 | 7–52 | 12–23 | 7–52

Hb g/dL = hemoglobin grams per deciliter; N/A = not applicable

a Average of reported means or medians

Percentages may not add up to 100 due to unclear trial characteristics

##### Results

More patients randomized to darbepoetin received one or more transfusions—pooled RR 1.14 (95% CI: 0.82 to 1.59; I^2^=43%); including all comparisons from Glaspy et al.132 yielded a similar estimate—RR 1.12 (95% CI: 0.82 to 1.53; I^2^=35%). Similar to results for hemoglobin response, analytical methods applied in these trials did not account for dose-adjustment strategies. Results are consistent with no difference between agents in risk for transfusion.

##### Changes From 2006 Review

One trial from the previous review was excluded, three trials were included unchanged, data were updated for one trial, and one new trial was identified (Appendix Table F1). Table 22 compares current results with the 2006 review and sensitivity analysis with the excluded trial.

Table 22 Risk of transfusion: darbepoetin versus epoetin—current report, current with trials excluded but in 2006 review, and 2006 review

Comparison | Trials | Darbepoetin N | Epoetin N | RR (95% CI) | I^2^
Current | 5 | 1,016 | 989 | 1.14 (0.82 to 1.59) | 43%
Current & Excluded | 6 | 1,041 | 1,014 | 1.16 (0.85 to 1.56) | 34%
2006 review | 6 | 1,169 | 989 | 1.10 (0.93 to 1.29) | 48%

CI = confidence interval; RR = relative risk

#### Epoetin Versus Control

Thirty-one trials comparing transfusion between patients randomized to epoetin (N=4,222) or control (N=3,781) were included (Table 14). Seventeen trials were unblinded and 18 were judged to be low quality. Trial characteristics varied in other respects, including chemotherapeutic agents, dose adjustment protocols, and transfusion triggers (mean 8.3 g/dL, as high as 10 g/dL, and nine unblinded trials using physician discretion).

##### Results

Fewer patients randomized to epoetin received one or more transfusions—pooled RR 0.58 (95% CI: 0.52 to 0.65; I^2^=60%). Heterogeneity displayed in the forest plot (Figure 9) is consistent with varied trial characteristics. The results are consistent with superiority of epoetin over a transfusion strategy for avoiding transfusion. The data do not allow estimating the number of transfusions avoided.

Figure 9 Forest plot—relative risk of transfusion: epoetin versus control

CI = confidence interval; ESA = erythropoiesis-stimulating agent; RR = relative risk; W = weight

Figure 9 displays a forest plot of studies reporting the relative risk of transfusion: epoetin versus control. Data for figure 9 are presented in Table 14. This figure is described further in section “Epoetin vsersus Control: Results” as follows: “Fewer patients randomized to epoetin received one or more transfusions—pooled RR 0.58 (95 percent CI: 0.52, 0.65; I2=60 percent). Heterogeneity displayed in the forest plot is consistent with varied trial characteristics. The results are consistent with superiority of epoetin over a transfusion strategy for avoiding transfusion. The data do not allow estimating the number of transfusions avoided.”

##### Changes From 2006 Review

Eighteen trials from the previous review were excluded, 14 trials were included unchanged, data were updated for two trials, and 15 new trials were identified (Appendix Table F1). Table 23 compares current results with the 2006 review and sensitivity analysis with excluded trials—all are similar.

Table 23 Risk of transfusion: epoetin versus control—current report, current with trials excluded but in 2006 review, and 2006 review

Comparison | Trials | Epoetin N | Control N | RR (95% CI) | I^2^
Current | 31 | 4,222 | 3,781 | 0.58 (0.52 to 0.65) | 60%
Current & Excluded | 49 | 5,016 | 4,375 | 0.56 (0.51 to 0.62) | 64%
2006 review | 34 | 2,859 | 2,351 | 0.63 (0.59 to 0.67) | 63%

CI = confidence interval; RR = relative risk

#### Darbepoetin Versus Control

Seven trials comparing transfusion between patients randomized to darbepoetin (N=1,461) or control (N=1,345) were included (Table 14). Kotasek et al.129 examined six doses. Five trials were blinded and judged to be high quality, but other characteristics varied. Transfusion triggers were specified as 8 g/dL in four trials (also allowing physician discretion) but not reported in the others.

##### Results

Fewer patients randomized to darbepoetin received one or more transfusions—pooled RR 0.58 (95% CI: 0.51 to 0.65; I^2^=0%).

##### Changes From 2006 Review

One trial was excluded, three trials were included unchanged, and four new trials were identified (Appendix Table F1). Table 24 compares current results with the 2006 review and sensitivity analysis with the excluded trial.

Table 24 Risk of transfusion: darbepoetin versus control—current report, current with trials excluded but in 2006 review, and 2006 review

Comparison | Trials | Darbepoetin N | Control N | RR (95% CI) | I^2^
Current | 7 | 1,461 | 1,345 | 0.58 (0.51 to 0.65) | 0%
Current & Excluded | 8 | 1,516 | 1,356 | 0.57 (0.51 to 0.65) | 0%
2006 review | 4 | 566 | 384 | 0.61 (0.52 to 0.72) | 0%

CI = confidence interval; RR = relative risk

#### Hematologic Outcomes—Erythropoietic-Stimulating Agents

Considering all ESA trials, pooled effects indicate that these agents improve hemoglobin (pooled RR 3.4; 95% CI: 2.8 to 4.2; I^2^=64%; 20 trials) and result in fewer transfusions (pooled RR 0.58; 95% CI: 0.53 to 0.64; I^2^=51%; 38 trials). The consistency of these corresponding relationships is illustrated in Figure 10. Still, these agents decrease but do not eliminate the risk of receiving transfusions.

Figure 10 Hemoglobin response rates and proportions receiving ≥1 transfusion in treated and control arms of included trials^*^ * 20 trials of Hb response; 38 trials of transfusion risk.

ESA = erythropoiesis-stimulating agent; Hb = hemoglobin

This figure juxtaposes hemoglobin response rate in ESA arms and in control arms corresponding to patients receiving 1 or more transfusion. It illustrates that hemogloblin response is associated with a transfusion sparing effect. However, there is variability across trials in both response to ESA (from 20 percent to just over 80 percent) or in control arms (from 0 percent to just under 40 perecent), and in the proproprion transfused in the ESA arms (most from 0 percent to 90 percent) or in control arms (from 0 to 100 percent).

The pooled proportion receiving ≥1 transfusion with ESA treatment was 0.22 (95% CI: 0.17 to 0.27; I^2^=95%) compared with control of 0.39 (95% CI; 0.32 to 0.46; I^2^=96%); respective pooled proportions experiencing hemoglobin response were 0.52 (95% CI: 0.45 to 0.59; I^2^=92%) and 0.14 (95% CI: 0.10 to 0.19; I^2^=86%).

Finally, while these results are consistent, they are based on a clinically heterogeneous collection of trials. To explore that heterogeneity, we examined trial characteristics that might modify pooled estimates for transfusion risk (Table 25). Only transfusion risk was examined, both for its clinical relevance and because just over half the trials reported hemoglobin response. The relative proportion receiving ≥1 transfusion estimates varied by baseline hemoglobin, trial quality, blinding, use of platinum-based chemotherapy, and iron administration. These results are consistent with a notion that physician judgment influenced transfusion policies in these trials and probably more so in unblinded ones.

Table 25 Relative risks from single covariate meta-regressions—transfusion risk

Covariate | Factor | RR (95% CI) | p-Value
Dose Escalation | No | 0.56 (0.49 to 0.65) | 0.45
Dose Escalation | Yes | 0.61 (0.48 to 0.77) | 0.45
Iron | All other | 0.49 (0.41 to 0.58) | 0.01
Iron | As necessary | 0.63 (0.49 to 0.81) | 0.01
Platinum-Base Chemotherapy | No | 0.68 (0.60 to 0.77) | 0.003
Platinum-Base Chemotherapy | Yes | 0.53 (0.44 to 0.65) | 0.003
Baseline Hb | >10 g/dL | 0.71 (0.65 to 0.79) | <0.001
Baseline Hb | ≤10 g/dL | 0.49 (0.41 to 0.59) | <0.001
Study Duration | ≤12 weeks | 0.69 (0.52 to 0.93) | 0.22
Study Duration | >12 weeks | 0.62 (0.44 to 0.88) | 0.22
Trial Quality | Low | 0.51 (0.45 to 0.58) | 0.006
Trial Quality | High | 0.65 (0.52 to 0.81) | 0.006
Blinding | No | 0.49 (0.41 to 0.59) | <0.001
Blinding | Yes | 0.67 (0.61 to 0.73)

CI = confidence interval; RR = relative risk

#### Evidence GRADE

ESAs reduced the proportion of patients receiving transfusions (overall strength of evidence moderate, Table 26).

Table 26 Risk of transfusion: ESA versus control (GRADE evidence table)

Trials (N) | Subjects (N) | Risk of Bias Design/Quality | Consistency | Directness | Precision | Results RR (95% CI) I^2^ | Overall Strength of Evidence
38 | 10,809 | Medium trial quality: high-18; low-20 | Consistent | Direct | Precise | 0.58 (0.53 to 0.64) 51% | Moderate

CI = confidence interval; RR = relative risk

The evidence does not show any meaningful difference between epoetin and darbepoetin in the proportion of patients receiving transfusion (overall strength of evidence moderate, Table 27).

Table 27 Risk of transfusion: darbepoetin versus epoetin, epoetin versus control, and darbepoetin versus control (GRADE evidence table)

Trials (N) | Subjects (N) | Risk of Bias Design/Quality | Consistency | Directness | Precision | Results RR (95% CI) I^2^ | Overall Strength of Evidence
5 Darbepoetin vs. Epoetin | 2,005 | Medium trial quality high-0; low-5 | Consistent | Direct/Indirect^a^ | Precise | 1.14 (0.82 to 1.59) 43% | Moderate
31 Epoetin vs. Control | 8,003 | Medium trial quality: high-13; low-18 | Consistent | Direct | Precise | 0.58 (0.52 to 0.65) 60% | Moderate
7 Darbepoetin vs. Control | 2,806 | Low trial quality: high-5; low-2 | Consistent | Direct | Precise | 0.58 (0.51 to 0.65) 0% | High

CI = confidence interval; RR = relative risk

a 5 trials and 2,005 participants direct evidence; similar effect magnitudes for darbepoetin vs. control and epoetin versus control in table constitute indirect evidence.

### Survival Outcomes

We evaluated survival from two perspectives—“overall survival” and “on-study mortality.” Overall survival was defined as survival over the longest available follow-up; on-study mortality as mortality ascertained during, and up to 1 month following, ESA treatment (the period of active treatment). Although important, limitations accompany the overall survival outcome: (1) fewer than half the trials included an overall survival endpoint and detailed a survival analyses; (2) over the longer term during post-treatment follow-up, many nonrandom interventions can affect survival (i.e., potentially causing a bias to the null or no difference); (3) adverse consequences of ESAs are biologically most plausible during the active treatment period or soon thereafter—not well after treatment is stopped;^b^ and (4) different trial durations introduce issues for pooling (discussed below). Mortality during the active study period is therefore most informative because it represents the most biologically plausible causal effect and is little prone to the limitations accompanying overall survival, as outlined.

b Unless ESAs promote tumor progression

Matters to contemplate when examining survival and mortality results include: trials of varying lengths of followup; different underlying mortality risks; and some trials lacking deaths in one or both treatment arms. To address these issues, this section is organized as follows. First, sources and important aspects of the evidence are detailed. Next, the approaches to pooling trial results and exploring potential subgroup effects are outlined. Finally, details of included trials and results for overall survival and on-study mortality are presented. There are considerably fewer darbepoetin than epoetin trials and pooled results restricted to darbepoetin are necessarily imprecise. Given consistent magnitude of effects and pharmacologic basis of these agents, evidence from different ESAs were combined for synthesis.

Overall survival data were abstracted for the longest available follow-up reported—updated or obtained from Bohlius et al.48 for 34 trials (see Table 14). For trials not included in Bohlius et al.,48 as outlined in Parmar et al.66 data were abstracted. Deaths in three trials82,91,103 were estimated from the published Kaplan-Meier curves. On-study mortality data were taken primarily from a published individual patient data meta-analysis48 where on-study mortality was defined “as death from any cause between date of randomization and 28 days after the end of the active study phase. While these trials were in general not designed to evaluate on-study mortality, Bohlius et al.48 applied a standardized approach and any measurement error is most likely non-differential. Any accompanying bias would therefore be conservative or to the null. On-study mortality for four trials79,85,99,111 were not derived from Bohlius et al.48 but adequately reported. One trial enrolled pediatric patients and was therefore not included in the main analyses.79

There are three important methodologic issues to consider when pooling survival and mortality results. First, while study duration and active treatment periods varied, combining estimates assumes that followup duration did not affect relative effects. This, essentially a proportional hazards assumption, is unverifiable. Furthermore, if as indicated in other meta-analyses, mortality is increased during the on-study period,48,141 but not over the long term, then the assumption of constant relative effect (proportional hazards) over longest follow-up may not hold. Second, it can be difficult to evaluate the relationship between underlying mortality rate or baseline risk (i.e., control arms) and relative risk of mortality with ESA use. Yet the relationship is of interest because current labeling recommends avoiding ESA use in patients undergoing chemotherapy with curative intent—that is, patients with low expected mortality rates. Examining the relationship between underlying mortality rates and relative effects can be problematic due to their inherent correlation (control mortality rate is used to calculate relative effect). Third, the absence of events in some trial arms, as occurs in these data, can be problematic in standard meta-analyses.142

Because of these issues and fundamental importance of mortality effects, these data were analyzed using two approaches. First, from calculated observed and expected events with accompanying variance,66 the pooled hazard ratio was estimated using the Peto method, the same method used in the 2006 review. 143 The approach includes trials without events in one arm and is a fixed-effects estimate. Overall survival was pooled in this manner. In addition, for on-study mortality the main results were also pooled in Bayesian hierarchical (random-effects) models. The Bayesian approach models events directly (not relative effects) and so appropriately incorporates trials lacking events in one arm. To obtain relative risks (as opposed to odds ratios), the approach outlined by Warn et al.68 was used. A Bayesian model was also used to examine the relationship between underlying risk (control group mortality rate) and relative risk—a model that appropriately accounts for correlation between relative effect and underlying risk.69 Noninformative priors were specified in these models which were fitted using OpenBUGS.75 Finally, reported or estimated 12- to 16-week mortality rates in the control arms were used to represent underlying mortality risk. Because the most common trial duration was 12 weeks, for those trials longer or shorter we estimated 12-week mortality in the control arm using the relationship between rate, probability, and time.

### KQ1 Overall Survival

Trials included in overall survival analyses are listed in Table 14 and summary characteristics shown in Table 28. Trials varied in quality, use of iron, tumor types, cancer treatment, baseline hemoglobin, and duration. Approximately two-thirds of trials reported following patients a median or longest followup exceeding 1 year. One trial enrolled pediatric patients.79

Table 28 Summary of characteristics for trials included in analysis of overall survival

Characteristics | Group | Epoetin vs. Control^a^ | Darbepoetin vs. Control | Epoetin or Darbepoetin vs. Control^a^
Trials | N/A | 37 | 7 | 44
Patients | Treatment | 5,831 | 1,638 | 7,469
Patients | Comparator | 5,300 | 1,509 | 6,809
Mean Age Range^b^ | Treatment | 35.0–68.3 | 49.0–64.8 | 35.0–68.3
Mean Age Range^b^ | Comparator | 34.0–68.1 | 48.0–64.6 | 34.0–68.1
Trial Quality n (%) | High | 15 (40.5) | 5 (71.4) | 20 (45.5)
Trial Quality n (%) | Low | 22 (59.5) | 2 (28.6) | 24 (54.5)
Treatment Modality n (%) | Chemotherapy | 28 (75.7) | 6 (85.7) | 34 (77.3)
Treatment Modality n (%) | Chemo with platinum | 23 (62.2) | 4 (57.1) | 27 (61.4)
Treatment Modality n (%) | Radiotherapy | 4 (10.8) | 1 (14.3) | 5 (11.4)
Treatment Modality n (%) | Chemoradiotherapy | 5 (13.5) | 0 (0) | 5 (11.4)
Dose Escalation n (%) | Allowed | 18 (48.6) | 2 (28.6) | 20 (45.5)
Dose Escalation n (%) | Not allowed | 16 (43.2) | 4 (57.1) | 20 (45.5)
Dose Escalation n (%) | Unknown | 3 (8.1) | 1 (14.3) | 4 (9.1)
Iron n (%) | As necessary | 25 (67.6) | 5 (71.4) | 30 (68.2)
Iron n (%) | Other including fixed | 9 (24.3) | 2 (28.6) | 11 (25.0)
Iron n (%) | Unknown | 3 (8.1) | 0 (0) | 3 (6.8)
Tumor Type n (%) | Solid | 24 (64.9) | 5 (71.4) | 29 (65.9)
Tumor Type n (%) | Mixed | 7 (18.9) | 1 (14.3) | 8 (18.2)
Tumor Type n (%) | Hematologic | 4 (10.8) | 1 (14.3) | 5 (11.4)
Baseline Hb g/dL | N/A | 9.0–13.7 | 9.5–13.6 | 9.0–13.7
Therapy Duration (weeks) | N/A | 4–52 | 9–23 | 4–52

Hb g/dL = hemoglobin grams per deciliter; N/A = not applicable

a Excludes trial of pediatric patients.79

b Of reported means or medians.

#### Darbepoetin Versus Epoetin

No trials reported long-term survival.

#### Epoetin Versus Control

Thirty-seven trials (Table 14) reported overall survival in adult patients randomized to epoetin (N=5,831) or control (N=5,300). Trial characteristics varied considerably as summarized in Table 28 and detailed in Appendix Table C1. One trial included pediatric patients;79 10 trials included only women with gynecologic and/or breast cancers.

##### Results

In adults there was no apparent increased risk accompanying epoetin use—HR 1.04 (95% CI: 0.98 to 1.11; I^2^=35%). Including the single trial in pediatric patients resulted in the same relative hazard—HR 1.04 (95% CI: 0.96 to 1.09).

##### Changes From 2006 Review

Thirteen trials were excluded, 1 trial was included unchanged, data were updated for 21 trials, and 16 new trials were identified (Appendix Table F1). Table 29 compares current results with the 2006 review and sensitivity analysis with the excluded trials.

Table 29 Overall survival: epoetin versus control—current report, current with trials excluded but in 2006 review, and 2006 review

Comparison | Trials | Epoetin N | Control N | HR (95% CI) | I^2^
Current | 37 | 5,831 | 5,300 | 1.04 (0.98 to 1.11) | 35%
Current (all)^a^ | 38 | 5,943 | 5,410 | 1.04 (0.96 to 1.09) | 38%
Current (all)^a^ & Excluded | 50 | 6,467 | 5,694 | 1.03 (0.97 to 1.10) | 26%
2006 review | 35 | 3,825 | 3,093 | 1.11 (1.00 to 1.22) | 48%

CI = confidence interval; HR = hazard ratio

a Includes trial of pediatric patients79 also included in the 2006 result.

#### Darbepoetin Versus Control

Overall survival was reported in seven trials (Table 14) for patients randomized to darbepoetin treatment (N=1,638) or control (N=1,509). Similar to epoetin trials, characteristics varied (Table 28), none included pediatric patients and one only women with breast cancer.37 Five trials were designed for long-term follow-up of at least 12 months.8,37,46,126,130

##### Results

There was no apparent increased relative risk in darbepoetin treated patients—pooled HR 1.04 (95% CI: 0.94 to 1.17; I^2^=51%).

##### Changes From 2006 Review

One trial from the previous review was excluded, three trials were included unchanged, and four new trials were identified (Appendix Table F1).

Table 30 compares current results with the 2006 review and sensitivity analysis with the excluded trials.

Table 30 Overall survival: darbepoetin versus control—current report, current with trials excluded but in 2006 review, and 2006 review

Comparison | Trials | Darbepoetin N | Control N | HR (95% CI) | I^2^
Current | 7 | 1,638 | 1,509 | 1.04 (0.94 to 1.17) | 51%
Current & Excluded | 8 | 1,701 | 1,527 | 1.04 (0.93 to 1.16) | 50%
2006 review | 4 | 583 | 390 | 0.96 (0.78 to 1.17) | 72%

CI = confidence interval; HR = hazard ratio

#### Evidence Regarding Erythropoietic-Stimulating Agents

Combined results from the 44 trials of either ESA versus control were similar—pooled HR 1.04 (95% CI: 0.99 to 1.10; I^2^=38%). However, this result was obtained from a clinically heterogeneous set of trials, so we explored trial characteristics that might modify pooled estimates (Table 31). Because the Peto method of combining hazard ratios is not easily amenable to including covariates, meta-regressions were performed in random-effects models and so point estimates are not precisely comparable. Nonetheless, there is no indication that any of the characteristics modifies the pooled estimate.

Table 31 Relative risks from single covariate meta-regressions—overall survival: epoetin or darbepoetin versus control

Characteristic | Group | RR (95% CI) | p-value
Dose Escalation | Yes | 1.00 (0.95 to 1.05) | 0.98
Dose Escalation | No | 0.99 (0.90 to 1.09) | 0.98
Iron | All other | 0.96 (0.89 to 1.03) | 0.07
Iron | As necessary | 1.04 (0.93 to 1.17) | 0.07
Platinum-Base Chemotherapy | Yes | 1.05 (0.98 to 1.13) | 0.12
Platinum-Base Chemotherapy | No | 0.98 (0.87 to 1.10) | 0.12
Chemo or Radiotherapy | Chemo ± Radiotherapy | 1.00 (0.95 to 1.05) | 0.19
Chemo or Radiotherapy | Radiotherapy | 1.09 (0.94 to 1.25) | 0.19
Baseline Hb b | > 10 g/dL | 0.97 (0.88 to 1.07) | 0.30
Baseline Hb b | ≤ 10 g/dL | 1.03 (0.89 to 1.20) | 0.30
Study Duration | ≤ 12 weeks | 0.97 (0.83 to 1.13) | 0.67
Study Duration | > 12 weeks | 1.00 (0.83 to 1.20) | 0.67
Study Quality | Low | 1.00 (0.94 to 1.07) | 0.71
Study Quality | High | 1.02 (0.90 to 1.14) | 0.71
Blinding | Yes | 1.02 (0.95 to 1.09) | 0.71
Blinding | No | 1.00 (0.89 to 1.13) | 0.71

CI = confidence interval; RR = relative risk

##### Changes From 2006 Review

Fourteen trials from the previous review were excluded, four trials were included unchanged, results for 21 trials were updated, and 20 new trials were identified (Appendix Table F1).

Table 32 compares current results with the 2006 review and sensitivity analysis with excluded trials.

Table 32 Overall survival: epoetin or darbepoetin versus control—current report, current with trials excluded but in 2006 review, and 2006 review

Comparison | Trials | Epoetin or Darbepoetin N | Control N | RR (95% CI) | I^2^
Current | 44 | 7,469 | 6,809 | 1.04 (0.99 to 1.10) | 38%
Current (all)^a^ | 45 | 7,581 | 6,919 | 1.04 (0.99 to 1.10) | 36%
Current (all)^a^ & Excluded | 59 | 8,257 | 7,313 | 1.04 (0.98 to 1.10) | 29%
2006 review | 39 | 4,408 | 3,483 | 1.08 (0.98 to 1.18) | 13%

CI = confidence interval; RR = relative risk

a Includes trial of pediatric patients79 also included in the 2006 result.

In summary, we did not detect an association between ESA use and survival over the longest available follow-up. There were no meaningful differences from the 2006 effect estimate.

#### Evidence GRADE

The evidence does not show an effect of ESAs on survival over the longest available follow-up—including both during and following ESA treatment (overall strength of evidence moderate, Table 33).

Table 33 Overall survival: ESA versus control (GRADE evidence table)

Trials (N) | Subjects (N) | Risk of Bias Design/Quality | Consistency | Directness | Precision | Results RR (95% CI) I^2^ | Overall Strength of Evidence
44 | 14,278 | High^a^ trial quality high-21; low-23 | Consistent | Direct | Precise | 1.04 (0.99 to 1.10) 38% | Low

CI = confidence interval; RR = relative risk

a Fewer than half of trials included survival as a primary or secondary outcome; no trial was powered to detect a survival difference; time-dependent confounding not considered in analyses.

### KQ1 On-Study Mortality

On-study mortality was not reported in the 2006 review. The individual patient data meta-analysis of Bohlius et al.48 allowed evaluating on-study mortality. Trials included in these analyses and data source for each trial are listed in Table 14; summary characteristics are shown in Table 34.

Table 34 Summary of characteristics for trials included in analysis of on-study mortality

Characteristics | Factors | Darbepoetin vs. Control | Epoetin vs. Control^a^ | Darbepoetin vs. Control | Epoetin or Darbepoetin vs. Control^a^
Trials | | 2 | 31 | 6 | 37
Patients | Treatment | 791 | 4,580 | 1,391 | 5,971
Patients | Comparator | 776 | 4,038 | 1,257 | 5,295
Mean Age Range^b^ | Treatment | 62.1–63.7 | 46.0–68.3 | 49.0–64.8 | 46.0–68.3
Mean Age Range^b^ | Comparator | 63.2–63.4 | 50.0–68.1 | 48.0–64.6 | 48.0–68.1
Trial Quality n (%) | High | 0 (0) | 13 (41.9) | 5 (83.3) | 18 (48.6)
Trial Quality n (%) | Low | 2 (100) | 18 (58.1) | 1 (16.7) | 19 (51.4)
Treatment Modality n (%) | Chemotherapy | 2 (100) | 25 (80.6) | 6 (100) | 31 (83.8)
Treatment Modality n (%) | Chemotherapy Includes Platinum | 2 (100) | 19 (61.3) | 4 (66.7) | 23 (62.2)
Treatment Modality n (%) | Radiotherapy | 0 (0) | 3 (9.7) | 0 (0) | 3 (8.1)
Treatment Modality n (%) | Chemoradiotherapy | 0 (0) | 3 (9.7) | 0 (0) | 3 (8.1)
Dose Escalation n (%) | Allowed | 0 (0) | 14 (45.2) | 2 (33.3) | 16 (43.2)
Dose Escalation n (%) | Not allowed | 2 (100) | 15 (48.4) | 4 (66.7) | 19 (51.4)
Dose Escalation n (%) | Unknown | 0 (0) | 2 (6.5) | 0 (0) | 2 (5.4)
Iron n (%) | As necessary | 0 (0) | 24 (77.4) | 4 (66.7) | 28 (75.7)
Iron n (%) | Other including fixed | 1 (50) | 5 (16.1) | 2 (33.3) | 7 (18.9)
Iron n (%) | Not reported | 1 (50) | 2 (6.5) | 0 (0) | 2 (5.4)
Tumor Type n (%) | Solid | 1 (50) | 20 (64.5) | 4 (66.7) | 24 (64.9)
Tumor Type n (%) | Mixed | 1 (50) | 6 (19.4) | 1 (16.7) | 7 (18.9)
Tumor Type n (%) | Hematologic | 0 (0) | 3 (9.7) | 1 (16.7) | 4 (10.8)
Baseline Hb g/dL | | 10.1–10.2 | 9.0–13.7 | 9.5–14.0 | 9.0–13.7
Therapy Duration (weeks) | | 14–16 | 4–52 | 12–23 | 4–52

Hb g/dL = hemoglobin grams per deciliter

a Excludes trial of pediatric patients.79

b Of reported means or medians.

#### Darbepoetin Versus Epoetin

Two trials reported on-study mortality for participants randomized to darbepoetin or epoetin.134,137 The trials differed in tumor type, although they were otherwise generally similar and judged of low quality.

##### Results

Neither trial reported a survival advantage for a particular agent; no difference was noted when the trial results were combined—HR 0.90 (95% CI: 0.67 to 1.20; I^2^=72%).

##### Changes From 2006 Review

On-study mortality was not reported, but results from one trial were included as overall survival.137

#### Epoetin Versus Control

Thirty-one trials (Table 14) reported on-study mortality in adult patients randomized to epoetin (N=4,580) or control (N=4,038). Trial characteristics varied (Table 34) and are detailed in Appendix Table C1. One trial enrolled pediatric patients;79 eight trials enrolled only women with gynecologic or breast cancers.

##### Results

The pooled hazard ratio was consistent with an increased risk of mortality during the on-study period—HR 1.19 (95% CI: 1.05 to 1.36; I^2^=3%); Bayesian random effects RR of 1.16 (95% CrI: 1.00 to 1.32). Including six trials where on-study mortality was not reported at the end of the active study period, but estimated from Kaplan-Meier curves82,91,95,103 or from overall survival123,144 yielded a pooled HR of 1.13 (95% CI: 1.01 to 1.26; I^2^=0%). Including the single trial enrolling pediatric patients79 did not alter the estimated relative effect or confidence interval.

##### Changes From 2006 Review

On-study mortality was not examined in the 2006 review.

#### Darbepoetin Versus Control

Six trials (Table 14) reported on-study mortality in patients randomized to darbepoetin (N=1,391) or control (N=1,257). The characteristics of included trials (Table 34) were less varied than epoetin trials (detailed in Appendix Table C2). None enrolled pediatric patients; one trial enrolled only women with gynecologic or breast cancers;37 no patients in the trial died in the active treatment period.

##### Results

The pooled hazard ratio during the on-study period was 1.05 (95% CI: 0.80 to 1.38; I^2^=0%); Bayesian random effects RR of 1.10 (95% CI: 0.76 to 1.58). While the small number of trials (six contributing to the effect estimate) limits statistical inferences, the result magnitude is consistent with an increased risk of mortality during the active treatment period.

##### Changes From 2006 Review

On-study mortality was not examined.

#### Evidence Regarding Erythropoietic-Stimulating Agents

Given the basis for considering ESAs as agents with similar effects and evidence consistent with increased mortality during the active treatment period, all trial results were combined for analysis with three aims: 1) estimate overall pooled effect, 2) examine potential subgroup differences, and 3) explore any relationship between relative and underlying mortality risk (i.e., on-study mortality in the control arms).

Pooling on-study mortality from the 37 trials^c^ yielded an estimated hazard ratio of 1.17 (95% CI: 1.04 to 1.31; I^2^=0%) as shown in Figure 11 (including the trial enrolling pediatric patients left estimate unchanged) and a Bayesian random effects RR of 1.15 (95% CI: 1.02 to 1.31). I^2^, while zero percent, should not be interpreted as a lack of heterogeneity70 because it depends on within-study precision, which in these trials is exceedingly low. Considered as a whole and displayed in Table 35, the estimates are consistent with an association between ESA treatment and increased mortality during the active treatment period. A limitation of these data is the uncertainty (wide confidence intervals) accompanying individual trial results, as none were designed or powered to detect even a lower limit for increased mortality risk during the active treatment period. To illustrate, a trial randomized 1:1 to treatment or control with an anticipated 10 percent mortality rate in the control arm would require just over 13,000 patients to detect a 15 percent relative increase in mortality with 80 percent power and α=0.05.^d^

c Hazard ratio for the longest-available follow-up for these 37 trials was 1.05 (95% CI: 0.99 to 1.11) or consistent with the estimate in the previous section for the 44 trials analyzed.

d Obtained from a sample size estimate for proportions assuming complete follow-up.

Figure 11 Forest plot of trials pooled to estimate on-study mortality

CI = confidence interval; ESA = erythropoiesis-stimulating agent; HR = hazard ratio

Figure 11 displays a forest plot of studies reporting the hazard ratio estimate on-study mortality. Data for figure 11 are presented in Table 35. This figure is described further in section “Evidence Regarding the Class of Erythropoietic-Stimulating Agents” as follows: “Pooling on-study mortality from the 37 trials yielded an estimated hazard ratio of 1.17 (95 percent CI: 1.04, 1.31; I2=0 percent) as shown in (including the trial enrolling pediatric patients left estimate unchanged) and a Bayesian random effects RR of 1.15 (95 percent CI: 1.02, 1.31). I2, while zero percent, should not be interpreted as a lack of heterogeneity69 because it depends on within-study precision, which in these trials is exceedingly low. Considered as a whole and displayed in the estimates are consistent with an association between ESA treatment and increased mortality during the active treatment period. A limitation of these data is the uncertainty (wide confidence intervals) accompanying individual trial results, as none were designed or powered to detect even a lower limit for increased mortality risk during the active treatment period. To illustrate, a trial randomized 1:1 to treatment or control with an anticipated 10 percent mortality rate in the control arm would require just over 13,000 patients to detect a 15 percent relative increase in mortality with 80 percent power and α=0.05.”

Table 35 All pooled results for on-study mortality

Variable | Darbepoetin vs. Epoetin | Epoetin vs. Control | Darbepoetin vs. Control | Epoetin or Darbepoetin vs. Control
Number of trials | 2 | 31 | 6 | 37
Patients analyzed | 1,567 | 8,618 | 2,648 | 11,266
Pooled hazard ratio | 0.90 | 1.19^a,b^ | 1.05^c^ | 1.17^d,e,f^
(95% confidence interval) | (0.67 to 1.20) | (1.05 to 1.36) | (0.80 to 1.38) | (1.04 to 1.31)
I^2^ | 72% | 3% | 0% | 0%

a Including the trial enrolling pediatric patients left estimate and CI unchanged.

b Estimate in Bayesian random effects model 1.16 (95% CrI: 1.00 to 1.32).

c Estimate in Bayesian random effects model 1.10 (95% CrI: 0.76 to 1.58).

d Estimate in Bayesian random effects model 1.15 (95% CrI: 1.02 to 1.31).

e Including the trial enrolling pediatric patients left estimate and CI unchanged.

f Excluding the 2 radiotherapy only trials34,81 1.16 (95% CI: 1.03 to 1.31), or the 3 trials classified here as radiotherapy or predominantly radiotherapy34,81,83 1.16 (95% CI: 1.03 to 1.30).

Subgroup differences were explored in meta-regressions. As with overall survival, the Peto method of combining hazard ratios is not readily amenable to including covariates, so meta-regressions were performed using a random-effects model so that estimates are not precisely comparable. The lack of effect modification by any study characteristic (Table 36) is consistent with the wide confidence intervals among trials. However, given the magnitude of effects, lack of precision, and trial variability, meaningful differences would not be expected.

Table 36 Relative risks from single covariate meta-regressions—on-study mortality epoetin or darbepoetin versus control

Covariate | Group | RR (95% CI) | p-Value
Dose Escalation | Yes | 1.16 (0.97 to 1.38) | 0.96
Dose Escalation | No | 1.15 (0.86 to 1.54) | 0.96
Iron | All other | 1.16 (0.93 to 1.46) | 0.89
Iron | As necessary | 1.14 (0.81 to 1.61) | 0.89
Platinum-Base Chemotherapy | Yes | 1.21 (1.03 to 1.42) | 0.39
Platinum-Base Chemotherapy | No | 1.09 (0.83 to 1.44) | 0.39
Chemo or Radiotherapy | Chemo ± Radiotherapy | 1.14 (1.02 to 1.28) | 0.47
Chemo or Radiotherapy | Radiotherapy | 1.49 (0.72 to 3.09) | 0.47
Baseline Hb | > 10 g/dL | 0.98 (0.78 to 1.23) | 0.12
Baseline Hb | ≤ 10 g/dL | 1.21 (0.85 to 1.72) | 0.12
Study Duration | ≤ 12 weeks | 0.95 (0.62 to 1.47) | 0.39
Study Duration | > 12 weeks | 1.06 (0.64 to 1.76) | 0.39
Study Quality | Low | 1.17 (0.98 to 1.41) | 0.75
Study Quality | High | 1.13 (0.84 to 1.52) | 0.75
Blinding | Yes | 1.13 (0.98 to 1.30) | 0.75
Blinding | No | 1.17 (0.89 to 1.54) | 0.75

CI = confidence interval; RR = relative risk

Finally, we explored the relationship of underlying mortality rates to increased risk accompanying ESA treatment. The single trial of pediatric patients was excluded from these analyses. Figure 12 plots the 16-week mortality rate in the control arms (either reported in Bohlius et al.48 for trials with 12-weeks of ESA treatment, or estimated for trials of different length) against the logarithm^e^ of on-study relative risk of mortality. The depiction is consistent with a higher relative risk in trials with lower control arm mortality rates. Moreover, when included in a model,69 control arm mortality modified the relative effect (p=0.002). Table 37 displays the estimated relative risks according to approximate quartiles^f^ of 16-week mortality rate in control patients, as well as for a trial with very low (1%) control arm on-study mortality. These results are consistent with higher relative risks in trials enrolling patients at lower risk of mortality during the active treatment period.

e The log(RR) is a linear variable while RR is not.

f Actual quartiles were 0.022, 0.057, and 0.094.

Figure 12 Plot of control arm mortality rate during ESA treatment and the four following weeks versus relative risk plotted on a logarithmic scale^*^ * Excludes trials with no control arm deaths. For trials administering ESA for fewer or more than 12 weeks, the 16-week mortality rate was calculated. Symbols proportional to study size.

Figure 12 is a plot of control arm mortality rate during ESA treatment and the four following weeks versus relative risk plotted on a logarithmic scale. This figure is described further in section “Evidence Regarding the Class of Erythropoietic-Stimulating Agents” as follows: “plots the 16-week mortality rate in the control arms (either reported in Bohlius et al. for trials with 12-weeks ESA treatment, or estimated for trials of different length) against the logarithm of on-study relative risk of mortality. The depiction is consistent with a higher relative risk in trials with lower control arm mortality rates. Moreover, when included in a model, control arm mortality modified the relative effect (p=0.002).”

Table 37 Relationship between 16-week mortality rate in control arm and relative risk

Control Arm 12-Week Mortality | Relative Risk | 95% CrI^a^
1.0% | 1.66 | (1.25 to 2.16)
2.5% | 1.55 | (1.23 to 1.95)
7.5% | 1.25 | (1.10 to 1.43)
10.0% | 1.13 | (1.00 to 1.27)

CrI = credible interval

a The credible interval overlapping with 1.0 should not be interpreted as lack of increased risk. The analysis in this collection of trials lacks sufficient power to support conclusions other than a modification of effect by underlying risk or prognosis.

##### On-Study Mortality and Number Needed To Harm

Applying the pooled relative risk estimates, we estimated the number of patients needing to be treated to result in one on-study death. Assuming the relative risk constant with control arm mortality rate (underlying risk) and on-study mortality rate of 1 percent, or patients with good prognoses, treating 588 patients would result in 1 additional death (Table 38). With an on-study mortality rate of 10 percent, or patients with generally poor prognosis, treating 59 patients would result in 1 additional death. If the relative risk varies with underlying risk as suggested by these analyses, the respective numbers of patients would be 152 and 77.

Table 38 Number needed to harm or resulting in one on-study death according to underlying mortality rate

Comparison | On-Study Mortality Rate^a^ | RR | NNH | 95% CI
RR uniform with underlying risk | 1.0% | 1.17 | 588 | (322 to 2500)
RR uniform with underlying risk | 2.5% | 1.17 | 235 | (129 to 1000)
RR uniform with underlying risk | 7.5% | 1.17 | 78 | (43 to 333)
RR uniform with underlying risk | 10.0% | 1.17 | 59 | (32 to 250)
RR associated with underlying risk | 1.0% | 1.66 | 152 | (86 to 400)
RR associated with underlying risk | 2.5% | 1.55 | 73 | (42 to 174)
RR associated with underlying risk | 7.5% | 1.25 | 53 | (31 to 133)
RR associated with underlying risk | 10.0% | 1.13 | 77 | (37 to undefined)

CI = confidence interval; NNH = number needed to harm; RR = relative risk

a In 21 trials (57 percent of those pooled), the estimated control arm on-study mortality rate exceeded 7.5 percent.

#### Summary of Overall Survival and On-Study Mortality Results

The body of evidence is consistent with increased mortality risk during the active treatment period that is not observed over the longer term including follow-up after active treatment. This increased risk is consistent with a biologically plausible effect. While overall or longer-term pooled relative hazards were not increased, the on-study results indicate that relative hazards are not constant over time and therefore obscured in the long-term estimates.^g^ As pointed out previously, a constant relative hazard (proportional hazards) was assumed, yet appears inconsistent with these results. The informative result is therefore that mortality risk is increased during the duration of ESA therapy. The estimated NNH, or number of patients treated to result in one death, was fewer than 100 for those with the poorest prognosis (highest underlying risk).

g The on-study results are hidden within the long-term estimates.

#### Evidence GRADE

The evidence (Table 39) shows an increase in mortality for ESAs during and shortly following ESA treatment (on-study) (overall strength of evidence moderate).

Table 39 On-study mortality: ESA versus control (GRADE evidence table)

Trials (N) | Subjects (N) | Risk of Bias Design/Quality | Consistency | Directness | Precision | Results HR (95% CI); I2 | Overall Strength of Evidence
37 | 11,266 | Medium^a^ trial quality high-18; low-19 | Inconsistent | Direct | Precise | 1.17 (1.04 to 1.31) 0% | Moderate

CI = confidence interval; HR = hazard ratio

a No trial was powered to detect a survival difference

### Meta-Analyses of Survival Outcomes

To further examine the consistency of the survival and on-study mortality results, we evaluated meta-analyses comparing ESA with control in patients undergoing cancer treatment (also reporting results for thromboembolic complications). Only meta-analyses including trials published following and not associated with our previous review were included to be able to compare results with this update. Our literature search for meta-analyses resulted in 116 citations, of which 56 were classified as meta-analyses and of which 15 were selected for full review.48,141,145–158 We included meta-analyses that:

1. Evaluated survival,
2. Were not limited by cancer type,
3. Excluded trials of patients with myelodysplastic syndrome, and
4. Analyzed a subgroup of trials in which patients received concurrent chemo/radiotherapy.

Table 40 shows the 15 published meta-analyses that were reviewed in full, included, or excluded (with reasons for exclusion). Appendix Table G1 lists the trials included in the four meta-analyses appraised in our assessment.

Table 40 Included and excluded published meta-analyses

Meta-Analysis | Included/Excluded | Perioperative, Myeloablative Procedures Excluded? (Required=Yes) | Limited by Cancer Type? (Required=No) | Other
Bennett 2008^145^ | Included | Yes | No
Bohlius 2009^48^ | Included | Yes | No
Glaspy 2010^146^ | Included | Yes | No
Ludwig 2009^141^ | Included | Yes | No
Shehata 2007^147^ | Excluded | | Yes
Aapro 2008^148^ & 2009^149^ | Excluded | No
Lambin 2009^150^ | Excluded | | Yes
Tonelli 2009^151^ | Excluded | No
Kimel 2008^152^ | Excluded | | | Included only trials reporting HRQoL
Gascon 2008^153^ | Excluded | | | Review of other meta-analyses
Cornes 2007^154^ | Excluded | | | Review of cost-effectiveness studies
Minton 2008^155^ | Excluded | | | Limited to fatigue outcomes
Ray-Coquard 2008^156^ | Excluded | | | Guidelines based on systematic review and expert judgment
Katsumata 2011^157^ | Excluded | | | Abstract only; insufficient information for AMSTAR review
Vansteenkiste 2012^158^ | Excluded | | Yes

AMSTAR = assessment of multiple systematic reviews; HRQoL = health-related quality of life

#### Quality Assessment

We evaluated the methodologic quality of the meta-analyses using AMSTAR,60 a measurement instrument for the “assessment of multiple systematic reviews” (Table 41). For each AMSTAR domain (question), the instrument provides detail on desirable information to include or methods to be used. Table 41 provides a brief summary of our assessment of each study for each question (desired answers are indicated in brackets after the question in the first column). AMSTAR does not provide a summary score; however, based on the results, Bohlius et al.48 appears to be the highest quality review and additionally is a patient-level meta-analysis. Ludwig et al.141 is limited compared to the other reviews being focused solely on darbepoetin trials in patients with chemotherapy-induced anemia, but is a patient-level meta-analysis.

Table 41 AMSTAR quality evaluation of meta-analyses

AMSTAR Component | Glaspy 2010^146^ | Bohlius 2009^48^ | Bennett 2008^145^ | Ludwig 2009^141^
A priori design provided? [Yes] | Not reported | Yes | Not reported | Not reported
Duplicate study selection/data abstraction? [Yes] | Not reported | Yes | Yes | Not reported
Comprehensive literature search? [Yes] | Yes | Yes | Yes | No
Publication status used as inclusion criterion? [No] | No | No | No | No
List of included and excluded trials provided? [Yes] | Yes - included only | Yes - included list in publication; excluded list in Cochrane review authored by same group | Yes - included only | Yes - included only
Characteristics of included trials provided? [Yes] | Yes - minimal | Yes | Yes | Yes
Quality of included trials assessed? [Yes] | No | Yes | Only with regard to prospective evaluation of outcomes of interest | No
Quality of included trials used in formulating conclusions? [Yes] | No | Yes | Yes | No
Methods used to combine study findings appropriate? [Yes] | Yes | Yes | Yes | Yes
Publication bias assessed? [Yes] | No | Yes | Yes | No
Conflict of interest stated? [Yes] | No | Yes - 7 of 23 authors received honoraria, travel grants, or research funding from ESA suppliers; 1 author conducts systematic reviews of health technology for the Blue Cross and Blue Shield Association | Yes - 2 of 21 authors were consultants and/or received research funding from an ESA supplier | Yes - all authors reported employment, stock ownership, consulting, honoraria, and/or research funding from an ESA supplier

AMSTAR = assessment of multiple systematic reviews; ESA = erythropoiesis-stimulating agent

#### Results

For overall survival using longest available follow-up, only Bennett et al.145 found significantly poorer survival with ESA use—HR 1.10 (95% CI: 1.01,1.20; I^2^=20%; 45 trials). Both Bohlius et al.48 and Ludwig et al.141 pooled trial results for the on-study or active treatment period only and found increased risks of mortality. In Bohlius et al.,48 including a much larger number of trials, the risk of on-study mortality was increased in the chemotherapy trials—HR 1.10 (95% CI: 0.98 to 1.24; I^2^=0%; 38 trials); and for all trials a HR of 1.17 (95% CI: 1.06 to 1.30; I^2^=0%; 53 trials) (Table 42). Ludwig et al.,141 including individual patient data from six darbepoetin trials, found an increased risk of mortality during the on-study period of similar magnitude—HR 1.11 (95% CI: 0.84 to 1.47; I^2^ NR). Both results are similar in magnitude to those obtained in the current analysis.

Table 42 Overall survival, thromboembolic events, and disease progression meta-analysis results by study

Characteristics | Factor | Glaspy 2010^146^ | Bohlius 2009^48^ | Bennett 2008^145^ | Ludwig 2009^141^
Analysis methods | | ORs were generated using the Comprehensive Meta-Analysis (V2) software and random-effects models; intention-to-treat (ITT) and modified-ITT approaches (only patients who received study drug were analyzed) were used; sensitivity analyses were carried out on 20 chemotherapy trials with long-term follow-up (46 months) “to address concerns regarding use of OR as a point estimate.” For sensitivity analyses, patient-level data from 16 of the 20 trials were obtained. | Authors calculated log hazard ratios with log-rank test and Cox regression for each study and combined these in fixed-effects and random-effects meta-analyses (2-stage method). Also calculated Cox regression models stratified by study (1-stage fixed-effects method). Trials with no events in both groups did not contribute. All analyses were by intention-to-treat. | Pooled RR, HR using random-effects models; “When mortality events were not available, HRs were calculated by using the inverse variance method to pool HRs. When VTE events were not available, a correction factor (0.5) was used to compute the RRs.” | Kaplan-Meier survival curves were created for overall survival, progression-free survival, and disease progression; all included long-term follow-up data. Effect of ESAs was characterized using Cox proportional hazards models stratified by study protocol.
Overall | Trials | 60 | 53 | 51 | 6
Overall | Patients | 15,323 | 13933 | 13,611 | 2,122
Chemotherapy and/or radiotherapy | Trials | 51 | 53 | 45
Chemotherapy and/or radiotherapy | Patients | 13,422 | 13933 | 11,522
Chemotherapy +/− radiotherapy | Trials | 47 (includes chemoradiotherapy) | 38 (no chemoradiotherapy) | | 6
Chemotherapy +/− radiotherapy | Patients | 12,108 (includes chemoradiotherapy) | 10,441 (no chemoradiotherapy) | | 2,122
Radiotherapy alone | Trials | 4 | 3 | 3
Radiotherapy alone | Patients | 1,314 | 799 | 1,173
No Treatment | Trials | 9 | 5 | 6
No Treatment | Patients | 1,901 | 1690 | 2,089
Results Report by followup | On-study or active treatment | No | Yes | No | Yes
Results Report by followup | Long- or mixed-term followup | Yes | Yes | Yes | Yes
Meta-Analysis Results – Overall Survival (Long- or Mixed-Term Pooled Effect [HR or [underlined: OR]]) | Chemotherapy and/or radiotherapy | NR | NR | 1.09 (0.99 to 1.19); I^2^=21%
Meta-Analysis Results – Overall Survival (Long- or Mixed-Term Pooled Effect [HR or [underlined: OR]]) | Chemotherapy +/− Radiotherapy | [underlined: 1.03 (0.93 to 1.13)]; I^2^=1% | 1.04 (0.97 to 1.11); I^2^=5% | NR | 0.97 (0.85 to 1.10); I^2^ NR
Meta-Analysis Results – Overall Survival (Long- or Mixed-Term Pooled Effect [HR or [underlined: OR]]) | Radiotherapy Only | [underlined: 1.18 (0.95 to 1.47)]; I^2^ NR | NR | NR | -
Meta-Analysis Results – Overall Survival (Long- or Mixed-Term Pooled Effect [HR or [underlined: OR]]) | All Trials | [underlined: 1.06 (0.97 to 1.15)]; I^2^=0% | 1.06 (1.00 to 1.12); I^2^=7% | 1.10 (1.01 to 1.20); I^2^=20%
Chemotherapy and/or Radiotherapy (On-Study or Active Treatment Pooled Effect [HR or [underlined: OR]]) | Chemotherapy +/− Radiotherapy | | 1.10 (0.98 to 1.24); I^2^=0% | | 1.11 (0.84 to 1.47); I^2^ NR
Chemotherapy and/or Radiotherapy (On-Study or Active Treatment Pooled Effect [HR or [underlined: OR]]) | Radiotherapy only | | NR
Chemotherapy and/or Radiotherapy (On-Study or Active Treatment Pooled Effect [HR or [underlined: OR]]) | All trials | | 1.17 (1.06 to 1.30); I^2^=0%
Thromboembolic events | N trials included | 44 | | 38 | 6
Thromboembolic events | Total N patients | 13,196 | | 8172 | 2,122
Thromboembolic events | (HR or [underlined: OR]) | [underlined: 1.48 (1.28 to 1.72)] | | 1.57 (1.31 to 1.87) | 1.57 (1.10 to 2.26)
Thromboembolic events | (HR or [underlined: OR]) | all reporting | | 1.57 (1.31 to 1.87) | 1.57 (1.10 to 2.26)
Thromboembolic events | (HR or [underlined: OR]) | [underlined: 1.48 (1.27 to 1.72)] | | 1.57 (1.31 to 1.87) | 1.57 (1.10 to 2.26)
Thromboembolic events | (HR or [underlined: OR]) | chemotherapy only | | 1.57 (1.31 to 1.87) | 1.57 (1.10 to 2.26)
Disease progression | N trials included | 26 | | | 6
Disease progression | Total N patients | 9646 | | | 2,122
Disease progression | (HR or [underlined: OR]) | [underlined: 1.01 (0.90 to 1.14)] | | | 0.92 (0.82 to 1.03)
Disease progression | (HR or [underlined: OR]) | all reporting | | | 0.92 (0.82 to 1.03)
Disease progression | (HR or [underlined: OR]) | [underlined: 0.95 (0.85 to 1.06)] | | | 0.92 (0.82 to 1.03)
Disease progression | (HR or [underlined: OR]) | chemotherapy only | | | 0.92 (0.82 to 1.03)

ESA = erythropoiesis-stimulating agent; HR = hazard ratio; NR = not reported; OR = odds ratio; RR = relative risk; VTE = venous thromboembolism

(As anticipated from previous reviews, estimates of relative effect of ESAs for thromboembolic events ranged from 1.5 to 1.6. No effect was found for disease progression.)

### KQ1 Progression-Free Survival and Related Outcomes

Twenty-two trials reported results related to survival with disease progression;8,34,35,46,51,81–84,86,96,97,99,100,102,110,114,116,124,125,130,131 few trials included progression free survival as a primary outcome. Trials and results are briefly summarized in Appendix Table H1.

Tumor progression was reported variably as a hazard ratio or a risk ratio for progression-free survival, as disease-free survival, as time to progression, or as the proportion of patients with tumor progression. Only a minority of trials defined how disease progression was measured in the published report. Where definitions were provided, they were not always consistent across trials. In light of such varied and insufficient reporting, combining results was not possible.

Of the 22 trials, only three reported significant differences in disease-free or progression-free survival, one trial in favor of epoetin82 and two in favor of control.34,46 Thus, these results do not add important information to the discussion of ESA outcomes.

### KQ1 Thromboembolic Events

Ascertainment of thromboembolic events differed considerably across trials. Definitions either varied or in a majority of trials were unstated (Appendix Tables C24 and C25). Given lack of uniformity, any of the following reported events were included: thrombosis, transient ischemic attack, stroke, pulmonary embolism, or myocardial infarction. There were also discrepancies in different data sources for the same trials (Appendix Tables C26 and C27). When there were discrepancies, the most complete source of data reporting absolute event rates was used or, alternatively, data with the most consistent definitions across trials and absolute event rates were included (similar to the 2006 review). Accordingly, much of the thromboembolic event data were obtained from the 2004 FDA ODAC hearings. Finally, the variable detail in reported diagnoses of thromboembolic events and discrepancies among sources advise that effects are accompanied by uncertainties in addition to those included in any pooled estimates.

Trials included in these analyses and data source are listed in Table 14; summary characteristics are shown in Table 43.

Table 43 Summary of characteristics for trials included in analysis of thromboembolic events

Characteristics | Factor | Darbepoetin vs. Epoetin | Epoetin vs. Control | Darbepoetin vs. Control | Epoetin or Darbepoetin vs. Control
Trials | N/A | 3 | 32^b^ | 6 | 38
Patients | Treatment | 945 | 5,107 | 1,398 | 6,505
Patients | Comparator | 928 | 4,594 | 1,471 | 6,065
Mean Age Range^a^ | Treatment | 61.7–63.7 | 12.4–68.3 | 49.0–64.8 | 12.4–68.3
Mean Age Range^a^ | Comparator | 58.7–63.4 | 10.8–68.1 | 48.0–64.6 | 10.8–68.1
Trial Quality n (%) | High | 0 (0) | 16 (50) | 4 (66.7) | 20 (52.6)
Trial Quality n (%) | Low | 3 (100) | 16 (50) | 2 (33.3) | 18 (47.4)
Treatment Modality n (%) | Chemotherapy | 3 (100) | 24 (75) | 5 (83.3) | 29 (76.3)
Treatment Modality n (%) | Chemotherapy includes Platinum | 3 (100) | 18 (56.2) | 3 (50) | 21 (55.3)
Treatment Modality n (%) | Radiotherapy | 0 (0) | 3 (9.4) | 1 (16.7) | 4 (10.5)
Treatment Modality n (%) | Chemoradiotherapy | 0 (0) | 5 (15.6) | 0 (0) | 5 (13.2)
Dose Escalation n (%) | Allowed | 0 (0) | 15 (46.9) | 1 (16.7) | 16 (42.1)
Dose Escalation n (%) | Not allowed | 3 (100) | 16 (50) | 4 (66.7) | 20 (52.6)
Dose Escalation n (%) | Unknown | 0 (0) | 1 (3.1) | 1 (16.7) | 2 (5.3)
Iron n (%) | As necessary | 0 (0) | 22 (68.8) | 4 (66.7) | 26 (68.4)
Iron n (%) | Other including fixed | 1 (33.3) | 7 (21.9) | 2 (33.3) | 9 (23.7)
Iron n (%) | Unknown | 2 (66.7) | 3 (9.4) | 0 (0) | 3 (7.9)
Tumor Type n (%) | Solid | 2 (66.7) | 20 (62.5) | 4 (66.7) | 24 (63.2)
Tumor Type n (%) | Mixed | 1 (33.3) | 7 (21.9) | 1 (16.7) | 8 (21.1)
Tumor Type n (%) | Hematologic | 0 (0) | 4 (12.5) | 1 (16.7) | 5 (13.2)
Baseline Hb g/dL | N/A | 10.1–10.4 | 9.1–13.7 | 9.5–13.6 | 9.1–13.7
Therapy Duration (weeks) | N/A | 14–16 | 4–52 | 9–23 | 4–52

Hb g/dL = hemoglobin grams per deciliter; N/A = not applicable

a Of reported means or medians.

b One trial103 reported no events in either treatment arm.

#### Darbepoetin Versus Epoetin

Three trials reported thromboembolic event rates for participants randomized to darbepoetin or epoetin.134,136,137 The trials differed in tumor type and iron supplementation (Table 43).

##### Results

The pooled relative risk from the three trials showed no difference between agents—RR 0.86 (95% CI: 0.61 to 1.21; I^2^=0%). Event rates in the trials ranged from 1.3 to 11.4 percent.

##### Changes From 2006 Review

There were no changes from the 2006 review.

#### Epoetin Versus Control

Thirty-two (Table 14) reported thromboembolic event rates in patients randomized to epoetin (N=5,107) or control (N=4,594), but there were no events in one trial.103 Trial characteristics varied, summarized in Table 43. One trial included pediatric patients,79 nine trials included only women with gynecologic and/or breast cancers.

##### Results

The pooled relative risk was consistent with an increased risk of thromboembolic events in epoetin treated patients—RR 1.50 (95% CI: 1.26 to 1.77; I^2^=0%). Absolute event rates in the epoetin and control arms ranged from 0 to 30.8 percent, and 0 to 12.3 percent, respectively.

##### Changes From 2006 Review

Ten trials from the previous review were excluded, 13 trials included unchanged, data were updated for seven trials, and 12 new trials were identified (Appendix Table F1). Table 44 compares current results with the 2006 review and sensitivity analysis with excluded trials showing similar results.

Table 44 Thromboembolic events: epoetin versus control—current report, current with trials excluded but in 2006 review, and 2006 review

Comparison | Trials | Epoetin N | Control N | RR (95% CI) | I^2^
Current | 31 | 5,050 | 4,535 | 1.50 (1.26 to 1.77) | 0%
Current & Excluded | 39 | 5,518 | 4,839 | 1.53 (1.30 to 1.81) | 0%
2006 review | 30 | 3,355 | 2,737 | 1.69 (1.36 to 2.10) | 0%

CI = confidence interval; RR = relative risk

#### Darbepoetin Versus Control

Six trials (Table 14) reported thromboembolic event rates in patients randomized to darbepoetin (N=1,080) or control (N=1,075). Trial characteristics varied somewhat (Table 43). In one trial, radiotherapy was the sole treatment modality.46

##### Results

There was evidence for an increased risk of thromboembolic events with darbepoetin—pooled RR 1.53 (95% CI: 1.18 to 2.00; I^2^=0%). Absolute event rates in the darbepoetin and control arms ranged from 2.7 to 21.6 percent and 0.6 to 14.5 percent, respectively.

##### Changes From 2006 Review

One trial from the previous review was included unchanged and five new trials were identified (Appendix Table F1). Table 45 compares current results and those from the single trial included in the 2006 review.

Table 45 Thromboembolic events: darbepoetin versus control—current report, current with trials excluded but in 2006 review, and 2006 review

Comparison | Trials | Darbepoetin N | Control N | RR (95% CI) | I^2^
Current | 6 | 1,398 | 1,471 | 1.53 (1.18 to 2.00) | 0%
2006 review | 1 | 155 | 159 | 1.44 (0.47 to 4.43) | —

CI = confidence interval; RR = relative risk

#### Evidence Regarding Erythropoietic-Stimulating Agents

Combining results from the 37 trials of epoetin or darbepoetin versus control yielded an association between treatment and thromboembolic events—pooled RR 1.51 (95% CI: 1.30 to 1.74; I^2^=0%). Absolute events rates ranged from 0 to 30.8 percent in treatment arms (pooled 5.8%) and from 0 to 14.5 percent in control arms (pooled 3.2%); risk differences ranged from -3.4 to 26.9 percent. Figure 13 displays the distribution of absolute risk differences showing that in almost all trials thromboembolic event rates accompanying ESA treatment exceeded, often substantially, control arm rates.

Figure 13 Distribution of risk differences in thromboembolic event rates—ESA versus control^*^ * A single outlier trial with a risk difference of 0.27 is not shown.

Figure 13 displays the distribution of risk differences in thromboembolic event rates ESA arms to control. It shows a distribution centered about 2.5 percent but skewed to the right or a tail with studies having higher risk differences up to 10 percent.

#### Changes From 2006 Review

Ten trials from the previous review were excluded, 14 included unchanged, data were updated for seven trials, and 17 new trials were identified (Appendix Table F1). Table 46 shows similar results for the current and 2006 reviews as well as sensitivity analysis with the excluded trials.

Table 46 Thromboembolic events: epoetin or darbepoetin versus control—current report, current with trials excluded but in 2006 review, and 2006 review

Comparison | Trials | Epoetin or Darbepoetin N | Control N | RR (95% CI) | I^2^
Current | 37 | 6,448 | 6,006 | 1.51 (1.30 to 1.74) | 0%
Current & Excluded | 44 | 6,916 | 6,310 | 1.53 (1.33 to 1.77) | 0%
2006 review | 31 | 3,510 | 2,896 | 1.68 (1.36 to 2.08) | 0%

CI = confidence interval; RR = relative risk

#### Evidence GRADE

The evidence is consistent an increased risk of thromboembolic events accompanying ESA treatment (overall strength of evidence moderate), but no clinically meaningful difference between epoetin and darbepoetin in thromboembolic events (Table 47).

Table 47 Thromboembolic events: ESA versus control (GRADE evidence table)

Trials (N) | Subjects (N) | Risk of Bias Design/Quality | Consistency | Directness | Precision | Results RR (95% CI); I^2^ | Overall Strength of Evidence
37 | 12,454 | Medium^a^ trial quality high-20; low-17 | Consistent | Direct | Precise | 1.51 (1.30 to 1.74); 0% | Moderate

CI = confidence interval; RR = relative risk

a Due to lack of consistent endpoint ascertainment across trials.

### KQ1 Health-Related Quality of Life

Quality of life is a general concept that is often inclusive of all aspects of life that impact on a person’s well-being. A more specific term, health-related quality of life (HRQoL), describes aspects of quality of life directly related to individual health and distinguishes these from experiences less directly related to the individual and more dependent on social and political trends.159 The FDA includes quality of life measures that support labeling claims, but avoids the use of “quality of life” terminology, preferring “patient reported outcomes” (PRO) for this particular purpose. A PRO is “any report of the status of a patient’s health condition that comes directly from the patient, without interpretation of the patient’s response by anyone.”160

Measuring HRQoL in clinical trials can be particularly helpful for eventual patient management when the symptoms of a condition are many and varied, and when the treatment of interest is expected to have little if any impact on survival but a positive impact on HRQoL. Note that only controlled trials can support causal inferences about the effects of a particular treatment on quality of life.161 Potentially confounding factors (e.g., changes in disease status) that may affect both direct treatment outcome and quality of life are distributed randomly and equally among trial arms and do not affect the results.

Instruments designed to measure change in HRQoL may be general (“global”) or specific to the disease under study. Global instruments are intended for use across various disease populations, and permit comparison of HRQoL outcomes among interventions and diseases. Global instruments, however, may be insensitive and fail to detect small but clinically important changes. Disease or condition-specific instruments address this problem, but may be limited by their narrow range of applicability. Thus, global and specific instruments are often used together. Researchers measuring the impact of anemia symptoms due to cancer therapy, and the treatment of anemia have used a variety of HRQoL instruments. In fact, one of the difficulties in attempting pooled analysis of results in this area has been lack of consensus on one or a very few validated instruments for use in clinical trials.

The FDA presupposes that use of a PRO as a clinical trial endpoint in order to support labeling claims is based on use of an instrument that has been “adequately developed and validated.”160 Validation of a fully developed questionnaire consists of studies that address the following elements, where patients meet the criteria for the type of study intervention:162 Reproducibility: repeated administration to stable patients produces the same result;

- Responsiveness: in stable patients administered a relevant intervention of known efficacy, the questionnaire should show sufficiently large improvement in HRQoL relative to the variability shown by stable patients;
- Construct validity: the questionnaire behaves in relation to other measures as expected if it was really measuring the intended domains of HRQoL.

In addition to using a validated instrument, the logistics of questionnaire administration should be handled to minimize the impact on the integrity of the quality of life assessment. Feedback from the investigator, treating physician, or staff that affects the patient’s reported sense of well-being is a potential source of bias. Ideally, the instrument should be administered prior to discussions with health care providers as to treatment response, adverse events, or other information (e.g., hemoglobin level) that could affect patients’ responses to the quality of life questionnaire. The study protocol should detail the time intervals for administering the instrument as well as training for staff or for the patient if the instrument is self-administered.

As noted, trials of ESAs reporting HRQoL outcomes have used a variety of instruments, some of them not validated. However, many of the more recent trials have used a validated, multi-dimensional instrument, The Functional Assessment of Cancer-Anemia (FACT-An),163 or one of its subscales. The core of the FACT-An is the Functional Assessment of Cancer Therapy—General (FACT-G), which contains 27 questions that can generate subscale scores regarding physical, functional, emotional, and social well-being.164 Data from 1,172 cancer patients who answered the FACT-G questionnaire indicated that fatigue was the symptom most often reported (73%). As a result, two additional subscales assess fatigue and anemia. The FACT-Fatigue (FACT-F) consists of a fatigue-specific subscale of 13 items; the FACT-Anemia (FACT-An) adds to the FACT-F seven nonfatigue items relevant to anemia in cancer patients. For details and references regarding instrument validation, the reader is referred to the Functional Assessment of Chronic Illness Therapy Web site.^h^ Other well-validated global instruments that have been used, sometimes in conjunction with the FACT-An or a subscale, include the Short Form (36) Health Survey (SF-36) and the European Organization for Research and Treatment of Cancer (EORTC) Quality of Life Questionnaire (QLQ-C30).

h http://facit.org/validity/validation_articles.aspx

HRQoL results have been evaluated in different ways and often incompletely reported (e.g., baseline scores, absolute values, and measures of result dispersion may be missing), making it difficult to pool results across trials. Analysis should compare change from baseline between study and control arms from randomized controlled trials to adequately control for placebo response. Other factors may need to be considered in the analysis. For example, in the previous systematic reviews conducted by TEC, only trials with average baseline hemoglobin less than 10 mg/dL reported statistically significant HRQoL results using FACT-An or subscales whereas trials of patients with higher average baseline hemoglobin were not significant for this outcome.

Missing data can substantially impact interpretation of HRQoL results. First, when HRQoL is a secondary outcome, not all patients in the trial may be administered questionnaires. Often missing from the trial report is a description of the HRQoL subset and evaluation of potential for selection bias. Second, among those followed for HRQoL, nonrandom missing data can result in serious bias. For example, patients with missing questionnaires may be the sickest patients or those least responsive to therapy; failure to respond to specific items in a questionnaire also raises concerns. Trial protocols should include a detailed plan for preventing missing data, investigating the pattern and mechanism of missing data, and addressing missing data in the analysis using acceptable methods and sensitivity analyses.

Statistically significant HRQoL results are often reported without additional discussion. However, statistically significant improvements in HRQoL measures in an ESA treated clinical trial population compared to control may not be clinically perceived by an individual patient as an improvement. For example, Clement et al.165 evaluated randomized controlled trials of ESA therapy in patients with anemia associated with chronic kidney disease that reported HRQoL results from a validated questionnaire (SF-36). The authors found that treating to attain hemoglobin >12 g/dL resulted in small, statistically significant, but not clinically meaningful changes in HRQoL. That is, on average, patients would not be able to perceive the improvement.

In recognition of the importance of clinical significance, the FDA160 encourages sponsors to “avoid proposing [PRO] labeling claims based on statistical significance alone.” Rather, results should ideally be compared to the minimal clinically important difference (MCID), the smallest difference in score in the domain of interest that patients perceive as beneficial and which would lead to a change in patient management.166 Modifications to this definition have addressed deterioration, such that harmful differences, which may be perceived on a different scale,167 are also considered.168 While the concept is appealing, MCID estimation is not simple, and estimates may vary depending on patient population, disease severity, and clinical study context.168,169

MCID estimation relies on anchor-based approaches, reviewed in a number of publications.168–171 Briefly, a well-understood external indicator (anchor) such as a laboratory measure, clinician rating, or patient-based global rating is used to categorize patients by degree of change from baseline in the anchor (e.g., none, small positive, large positive, small negative, large negative). The groups characterized as a little better or a little worse are the minimal change groups, and the change in the PRO in these groups is a measure of the MCID. Anchors should be selected for important qualities: change in the anchor should be clinically interpretable; and there should be a strong relationship between the anchor and the PRO measure. Use of multiple anchors is recommended for MCID estimation, and an MCID range, rather than a point estimate, is recommended to accommodate variability in the estimate as well as variability in the patient population and clinical scenario.168,169,172 Similarly, use of the lowest possible estimate is not recommended as some scores may be falsely included as meaningful; rather, a slightly higher cutoff may be more appropriate.173

Distribution-based methods, which rely on instrument score statistical distributions, may be used to supplement anchor-based MCID estimates but are not recommended as sole MCID estimation methods. These include defining MCID as one half of a standard deviation of a given HRQoL instrument based on a large review of studies by Norman et al.174 Standard error of measurement175,176 has also been proposed as a measure of MCID. Cohen et al.177 suggested 0.2, 0.5, and 0.8 standardized effects representing small, moderate, and large changes but in the context of power calculations. Such estimates are not always generalizable; in a review of studies using the FACT-G questionnaire,178 the authors found that use of Cohen’s thresholds resulted in at times overestimation and in other cases underestimation of an observed effect, concluding that “general rules for effect sizes may be too simplistic.”

Comparison of the mean difference in the PRO between study arms to the MCID should enable determination of clinical significance. However, and particularly when there are several HRQoL domains and results are close to the MCID, overall clinical significance may not be so clear. In addition to reporting data related to the mean difference, it is also helpful to report the difference between study arms in the proportion of patients achieving an improvement greater than the MCID as well as deterioration greater than the MCID. “Adding those differences in proportion yields a risk difference that one can convert to a number needed to treat (NNT),”170 a result that is intuitively easy to understand.

Both anchor- and distribution-based methods have been used to estimate MCID for FACT-An and subscales in cancer patients treated with epoetin. Two follow-up studies179,180 used change in hemoglobin as an anchor; only Patrick et al.180 reported correlations of 0.26 (FACT-G) and 0.29 (FACT-fatigue subscale) between QoL scale and a hemoglobin increase of 1 g/dL, similar to correlations reported in other trials.106,107 Neither study provided information on how to interpret change in hemoglobin. Cella et al.179 also used ECOG and Karnofsky performance scores as anchors. They did not report on the correlation of either performance scores with FACT scales, or on interpreting change in performance score. That these changes are closely linked to the physical aspects of QoL in epoetin and darbepoetin-treated patients is supported by data from an unrelated study of chemotherapy in patients with lung cancer, where baseline ECOG performance score was correlated with the EORTC QLQ C-30 scales at −0.52 (physical function), −0.63 (global health status), and 0.52 (fatigue).181 EORTC QLQ C-30 and FACT-G physical and functional domain scores have shown good correlation.182,183

In these studies, patients were separated only into “improved,” “unchanged/stable,” or “worsened” categories, with no identification of groups with only small improvement or small decline. Using simple differences between stable and improved groups, Patrick et al.180 estimated MCIDs at 2.5 for FACT-G and 4.2 for FACT-Fatigue. Cella et al.179 reported between-group changes for the FACT-Fatigue subscale as 0.2–8.8 score units and for the FACT-G Total as 1.9–9.9. Using Cohen’s recommendation of 0.2 as a “small” effect size to set MCID lower limits and point estimates, the authors reported MCIDs of 3 and 4 for FACT-Fatigue and FACT-G, respectively. While this study appropriately uses different anchors to accumulate between-group change data, it uses a distribution-based method to choose the actual MCID estimate, rather than identifying groups with perceived small changes in the anchor to determine the corresponding range of changes in FACT scores. Nevertheless, these MCID estimates have become widely reported in the literature.

Trials that convert health outcomes into a common result, such as quality-adjusted life years (QALYs) or cost (cost-utility and cost-benefit), cannot use the HRQoL results from PRO measures such as FACT scales. Rather, preference (utility)-based measures are required;184 their main purpose is to measure the “utility” of health states (that is, the preferences people have for different health states along a continuum extending from death to full health) in a way suitable for use in economic evaluation studies.

No ESA trials have reported HRQoL outcomes using utility-based measures. The scales used by instruments such as FACT scales may have minima and maxima that fall well within the conceptual range of utility-based measures, making conversion difficult. Such conversion has been attempted in other types of studies, and requires ad hoc assignment of reported health-status data categories to corresponding values on a standard health utility measure. However, the process has not been found uniform across studies or reliable within a single study.185 As an alternative, Ossa et al.186 used FACT-An to develop descriptions of health states related to anemia and the associated hemoglobin levels, and time tradeoff methods to determine utility values for the different states. Finally, Wilson et al.76 published utility values by hemoglobin level from ESA manufacturer submissions and used them to model cost per QALY.

Thus, recognized MCID estimates for the FACT-G and FACT-Fatigue scales are available to help determine whether HRQoL results for ESA clinical trials are clinically meaningful, and are used in the following discussion of HRQoL results. However, utility-based HRQoL measures are lacking to support decision analyses and health economic studies, forcing the use of basic surrogates such as hemoglobin levels (see section, “Decision Analysis”).

#### Quality of Life Outcomes

##### Summary of Trials

For this review, we included trials reporting health-related quality of life (HRQoL) evidence as change from baseline to final follow-up in each study arm, and change in treatment arm(s) compared to that in the control arm. Ideally, trials would also report the percentage of patients in each study arm that achieved a prespecified clinically meaningful improvement but few did. We also required trials to use a validated instrument; scales and subscales reported by included trials are described in Table 48. Trials reporting only linear analogue self-assessment (LASA) or visual analog scales (VAS) were excluded.

Table 48 Description of the scales and subscales evaluated in trials included in this review

FACT Instrument or Subscale | #Trials Reporting | Type of Instrument | Domains Addressed (#Questions) | Range of Scale (Highest=Most Favorable)
FACT-fatigue subscale | 20 (14 with complete data) | Symptom-specific | Fatigue-specific questions from anemia-specific questions of FACT-An (13) | 0–52
FACT non-fatigue anemia subscale | 8 | Symptom-specific | Questions from the anemia-specific questions of FACT-An that are not part of the FACT-fatigue subscale (7) | 0–28
FACT-An(emia) | 7 | Symptom-specific | Includes FACT-G, all domains (27)^a^ Anemia-specific symptoms (20) | 0–188
FACT-G(eneral) | 6 | General | Physical well-being (7) Social/family well-being (7) Emotional well-being (6) Functional well-being (7) | 0–108
SF-36 Physical Summary Component (PCS) score | 2 | General | Physical Functioning (10) Role Physical (4) Bodily Pain (2) (these scales contribute most to PSC scoring) | Transformed to mean of 50 and SD of 10 in the US population
EORTC QLQ-C30 core questionnaire | 2 | General | 5 functional domains 3 symptom scales single items for symptoms 2 global items (30) | Transformed to 0–100
SF-36 Mental Summary Component (MCS) score | 1 | General | Vitality (4) Social functioning (2) Role-emotional (3) Mental health (5) | Transformed to mean 50 and SD 10 in the US population
Nottingham Health Profile | 1 | General | Part I, 38 questions in 6 subareas:; - energy level (3); - pain (8); - emotional reaction (9); - sleep (5); - social isolation (5); - physical abilities (8); Part II, 7 life areas affected (7) | Part I:0–100 Part II: 0–7
Symptom Distress Scale | 1 | General | Nausea frequency, nausea severity, appetite, insomnia, pain frequency, pain severity, fatigue, bowel pattern, concentration, appearance, breathing, outlook, and cough (13) | Transformed to 0–100
PedsQL-GCS | 1 | General | Physical functioning (8) Emotional functioning (5) Social functioning (5) School functioning (5) | Transformed to 0–100
PedsQL 3.0 Cancer Module | 1 | Symptom-specific | Pain and hurt (2) Nausea (5) Procedural anxiety (3) Treatment anxiety (3) Worry (3) Cognitive problems (5) Perceived physical appearance (3) Communication (3) | Transformed to 0–100
Lung Cancer Symptom Scale | 1 | Symptom/Disease-specific | Patient scale: Symptoms, total symptomatic distress, activity status, overall quality of life Observer scale: Symptoms | VAS 0 (severe) to 100 Patient: 9 scales Observer: 6 scales

EORTC QLQ-C30 = ; FACT = Functional Assessment of Cancer Therapy; PedsQL-GCS = Pediatric Quality of Life Inventory-Generic Core Scale; SD = standard deviation

a While FACT-Anemia incorporates FACT-G, it was not classified as a general instrument since the results could be dominated by either the general FACT-G or the symptom-specific subscales.

Twenty-nine trials reported HRQoL results meeting the above criteria:

- 10,231 randomized patients (5,339 ESA; 4,835 control); number evaluated for HRQoL likely to be less
- 24 trials of epoetin (8,318 randomized; 4,304 epoetin, 4,014 control)
- 5 trials of darbepoetin (1,913 randomized; 1,035 epoetin, 878 control)
- 1 study of epoetin that reported a statistically significant difference in the total FACT-Anemia scale favoring ESA, but did not report data for inclusion in the evidence analysis.121 Three trials that reported results of FACT-Fatigue subscale results but with insufficient data to be included in a pooled analysis 99,109,115 Two of these studies also reported FACT-An Total Anemia and FACT non-fatigue subscale scores, but also without sufficient data for analysis.109,115

##### Objective of the Evidence Evaluation

The most commonly reported HRQoL instrument was the FACT-Fatigue subscale, with 14 trials of ESA versus no ESA reporting sufficient data for quantitative analysis (Table 48). The next most commonly reported instruments were the FACT nonfatigue anemia subscale and the total FACT-An in 8 and 7 trials, respectively. In view of the limited number of trials using the same instrument, and recommendations of Shekelle et al.57 that the 2006 evaluation of quality of life did not need updating (see Introduction), it was decided to limit the goals of the HRQoL evidence analysis and conduct a focused, quantitative evaluation of results from trials reporting data for the FACT-Fatigue subscale. The comparison is that for KQ1: epoetin (alfa or beta) or darbepoetin versus placebo/no treatment.

##### Data Analysis

The FACT-Fatigue subscale was evaluated in 20 trials; ESA treatment, compared to placebo or none, was found to statistically improve fatigue in eight trials (Table 50). Ten trials reported no statistically significant differences between ESA treatment and control arms. Vote-counting analysis (Table 50) found that no trial result favored the control arm. One trial reported results only in relation to increasing hemoglobin, finding a significant test of trend.129 One trial reported results without significance testing.130 Six trials did not report sufficient results for inclusion in a meta-analysis.35,99,109,115,124,127 Thus, 14 trials were included in a meta-analysis—3,643 participants (1,999 ESA; 1,644 control).

Table 50 Vote-counting results for trials reporting FACT-Fatigue subscale

Study | ESA | Evaluable for QoL N | Enrolled Not Evaluable % | Blinded | Significantly Favors ESA | Not Significant | Significantly Favors Control
Boogaerts 2003^87^ | Epo | 213 | 19 | No | •
Chang 2005^90^ | Epo | 338 | 3 | No | •
Christodoulou 2009^91^ | Epo | 153 | 55 | No | | •
Hedenus 2003^126^ | Epo | 303 | 13 | Yes | •^a^
Fujisaka 2011^99^ | Epo | 170 | 6 | Yes | | •
Hernandez 2009^127^ | Darb | 315 | 19 | Yes | | •
Hoskin 2009^81^ | Epo | NR | NR | No | | •
Iconomou 2003^106^ | Epo | 112 | 8 | No | •
Kotasek 2003^129^ | Darb | 249 | 2 | Yes | (NR) | (NR) | (NR)
Leyland-Jones 2005^35^ | Epo | NR | NR | Yes | | •
Littlewood 2001^107^ | Epo | 290 | 23 | Yes | •
Osterborg 2002^113^ | Epo | 263 | 23 | Yes | | •
Milroy 2011^109^ | Epo | 380 | 10 | No | | •
Pirker 2008^130^ | Darb | 484 | 19 | Yes
Pronzato 2010^115^ | Epo | 141 | 35 | No | •
Savonije 2005^119^ | Epo | 221 | 30 | No | •
Tsuboi 2009^123^ | Epo | 117 | 4 | Yes | | •
Vansteenkiste 2002^8^ | Darb | 255 | 20 | Yes | •
Wilkinson 2006^124^ | Epo | NR | NR | No | | •
Witzig 2005^125^ | Epo | 299 | 13 | Yes | | •

Darb = darbepoetin; Epo = epoetin; ESA = erythropoiesis-stimulating agent; NR = not reported; QoL = quality of life

a Significant after adjusting for baseline fatigue score.

Trial quality varied and only five of 14 identified HRQoL as a primary outcome (Table 48); up to 55 percent of enrolled patients were not evaluable for HRQoL in study arms. Blinding to treatment and patient blinding to hemoglobin value prior to HRQoL questionnaire administration was inconsistent. All trials administered ESA to achieve hemoglobin values greater than 12 g/dL in the treatment arms, higher than currently recommended. Few trials adjusted their analyses for the baseline value of the FACT-Fatigue; only eight reported baseline FACT-Fatigue results, so that it was not possible to adjust for this variable in the meta-regressions.

The mean difference between treatment arms was zero in one study, but never negative.

The pooled post-test difference in change was 2.74 (95% CI: 1.69 to 3.78; I^2^=45%) in favor of ESA treatment (Figure 14). The pooled mean change in the ESA arms was +2.1 (95% CI: −3.9 to 8.1; I^2^=0%), while in control arms −0.6 (95% CI: −6.4 to 5.2; I^2^=0%). Because it is important to control for the placebo effect in studies of HRQoL, we also evaluated the subset of studies reporting FACT-Fatigue outcomes that blinded patients to ESA treatment. In these eight studies,8,107,113,123,125,126,129,130 the pooled post-test difference in change was +1.92 (95% CI: 0.97 to 2.86; I^2^=0%; data not shown).

Figure 14 Forest plot—difference in change for FACT-Fatigue

CI = confidence interval; ESA = erythropoiesis-stimulating agent; SD = standard deviation; W = weight

Figure 14 displays a forest plot of studies mean difference in change for FACT-Fatigue. Data for figure 14 are presented in Table 50. This figure is described further in section “Quality of Life Outcomes: Objective of the Evidence Evaluation” as follows: “The mean difference between treatment arms was zero in one study, but never negative. The pooled post-test difference in change was 2.72 (95 percent CI: 1.69 to 3.74; I2=41 percent) in favor of ESA treatment. The pooled mean change in the ESA arms was +2.1 (95 percent CI: −3.9 to 8.1; I2=0 percent), while in control arms −0.6 (95 percent CI: −6.5 to 5.3; I2=0 percent).”

##### Conclusions

ESA treatment with epoetin or darbepoetin to high hemoglobin target values (>12 g/dL) was accompanied by higher HRQoL scores compared to transfusion as needed, as measured by the FACT-Fatigue subscale, in nearly all reporting trials (Appendix I). Vote-counting results suggest that ESA treatment may at least attenuate the decline seen in non-ESA treatment arms. The pooled end-of-treatment difference between study arms favored ESA treatment. The pooled mean change in the treatment arm and the pooled mean difference in change between study arms are less than 3, the generally accepted minimal clinically important difference estimated by Cella et al..179 However, the pooled mean difference between study arms (2.7) is the same as the lowest of the reported estimates of the MCID.179 In summarizing their data from anchor-based measures, Cella et al.179 accepted only mean differences that corresponded to a Cohen’s effect size of at least 0.2 (see Introduction: Health-related Quality of Life). The effect size for the mean difference calculated in the meta-analysis is 0.23 and for the change in the ESA treatment arm alone is 0.21. Thus, while statistically significant, the clinical significance of the FACT-Fatigue difference between ESA treatment and no ESA treatment is likely to be small referent to the MCID. Moreover, an analysis of only those studies reporting FACT-Fatigue that also blinded patients to treatment (i.e., ESA vs. placebo) resulted in a lower estimate of the pooled mean difference in change between study arms, which could be a result of the limited number of studies or an indication of a placebo effect in the unblinded studies.

This analysis has several limitations. First are those noted in the general QoL discussion with using MCID estimates as final arbiters of significant results, particularly here where results are nearly equal to the value of the estimated MCID. Other FACT scores were not analyzed due to insufficient data. In addition, FACT-Fatigue scores were reported in only a subset of included trials in this overall review, were not primary outcomes in most reporting studies, and were not reported for the vast majority of patients. Moreover, the conditions in which ESAs were administered (i.e. target values >12 g/dL) are not consistent with current practice. Thus, results may not be generalizable. However, they represent the current best estimate of HRQoL benefits, which would need to be considered along with the potential harms of treatment for each patient.

##### Changes From 2006 Review

Eight trials from the previous review were included unchanged and six new trials were included (Appendix Table F1).

#### Evidence GRADE

Treating to high target hemoglobin levels (≥12 g/dL) is accompanied by improved health-related quality of life (HRQoL) scores (e.g., FACT-Fatigue); any clinical significance of the improvement is likely to be small (overall strength of evidence low) (Table 49).

Table 49 HRQoL: ESA versus control (GRADE evidence table)

Trials (N) | Subjects (N) | Risk of Bias Design/Quality | Consistency | Directness | Precision | Results Mean Difference Change in FACT-Fatigue Score (95% CI); I^2^ | Overall Strength of Evidence
14 | 3,643 | High trial quality high-2; low-12 | Consistent | Direct | Precise | 2.74 (1.69 to 3.78); 45% | Low

GRADE = Grading of Recommendations Assessment, Development and Evaluation

### KQ1 Tumor Response and Progression

Different possible effects of erythropoietic stimulants on tumor response and progression have been posited. One is that through better tumor oxygenation, ESAs might improve chemotherapeutic agents’ cytocidal effects or enhance the effect of radiation therapy.138 However, overall and on-study mortality results are inconsistent with any potential beneficial effect. Moreover, stimulation of erythropoietin receptors on neoplastic cells187,188 could result in more rapid tumor growth.

To evaluate any effect of erythropoietic stimulants on tumor response and progression required trials with specific and homogeneous characteristics. Accordingly, we included only those that met the following criteria:

1. Enrolled a homogeneous population including patients with similar tumor types at the same stage when clinically appropriate; or trial results were stratified by tumor type and stage,
2. Participants were given a predefined and uniform anticancer therapy; or trial results were stratified by anticancer therapy, and
3. Trial was designed to prospectively assess tumor response or control, reporting either as a primary or secondary outcome.

Fifteen trials (13 epoetin,34,51,80,81,83,86,94,96,100,103,109,110,115 2 darbepoetin46,131) meeting these criteria were included. Because definitions of tumor response or progression varied, results were not pooled. Table 51 details characteristics of the 15 trials listing the variety of outcome measures assessed related to tumor progression and response. Results from those trials reporting tumor response outcomes are shown in Table 52. There was no evidence of an association between tumor response for any of the definitions and ESA use (results for other tumor outcomes are listed in Appendix J).

Table 51 Characteristics of trials reporting tumor response or duration-related outcomes

Study Characteristic | Blohmer 2011^86^ | Debus 2006^94^ | Engert 2010^96^ | Goss 2005^100^ | Gupta 2009^103^ | Henke 2003^34^ | Hoskin 2009^81^
Drug | Epoetin | Epoetin | Epoetin | Epoetin | Epoetin | Epoetin | Epoetin
Control N | 129 | 190 | 648 | 53 | 60 | 171 | 149
ESA N | 128 | 195 | 655 | 53 | 60 | 180 | 151
Malignancy | cervical (high risk) | NSCLC, stage IIIA/B, primarily inoperable | advanced HD | limited disease SCLC | cervical cancer (stage IIB–IIIB) | advanced (stage III, IV) head and neck | head and neck, stage I–IV
Treatment | Pt chemo + radio Tx | cisplatinum w/sequential chemoradiotherapy | chemotherapy, without platinum | Pt chemo + radio Tx | Pt chemo + radio Tx | radiotherapy | radiotherapy
Duration | 27 wks | NR | NR | 16–24 wks | NR | NR | 40 days
Outcome | RFS | TR | TR, FFTF, PFS | tumor control, PFS | DFS | PFS, tumor progression | local DFS, tumor response
Assessed | 1, 2, and 5 yrs | NR (planned 2 years) | NR | NR | 2 years (survival) | ≈2 years | 12 weeks
ESA dose | 3 × 10,000 IU/wk | 40,000 IU/wk | 40,000 IU/wk | 40,000 IU/wk | 3 × 10,000 IU/wk | 3 × 300 IU/kg/wk | if Hb <12.5 then 3 × 10,000 IU (25% of patients) if Hb >12.5 then 3 × 4,000 IU (75% of patients) sc
ESA duration (weeks) | 27 | 12 | 22–24 | 12–24 | 7 | 7 to 9 | 12
Baseline Hb (control/ESA) | 11.8/12.0 g/dL | NR | 12.3/12.2 g/dL | 13.5/13.5 g/dL | 10.7/10.4 g/dL | 11.8/11.7 g/dL | 13.7/13.4 g/dL
Hb target | 12.5–13.5 g/dL | 13–14 g/dL | 14 g/dL | 16 g/dL | NR | 14 g/dL, women 15 g/dL, men | 15 g/dL
Re-start if Hb less than | NR | 12 g/dL | NR | <14 g/dL | NR | 14 g/dL, women 15 g/dL, men | 14.5 g/dL
Drug | Epoetin | Epoetin | Epoetin | Epoetin | Epoetin | Epoetin | Darbepoetin
Control N | 71 | 167 | 325 | 109 | 55 | 20 | 262
ESA N | 77 | 160 | 333 | 107 | 58 | 18 | 260
Malignancy | head and neck nonmetastatic, not resected | non-small cell lung cancer | breast cancer | breast cancer | cervix carcinoma | neuroblastoma | head and neck cancer
Treatment | radiotherapy | Chemotherapy platinum based | chemotherapy, without platinum | chemotherapy | radiochemotherapy | chemotherapy | radiotherapy
Duration | NR | 28 wks | NR | 28 wks | 8 | 111 days | NR
Outcome | locoregional failure rate, locoregional PFS, CR | tumor response | DFS, local relapse | tumor response | PFS, local tumor control | PFS, tumor response | locoregional control, DFS
Assessed | 2 and 3 years | 28 wks | 5 years | 28 wks | 3 years | 5 years | 5 years
ESA dose | 1× 40,000 IU/wk | 3 × 10,000 IU/wk sc | 3 × 150 IU/kg/wk | if body weight > 45 kg 3 × 10,000 IU/wk sc (5000 IU if <45kg) | 1 × 40,000 IU/wk | 7 × 200 IU/kg | 150 mcg QW
ESA duration (weeks) | 8 to 9 | 28 | ≈18 | 28 | 6–9 | 12–16 | 8–10
Baseline Hb (control/ESA) | 12.1/12.0 g/dL | 12.8/12.6 g/dL | 12.8/12.4 g/dL | 10.8/10.6 | 10.9/10.6 g/dL | 9.4/8.8 g/dL | ≈13/≈13 g/dL
Hb target | 14 g/dLwomen 16 g/dLmen | 14 g/dL women 15 g/dL men | 14 g/dL | 12.5–14 g/dL | 14 g/dL | 13 g/dL | 15.5 g/dL
Re-start if Hb less than | 12.5g/dLwomen 13.5 g/dLmen | 13 g/dL women 13.5 g/dL men | NR | NR | 13 g/dL | 13g/dL | NR

DFS = disease-free survival; FFTF = freedom from treatment failure; g/dL = grams per deciliter; Hb = hemoglobin; HD = heart disease; IU = international units; NR = not reported; NSCLC = non small-cell lung cancer; PFS = progression-free survival; SCLC = small-cell lung cancer; TR = treatment response

Table 52 Tumor response outcomes—epoetin or darbepoetin versus control

Study ID | Drug | Outcome Reported | Response Definition | Intervention (Events/Total) | Control (Events/Total) | RR (95% CI) Calculated^a^
Engert 2009^95^ | Epoetin | complete response | CR/CRu | 619/648 | 614/655 | 0.98 (0.96 to 1.01)
Engert 2009^95^ | Epoetin | partial response | NR | 10/648 | 11/655 | 1.09 (0.47 to 2.54)
Goss 2005^100^ | Epoetin | overall response 6 wks post chemo | CR+PR | 48/52 | 42/52 | 0.88 (0.75 to 1.02)
Gupta 2009^103^ | Epoetin | overall response rate at 1 month | NR | 56/58 | 53/57 | 0.96 (0.88 to 1.05)
Hoskin 2009^81^ | Epoetin | tumor response | CR+PR | 149/151 | 148/149 | 1.01 (0.98 to 1.03)
Milroy 2011^109^ | Epoetin | tumor response | NR | 45/160 | 48/167 | 0.98 (0.69 to 1.38)
Pronzato 2010^115^ | Epoetin | tumor response | NR | 65/107 | 56/109 | 1.18 (0.93 to 1.50)
Wagner 2004^80^ | Epoetin | tumor response | CR+PR | 12/17 | 12/18 | 0.94 (0.60 to 1.48)
Untch 2011^131^ 2011^37^ | Darbepoetin | pathological complete response | w w/o noninvasive residual | 57/356 | 60/377 | 1.01 (0.72 to 1.40)

CR = complete response; Cru = unconfirmed complete response; NR = not reported; PR = partial response

a From event rates in tables.

#### Changes From 2006 Review

Three trials from the previous review were excluded, one trial included unchanged, four results updated, and eight new trials were identified (Appendix Table F1).

### KQ1 Other Adverse Events

Non-thromboembolic adverse events reported included hypertension, thrombocytopenia and/or hemorrhage, rash, and seizures. Data from trials on the development of potentially neutralizing antibodies to ESAs were also reviewed. Adverse events that could be definitively attributed to transfusions were not reported in any trial.

#### Darbepoetin Versus Epoetin

Three trials ascertained antibody levels to both drugs.134,136,137 Glaspy et al.132 assessed antibodies for only darbepoetin, but none were detected. There were no data reported on hypertension, thrombocytopenia and/or hemorrhage, rash, or seizure.

##### Changes From 2006 Report

One trial was excluded; two were included unchanged; data were updated for one trial; and one new trial was identified (Appendix Table F1).

#### Epoetin Versus Control

##### Hypertension

Fifteen trials (Table 14) reported hypertension incidence (epoetin N=1,855; control N=1,509) (Appendix Table C30) but one trial106 reported no events. Only one trial included a definition for hypertension. Incidences ranged from 0 to 56 percent and 0 to 59 percent in epoetin and control arms respectively. Because one trial118 reported extremely high incidence rates (56 and 59% vs. the next highest of 9%) the trial was excluded from pooling. In the remaining trials, the pooled relative risk was consistent with an increased risk of hypertension accompanying ESA treatment.

##### Thrombocytopenia and/or Hemorrhage

Ten trials (Table 14) reported incidence of thrombocytopenia and/or hemorrhage (epoetin N=1,321; control N=1,082) (Appendix Table C32). The pooled relative risk did not suggest an association (Table 53).

Table 53 Pooled relative risks and other adverse event rates—epoetin versus control

Outcome | Trials | Epoetin N | Control N | RR (95% CI) | I^2^ | Incidence Epoetin (95% CI) | Incidence Control (95% CI)
Hypertension | 13^a^ | 1,652 | 1,369 | 1.62 (1.05 to 2.50) | 0% | 3.5% (2.2 to 5.0) | 1.8% (0.7 to 3.2)
Thrombocytopenia and/or Hemorrhage | 10 | 1,321 | 1,082 | 1.11 (0.94 to 1.31) | 0% | 12.9% (4.9 to 23.7) | 10.5% (3.1 to 21.3)
Rash | 5^b^ | 739 | 728 | 2.00 (0.98 to 4.07) | 0% | 2.3% (1.3 to 5.6) | 1.0% (0.0 to 3.3)
Seizures | 3 | 359 | 245 | 1.49 (1.45 to 4.87) | 0% | 2.3% (0.9 to 4.3) | 1.3% (0.2 to 4.7)

CI = confidence interval; RR = relative risk

a Excluding one trial with no events106 and one outlier.118

b Pooled result excludes one trial with no events;103 six trials reported rash outcomes.

##### Rash

Six trials (Table 14) reported that the incidence of rash (epoetin N=739; control N=728) but one reported no events103 (Appendix Table C34). Rash appeared more common in the epoetin arms (Table 53).

##### Seizures

Three trials (Table 14) reported that seizure incidence (epoetin N=359; control N=245) (Appendix Table C35) was higher in the epoetin arms (Table 53).

##### Antibodies

Five trials ascertained antibody levels90,104,112,113,123 (epoetin N=498 [461 tested for antibodies]; control N=480 [445 tested for antibodies]). In only Henry et al. (1995 #97) were antibodies detected (2 patients of 26 tested in each trial arm) (Appendix Table C37).

Changes from 2006 review are shown in Table 54 and detailed in (Appendix Table F1).

Table 54 Changes in trials from 2006 review—adverse events epoetin versus control

Outcome | Trials Excluded | Trials Unchanged | Trials Updated | New Trials
Hypertension | 9 | 7 | 0 | 8
Thrombocytopenia/Hemorrhage | 4 | 3 | 0 | 7
Rash | 5 | 1 | 0 | 5
Seizures | 1 | 2 | 0 | 1
Antibodies | 2 | 4 | 0 | 1

#### Darbepoetin Versus Control

##### Hypertension

Three trials (Table 14) reported hypertension incidence (darbepoetin N=650; control N=647) (Appendix Table C31) but none included a definition of hypertension. Incidence rates ranged from 3.1 percent to 6.0 percent and 2.1 percent to 5.1 percent in darbepoetin and control arms, respectively.

##### Thrombocytopenia and/or Hemorrhage

Two trials (Table 14) reported incidence of thrombocytopenia and/or hemorrhage (darbepoetin N=697; control N=614) (Appendix Table C33). Incidence was high in both arms and relative risk elevated in with darbepoetin (Table 55).

Table 55 Pooled relative risks and other adverse event rates—darbepoetin versus control

Outcome | Trials | Darbepoetin N | Control N | RR (95% CI) | I^2^ | Incidence Darbepoetin (95% CI) | Incidence Control (95% CI)
Hypertension | 3 | 650 | 647 | 1.31 (0.79 to 2.18) | 0% | 5.2% (3.5 to 7.2) | 3.9% (2.3 to 5.9)
Thrombocytopenia and/or Hemorrhage | 2 | 697 | 614 | 1.46 (1.03 to 2.06) | 0% | 9.4% (0.0 to 32.6) | 6.8% (0.2 to 20.1)
Rash | – | – | – | – | – | – | –
Seizures | 2 | 495 | 488 | 0.88 (0.14 to 5.41) | 54% | 1.6% (0.7 to 2.9) | 1.8% (0.2 to 5.0)

CI = confidence interval; RR = relative risk

##### Rash

No trials comparing darbepoetin with control reported incidence of rash.

##### Seizures

Two trials (Table 14) reported seizure incidences of 1.3 percent and 1.6 percent in the darbepoetin and 0.5 percent and 3.0 percent in the control arms, respectively (Appendix Table C36) (Table 55).

##### Antibodies

Five trials ascertained antibody levels8,126,127,129,130 (darbepoetin N=1,038 [972 tested for antibodies]; control N=881 [812 tested for antibodies]) but none were detected (Appendix Table C38).

Changes from the 2006 review are shown in Table 56 and detailed in Appendix Table F1.

Table 56 Changes in trials from 2006 review—adverse events darbepoetin versus control

Outcome | Trials Excluded | Trials Unchanged | Trials Updated | New Trials
Hypertension | 0 | 0 | 0 | 0
Thrombocytopenia/Hemorrhage | 0 | 0 | 0 | 1
Rash | 0 | 0 | 0 | 0
Seizures | 0 | 0 | 0 | 0
Antibodies | 0 | 1 | 1 | 1

#### Evidence Regarding Erythropoietic-Stimulating Agents

Pooled results and incidence rates for epoetin and darbepoetin are shown in Table 57. These adverse events were generally more frequent with ESA use although the magnitude of difference was difficult to ascertain given the lack of standard definitions and limited trial data. There is no evidence to indicate antibodies to these agents develop during treatment for anemia related to cancer therapy.

Table 57 Pooled relative risks and other adverse event rates—epoetin or darbepoetin versus control

Outcome | Trials | ESA N | Control N | RR (95% CI) | I^2^ | Incidence ESA (95% CI) | Incidence Control (95% CI)
Hypertension | 16^a^ | 2,302 | 2,016 | 1.48 (1.07 to 2.06) | 0% | 3.8% (2.7 to 5.0) | 2.1% (1.1 to 3.4)
Thrombocytopenia and/or Hemorrhage | 12 | 2,018 | 1,696 | 1.17 (1.01 to 1.36) | 0% | 12.2% (5.5 to 20.9) | 9.9% (3.9 to 17.8)
Rash | 5^b^ | 739 | 728 | 2.00 (0.98 to 4.07) | 0% | 2.3% (0.2 to 5.6) | 1.0% (0.0 to 3.3)
Seizures | 5 | 854 | 733 | 0.93 (0.43 to 2.04) | 0% | 2.1% (1.2 to 3.1) | 1.8% (0.6 to 3.7)

CI = confidence interval; ESA = erythropoiesis-stimulating agent; RR = relative risk

a Excluding one trial with no events106 and one outlier.118

b Result excludes one trial with no events.103

## KQ2 How do alternative thresholds for initiating treatment compare regarding their effect on the benefits and harms of erythropoietic stimulants? Evidence is limited to directly comparative data from randomized controlled trials. Outcomes of interest include: hematologic response (change in hemoglobin or hematocrit), proportion of patients transfused, quality of life, survival (overall and progression-free), and adverse effects

### Overview of Evidence and Findings for KQ2

Five trials were included189–193 —a total of 468 patients were randomized to the early intervention and 465 to the late intervention (delay until hemoglobin ≤9 to 11 g/dL). All included trials were open-label, and thus quality was rated low. All trials were limited to adult patients.

The KQ pertains to all erythropoietin-stimulating agents; accordingly, results from all trials using epoetin and darbepoetin were combined. Among the five included trials, three used the same threshold for initiating treatment in the late arm.190–192 For purposes of meta-analysis by outcome, all trials reporting a specific outcome were combined (except for hematologic response, see following); and the three trials with the same treatment initiation threshold were combined in a separate analysis, where appropriate. Major findings are summarized in Table 58 to Table 62.

Table 58 Overview: hematologic response, early versus late ESA

Variable | ESA Early vs. Late Response = Hb Increase ≥2g/dL
Number of studies | 1^191^
Patients analyzed | 180
Pooled relative risk | 1.09
(95% CI) | (0.60 to 1.97)
I^2^ | N/A

CI = confidence interval; ESA = erythropoiesis-stimulating agent; Hb = hemoglobin; N/A = not applicable

Table 59 Overview: transfusion rates, early versus late ESA

Variable | ESA Early vs. Late All Trials | ESA Early vs. Late Same ESA Initiation Threshold
Number of studies | 5 | 3^a^
Patients analyzed | 908 | 520
Pooled relative risk | 0.73 | 0.74
(95% CI) | (0.56 to 0.96) | (0.52 to 1.04)
I^2^ | 0% | 0%

CI = confidence interval; ESA = erythropoiesis-stimulating agent

a 190–192.

Table 60 Overview: thromboembolic events, early versus late ESA

Variable | ESA Early vs. Late All Trials | ESA Early vs. Late Same ESA Initiation Threshold
Number of studies | 5 | 3^a^
Patients analyzed | 908 | 524
Pooled relative risk | 1.61 | 1.57
(95% CI) | (0.85 to 3.05) | (0.71 to 3.46)
I^2^ | 58% | 61%

CI = confidence interval; ESA = erythropoiesis-stimulating agent

a 190–192.

Table 61 Overview: on-study mortality, early versus late ESA

Variable | ESA Early vs. Late All Trials | ESA Early vs. Late Same ESA Initiation Threshold
Number of studies | 3 | 2^a^
Patients analyzed | 438 | 319
Pooled relative risk | 1.28 | 1.40
(95% CI) | (0.62 to 2.64) | (0.64 to 3.04)
I^2^ | 0% | 0%

CI = confidence interval; ESA = erythropoiesis-stimulating agent

a 190–192.

Table 62 Overview: overall survival, early versus late ESA

Variable | ESA Early vs. Late All Trials | ESA Early vs. Late Same ESA Initiation Threshold
Number of studies | 4 | 3^a^
Patients analyzed | 793 | 524
Pooled relative risk | 0.95 | 0.95
(95% CI) | (0.77 to 1.17) | (0.77 to 1.18)
I^2^ | 0% | 0%

CI = confidence interval; ESA = erythropoiesis-stimulating agent

a 190–192.

### Detailed Analysis

#### Characteristics of Included Trials

Each trial compared immediate treatment with ESA to treatment delayed until hemoglobin level decreased to, or below, a prespecified threshold. Characteristics of the five included trials are summarized in Table 63. All enrolled adult patients being treated with chemotherapy; two administered chemotherapy regimens including platinum190,192 while one did not report this information clearly.191 Hemoglobin level for patient eligibility was ≤12 g/dL in four trials; Crawford et al.190 enrolled patients with baseline hemoglobin less than 15 g/dL. As noted, three trials use a threshold of hemoglobin ≤10 g/dL for the delayed treatment arm190–192 while Straus et al.189 used a threshold hemoglobin ≤9 g/dL and Glaspy et al.193 hemoglobin ≤11 g/dL to start ESA treatment. Glaspy et al.193 also administered epoetin every 3 weeks while the other three studies of epoetin used the ESA weekly. Straus et al.189 and Charu et al.191 did not supplement with iron, whereas the other three trials did. Only Schouwink et al.192 reported information on a transfusion trigger, giving transfusion as necessary with the recommendation not to transfuse if hemoglobin greater than 9.7 g/dL.

Table 63 Characteristics of the five included studies, early versus late ESA

Study | Malignancy | Total Patients (N); Patients Randomized (E: early; L:late)^a^ | ESA | Treatment Duration (weeks) | ESA Early (E) | ESA Late (L) (% Treated) | Hb Level for Eligibility to Enter Trial | Baseline Hb Early (E), Late (L)
Charu 2007^191^ | solid and hematologic tumors | N=204; E: 102, L: 102 | Darb | 22 | 300 μg Q3W | Observation until Hb ≤10 g/dL then start treatment 300 μg Q3W (63%) | ≥ 10.5 g/dL but ≤ 12.0 g/dL; | E: 11.1, L: 11.2
Crawford 2007^190^ | solid tumors (lung) | N=216; E: 109, L: 107 | Epo | 16 | 40,000 IU QW | Observation until Hb ≤10 g/dL then start treatment 40,000 IU QW (46%) | ≥ 11.0 g/dL to < 15 g/dL; | E: 13.1, L: 13.0
Schouwink 2008^192^ | solid tumors (lung, ovary, and breast) | N=110; E: 54, L: 54 | Epo | 24 | 40,000 IU QW | Observation until Hb ≤10 g/dL then start treatment 40,000 IU QW (61%) | > 10.0 g/dL to ≤ 12.0 g/dL | E: 11.2, L: 11.2
Straus 2006^189^ | hematologic tumors | N=269; E: 135, L: 134 | Epo | 16 | 40,000 IU QW | Observation until Hb ≤9 g/dL after 2nd chemotherapy cycle, then start treatment: 40,000 IU QW (19.4%) | ≥ 10.0 g/dL to ≤ 12.0 g/dL | E: 11.1, L: 11.2
Glaspy 2009^193^ | solid or hematologic tumors | N=136; E: 68, L: 68 | Epo | 16 | 120,000 Q3W | Observation until Hb <11 g/dL then start treatment 120,000 IU Q3W (75%) | ≥ 11.0 g/dL to ≤ 12.0 g/dL | E: 11.5, L: 11.5

Darb = darbepoetin; Epo = epoetin; ESA = erythropoiesis-stimulating agent; Hb = hemoglobin; IU = international unit

a Note totals represent patients randomized whereas overview includes those analyzed.

#### Hematologic Response

Four trials compared hematologic response rates of patients randomized to early or late treatment.189–191,193 Of these, only Charu et al.191 reported hemoglobin responses as defined in this review (hemoglobin increase ≥2 g/dL); the other trials were not included in the analysis of hematologic response. In Charu et al.,191 nearly 20 percent of early and 30 percent of late randomized patients were not evaluated. Of those assessed, hemoglobin responses were reported for 19 of 94 patients (20.2%) in the early arm treated at a mean hemoglobin of 11.1 g/dL and for 16 of 86 patients (18.6%) in the arm delayed to a threshold of 10 g/dL (Table 58; RR 1.09; 95% CI: 0.60 to 1.97) or no detectable difference.

#### Transfusion Rates

All five trials reported effects on transfusion. Trials differed in treatment duration, iron supplementation, chemotherapy, and baseline hemoglobin. Results from the five trials and from the three using the same late arm hemoglobin threshold for initiating ESA treatment190–192 were pooled with nearly the same results (Table 59; for all trials, RR 0.73; 95% CI: 0.56 to 0.96; I^2^=0%). Accordingly, results favor early ESA treatment.

#### Thromboembolic Events

All five trials reported thromboembolic event rates. Trials differed in treatment duration, iron supplementation, chemotherapy, and baseline. For all five trials and the three trials using the same late arm hemoglobin threshold for initiating ESA treatment190–192 pooled results favored late ESA treatment (Table 60; all trials, RR 1.61; 95% CI: 0.85 to 3.05; I^2^=58%).

Individual trial results for this outcome varied considerably. For example, Crawford et al.190 and Glaspy et al.193 found no difference between early and late ESA initiation. In contrast, Straus et al.,189 obtained a RR of 3.72 (95% CI: 1.27 to 10.92), favoring late ESA. The threshold for late initiation in this trial was the lowest at less than 9 g/dL and baseline hemoglobin 11.1 g/dL for the early treatment arm. Consequently, only 19 percent of late patients were treated with ESA. In addition, patients had hematologic malignancies and were being treated with chemotherapy, a population in which risk of thromboembolic complications may be elevated. Thus, late ESA initiation, a low threshold, and overall much lower population exposure in the late intervention arm likely resulted in fewer events.

#### Survival

Three trials reported on-study mortality;190,192,193 two of these used similar ESA initiation thresholds.190,192 Results were similar whether two or three trials were pooled (Table 61; for all trials, the pooled RR was 1.28 (95% CI: 0.62 to 2.64; I^2^=0%) favoring late ESA but was not significant.

Four trials reported overall survival;189–192 three trials used the same late ESA initiation threshold190–192 but observation duration varied among the trials—from 40 months in Crawford et al.190 to the on-study time189 of 20 weeks. There was no evidence of difference in pooled relative effects comparing risk of early to late initiation for the three trials: RR 0.95 (95% CI: 0.77 to 1.17; I^2^=0%).

#### Quality of Life

Of the five trials, only one192 reported no QoL results. Where possible, we focus on FACT-Fatigue subscale results, as in KQ1.

In Charu et al.191 the change in FACT-Fatigue scores from baseline were reported according to the change in hemoglobin from baseline to end of treatment. We calculated the weighted mean change in FACT-F for the early intervention group and for the late intervention group separately (for calculation see Methods). The mean FACT-Fatigue changes from baseline to end of treatment (week 22) were 0.7 ± 12.9 (n=94) and 0.6 ± 14.2 (n=86) in the early and late groups respectively; less than the MCID of 3.^179^

Crawford et al.190 noted that “[i]n the immediate epoetin alfa group, FACT-An subscale scores declined significantly from baseline to study end with a mean change of −7.7 and a p-value of 0.0187.” No data were reported for the delayed intervention group, thus no comparative conclusions can be drawn.

Glaspy et al.193 reported FACT-Fatigue at baseline in the early and late treatment arms of 33.5 ± 13.2 and 27.8 ± 12.0, and at last visit of 32.0 ± 13.2 and 30.4 ± 11.7 respectively; a decrease in the early group of −1.5 and increase in delayed of +2.6.

Straus et al.189 found an increase of 1.45 for FACT-Fatigue subscale results in the early intervention arm and a decrease of −1.68 in the delayed intervention arm; clinically not significant changes.

Overall there is little evidence to support a clinically meaningful improvement in QoL using either early or late ESA treatment initiation.

#### Other Outcomes

There was insufficient evidence to report other adverse events or tumor progression.

#### Changes From 2006 Review

Three trials included in the previous review published as abstracts were included as full text,189–191 and two new trials were included.192,193

### KQ2 Discussion and Conclusions

Five trials compared early to late ESA intervention when hemoglobin level decreased below a pre-specified threshold. These trials were unblinded and lacked placebo arms, and thus were evaluated as low quality, potentially subject to bias. Absence of information on a transfusion trigger further complicates interpretation. The evidence base is small and may not be reliable.

Hematologic response and transfusion rates favored early ESA treatment, in keeping with the established hematologic outcomes of ESA treatment, but the estimate was only just significant for transfusion. In contrast, thromboembolic event outcomes favored late treatment, which exposed fewer patients to treatment, also in keeping with the known increased risk for thromboembolic events with increased ESA exposure, but results were not significant. On-study mortality outcomes favored delayed treatment as well, but were not significant. The quality of life evidence, evaluating the FACT-Fatigue subscale in four trials and FACT-An in a fifth, was inconsistent and did not support a clinically meaningful improvement in either study arm.

In short, the strength of the evidence base is low to determine whether immediate or treatment delayed to when hemoglobin falls below a prespecified threshold results in different outcomes. Nor is evidence sufficient to identify a preferred hemoglobin threshold, among three tested, for initiating ESA treatment.

#### Evidence GRADE for Central Outcomes

The evidence is lacking to determine whether immediate treatment versus delayed treatment produces better transfusion outcomes or fewer thromboembolic events (overall strength of evidence low) (Table 64 and Table 65).

Table 64 Transfusions: early versus late ESA (GRADE evidence table)

Trials (N) | Subjects (N) | Risk of Bias Design/Quality | Consistency | Directness | Precision | Results RR (95% CI); I^2^ | Overall Strength of Evidence
5 | 908 | High trial quality high-0; low-5 | Consistent | Direct | Precise | 0.73 (0.56 to 0.96); 0% | Low

CI = confidence interval

Table 65 Thromboembolic events: early versus late ESA (GRADE evidence table)

Trials (N) | Subjects (N) | Risk of Bias Design/Quality | Consistency | Directness | Precision | Results RR (95% CI); I^2^ | Overall Strength of Evidence
5 | 908 | High trial quality high-0; low-5 | Consistent | Direct | Imprecise | 1.61 (0.85 to 3.05); 58% | Low

CI = confidence interval

## KQ3 How do different criteria for discontinuing therapy or for optimal duration of therapy compare regarding their effect on the benefits and harms of erythropoietic stimulants?

Evidence is limited to directly comparative data from randomized controlled trials. Outcomes of interest include: hematologic response (change in hemoglobin or hematocrit), proportion of patients transfused, quality of life, overall and progression-free survival, and other adverse effects.

No randomized controlled trials were identified that fulfill the inclusion criteria of this review. Therefore, no results can be provided.

## Decision Analysis

The main benefits of ESA treatment are increased hemoglobin and lower risk of transfusion. The most significant potential harm is mortality. While there is uncertainty in the magnitude and clinical importance of measured improvements in quality of life with alleviation of anemia (higher hemoglobin), utilities (values between 0 and 1 with extremes representing death and perfect health, respectively) corresponding to hemoglobin levels have been quantified in cancer patients.76 A central question in the decision to administer ESAs is the tradeoff between higher hemoglobin and its potential benefit with the relative increase in mortality. What is the balance of benefit and harm? Incorporating results obtained from the systematic review in a decision model examining that balance is then relevant to the evidence synthesis. For that purpose, we have organized this section as follows. First, the basic model and two base cases are outlined. Second, base case results are presented. Next, analyses varying relative risk with baseline risk and sensitivity analyses are shown. Finally, potential implications and limitations are noted. Results are presented for both quality adjusted life-years and life-years in a hypothetical cohort of 1,000 similar patients. While transfusions are not without risk, as noted by others194 the frequency of adverse transfusion events is too low to be included here. This is supported by our review for reported adverse events attributed to transfusions in the included trials and by review of summary articles on the topic.195–200 The model also does not incorporate any decrement in quality of life accompanying thromboembolic events more frequent with ESA administration. While most are generally short in duration (venous thrombosis) others less common (stroke) may have lasting effects.

### Model

The decision model is depicted in Figure 15 and includes three health states—patients with a baseline hemoglobin of 9 g/dL, an achieved of 11 g/dL through either ESA or transfusion, and death. A 12-week course of chemotherapy and ESA treatment is assumed (the most common scenario in included trials) and patients are followed one year. If an ESA is used, the model considered it administered for 12 weeks and any increase in mortality persisting through week 16.^48^ From week 16 through week 52 we assumed similar mortality and hemoglobin levels in patients initially treated with an ESA or transfusion strategy—based on the lack of evidence here for increased long-term mortality risk.

Figure 15 Decision model structure

g/dl = grams per deciliter; Hb = hemoglobin

Figure 15 displays a decision model structure and includes three health states—patients with a baseline hemoglobin of 9 g/dL, an achieved of 11 g/dL through either ESA or transfusion, and death.

Two base case scenarios were developed from results obtained in this review, published studies, and current recommendations regarding ESA use (i.e., applying to patients treated with curative intent versus others). Survival following chemotherapy can vary substantially by tumor and stage. Here, mortality ranged from 3 to 93 percent following the on-study period—estimated in 15 studies34,81,83,84,99,107,109,110,114–116,119,125,130,201 included in this review with follow-up of one year or more and extractable data. From this range, the two base case scenarios were specified: (1) patients treated with curative intent (5% annual mortality following treatment or at the lowest portion of the distribution), and (2) those not treated with curative intent having an annual mortality rate the approximate median or 50 percent. Corresponding on-study mortality rates were applied to the two base cases: low or curative intent (2.5% or lower quartile of studies included in the review) and higher or noncurative intent (7.5% or the approximate median). Utilities, obtained from four studies as described in the methods, corresponding to hemoglobin levels of 9 and 11 g/dL were assigned values of 0.61 and 0.70 respectively. Hemoglobin levels for treatment were chosen to fall within current guidance. Other parameter estimates and sources are shown in Table 66. Ranges for sensitivity analyses were informed by either confidence intervals in parameters, distribution quartiles, or relevant upper and lower bounds from reported studies (e.g., for utilities). Parameter values and sources are detailed in Table 66.

Table 66 Base case parameters for decision model—1-year time horizon

Parameter | | Value | Range | Source
Hemoglobin | Baseline | 9 | — | Guideline56
Hemoglobin | Achieved during therapy (4 to 16 weeks) | 11 | — | Guideline56
Hemoglobin | Following therapy (to week 52) | 11 | — | Estimate
Response rates | ESA | 52% | 45% to 59% | Current meta-analysis
Response rates | Control (transfusion only) | 14% | 10% to 19% | Current meta-analysis
Utilities | Hemoglobin 9 g/dL | 0.61 | 0.56 to 0.64 | Four ESA-manufacturer studies76
Utilities | Hemoglobin 11 g/dL | 0.70 | 0.67 to 0.78 | Four ESA-manufacturer studies76
Utilities | Dead | 0 | —
On-study control mortality rate | Patient treated with curative intent | 2.5% | — | Current review
On-study control mortality rate | Patient not treated with curative intent | 7.5% | 5.0% to 10% | Current review
Annual mortality rates weeks 20 to 52 | Patient treated with curative intent | 5% | —
Annual mortality rates weeks 20 to 52 | Patient not treated with curative intent | 50% | 25%, 50%, 75% | Approximate quartiles of included studies
Mortality relative risk on-study with ESA use | | 1.17 | 1.04 to 1.31 | Current meta-analysis
Utilities | Hemoglobin 9 g/dL | 0.61 | 0.56 to 0.64 | Four ESA-manufacturer studies76
Utilities | Hemoglobin 11 g/dL | 0.70 | 0.67 to 0.78 | Four ESA-manufacturer studies76
Utilities | Dead | 0 | —

ESA = erythropoiesis-stimulating agent

For all patients, the risk of mortality was incorporated as follows: during the first 16 weeks or on-study period the underlying mortality rate was that accompanying a transfusion strategy (no ESA). In the base cases (Table 66), the approximate median of these studies or 7.5 percent was used; results are also estimated over approximate quartiles of on-study mortality and a low-risk population with a 2.5 percent rate. Based on the on-study mortality and long-term results obtained here, receiving ESAs is accompanied by a 17 percent relative increased risk of mortality during the first 16 weeks but not thereafter. We assume that following the on-study period annual mortality rates as noted. No discounting was used given the short time horizon.

To illustrate the assumptions and model, consider a hypothetical patient undergoing a 12-week course of chemotherapy with initial hemoglobin of 9 g/dL who receives and responds to ESA and survives 52 weeks. The patient begins with hemoglobin of 9 g/dL, which by week 4 is 11 g/dL, and quality of life or utility improved from 0.61 to 0.70. The model assumes a patient spends the entire 4 weeks with hemoglobin of 11 g/dL or favorable to an ESA strategy (response typically is seen in 3 to 4 weeks) and with the same hemoglobin through 52 weeks. If a patient did not respond, the hemoglobin remains 9 g/dL but following chemotherapy (after week 16) improves to 11 g/dL. For the purposes of modeling, a 4-week cycle length was used (without mid-cycle correction). As noted in the methods, the model was constructed in Excel^®^ and replicated in TreeAge Pro.77 A cohort of 1,000 patients was simulated.

### Results

Results for the two base cases are shown in Table 67. In both, ESA treatment resulted in more quality-adjusted life years attributable to more patients achieving the target hemoglobin during the on-study period. Expected quality of life gains are obtained during that period. The tradeoff is fewer life-years—3.6 per 1,000 patients treated with curative intent and 9.2 per 1,000 patients not treated with curative intent. Table 68 and 69 display results over the range of likely parameter values for the two different cases as one-way sensitivity analyses. In curative intent, quality adjusted life years were higher with an ESA strategy but life years fewer. In the noncurative intent case, almost all parameter values resulted in more quality adjusted life-years, but again life-years were lost. Notably, more life years were lost in the noncurative case compared with the curative one. Overall, estimates were most sensitive to ESA relative risk for mortality and utilities (for quality of life).

Table 67 Quality-adjusted life-years and life years gained or lost over a 1-year period in the two base cases for 1,000 patients

Base Case | QALYs ESA | QALYs Transfuse | Difference (+ESA Better −ESA Worse) | Life Years ESA | Life Years Control | Difference (+ESA Better −ESA Worse)
Curative intent | 660.2 | 652.2 | +7.9 | 961.6 | 965.2 | −3.6
Non curative intent | 557.9 | 554.0 | +3.9 | 814.6 | 823.8 | −9.2

ESA = erythropoiesis-stimulating agent; QALYs = quality-adjusted life years

Table 68 Curative intent—sensitivity to changes in parameters values of quality-adjusted life-years and life years gained or lost over a 1-year period for 1,000 patients

Characteristic | | QALYs ESA | QALYs Transfuse | QALY Difference (+ESA Better −ESA Worse | Life Years ESA | Life Years Control | Life-Year Difference (+ESA Better −ESA Worse)
Relative risk | 1.04 | 662.1 | 652.2 | +9.8 | 964.4 | 965.2 | −0.9
Relative risk | 1.17 | 660.2 | 652.2 | +7.9 | 961.6 | 965.2 | −3.6
Relative risk | 1.31 | 658.1 | 652.2 | +5.9 | 958.6 | 965.2 | −6.6
On-study control mortality | 2.5% | 660.2 | 652.2 | +7.9 | 961.6 | 965.2 | −3.6
On-study control mortality | 5.0% | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
On-study control mortality | 7.5% | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
On-study control mortality | 10.0% | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Annual mortality 20 to 52 weeks | 5% | 660.2 | 652.2 | +7.9 | 961.6 | 965.2 | −3.6
Annual mortality 20 to 52 weeks | 25% | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Annual mortality 20 to 52 weeks | 50% | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Annual mortality 20 to 52 weeks | 75% | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Response rate ESA | 45% | 658.2 | 652.2 | +6.0 | 961.6 | 965.2 | −3.6
Response rate ESA | 52% | 660.2 | 652.2 | +7.9 | 961.6 | 965.2 | −3.6
Response rate ESA | 59% | 662.1 | 652.2 | +9.8 | 961.6 | 965.2 | −3.6
Response rate transfusion | 10% | 660.7 | 651.1 | +9.6 | 961.6 | 965.2 | −3.6
Response rate transfusion | 14% | 660.2 | 652.2 | +7.9 | 961.6 | 965.2 | −3.6
Response rate transfusion | 19% | 660.7 | 653.6 | +7.1 | 961.6 | 965.2 | −3.6
Utility Hgb 9 g/dL | 0.56 | 653.8 | 639.2 | +14.6 | 961.6 | 965.2 | −3.6
Utility Hgb 9 g/dL | 0.61 | 660.2 | 652.2 | +7.9 | 961.6 | 965.2 | −3.6
Utility Hgb 9 g/dL | 0.64 | 664.8 | 660.0 | +4.8 | 961.6 | 965.2 | −3.6
Utility Hgb 11 g/dL | 0.67 | 636.0 | 631.1 | +4.9 | 961.6 | 965.2 | −3.6
Utility Hgb 11 g/dL | 0.70 | 660.2 | 652.2 | +7.9 | 961.6 | 965.2 | −3.6
Utility Hgb 11 g/dL | 0.78 | 726.6 | 708.6 | +18.0 | 961.6 | 965.2 | −3.6

ESA = erythropoiesis-stimulating agent; Hgb = hemoglobin; QALYs = quality-adjusted life years

Note: Base case in italics.

Table 69 Non curative intent—sensitivity to changes in parameters values of quality-adjusted life-years and life years gained or lost over a 1-year period for 1,000 patients

Characteristic | | QALYs ESA | QALYs Transfuse | Difference (+ESA Better −ESA Worse | Life Years ESA | Life Years Control | Difference (+ESA Better −ESA Worse)
Relative risk | 1.04 | 562.7 | 554.0 | +8.7 | 821.6 | 823.8 | −2.2
Relative risk | 1.17 | 557.9 | 554.0 | +3.9 | 814.6 | 823.8 | −9.2
Relative risk | 1.31 | 552.8 | 554.0 | −1.2 | 807.0 | 823.8 | −16.7
On-study control mortality | 2.5% | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
On-study control mortality | 5.0% | 572.5 | 566.4 | +6.0 | 835.8 | 842.1 | −6.3
On-study control mortality | 7.5% | 557.9 | 554.0 | +3.9 | 814.6 | 823.8 | −9.2
On-study control mortality | 10.0% | 543.7 | 541.8 | +1.9 | 793.8 | 805.8 | −12.0
Annual mortality 20 to 52 weeks | 5% | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Annual mortality 20 to 52 weeks | 25% | 594.5 | 591.0 | +3.4 | 866.8 | 876.7 | −9.9
Annual mortality 20 to 52 weeks | 50% | 557.9 | 554.0 | +3.9 | 814.6 | 823.8 | −9.2
Annual mortality 20 to 52 weeks | 75% | 511.7 | 509.2 | +2.5 | 748.0 | 759.2 | −11.2
Response rate ESA | 45% | 556.1 | 554.0 | +2.1 | 814.6 | 823.8 | −9.2
Response rate ESA | 52% | 557.9 | 554.0 | +3.9 | 814.6 | 823.8 | −9.2
Response rate ESA | 59% | 559.8 | 554.0 | +5.8 | 814.6 | 823.8 | −9.2
Response rate transfusion | 10% | 557.9 | 552.9 | +5.0 | 814.6 | 823.8 | −9.2
Response rate transfusion | 14% | 557.9 | 554.0 | +3.9 | 814.6 | 823.8 | −9.2
Response rate transfusion | 19% | 557.9 | 555.3 | +2.6 | 814.6 | 823.8 | −9.2
Utility Hgb 9 g/dL | 0.56 | 551.1 | 541.4 | +9.7 | 814.6 | 823.8 | −9.2
Utility Hgb 9 g/dL | 0.61 | 557.9 | 554.0 | +3.9 | 814.6 | 823.8 | −9.2
Utility Hgb 9 g/dL | 0.64 | 562.0 | 561.5 | +0.5 | 814.6 | 823.8 | −9.2
Utility Hgb 11 g/dL | 0.67 | 537.6 | 536.8 | +0.7 | 814.6 | 823.8 | −9.2
Utility Hgb 11 g/dL | 0.70 | 557.9 | 554.0 | +3.9 | 814.6 | 823.8 | −9.2
Utility Hgb 11 g/dL | 0.78 | 612.2 | 599.8 | +12.4 | 814.6 | 823.8 | −9.2

ESA = erythropoiesis-stimulating agent; Hgb = hemoglobin; QALYs = quality-adjusted life years

Note: Base case in italics.

### Implications and Limitations

Using base case scenarios representative of patients enrolled in this review and reflecting those covered by current guidance for ESA use, these results may clarify the tradeoffs accompanying ESA use. Assuming utilities reasonably accurate, there was an expected gain in quality-adjusted years at the expense of life-years lost. However, these results must be considered together with those obtained in the main body of this CER. As detailed in the HRQoL section, results from the most relevant PRO measures such as FACT scales are not equivalent to the utilities required for the type of analyses conducted here. In addition, ESA trials have not reported HRQoL outcomes using utility-based measures. Given that any improvements in quality of life for individual patients given ESAs are on average less than what is clinically meaningful, the life-years lost are the most important result. Moreover, the loss of life-years was greatest in the patient cohort with the poorest prognosis.

An important limitation of the decision model used for this analysis is that it is a simplistic representation of circumstances that are otherwise complex. For example, details of ESA dosing, escalation strategies, and cancer therapies were not accounted or in the model. However, the assumptions made are consistent with the natural history of, and evidence surrounding, anemia accompanying cancer treatment. Consequences of thromboembolic events were not included in the model; however, doing so would favor a transfusion strategy. Additionally, the estimates of utilities used in the model may not be precise but were based on the findings from four studies. Finally, we limited ourselves to one-way sensitivity analyses for clarity. While further analyses could be performed, the results were highly consistent under the different parameter values and sufficiently define the tradeoff involved.

In summary, these results are consistent with others in this review. There is a potential benefit obtained from ESA use with cancer therapy, but one that is on average as assessed by patient-reported HRQoL measures, not clinically meaningful. The tradeoff is an increased risk of mortality that appears most apparent among patients with the poorest prognosis.