# References

1 Seidenfeld J, Piper M, Bohlius J, Weingart O, Trelle S, Engert A, Skoetz N, Schwarzer G, Wilson J, Brunskill S, Hyde C, Bonnell C, Ziegler KM, Aronson N. Comparative Effectiveness of Epoetin and Darbepoetin for Managing Anemia in Patients Undergoing Cancer Treatment. Comparative Effectiveness Review No. 3. (Prepared by Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-02-0026). Rockville, MD. Agency for Healthcare Research and Quality. May. 2006. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
2 Dessypris EN, Sawyer SI. Erythropoiesis. Greer JP, et al., editors. Wintrobe’s Clinical Hematology. 12 ed. Philadelphia. Lippincott Williams & Wilkins. 2009:106-25.
3 Halstenson CE, Macres M, Katz SA, et al. Comparative pharmacokinetics and pharmacodynamics of epoetin alfa and epoetin beta. Clin Pharmacol Ther. Dec. 1991;50(6):702-12. [pmid: 1752115].
4 Storring PL, Tiplady RJ, Gaines Das RE, et al. Epoetin alfa and beta differ in their erythropoietin isoform compositions and biological properties. Br J Haematol. Jan. 1998;100(1):79-89. [pmid: 9450795].
5 Joy MS. Darbepoetin alfa: a novel erythropoiesis-stimulating protein. Ann Pharmacother. Jul–Aug. 2002;36(7–8):1183-92. [pmid: 12086553].
6 Glaspy JA, Jadeja JS, Justice G, et al. A randomized, active-control, pilot trial of front-loaded dosing regimens of darbepoetin-alfa for the treatment of patients with anemia during chemotherapy for malignant disease. Cancer. Mar. 1. 2003;97(5):1312-20. [pmid: 12599240].
7 Hedenus M, Hansen S, Taylor K, et al. Randomized, dose-finding study of darbepoetin alfa in anaemic patients with lymphoproliferative malignancies. Br J Haematol. Oct. 2002;119(1):79-86. [pmid: 12358906].
8 Vansteenkiste J, Pirker R, Massuti B, et al. Double-blind, placebo-controlled, randomized phase III trial of darbepoetin alfa in lung cancer patients receiving chemotherapy. J Natl Cancer Inst. Aug. 21. 2002;94(16):1211-20. [pmid: 12189224].
9 Groopman JE, Itri LM. Chemotherapy-induced anemia in adults: incidence and treatment. J Natl Cancer Inst. Oct. 6. 1999;91(19):1616-34. [pmid: 10511589].
10 Knight K, Wade S, Balducci L. Prevalence and outcomes of anemia in cancer: a systematic review of the literature. Am J Med. Apr. 5. Suppl 7A. 2004;116:11S-26S. [pmid: 15050883].
11 Samol J, Littlewood TJ. The efficacy of rHuEPO in cancer-related anaemia. Br J Haematol. Apr. 2003;121(1):3-11. [pmid: 12670326].
12 Barrett-Lee PJ, Ludwig H, Birgegard G, et al. Independent risk factors for anemia in cancer patients receiving chemotherapy: results from the European Cancer Anaemia Survey. Oncology. 2006;70(1):34-48. [pmid: 16493206].
13 Kosmidis P, Krzakowski M. Anemia profiles in patients with lung cancer: what have we learned from the European Cancer Anaemia Survey (ECAS)?. Lung Cancer. Dec. 2005;50(3):401-12. [pmid: 16191450].
14 Ludwig H, Fritz E. Anemia in cancer patients. Semin Oncol. Jun. 1998;25(3 Suppl 7):2-6. [pmid: 9671322].
15 Wood PA, Hrushesky WJ. Cisplatin-associated anemia: an erythropoietin deficiency syndrome. J Clin Invest. Apr. 1995;95(4):1650-9. [pmid: 7706473].
16 Ludwig H, Strasser K. Symptomatology of anemia. Semin Oncol. Apr. 2001;28(2 Suppl 8):7-14. [pmid: 11395846].
17 Leitgeb C, Pecherstorfer M, Fritz E, et al. Quality of life in chronic anemia of cancer during treatment with recombinant human erythropoietin. Cancer. May. 15. 1994;73(10):2535-42. [pmid: 8174050].
18 Cella D. Factors influencing quality of life in cancer patients: anemia and fatigue. Semin Oncol. Jun. 1998;25(3 Suppl 7):43-6. [pmid: 9671330].
19 Thomas ML. Impact of anemia and fatigue on quality of life in cancer patients: a brief review. Med Oncol. Aug. Suppl 1. 1998;15:S3-7. [pmid: 9785330].
20 Hasenclever D, Diehl V. A prognostic score for advanced Hodgkin’s disease. International Prognostic Factors Project on Advanced Hodgkin’s Disease. N Engl J Med. Nov. 19. 1998;339(21):1506-14. [pmid: 9819449].
21 Vaupel P, Hockel M. Blood supply, oxygenation status and metabolic micromilieu of breast cancers: characterization and therapeutic relevance. Int J Oncol. Nov. 2000;17(5):869-79. [pmid: 11029486].
22 Glaser CM, Millesi W, Kornek GV, et al. Impact of hemoglobin level and use of recombinant erythropoietin on efficacy of preoperative chemoradiation therapy for squamous cell carcinoma of the oral cavity and oropharynx. Int J Radiat Oncol Biol Phys. Jul. 1. 2001;50(3):705-15. [pmid: 11395239].
23 Knocke TH, Weitmann HD, Feldmann HJ, et al. Intratumoral pO2-measurements as predictive assay in the treatment of carcinoma of the uterine cervix. Radiother Oncol. Nov. 1999;53(2):99-104. [pmid: 10665785].
24 Grau C, Overgaard J. Significance of hemoglobin concentration for treatment outcome. Molls M, Vaupel P, editors. Blood Perfusion and Microenvironment of Human Tumors. New York. Springer. 2000:101-12.
25 Koeller JM. Clinical guidelines for the treatment of cancer-related anemia. Pharmacotherapy. Jan–Feb. 1998;18(1):156-69. [pmid: 9469689].
26 Engert A. Recombinant human erythropoietin as an alternative to blood transfusion in cancer-related anaemia. Dis Manag Clin Outcomes. 2000;8(5):259-72.
27 Landers DF, Hill GE, Wong KC, et al. Blood transfusion-induced immunomodulation. Anesth Analg. Jan. 1996;82(1):187-204. [pmid: 8712400].
28 Goodnough LT. Risks of blood transfusion. Anesthesiol Clin North America. Jun. 2005;23(2):241-52. v. [pmid: 15922896].
29 Biggerstaff BJ, Petersen LR. Estimated risk of West Nile virus transmission through blood transfusion during an epidemic in Queens, New York City. Transfusion. Aug. 2002;42(8):1019-26. [pmid: 12385413].
30 Allain JP. Transfusion risks of yesterday and of today. Transfus Clin Biol. Feb. 2003;10(1):1-5. [pmid: 12668180].
31 Barosi G, Marchetti M, Liberato NL. Cost-effectiveness of recombinant human erythropoietin in the prevention of chemotherapy-induced anaemia. Br J Cancer. Sep. 1998;78(6):781-7. [pmid: 9743301].
32 Cremieux PY, Finkelstein SN, Berndt ER, et al. Cost effectiveness, quality-adjusted life-years and supportive care. Recombinant human erythropoietin as a treatment of cancer-associated anaemia. Pharmacoeconomics. Nov. 1999;16(5 Pt 1):459-72. [pmid: 10662393].
33 Beguin Y. A risk-benefit assessment of epoetin in the management of anaemia associated with cancer. Drug Saf. Oct. 1998;19(4):269-82. [pmid: 9804442].
34 Henke M, Laszig R, Rube C, et al. Erythropoietin to treat head and neck cancer patients with anaemia undergoing radiotherapy: randomised, double-blind, placebo-controlled trial. Lancet. Oct. 18. 2003;362(9392):1255-60. [pmid: 14575968].
35 Leyland-Jones B, Semiglazov V, Pawlicki M, et al. Maintaining normal hemoglobin levels with epoetin alfa in mainly nonanemic patients with metastatic breast cancer receiving first-line chemotherapy: a survival study. J Clin Oncol. Sep. 1. 2005;23(25):5960-72. [pmid: 16087945].
36 Epogen®. Full prescribing information. http://pi.amgen.com/united_states/epogen/epogen_pi_hcp_english.pdf. Accessed on August 24 2010.
37 Untch M, Fasching P, Bauerfeind I, et al. PREPARE trial. A randomized phase III trial comparing preoperative, dose-dense, dose-intensified chemotherapy with epirubicin, paclitaxel and CMF with a standard dosed epirubicin/cyclophosphamide followed by paclitaxel +/− darbepoetin alfa in primary breast cancer: A preplanned interim analysis of efficacy at surgery. [abstract no. 517]. J Clin Oncol. 2008;26(15S Part I):10.
38 Seidenfeld J, Aronson N, Piper M, et al. Uses of epoetin for anemia in oncology. Evidence Report/Technology Assessment No. 30. (Prepared by Blue Cross and Blue Shield Association Technology Evaluation Center under Contract No. 290-97-0015.) AHRQ Publication No. 01-E009. Rockville, MD. Agency for Healthcare Research and Quality. 2001.
39 Bohlius J, Langensiepen S, Schwarzer G, et al. Erythropoietin for patients with malignant disease. Cochrane Database Syst Rev. 2004;(3):CD003407. [pmid: 15266483].
40 Straus DJ, Testa M, Riggs SA, et al. Early treatment with epoetin alfa improves anemia, quality of life, and productivity in patients with hematologic malignancies and mild anemia during chemotherapy. Blood. 2003;102:497a. Abstract 1811. [pmid: 12649146].
41 Rearden TP, Charu V, Saidman B, et al. Results of a randomized study of every three-week dosing (Q3W) of darbepoetin alfa for chemotherapy-induced anemia (CIA). J Clin Oncol. 2004;22(14 Suppl). Abstract 8064.
42 Crawford J, Robert F, Perry M, et al. Epoetin alfa 40,000 IU once weekly maintains hemoglobin in advanced non-small cell lung cancer patients receiving first-line chemotherapy. Proc Am Soc Clin Oncol. 2003;22:628. Abstract 2527.
43 Amgen. Update to Hedenus, et al 2003 in Safety of Erythropoiesis-Stimulating Agents (ESAs). Oncology: Background Information for Oncologic Drugs Advisory Committee. http://www.fda.gov/ohrms/dockets/ac/07/briefing/2007-4301b2-01-01-Amgen.pdf. 2007.
44 Smith RE Jr, Aapro MS, Ludwig H, et al. Darbepoetin alpha for the treatment of anemia in patients with active cancer not receiving chemotherapy or radiotherapy: results of a phase III, multicenter, randomized, double-blind, placebo-controlled study. J Clin Oncol. Mar. 1. 2008;26(7):1040-50. [pmid: 18227526].
45 Wright JR, Ung YC, Julian JA, et al. Randomized, double-blind, placebo-controlled trial of erythropoietin in non-small-cell lung cancer with disease-related anemia. J Clin Oncol. Mar. 20. 2007;25(9):1027-32. [pmid: 17312332].
46 Overgaard J Sr, Hoff CM, Hansen HS, et al. Randomized study of darbepoetin alfa as modifier of radiotherapy in patients with primary squamous cell carcinoma of the head and neck (HNSCC): Final outcome of the DAHANCA 10 trial. J Clin Oncol. 2009;27(15S):6007.
47 Leyland-Jones B. Breast cancer trial with erythropoietin terminated unexpectedly. Lancet Oncol. Aug. 2003;4(8):459-60. [pmid: 12901958].
48 Bohlius J, Schmidlin K, Brillant C, et al. Recombinant human erythropoiesis-stimulating agents and mortality in patients with cancer: a meta-analysis of randomised trials. Lancet. May. 2. 2009;373(9674):1532-42. [pmid: 19410717].
49 Bohlius J, Schmidlin K, Brillant C, et al. Erythropoietin or darbepoetin for patients with cancer--meta-analysis based on individual patient data. Cochrane Database Syst Rev. 2009;2009(3):CD007303. [pmid: 19588423].
50 Singh AK, Szczech L, Tang KL, et al. Correction of anemia with epoetin alfa in chronic kidney disease. N Engl J Med. Nov. 16. 2006;355(20):2085-98. [pmid: 17108343].
51 Thomas G, Ali S, Hoebers FJ, et al. Phase III trial to evaluate the efficacy of maintaining hemoglobin levels above 12.0 g/dL with erythropoietin vs above 10.0 g/dL without erythropoietin in anemic patients receiving concurrent radiation and cisplatin for cervical cancer. Gynecol Oncol. Feb. 2008;108(2):317-25. [pmid: 18037478].
52 Aranesp®. Full prescribing information. http://www.aranesp.com/pdf/aranesp_pi.pdf. Accessed on August 24 2010.
53 Procrit®. Full prescribing information. http://www.procrit.com/sites/default/files/shared/OBI/PI/ProcritBooklet.pdf#page=1. Accessed on June 16 2011.
54 Rizzo JD, Brouwers M, Hurley P, et al. American Society of Hematology/American Society of Clinical Oncology clinical practice guideline update on the use of epoetin and darbepoetin in adult patients with cancer. Blood. 2010. Oct. 25. [pmid: 20974674].
55 Rizzo JD, Brouwers M, Hurley P, et al. American Society of Clinical Oncology/American Society of Hematology Clinical Practice Guideline Update on the Use of Epoetin and Darbepoetin in Adult Patients With Cancer. J Clin Oncol. 2010. Oct. 25. [pmid: 20975064].
56 NCCN. National Comprehensive Cancer Network, Clinical Practice Guidelines in Oncology, Cancer and Chemotherapy-Induced Anemia Version 2.2012.
57 Shekelle P, Newberry S, Maglione M, et al. Assessment of the Need to Update Comparative Effectiveness Reviews: Report of an Initial Rapid Program Assessment 2005–2009. Prepared for the Agency for Healthcare Research and Quality. 2009. http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productID=331. Accessed on June 16 2011.
58 AHRQ. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2011.
59 Higgins JPT, Altman DG. Assessing risk of bias in included studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.0.2 ed. September. 2009.
60 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
61 R-Core-Development-Team R. A language and environment for statistical computing. R Foundation for Statistical Computing. Vienna, Austria. 3-900051-07-0. 2010. www.R-project.org/. Accessed on June 16 2011.
62 Liberati A, Altman DG, Tetzlaff J, et al. The PRISMA statement for reporting systematic reviews and meta-analyses of studies that evaluate health care interventions: explanation and elaboration. Ann Intern Med. Aug. 18. 2009;151(4):W65-94. [pmid: 19622512].
63 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions. Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews. Rockville, MD. 2009. http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=328&pageaction=displayproduct. Accessed on June 16 2011.
64 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. Jun. 19. 2004;328(7454):1490. [pmid: 15205295].
65 Sutton AJ, Abrams KR, Jones DR, et al. Methods for meta-analysis in medical research. Chichester; New York. John Wiley. 2000.
66 Parmar MK, Torri V, Stewart L. Extracting summary statistics to perform meta-analyses of the published literature for survival endpoints. Stat Med. Dec. 30. 1998;17(24):2815-34. [pmid: 9921604].
67 Tierney JF, Stewart LA, Ghersi D, et al. Practical methods for incorporating summary time-to-event data into meta-analysis. Trials. 2007;8:16. [pmid: 17555582].
68 Warn DE, Thompson SG, Spiegelhalter DJ. Bayesian random effects meta-analysis of trials with binary outcomes: methods for the absolute risk difference and relative risk scales. Stat Med. Jun. 15. 2002;21(11):1601-23. [pmid: 12111922].
69 Thompson SG, Smith TC, Sharp SJ. Investigating underlying risk as a source of heterogeneity in meta-analysis. Stat Med. Dec. 15. 1997;16(23):2741-58. [pmid: 9421873].
70 Rucker G, Schwarzer G, Carpenter JR, et al. Undue reliance on I(2) in assessing heterogeneity may mislead. BMC Med Res Methodol. 2008;8:79. [pmid: 19036172].
71 RevMan. Review Manager (RevMan) [Computer program]. Version 5.1. Copenhagen. The Nordic Cochrane Centre, The Cochrane Collaboration. 2011.
72 Viechtbauer W. Conducting meta-analyses in R with the metafor package. J Stat Software. 2010;36(3):1-48.
73 Schwarzer G. meta: Meta-Analysis with R (version 1.6-1). 2010. http://CRAN.R-project.org/. Accessed on June 16 2011.
74 Wickham H. ggplot2: elegant graphics for data analysis. New York. Springer. 2009.
75 Spiegelhalter D, Thomas A, Best N, et al. OpenBUGS User Manual Version 3.1.2. September. 2010. http://www.openbugs.info/w/. Accessed on June 16 2011.
76 Wilson J, Yao GL, Raftery J, et al. A systematic review and economic evaluation of epoetin alpha, epoetin beta and darbepoetin alpha in anaemia associated with cancer, especially that attributable to cancer treatment. [Review] [171 refs]. Health Technology Assessment (Winchester, England). 2007;11(13):1-202.
77 TreeAge Pro 2012 Software. 2012. http://www.treeage.com/.
78 Porter JC, Leahey A, Polise K, et al. Recombinant human erythropoietin reduces the need for erythrocyte and platelet transfusions in pediatric patients with sarcoma: a randomized, double-blind, placebo-controlled trial. J Pediatr. Nov. 1996;129(5):656-60. [pmid: 8917229].
79 Razzouk BI, Hord JD, Hockenberry M, et al. Double-blind, placebo-controlled study of quality of life, hematologic end points, and safety of weekly epoetin alfa in children with cancer receiving myelosuppressive chemotherapy. J Clin Oncol. Aug. 1. 2006;24(22):3583-9. [pmid: 16877725].
80 Wagner LM, Billups CA, Furman WL, et al. Combined use of erythropoietin and granulocyte colony-stimulating factor does not decrease blood transfusion requirements during induction therapy for high-risk neuroblastoma: a randomized controlled trial. J Clin Oncol. May. 15. 2004;22(10):1886-93. [pmid: 15143081].
81 Hoskin PJ, Robinson M, Slevin N, et al. Effect of epoetin alfa on survival and cancer treatment-related anemia and fatigue in patients receiving radical radiotherapy with curative intent for head and neck cancer. J Clin Oncol. Dec. 1. 2009;27(34):5751-6. [pmid: 19884550].
82 Antonadou D, Cardamakis E, Puglisi M, et al. Erythropoietin enhances radiation treatment efficacy in patients with pelvic malignancies: final results of a randomized phase Ill study. Eur J Cancer. 2001;37(Suppl 6):A530.
83 Machtay M, Pajak TF, Suntharalingam M, et al. Radiotherapy with or without erythropoietin for anemic patients with head and neck cancer: a randomized trial of the Radiation Therapy Oncology Group (RTOG 99-03). Int J Radiat Oncol Biol Phys. Nov. 15. 2007;69(4):1008-17. [pmid: 17716826].
84 Aapro M, Leonard RC, Barnadas A, et al. Effect of once-weekly epoetin beta on survival in patients with metastatic breast cancer receiving anthracycline- and/or taxane-based chemotherapy: results of the Breast Cancer-Anemia and the Value of Erythropoietin (BRAVE) study. J Clin Oncol. Feb. 1. 2008;26(4):592-8. [pmid: 18235117].
85 Bamias A, Aravantinos G, Kalofonos C, et al. Prevention of anemia in patients with solid tumors receiving platinum-based chemotherapy by recombinant human Erythropoietin (rHuEpo): a prospective, open label, randomized trial by the Hellenic Cooperative Oncology Group. Oncology. 2003;64(2):102-10. [pmid: 12566906].
86 Blohmer JU, Paepke S, Sehouli J, et al. Randomized phase III trial of sequential adjuvant chemoradiotherapy with or without erythropoietin Alfa in patients with high-risk cervical cancer: results of the NOGGO-AGO intergroup study. J Clin Oncol. Oct. 1. 2011;29(28):3791-7. [pmid: 21860000].
87 Boogaerts M, Coiffier B, Kainz C. Impact of epoetin beta on quality of life in patients with malignant disease. Br J Cancer. Apr. 7. 2003;88(7):988-95. [pmid: 12671693].
88 Impact of epoetin beta versus standard care on quality of life in patients with malignant disease. 6th Congress of the European Haematology Association. 2001.
89 Case DC Jr, Bukowski RM, Carey RW, et al. Recombinant human erythropoietin therapy for anemic cancer patients on combination chemotherapy. J Natl Cancer Inst. May. 19. 1993;85(10):801-6. [pmid: 8487324].
90 Chang J, Couture F, Young S, et al. Weekly epoetin alfa maintains hemoglobin, improves quality of life, and reduces transfusion in breast cancer patients receiving chemotherapy. J Clin Oncol. Apr. 20. 2005;23(12):2597-605. [pmid: 15452188].
91 Christodoulou C, Dafni U, Aravantinos G, et al. Effects of epoetin-alpha on quality of life of cancer patients with solid tumors receiving chemotherapy. Anticancer Res. Feb. 2009;29(2):693-702. [pmid: 19331224].
92 Janinis J, Dafni U, Aravantinos G, et al. Quality of life (QoL) outcome of epoietin-alfa (EPO-A) in anemic cancer patients undergoing platinum or non-platinum-based chemotherapy: a randomized study conducted by the Hellenic Cooperative Oncology Group. Proc Am Soc Clin Oncol. 2003;22:789.
93 Dammacco F, Castoldi G, Rodjer S. Efficacy of epoetin alfa in the treatment of anaemia of multiple myeloma. Br J Haematol. Apr. 2001;113(1):172-9. [pmid: 11328297].
94 Debus JHS, Morr H, et al. Epoetin alfa (EPO) and survival in patients with non-resectable NSCLC-Interim results. 27th Congress of the German Cancer Society. Berlin, Germany. German Medical Science. 2006.
95 Engert A, Borchmann P, Fuchs M. A prospectively randomized placebo-controlled trial of epoetin-in patients with advanced-stage Hodgkin lymphoma: Final analysis of the GHSG HD15-EPO trial. Haematologica. 2009;94.
96 Engert A, Josting A, Haverkamp H, et al. Epoetin alfa in patients with advanced-stage Hodgkin’s lymphoma: results of the randomized placebo-controlled GHSG HD15EPO trial. J Clin Oncol. May. 1. 2010;28(13):2239-45. [pmid: 20368566].
97 EPO-INT-1. EPO-INT-1: Safety concerns associated with Aranesp (darbepoetin alfa) Amgen, Inc and Procrit (epoetin alfa) Ortho Biotech, LP, for the treatment of anemia associated with cancer chemotherapy. Department of Health and Human Services, Food and Drug Administration, Center for Drug Evaluation and Research, Oncologic Drugs Advisory Committee. 2004.
98 EPO-INT-3. EPO-INT-3: Safety concerns associated with Aranesp (darbepoetin alfa) Amgen, Inc and Procrit (epoetin alfa) Ortho Biotech, LP, for the treatment of anemia associated with cancer chemotherapy. Department of Health and Human Services, Food and Drug Administration, Center for Drug Evaluation and Research, Oncologic Drugs Advisory Committee. 2004.
99 Fujisaka Y, Sugiyama T, Saito H, et al. Randomised, phase III trial of epoetin-beta to treat chemotherapy-induced anaemia according to the EU regulation. Br J Cancer. Oct. 25. 2011;105(9):1267-72. [pmid: 21959870].
100 Goss G, Feld R, BezJak A, et al. Impact of maintaining Hb with epoetin alfa on time to progression (TTP), overall survival (OS), quality of life (QOL) and transfusion reduction in limited disease SCLC patients. Lung Cancer. 2005;49(S53):O-154.
101 EPO-CAN-15. EPO-CAN-15: Safety concerns associated with Aranesp (darbepoetin alfa) Amgen Inc and Procrit (epoetin alfa) Ortho Biotech LP for the treatment of anemia associated with cancer chemotherapy. Department of Health and Human Services, Food and Drug Administration, Center for Drug Evaluation and Research, Oncologic Drugs Advisory Committee. 2004.
102 Grote T, Yeilding AL, Castillo R, et al. Efficacy and safety analysis of epoetin alfa in patients with small-cell lung cancer: a randomized, double-blind, placebo-controlled trial. J Clin Oncol. Dec. 20. 2005;23(36):9377-86. [pmid: 16361638].
103 Gupta S, Singh PK, Bisth SS, et al. Role of recombinant human erythropoietin in patients of advanced cervical cancer treated “by chemoradiotherapy”. Cancer Biol Ther. Jan. 2009;8(1):13-7. [pmid: 18981719].
104 Henry DH, Brooks BJ Jr, Case DC Jr, et al. Recombinant human erythropoietin therapy for anemic cancer patients receiving cisplatin chemotherapy. Cancer J Sci Am. Nov–Dec. 1995;1(4):252-60. [pmid: 9166485].
105 EPO-GBR-7. EPO-GBR-7: Safety concerns associated with Aranesp (darbepoetin alfa) Amgen Inc and Procrit (epoetin alfa) Ortho Biotech LP, for the treatment of anemia associated with cancer chemotherapy. Department of Health and Human Services, Food and Drug Administration, Center for Drug Evaluation and Research, Oncologic Drugs Advisory Committee. 2004.
106 Iconomou G, Koutras A, Rigopoulos A, et al. Effect of recombinant human erythropoietin on quality of life in cancer patients receiving chemotherapy: results of a randomized, controlled trial. J Pain Symptom Manage. Jun. 2003;25(6):512-8. [pmid: 12782431].
107 Littlewood TJ, Bajetta E, Nortier JW, et al. Effects of epoetin alfa on hematologic parameters and quality of life in cancer patients receiving nonplatinum chemotherapy: results of a randomized, double-blind, placebo-controlled trial. J Clin Oncol. Jun. 1. 2001;19(11):2865-74. [pmid: 11387359].
108 Machtay M, Pajak T, Suntharalingam M, et al. Definitive radiotherapy +/− erythropoietin for squamous cell carcinoma of the head and neck: preliminary report of RTOG 99-03. Int J Radiat Oncol Biol Phys. 2004;60(Suppl 1):S132.
109 Milroy R, Bajetta E, van den Berg PM, et al. Effects of epoetin alfa on anemia and patient-reported outcomes in patients with non-small cell lung cancer receiving chemotherapy: Results of a European, multicenter, randomized, controlled study. Eur J Clin Med Onc. 2011;3(2):49-56.
110 Moebus V, Lueck HJ, Thomssen C, et al. The impact of epoetin-alpha on anemia, red blood cell (RBC) transfusions, and survival in breast cancer patients (pts) treated with dose-dense sequential chemotherapy: Mature results of an AGO phase III study (ETC trial). J Clin Oncol. 2007;25:569.
111 Shanghai-Roche-Pharmaceuticals. ML17620. Multicenter open label study of NeoRecormon prevention and treatment for anemia in adult patients with solid tumors and treated with platinum-based chemotherapy prone to induce anemia. 2006.
112 Oberhoff C, Neri B, Amadori D, et al. Recombinant human erythropoietin in the treatment of chemotherapy-induced anemia and prevention of transfusion requirement associated with solid tumors: a randomized, controlled study. Ann Oncol. Mar. 1998;9(3):255-60. [pmid: 9602258].
113 Osterborg A, Brandberg Y, Molostova V, et al. Randomized, double-blind, placebo-controlled trial of recombinant human erythropoietin, epoetin Beta, in hematologic malignancies. J Clin Oncol. May. 15. 2002;20(10):2486-94. [pmid: 12011126].
114 Osterborg A, Brandberg Y, Hedenus M. Impact of epoetin-beta on survival of patients with lymphoproliferative malignancies: long-term follow up of a large randomized study. Br J Haematol. Apr. 2005;129(2):206-9. [pmid: 15813848].
115 Pronzato P, Cortesi E, van der Rijt CC, et al. Epoetin alfa improves anemia and anemia-related, patient-reported outcomes in patients with breast cancer receiving myelotoxic chemotherapy: results of a European, multicenter, randomized, controlled trial. Oncologist. 2010;15(9):935-43. [pmid: 20798194].
116 Ray-Coquard I, Dussart S, Goillot C, et al. A risk model for severe anemia to select cancer patients for primary prophylaxis with epoetin alpha: a prospective randomized controlled trial of the ELYPSE study group. Ann Oncol. Jun. 2009;20(6):1105-12. [pmid: 19174452].
117 Razzouk BI, Hockenberry M, Hinds PS, et al. A double-blind, placebo-controlled study of once-weekly epoetin alfa in children with cancer undergoing myelosuppressive chemotherapy. Abstract #8527. J Clin Oncol. 2004;22.
118 Rose E, Rai K, Revicki D, et al. Clinical and health status assessments in anemic chronic lymphocytic leukemia (CLL) patients treated with epoetin alfa (EPO). Blood. 1994;84(10 (Suppl 1)):526a. [pmid: 8025281].
119 Savonije JH, van Groeningen CJ, van Bochove A, et al. Effects of early intervention with epoetin alfa on transfusion requirement, hemoglobin level and survival during platinum-based chemotherapy: Results of a multicenter randomised controlled trial. Eur J Cancer. Jul. 2005;41(11):1560-9. [pmid: 15953714].
120 Savonije JH, van Groeningen CJ, Wormhoudt LW, et al. Early intervention with epoetin alfa during platinum-based chemotherapy: an analysis of the results of a multicenter, randomized, controlled trial based on initial hemoglobin level. Oncologist. Feb. 2006;11(2):206-16. [pmid: 16476841].
121 Thomas H, McAdam KF, Thomas RJ, et al. Early intervention with epoetin alfa for treatment of anaemia and improvement of quality of life in cancer patients undergoing myelotoxic chemotherapy. Ann Oncol. 2002;13(suppl 5):177. [pmid: 12401687].
122 GOG-191. GOG-191: Safety concerns associated with Aranesp (darbepoetin alfa) Amgen Inc and Procrit (epoetin alfa) Ortho Biotech LP, for the treatment of Anemia associated with cancer chemotherapy. Department of Health and Human Services, Food and Drug Administration, Center for Drug Evaluation and Research, Oncologic Drugs Advisory Committee. 2004.
123 Tsuboi M, Ezaki K, Tobinai K, et al. Weekly administration of epoetin beta for chemotherapy-induced anemia in cancer patients: results of a multicenter, Phase III, randomized, double-blind, placebo-controlled study. Jpn J Clin Oncol. Mar. 2009;39(3):163-8. [pmid: 19164318].
124 Wilkinson PM, Antonopoulos M, Lahousen M, et al. Epoetin alfa in platinum-treated ovarian cancer patients: results of a multinational, multicentre, randomised trial. Br J Cancer. Apr. 10. 2006;94(7):947-54. [pmid: 16570051].
125 Witzig TE, Silberstein PT, Loprinzi CL, et al. Phase III, randomized, double-blind study of epoetin alfa compared with placebo in anemic patients receiving chemotherapy. J Clin Oncol. Apr. 20. 2005;23(12):2606-17. [pmid: 15452187].
126 Hedenus M, Adriansson M, San Miguel J, et al. Efficacy and safety of darbepoetin alfa in anaemic patients with lymphoproliferative malignancies: a randomized, double-blind, placebo-controlled study. Br J Haematol. Aug. 2003;122(3):394-403. [pmid: 12877666].
127 Hernandez E, Ganly P, Charu V, et al. Randomized, double-blind, placebo-controlled trial of every-3-week darbepoetin alfa 300 micrograms for treatment of chemotherapy-induced anemia. Curr Med Res Opin. Sep. 2009;25(9):2109-20. [pmid: 19601709].
128 Katakami N, Nishiwaki Y, Fujiwara Y, et al. Randomized, Double-Blind, Placebo-Controlled Phase III Study of Weekly Administration of Darbepoetin Alfa (DA) in Anemic Patients With Lung or Gynecologic Cancer Receiving Platinum-Containing Chemotherapy. Ann Oncol. 2008;19(Suppl 8):277-8.
129 Kotasek D, Steger G, Faught W, et al. Darbepoetin alfa administered every 3 weeks alleviates anaemia in patients with solid tumours receiving chemotherapy; results of a double-blind, placebo-controlled, randomised study. Eur J Cancer. Sep. 2003;39(14):2026-34. [pmid: 12957457].
130 Pirker R, Ramlau RA, Schuette W, et al. Safety and efficacy of darbepoetin alpha in previously untreated extensive-stage small-cell lung cancer treated with platinum plus etoposide. J Clin Oncol. May. 10. 2008;26(14):2342-9. [pmid: 18467726].
131 Untch M, Fasching PA, Konecny GE, et al. PREPARE trial: a randomized phase III trial comparing preoperative, dose-dense, dose-intensified chemotherapy with epirubicin, paclitaxel and CMF versus a standard-dosed epirubicin/cyclophosphamide followed by paclitaxel +/− darbepoetin alfa in primary breast cancer--results at the time of surgery. Ann Oncol. Sep. 2011;22(9):1988-98. [pmid: 21385882].
132 Glaspy JA, Jadeja JS, Justice G, et al. Darbepoetin alfa given every 1 or 2 weeks alleviates anaemia associated with cancer chemotherapy. Br J Cancer. Jul. 29. 2002;87(3):268-76. [pmid: 12177793].
133 Glaspy J, Berg R, Tomita D, et al. Final results of a phase 3, randomized, open-label study of darbepoetin alfa 200 mcg every 2 weeks (Q2W) versus epoetin alfa 40,000 U weekly (QW) in patients with chemotherapy-induced anemia (CIA). J Clin Oncol. 2005;23(No. 16S Part I of II (June)):8125.
134 Glaspy J, Vadhan-Raj S, Patel R, et al. Randomized comparison of every-2-week darbepoetin alfa and weekly epoetin alfa for the treatment of chemotherapy-induced anemia: the 20030125 Study Group Trial. J Clin Oncol. May. 20. 2006;24(15):2290-7. [pmid: 16710026].
135 Kotsori AA, Alexopoulos CG. A randomized comparison of darbepoetin alfa with epoetin for chemotherapy induced anemia in nonhematological tumors. J Clin Oncol. 2006;24(18 Suppl):18554.
136 Schwartzberg LS, Yee LK, Senecal FM, et al. A randomized comparison of every-2-week darbepoetin alfa and weekly epoetin alfa for the treatment of chemotherapy-induced anemia in patients with breast, lung, or gynecologic cancer. Oncologist. 2004;9(6):696-707. [pmid: 15561813].
137 Waltzman R, Croot C, Justice GR, et al. Randomized comparison of epoetin alfa (40,000 U weekly) and darbepoetin alfa (200 microg every 2 weeks) in anemic patients with cancer receiving chemotherapy. Oncologist. Sep. 2005;10(8):642-50. [pmid: 16177289].
138 Glaspy JA. The potential for anemia treatment to improve survival in cancer patients. Oncology (Williston Park). Sep. 2002;16(9 Suppl 10):35-40. [pmid: 12380953].
139 Robins J. The analysis of randomized and non-randomized AIDS treatment trials using a new approach to causal inference in longitudinal studies. Sechrest L, Freeman H, Mulley A, editors. Health Service Research Methodology: A Focus on AIDS. NCHSR, U.S. Public Health Service. 1989:113-59.
140 Vansteenkiste J, Poulsen E, Rossi G, et al. Darbepoetin alfa: impact on treatment for chemotherapy-induced anemia and considerations in special populations. Oncology (Williston Park). Oct. 2002;16(10 Suppl 11):45-55. [pmid: 12435173].
141 Ludwig H, Crawford J, Osterborg A, et al. Pooled analysis of individual patient-level data from all randomized, double-blind, placebo-controlled trials of darbepoetin alfa in the treatment of patients with chemotherapy-induced anemia. J Clin Oncol. Jun. 10. 2009;27(17):2838-47. [pmid: 19380447].
142 Bradburn MJ, Deeks JJ, Berlin JA, et al. Much ado about nothing: a comparison of the performance of meta-analytical methods with rare events. Stat Med. Jan. 15. 2007;26(1):53-77. [pmid: 16596572].
143 Egger M, Smith G, Altman D. Systematic reviews in health care : meta-analysis in context. 2nd ed. London. BMJ. 2001.
144 Blohmer JU, Wuerschmidt J, Petry K, et al. Results with sequential adjuvant chemoradiotherapy with vs. without epoetin alfa for patients with high-risk cervical cancer: results of a prospective, randomized, open and controlled AGO and NOGGO-intergroup study. Ann Oncol. 2004;15(Suppl 3):128.
145 Bennett CL, Silver SM, Djulbegovic B, et al. Venous thromboembolism and mortality associated with recombinant erythropoietin and darbepoetin administration for the treatment of cancer-associated anemia. JAMA. Feb. 27. 2008;299(8):914-24. [pmid: 18314434].
146 Glaspy J, Crawford J, Vansteenkiste J, et al. Erythropoiesis-stimulating agents in oncology: a study-level meta-analysis of survival and other safety outcomes. Br J Cancer. Jan. 19. 2010;102(2):301-15. [pmid: 20051958].
147 Shehata N, Walker I, Meyer R, et al. The use of erythropoiesis-stimulating agents in patients with non-myeloid hematological malignancies: a systematic review. Ann Hematol. Dec. 2008;87(12):961-73. [pmid: 18629499].
148 Aapro M, Scherhag A, Burger HU. Effect of treatment with epoetin-beta on survival, tumour progression and thromboembolic events in patients with cancer: an updated meta-analysis of 12 randomised controlled studies including 2301 patients. Br J Cancer. Jul. 8. 2008;99(1):14-22. [pmid: 18542079].
149 Aapro M, Osterwalder B, Scherhag A, et al. Epoetin-beta treatment in patients with cancer chemotherapy-induced anaemia: the impact of initial haemoglobin and target haemoglobin levels on survival, tumour progression and thromboembolic events. Br J Cancer. Dec. 15. 2009;101(12):1961-71. [pmid: 19997109].
150 Lambin P, Ramaekers BL, van Mastrigt GA, et al. Erythropoietin as an adjuvant treatment with (chemo) radiation therapy for head and neck cancer. Cochrane Database Syst Rev. 2009;2009(3):CD006158. [pmid: 19588382].
151 Tonelli M, Hemmelgarn B, Reiman T, et al. Benefits and harms of erythropoiesis-stimulating agents for anemia related to cancer: a meta-analysis. CMAJ. May. 26. 2009;180(11):E62-71. [pmid: 19407261].
152 Kimel M, Leidy NK, Mannix S, et al. Does epoetin alfa improve health-related quality of life in chronically ill patients with anemia? Summary of trials of cancer, HIV/AIDS, and chronic kidney disease. Value Health. Jan–Feb. 2008;11(1):57-75. [pmid: 18237361].
153 Gascon P. Safety update on erythropoiesis-stimulating agents: trials within and outside the accepted indications. Oncologist. Suppl 3. 2008;13:4-10. [pmid: 18458118].
154 Cornes P, Coiffier B, Zambrowski JJ. Erythropoietic therapy for the treatment of anemia in patients with cancer: a valuable clinical and economic option. Curr Med Res Opin. Feb. 2007;23(2):357-68. [pmid: 17288690].
155 Minton O, Richardson A, Sharpe M, et al. A systematic review and meta-analysis of the pharmacological treatment of cancer-related fatigue. J Natl Cancer Inst. Aug. 20. 2008;100(16):1155-66. [pmid: 18695134].
156 Ray-Coquard I, Kassab CD, Casadevall N, et al. Standards, options: recommendations for the use of erythropoiesis-stimulating agents (ESA: epoetin alfa, epoetin beta, darbepoetin) in anaemic patients with cancer 2007 Update (Provisional abstract). Oncologie. 2008;10:160-6.
157 Katsumata N, Fujiwara Y, Sugiyama T, et al. Erythropoiesis-stimulating Agents for the Treatment of Chemotherapy-induced Anemia and Mortality: a Meta-analysis of Individual Patient Data From Japanese Randomized Trials. Eur J Cancer. 2011;47:S242.
158 Vansteenkiste J, Glaspy J, Henry D, et al. Benefits and risks of using erythropoiesis-stimulating agents (ESAs) in lung cancer patients: Study-level and patient-level meta-analyses. Lung Cancer. 2012. Jan. 23. [pmid: 22277104].
159 Meyer KB, Clayton KA. Measurement and analysis of patient-reported outcomes. Methods Mol Biol. 2009;473:155-69. [pmid: 19160737].
160 FDA. FDA guidance for Industry, Patient-Reported Outcome Measures: Use in Medical Product Development to Support Labeling Claims. 2009. http://www.fda.gov/downloads/Drugs/GuidanceComplianceRegulatoryInformation/Guidances/UCM193282.pdf. Accessed on June 16 2011.
161 Leidy NK, Revicki DA, Geneste B. Recommendations for evaluating the validity of quality of life claims for labeling and promotion. Value Health. Mar–Apr. 1999;2(2):113-27. [pmid: 16674343].
162 Guyatt GH, Bombardier C, Tugwell PX. Measuring disease-specific quality of life in clinical trials. Can Med Assoc J. Apr. 15. 1986;134(8):889-95. [pmid: 3955482].
163 Cella D. The Functional Assessment of Cancer Therapy-Anemia (FACT-An) Scale: a new tool for the assessment of outcomes in cancer anemia and fatigue. Semin Hematol. Jul. 1997;34(3 Suppl 2):13-9. [pmid: 9253779].
164 Cella DF, Tulsky DS, Gray G, et al. The Functional Assessment of Cancer Therapy scale: development and validation of the general measure. J Clin Oncol. Mar. 1993;11(3):570-9. [pmid: 8445433].
165 Clement FM, Klarenbach S, Tonelli M, et al. The impact of selecting a high hemoglobin target level on health-related quality of life for patients with chronic kidney disease: a systematic review and meta-analysis. Arch Intern Med. Jun. 22. 2009;169(12):1104-12. [pmid: 19546410].
166 Jaeschke R, Singer J, Guyatt GH. Measurement of health status. Ascertaining the minimal clinically important difference. Control Clin Trials. Dec. 1989;10(4):407-15. [pmid: 2691207].
167 Santana MJ, Feeny D, Jackson K, et al. Improvement in health-related quality of life after lung transplantation. Can Respir J. Sep–Oct. 2009;16(5):153-8. [pmid: 19851533].
168 Guyatt GH, Osoba D, Wu AW, et al. Methods to explain the clinical significance of health status measures. Mayo Clin Proc. Apr. 2002;77(4):371-83. [pmid: 11936935].
169 Revicki D, Hays RD, Cella D, et al. Recommended methods for determining responsiveness and minimally important differences for patient-reported outcomes. J Clin Epidemiol. Feb. 2008;61(2):102-9. [pmid: 18177782].
170 Guyatt G, Schunemann H. How can quality of life researchers make their work more useful to health workers and their patients?. Qual Life Res. Sep. 2007;16(7):1097-105. [pmid: 17530444].
171 Yost KJ, Eton DT. Combining distribution- and anchor-based approaches to determine minimally important differences: the FACIT experience. Eval Health Prof. Jun. 2005;28(2):172-91. [pmid: 15851772].
172 Make B. How can we assess outcomes of clinical trials: the MCID approach. COPD. Sep. 2007;4(3):191-4. [pmid: 17729062].
173 Osoba D. Translating the science of patient-reported outcomes assessment into clinical practice. J Natl Cancer Inst Monogr. 2007;(37):5-11. [pmid: 17951224].
174 Norman GR, Sloan JA, Wyrwich KW. Interpretation of changes in health-related quality of life: the remarkable universality of half a standard deviation. Med Care. May. 2003;41(5):582-92. [pmid: 12719681].
175 Wyrwich KW, Nienaber NA, Tierney WM, et al. Linking clinical relevance and statistical significance in evaluating intra-individual changes in health-related quality of life. Med Care. May. 1999;37(5):469-78. [pmid: 10335749].
176 Wyrwich KW, Tierney WM, Wolinsky FD. Further evidence supporting an SEM-based criterion for identifying meaningful intra-individual changes in health-related quality of life. J Clin Epidemiol. Sep. 1999;52(9):861-73. [pmid: 10529027].
177 Cohen J. Statistical power analysis for the behavioral sciences. Hillsdale, NJ. L. Erlbaum Associates. 1988.
178 King MT, Stockler MR, Cella DF, et al. Meta-analysis provides evidence-based effect sizes for a cancer-specific quality-of-life questionnaire, the FACT-G. J Clin Epidemiol. Mar. 2010;63(3):270-81. [pmid: 19716264].
179 Cella D, Eton DT, Lai JS, et al. Combining anchor and distribution-based methods to derive minimal clinically important differences on the Functional Assessment of Cancer Therapy (FACT) anemia and fatigue scales. J Pain Symptom Manage. Dec. 2002;24(6):547-61. [pmid: 12551804].
180 Patrick DL, Gagnon DD, Zagari MJ, et al. Assessing the clinical significance of health-related quality of life (HrQOL) improvements in anaemic cancer patients receiving epoetin alfa. Eur J Cancer. Feb. 2003;39(3):335-45. [pmid: 12565986].
181 Bircan A, Berktas BM, Bayiz H. Effects of chemotherapy on quality of life for patients with lung cancer. Turkish Respir J. 2003;4:61-6.
182 Kemmler G, Holzner B, Kopp M, et al. Comparison of two quality-of-life instruments for cancer patients: the functional assessment of cancer therapy-general and the European Organization for Research and Treatment of Cancer Quality of Life Questionnaire-C30. J Clin Oncol. Sep. 1999;17(9):2932-40. [pmid: 10561373].
183 Holzner B, Bode RK, Hahn EA, et al. Equating EORTC QLQ-C30 and FACT-G scores and its use in oncological research. Eur J Cancer. Dec. 2006;42(18):3169-77. [pmid: 17045472].
184 Torrance GW, Feeny D. Utilities and quality-adjusted life years. Int J Technol Assess Health Care. 1989;5(4):559-75. [pmid: 2634630].
185 Coast J. Reprocessing data to form QALYs. BMJ. Jul. 11. 1992;305(6845):87-90. [pmid: 1379096].
186 Ossa DF, Briggs A, McIntosh E, et al. Recombinant erythropoietin for chemotherapy-related anaemia: economic value and health-related quality-of-life assessment using direct utility elicitation and discrete choice experiment methods. Pharmacoeconomics. 2007;25(3):223-37. [pmid: 17335308].
187 Westenfelder C, Baranowski RL. Erythropoietin stimulates proliferation of human renal carcinoma cells. Kidney Int. Aug. 2000;58(2):647-57. [pmid: 10916088].
188 Acs G, Zhang PJ, Rebbeck TR, et al. Immunohistochemical expression of erythropoietin and erythropoietin receptor in breast carcinoma. Cancer. Sep. 1. 2002;95(5):969-81. [pmid: 12209679].
189 Straus DJ, Testa MA, Sarokhan BJ, et al. Quality-of-life and health benefits of early treatment of mild anemia: a randomized trial of epoetin alfa in patients receiving chemotherapy for hematologic malignancies. Cancer. Oct. 15. 2006;107(8):1909-17. [pmid: 16977654].
190 Crawford J, Robert F, Perry MC, et al. A randomized trial comparing immediate versus delayed treatment of anemia with once-weekly epoetin alfa in patients with non-small cell lung cancer scheduled to receive first-line chemotherapy. J Thorac Oncol. Mar. 2007;2(3):210-20. [pmid: 17410044].
191 Charu V, Saidman B, Ben-Jacob A, et al. A randomized, open-label, multicenter trial of immediate versus delayed intervention with darbepoetin alfa for chemotherapy-induced anemia. Oncologist. Oct. 2007;12(10):1253-63. [pmid: 17962619].
192 Schouwink JH, Codrington H, Sleeboom HP, et al. Prevention of anaemia by early intervention with once weekly epoetin alfa during chemotherapy. Eur J Cancer. Apr. 2008;44(6):819-29. [pmid: 18343652].
193 Glaspy JA, Charu V, Luo D, et al. Initiation of epoetin-alpha therapy at a starting dose of 120,000 units once every 3 weeks in patients with cancer receiving chemotherapy: an open-label, multicenter study with randomized and nonrandomized treatment arms. Cancer. Mar. 1. 2009;115(5):1121-31. [pmid: 19170225].
194 Tonelli M, Lloyd A, Lee H, et al. Erythropoiesis-stimulating agents for anemia of cancer or of chemotherapy: systematic review and economic evaluation. Canadian Agency for Drugs and Technologies in Health. Ottawa. 2009.
195 Blajchman MA, Vamvakas EC. The continuing risk of transfusion-transmitted infections. N Engl J Med. Sep. 28. 2006;355(13):1303-5. [pmid: 17005947].
196 Kitchen AD, Barbara JAJ. Current information on the infectious risks of allogeneic blood transfusion. Transfusion Alternatives in Transfusion Medicine. 2008;10(3):102-11.
197 Klein HG, Spahn DR, Carson JL. Red blood cell transfusion in clinical practice. Lancet. Aug. 4. 2007;370(9585):415-26. [pmid: 17679019].
198 Miller Y BG, Benjamin R, et al. Practice guidelines for blood transfusion: A compilation from recent peer-reviewed literature. 2nd ed. Red Cross. 2007. http://www.sld.cu/galerias/pdf/sitios/anestesiologia/practical_guidelines_blood_transfusion.pdf.
199 Spiess BD. Risks of transfusion: outcome focus. Transfusion. Dec. 2004;44(12 Suppl):4S-14S. [pmid: 15585000].
200 Vamvakas EC, Blajchman MA. Transfusion-related mortality: the ongoing risks of allogeneic blood transfusion and the available strategies for their prevention. Blood. Apr. 9. 2009;113(15):3406-17. [pmid: 19188662].
201 Untch M, von Minckwitz G, Konecny GE, et al. PREPARE trial: a randomized phase III trial comparing preoperative, dose-dense, dose-intensified chemotherapy with epirubicin, paclitaxel, and CMF versus a standard-dosed epirubicin-cyclophosphamide followed by paclitaxel with or without darbepoetin alfa in primary breast cancer--outcome on prognosis. Ann Oncol. Sep. 2011;22(9):1999-2006. [pmid: 21382868].
202 Zhang Y, Thamer M, Stefanik K, et al. Epoetin requirements predict mortality in hemodialysis patients. Am J Kidney Dis. Nov. 2004;44(5):866-76. [pmid: 15492953].
203 Solomon SD, Uno H, Lewis EF, et al. Erythropoietic response and outcomes in kidney disease and type 2 diabetes. N Engl J Med. Sep. 16. 2010;363(12):1146-55. [pmid: 20843249].
204 Hernan MA, Hernandez-Diaz S. Beyond the intention-to-treat in comparative effectiveness research. Clin Trials. Feb. 2012;9(1):48-55. [pmid: 21948059].
205 Larholt K, Pashos CL, Wang Q, et al. Dosing and outcomes study of erythropoiesis-stimulating therapies (DOSE): a registry for characterizing anaemia management and outcomes in oncology patients. Clin Drug Investig. 2008;28(3):159-67. [pmid: 18266401].