# Methods

This report updates the 2006 report, “Comparative Effectiveness of Epoetin and Darbepoetin for Managing Anemia in Patients Undergoing Cancer Treatment.” The current chapter describes the search strategies used to identify literature; criteria and methods for selecting eligible articles; methods for data abstraction, quality assessment, and evidence synthesis; and, finally, the process for technical expert advice and peer review. General and specific guidance from the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews was used throughout to advise review conduct.58

A Technical Expert Panel (TEP) provided consultation for the development phase of the systematic review. The draft report was reviewed by external peer reviewers. Revisions were made to the draft report based on reviewers’ comments.

## Search Strategies

The search for randomized controlled trials published subsequent to the 2006 Report was initially updated through electronic searching of the Cochrane Central Register of Controlled Trials Register (CENTRAL, 03/2005 to 11/2009), MEDLINE^®^ (03/2005 to 10/2009), and Embase (03/2005 to 10/2009). Electronic searching also included the conference proceedings of the American Society of Clinical Oncology (03/2005 to 10/2009), European Society of Medical Oncology (03/2005 to 10/2009), and American Society of Hematology (03/2005 to 10/2009).

A separate search for comparative observational studies, primarily to augment the evidence on adverse events, was conducted in MEDLINE^®^ only. A separate search for published meta-analyses and individual patient data analyses addressing outcomes of ESA treatment was conducted in PubMed and Cochrane databases in March 2010.

Literature searches were updated (through 12/2011) prior to finalizing the report to determine if any new studies were published that might potentially impact the review. New studies were screened and evaluated against inclusion/exclusion criteria in the same manner as all other studies. Those meeting criteria were included as well as any recent publications of results from previously included studies.

TEP members were invited to provide additional studies. Studies suggested by stakeholders during the public review period were also evaluated against inclusion/exclusion criteria in the same manner as all other studies. In addition, we received the following materials from the Scientific Resource Center:

1. A search of the grey literature included following sources: regulatory information, clinical trial registries (completed trials only), abstracts and conference papers, grants and federally funded research, and other miscellaneous sources.
2. Scientific information packets submitted by Amgen and Centocor Ortho Biotech, Inc.

All search results were compiled into an EndNote^®^ reference manager database with exclusion of duplicates.

Additional details on these materials and results of our review are provided in the Results chapter. Search strategies are detailed in Appendix A.

## Grey Literature

The Scientific Resource Center for the AHRQ Effective Health Care Program conducted a search of the following grey literature sources in support of this review:

- Regulatory Information
  a. FDA
  b. Health Canada
  c. Authorized Medicines for EU
- Clinical Trial Registries (completed trials only)
  a. ClinicalTrials.gov
  b. Current Controlled Trials
  c. Clinical Study Results
  d. WHO Clinical Trials
- Abstracts and Conference Papers
  a. Conference Papers Index
  b. Scopus
- Grants and Federally Funded Research
  a. NIH RePORTER (a searchable database of federally funded biomedical research projects conducted at universities, hospitals, and other research institutions)
  b. HSRPROJ (a database providing access to ongoing grants and contracts in health services research)
- Other Miscellaneous Sources
  a. Hayes, Inc. Health Technology Assessment
  b. NY Academy of Medicine’s Grey Literature Report

These sources were searched using sensitive searches similar to the searches in bibliographic databases. Citations for published articles linked to trials registered at ClinicalTrials.gov were included.

We evaluated the results of the grey literature search with results summarized in Figure 2. Twenty-six literature citations were already included in our reference database. Fifty-six references were reviewed at the abstract or summary level, in duplicate, and were excluded according to our study protocol. Seven references were retrieved in full and all were excluded (or had already been included) according to our study protocol. Thus, no new references were added to our review as a result of the grey literature search. We were unable to identify results, publications, or reports from 49 trial registry entries noted as completed trials (no results, citations, or links to results were listed in the trial registry entries).

Figure 2 PRISMA diagram for identified grey literature

EU = European Union; FDA = U.S. Food and Drug Administration; ISRCTN = International Standard Randomised Controlled Trials Number; NCT = Nationales Centrum für Tumorerkrankungen (National Center for Tumor Diseases); RCT = randomized controlled trial

Figure 2 is a flow chart that outlines study retrieval and selection process from the grey literature. It begins with the total citations retrieved from the grey literature searches and ends with the number of studies that satisfied the inclusion criteria for the report. This figure is described further in the Section entitled “Methods: Grey Literature” as follows: “Twenty-six literature citations were already included in our reference database. Fifty-six references were reviewed at the abstract or summary level, in duplicate, and were excluded according to our study protocol. Seven references were retrieved in full and all were excluded (or had already been included) according to our study protocol. Thus, no new references were added to our review as a result of the grey literature search. We were unable to identify results, publications, or reports from 49 trial registry entries noted as completed trials (no results, citations, or links to results were listed in the trial registry entries).”

## Scientific Information Packets

Industry stakeholders were invited to submit the following types of information for possible inclusion as evidence:

- A current product label;
- Published randomized controlled trials and observational studies relevant to the clinical outcomes; and
- Unpublished randomized controlled trials and observational studies relevant to the clinical outcomes.

In response, scientific information packets (SIPs) were received from Centocor Ortho Biotech, Inc. and Amgen. Disposition of the material can be found in Figure 3. In addition to product labels, the submissions consisted of either published references or listings of clinical trials; no unpublished data were provided by either company.

Figure 3 PRISMA diagram for scientific information packets

Figure 3 is a flow chart that outlines retrieval process for scientific information packets. It begins with the total citations retrieved from Amgen and Centocor Ortho Biotech and ends with the number of studies that satisfied the inclusion criteria for the report. This figure is described further in the Section entitled “Methods: References” as follows: “Centocor Ortho Biotech, Inc. submitted 56 citations and Amgen submitted 165. These were first compared to our database excluding duplicates. Of the 71 remaining references, 18 were duplicates. One reviewer reviewed abstracts for the 53 outstanding references; 5 were identified for full review; and those remaining were excluded as not relevant or already were addressed in our review. A second reviewer evaluated the 5 studies in full; all were excluded.”

## Product Labels

All submitted product labels, which included labels for countries other than the United States, were reviewed for clinical studies that were not included in our search. No new studies were found.

## References

Centocor Ortho Biotech, Inc. submitted 56 citations and Amgen submitted 165. These were first compared to our database excluding duplicates. Of the 71 remaining references, 18 were duplicates. One reviewer reviewed abstracts for the 53 outstanding references; 10 were identified for full review; and those remaining were excluded as not relevant or already were addressed in our review. A second reviewer evaluated the 10 studies in full; all were excluded.

## Observational Studies

We identified 175 observational studies in the MEDLINE^®^ search. Disposition of the studies according to selection criteria is shown in Figure 4.

Figure 4 PRISMA diagram for observational studies

Figure 4 is a flow chart that outlines study retrieval and selection process for observational studies. It begins with the total citations retrieved from the literature search for observational studies and end with the number of studies that satisfied the inclusion criteria for the report. The search identified 175 references. The title and abstract screen excluded 147 references (not relavant, 108; unmet study criteria, 39). A full text review excluded the remaining 28 references (not relavant, 10; unmet study criteria, 18).

## Trials

Sources and disposition for identified trials are shown in Figure 5 and Figure 6.

Figure 5 PRISMA diagram for identified trials—KQs

KQ = Key Question; RCT = randomized controlled trial

Figure 5 is a flow chart that outlines study retrieval and selection process for identified trials for all key questions. It begins with the 3 sets of citations retrieved from electronic database searching and abstract citations from conference proceedings (2391), citations from previous report (229), and citations from other sources (31) for a total of 2651 citations. A title and abstract screen resulted in the exclusion of 2382 references and a full text and selected abstract screening eliminated an additional 134 references (comments, 6; dose finding, 14; duplicate, 4; no treatment, 4; number of patients, 56; not RCT, 17; myelodysplastic, 5; ongoing studies, 5; surgery, 3; and other reason, 20). The remaining articles were sorted into 3 categories: Included for KQ1 – Epoetin or Darbepoetin vs. control (111), Included for KQ1 – Darbepoetin vs. Epoetin (11), and Included for KQ2 (13). Of the 111 references, 49 were included for quantitative synthesis KQ1 Epoetin or Darbepoetin vs. control, and the remaining 62 were placed into an additional references category. Of the 11 references, 5 were included for quantitative synthesis KQ1 Epoetin or Darbepoetin vs. control, and the remaining 6 were placed into an additional references category. Of the 13 references, 5 were included for quantitative synthesis KQ1 Epoetin or Darbepoetin vs. control, and the remaining 8 were placed into an additional references category.

Figure 6 PRISMA diagram for identified trials—KQ1, tumor progression

Figure 6 is a flow chart that outlines study retrieval and selection process for identified trials relating to key question 1, tumor progression. It begins with the total citations retrieved from the literature search for tumor progression trials and end with the number of studies that satisfied the inclusion criteria for the report. The search identified 49 references. A review excluded 34 articles (non homogeneous patient population, 23; not clearly definited treatment, 9; and not prospectively designed to assess tumor response, 2). Fifteen studies were included in the report.

## Meta-Analyses

Figure 7 outlines the identification of meta-analyses and systematic reviews.

Figure 7 PRISMA diagram for meta-analyses

FDA = U.S. Food and Drug Administration

Figure 7 is a flow chart that outlines retrieval and selection process for meta-analyses studies. It begins with the 2 sets of citations, references identified by literature search minus duplicates (110), and references identified through other sources (6) for a total of 116 citations. A title and abstract screen resulted in the exclusion of 49 references and a full text and selected abstract screening eliminated an additional 21 references (duplicate, 7; response study, 2; FDA document, 1; chart review study, 4; not systematic review, 2; myelodyplastic, 4; and not retrievable, 1). An additional 2 articles were added to the remaining articles (46) and a full text and selected abstract screening eliminated an additional 33 references (publication date <−2006, 28; duplicate, 4; and not cancer treatment, 1). Fifteen studies were included in the report.

## Study Selection Criteria

Study selection criteria were drafted and described in detail for randomized controlled trials and meta-analyses in Table 4. A primary source for survival evidence was a recently published individual patient data meta-analysis.48 In that meta-analysis, patient data were obtained from investigators for studies enrolling more than 50 patients per arm. Because those data constitute the most currently available, as well as the source for on-study mortality data, we limited inclusion in the current report to similar size studies to avoid potential differential endpoint ascertainment in smaller studies. This contrasts with the previous report that included studies enrolling 10 or more patients per arm. Sensitivity analyses were performed for each outcome including any studies excluded for that reason. Inclusion criteria for comparative observational studies were as in Table 4 except for “Types of studies.” Exclusion criteria were also the same except that studies enrolling fewer than 250 patients were excluded.

Table 4 Inclusion/exclusion criteria for randomized controlled trials; and study-level and individual patient data meta-analyses

| Inclusion Criteria | Exclusion Criteria
Types of studies | - Randomized controlled clinical trials.; - For studies where the specific randomization method is unclear, but the study is described as “randomized,” retain and categorize as “randomization unclear.”; - Study-level and individual patient data meta-analyses.; - Studies in European languages such as German, French, and Spanish; no effort will be made to translate languages such as Chinese or Arabic. | - Trials with inadequate allocation concealment, e.g. where patients were allocated by alternation, the use of case record numbers, dates of birth or day of week, and any other procedure that is transparent before allocation, such as an open list of random numbers. Trials with unclear allocation concealment were retained.; - Trials with 50 or fewer randomized participants per study arm for studies of adults; 10 or fewer participants per study arm in pediatric samples.; - Ongoing studies and interim analyses.
Sources of evidence | - Full text publications.; - Meeting abstract publications, PowerPoint presentations, or posters.; - Supplementary data communicated by primary authors of included trials or studies.; - Data presented at the ODAC, FDA hearings on May 10, 2007 and March 13, 2008. These data will be taken from the official FDA report and documents submitted by pharmaceutical companies and posted on the FDA’s Web site. These documents include both reports and power point presentations and are publicly available.
Types of participants | - Only participants diagnosed with malignant disease, using clinical or histological/cytological criteria, regardless of type or stage of the disease or previous therapy.; - Only participants who are anemic or at risk for anemia from chemotherapy and/or radiotherapy or the underlying malignant disease.; Patients of any/all ages. | - Studies of patients with a malignant disease NOT undergoing anticancer therapy.; - Studies of high-dose myeloablative chemotherapy regimens followed by bone marrow or peripheral blood stem cell transplantation.; - Studies using erythropoietin for short-term preoperative treatment to correct anemia or to support collection of autologous blood prior to cancer surgery for use during or after surgery.; - Studies in which patients received surgical treatment while being administered ESA. Studies on patients with myelodysplastic syndrome or acute leukemia.
Types of interventions | - Trials on the use of erythropoietin plus chemotherapy and/or radiotherapy and red blood cell transfusions if necessary, compared with identical anticancer therapy and red blood cell transfusions if necessary (alone or with placebo) will be included.; - Dose adaptation of erythropoietin depending on hematologic response allowed.; Concomitant supportive treatments, e.g., granulocyte colony-stimulating factors (G-CSF), must be given equally in all study arms or any differential effect of supportive treatments on outcomes ascertainable, EXCEPT studies where iron was given only in the ESA arm. These studies will be included and sensitivity analyses conducted with vs. without them.
Types of outcome measures | - Hematologic response: proportion of patients with an increase in hemoglobin level of 2 g/dl or more, or increase in hematocrit of 6 points or more, independent of blood transfusions.; - Proportion of patients receiving red blood cell transfusions.; - Quality of Life data will be only abstracted from studies employing a validated instrument, such as SF-36; EORTC Quality of life Questionnaire (QLQ-C30); Functional Assessment of Cancer Therapy (FACT, including G-General; F-Fatigue; An-Anemia). Sample size and extent of missing data will be extracted.; - Tumor response will only be evaluated in studies that were prospectively designed to assess tumor response, i.e., studies with a homogeneous patient population undergoing a predefined anticancer therapy, with predefined criteria when and how tumor response will be assessed and a clear definition of tumor response.; - Overall survival, disease-free, and progression-free survival.; Adverse effects limited to thromboembolic events, hypertension, rash and similar symptoms, seizures, rEPO antibodies, and transfusion adverse events. | Linear Analog Scale Assessment (LASA), Visual Analog Scale (VAS), and Cancer Linear Analog Scale (CLAS) scales will be excluded

## Randomized Controlled Trial Selection

One reviewer screened titles and abstracts of trials identified from the above sources against the inclusion/exclusion criteria. If this could not be done satisfactorily from the title and abstract, a full-text version was obtained for review. We evaluated studies that appeared to meet the inclusion criteria in the initial screening with an eligibility form containing the following questions:

1. Is the study described as randomized?
2. Did the participants in the study have a previously treated or untreated malignant disease?
3. Were the participants anemic or at risk for anemia from chemotherapy and/or radiotherapy?
4. Was one group given epoetin (alfa or beta) or darbepoetin subcutaneously or intravenously for at least four weeks?
5. Did the control group receive the same care (e.g., chemotherapy and supportive therapies) with or without placebo, or is any differential effect of supportive treatments on outcomes ascertainable? (Note exception for iron supplementation; see Criteria for Considering Studies, Types of Interventions.)
6. Did the study document one of the relevant outcome measures?

Eligible trials met all of the criteria listed above. Disagreements between the reviewers were resolved by discussion. Duplicate studies were identified and data extracted from the most recent publication. However, if there were additional data in one of the older publications, these were extracted as well. Full-text versions of all eligible studies were obtained for quality assessment and data extraction. A list of studies excluded, with reasons for exclusion, can be found in Appendix B. Detailed data abstraction/evidence tables can be found in Appendix C.

## Observational Study Selection

A first reviewer screened titles and abstracts of identified studies from the above sources against the eligibility criteria. If the first reviewer was unable to categorize the study, it was screened by a second reviewer and inclusion/exclusion status established by consensus. If this could not be done satisfactorily from the title and abstract, a full-text version was obtained for review. Eligible studies met the following criteria:

1. Was treatment assignment (use) nonrandom?
2. Were there more than 250 subjects?
3. Did the participants in the study have a previously treated or untreated malignant disease?
4. Were the participants anemic or at risk for anemia from chemotherapy and/or radiotherapy?
5. Was epoetin (alfa or beta) or darbepoetin given subcutaneously or intravenously for at least 4 weeks?
6. Did the study document one of the relevant outcome measures (benefit or harm)?
7. In the study analyses was one of the following techniques used to examine causal effects: (a) appropriate propensity score approaches, (b) instrumental variable methods, (c) inverse probability weighting, or (d) G-estimation techniques to take into account potential bias.

Selection criteria were defined to identify both carefully conducted observational studies (registry or otherwise) accompanied by analyses that could account to nonrandom treatment assignment (criterion 7) to identify causal effects. Of particular interest was identifying studies that examine dose effects while accounting for time-varying confounding of hemoglobin levels.

## Study and Independent Patient-Level Meta-Analysis Selection

Both study- and patient-level meta-analyses examining benefits or harms of ESA treatment were included. Progression-free or disease-free survival study-level results from industry-funded meta-analyses were also included if the original study was designed to evaluate that outcome.

## Assessment of Methodologic Quality

### Quality Assessment of Included Randomized Clinical Trials

Two reviewers evaluated the full text articles included in the review for study quality. Any discordance was discussed with the project group until consensus was obtained. We used a modification of the The Cochrane Collaboration’s tool for assessing risk of bias (The Cochrane Handbook, Table 8.5.a)59 containing the following questions:

1. Was allocation truly random?
2. Was the treatment allocation concealed?
3. Were study participants blinded (masked) to the treatment they received?
4. Were study clinicians blinded (masked) to the treatment received by individual study participants?
5. Were the number of patient withdrawals, dropouts, and those lost to follow-up in each group stated in the main publication?
6. Did the analysis include an intention-to-treat analysis? That is, did the analysis include all patients randomized according to their randomized assignment?
7. Were the participant characteristics similar at baseline in the study groups compared?

For health-related quality-of-life studies (HRQoL), we also evaluated whether patients were blinded to their hemoglobin levels when HRQoL questionnaires were completed. For studies for which there were several reports/analyses, we used our best judgment for accurately and efficiently assessing quality (study level was the default).

Trials were excluded from the analysis if they were not truly randomized or had inadequately concealed allocation. Studies that met all criteria listed below were included in the group of higher quality trials for purposes of sensitivity analysis.

1. The study was a randomized controlled trial (see details under Criteria for Study Selection).
2. The study was double blind.
3. At least one of the following conditions was true: Less than 10 percent of subjects within each study arm were excluded from the analysis and the percentage of subjects excluded from analysis in each arm was less than 2:1; or less than 5 percent of subjects were excluded in each study arm.

### Quality Assessment of Published Meta-Analyses

AMSTAR (Assessment of Multiple Systematic Reviews) is a validated instrument used for quality assessment of meta-analyses.60 While the instrument has been validated with study-level meta-analyses, nine of the 11 elements apply directly and the remaining two elements indirectly to individual patient meta-analyses. Accordingly, the instrument was applied to all meta-analyses.

### Quality Assessment of Observational Studies

No quality assessment of observational studies was conducted (no studies met inclusion criteria).

## Data Extraction

One reviewer performed data extraction for the review using a standardized data extraction form modified slightly from the previous systematic review (Appendix D), including the types of items listed below. An independent reviewer checked abstracted data.

For randomized controlled clinical trials, the following were abstracted:

1. General information: title, authors, source, contact address, year of publication, duplicate publications, setting, funding.
2. Trial characteristics: design, method of randomization, concealment of allocation, blinding of patients and clinicians.
3. Patients: sampling, exclusion criteria, sample size, baseline characteristics, similarity of groups at baseline, diagnostic criteria, withdrawals, losses to followup.
4. Interventions: placebo use, dose, dosing regimen, duration, route, red blood cell (RBC) transfusion trigger, co-medications with dose, route and timing. Outcomes as specified previously.
5. Analytical methods.

Any disagreements at any stage were resolved by discussion and consensus.

## Discrepant Data

For trials published in multiple articles, reports or presentations, we extracted the most recent or most comprehensive data. The data of any trial taken from different sources were compared. If data from different sources were discrepant, data were selected for analysis using the following rules:

1. We used the most complete data sets (i.e., those with the largest sample size), or data with consistently defined outcomes across trials.
2. If different results were available from the same trial, i.e. “intention-to-treat” and “as treated” analyses, we use the intention-to-treat based data for analysis and explored the influence of alternative results in sensitivity analyses if appropriate.

## Other Issues

If a trial only reported the overall number of randomized patients but failed to report the number of patients per study arm, we assigned 50 percent of the study patients to each of the study arms. For updating reports that were already included in the previous review, the focus was on variables important to the analyses, rather than on a global update.

Trial-level evidence tables were created in Microsoft Excel^®^ and Word^®^. For summary evidence tables, data were entered into Excel^®^ then summarized using and formatted in R.61 Templates similar to the 2006 report were used. One reviewer performed primary data entry into the Excel^®^ evidence tables, and a second performed accuracy checks.

PRISMA62 or PRISMA-like diagrams were constructed for each KQ and other applicable searches (meta-analyses, observational studies, grey literature, scientific information packets).

Abstracted data used in meta-analyses are either reported in the text or succinctly in Appendix G.

## Rating the Body of Evidence

We rated the overall body of evidence as outlined in the AHRQ EPC Methods Guide for Comparative Effectiveness Reviews.63 The EPC approach is largely based on the system developed by the GRADE (Grading of Recommendations Assessment, Development and Evaluation) Working Group.64 The EPC method explicitly addresses the following domains: risk of bias, consistency, directness, and precision. Additional domains are added where appropriate; we also considered strength of association and publication bias. We identified five key outcomes as the most clinically important for rating: transfusion risk, overall survival, on-study mortality, thromboembolic events, and health-related quality-of-life (FACT-Fatigue).

Strength of evidence was classified into the following four grades:

1. High: High confidence that the evidence reflects the true effect. Further research is very unlikely to change confidence in the estimate of effect.
2. Moderate: Moderate confidence that the evidence reflects the true effect. Further research may change confidence in the estimate of effect and may change the estimate.
3. Low: Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
4. Insufficient: Evidence either is unavailable or does not permit a conclusion.

### Grading the Evidence

Two reviewers with primary roles in the report developed consensus for each outcome and comparison as follows. First, domains and associated criteria were reviewed alongside AHRQ guidance.63 The two reviewers jointly rated domains and rated quality of evidence for each outcome and comparison. Agreement was achieved by discussion and consensus.

## Data Analysis

When study-level outcome data were available from multiple trials (three or more), results were pooled in meta-analyses. For overall survival, owing to censoring in individual studies, hazard ratios (HR) over the longest follow-up reported were combined in fixed effects models using Peto’s method65 for observed and expected events with accompanying variance estimates.66,67 For on study mortality, the approach was also used, but because censoring was of lesser concern and few deaths occurred in some studies, event rates were additionally pooled in Bayesian hierarchical models. From these models posterior 95% credible intervals were estimated to convey uncertainty. A credible interval is a Bayesian analogue to the confidence intervals—it differs from a confidence interval by representing the probability a true value is contained within it, and not the confidence with repeated sampling of including the true value. Noninformative priors were specified in these models. To obtain relative risks, the approach outlined by Warn et al.68 was adopted. A Bayesian model was also used to examine the association between baseline risk (as reflected by control group mortality rate) and relative risk; the model accounts for the inherent correlation between relative effect and baseline risk.69 For all other meta-analyses, random effects models were fitted and relative risks reported. While values of I^2^ were reported throughout, in many instances its magnitude does not correctly or appropriately reflect statistical heterogeneity due to the low event rates in individual trials and accompanying imprecision.70 Accordingly and as noted in the Results section, I^2^ cannot be used under such circumstances as an adequate representation of statistical heterogeneity. Between-study heterogeneity was explored as appropriate in sensitivity analyses examining subgroups through meta-regressions.

Hazard ratios for time to event data were calculated based on individual patient data (IPD) when available from Bohlius et al.48 If IPD data were not available, no efforts were made to obtain it and the HR calculated from published reports. Recognizing limitations, indications of possible publication bias were explored in funnel plots. Funnel plots were inspected, but noted only if suggestive of publication bias. Forest plots were included in the main report when considered informative.

Subgroup analyses were performed including the following factors, if feasible and appropriate:

- Hemoglobin at study entry (e.g., continuous and hemoglobin level <10 g/dL versus 10–12 g/dL versus >12 g/dL)
- Achieved hemoglobin (e.g., continuous and hemoglobin level 10–11 g/dL versus 11–12 g/dL versus >12 g/dL)
- Difference between target and achieved hemoglobin
- Solid tumors versus hematologic malignancies versus mixed (studies including both solid tumors and hematologic malignancies)
- Type of treatment given (platinum-based chemotherapy versus chemotherapy without platinum; chemotherapy alone versus chemotherapy plus radiotherapy versus radiotherapy alone)
- Radiotherapy alone versus chemotherapy/radio-chemotherapy
- Planned iron supplementation (e.g., fixed versus as necessary versus none)
- Planned duration of epoetin or darbepoetin treatment
- Epoetin versus darbepoetin
- Study quality (high- versus low-quality studies); (domains of study quality included blinding, allocation concealment, and intention to treat analyses)
- Source of data (full-text publications versus abstract publications versus unreported data versus data presented at FDA hearing versus data from published IPD meta-analyses; source for data for a given study could differ between outcomes, e.g., survival data taken from FDA hearing, transfusion data taken from publication)

While the protocol included potential categorizations of covariates, to obtain sufficient precision (i.e., avoid strata with few trials) subgroup analyses were performed with covariates dichotomized into the most clinically relevant categories in meta-regressions. Additionally, there was evidence of substantial clinical heterogeneity between trials—design, tumor type, baseline and target hemoglobin (defined as the lowest acceptable hemoglobin value—for example, if ESA treatment was stopped because of high hemoglobin, it was restarted if hemoglobin level fell below this value), chemotherapy, dosing, escalation and de-escalation rules, iron supplementation, and length of follow-up, to name a few. Under these conditions, any subgroup findings require cautious interpretation and may be problematic. Accordingly, subgroup results were explored but not generally discussed at length. Finally, potential ecological bias further limits subgroup interpretation (e.g., for hemoglobin).

Summary descriptive statistics for characteristics of trials included in each meta-analysis were calculated based on those reported for the entire trial. Because not all patients were included for some outcomes, certain descriptive statistics may not be perfectly precise—e.g., a summary statistic was reported for all patients, but the outcome assessed on 95 percent of those randomized. Still, the values represent the group of trials examined, albeit with some small random error.

Results in the current report were compared to the 2006 review38 in sensitivity analyses. Differences in study inclusion were due to newly identified studies, updated data from recent publications, and because inclusion criteria here required more than 50 patients per arm—a criterion not previously applied. Also, prior results were generally obtained from fixed effects models, while random effects were used here throughout. Consequently, some differences between the current and 2006 reviews results may be due to the model used.

### Software

Analyses were performed using RevMan,71 R61,72–74, and OpenBUGS.75

## Decision Analysis

To examine the balance of potential benefit and harms, a decision model was developed and used to quantify life-years and quality-adjusted life years for representative ESA and non-ESA strategies. Utilities accompanying the two alive health states included in the model (9 g/dL and 11 g/dL) were estimated using those obtained in four manufacturer studies using time trade-off (2 studies) and EQ-5D (2 studies) as reported in a prior technology assessment.76 Midpoints were assigned to reported hemoglobin range for the reported utilities and included in a hierarchical model (with study as group) to estimate the two utility values used here. Over a 1-year time horizon (for the base case and other likely conditions), life years and quality-adjusted life years were calculated for a hypothetical cohort of 1,000 patients undergoing 12 weeks of ESA treatment and presumed to be at increased risk of mortality through 16 weeks. A 4-week cycle (without mid-cycle correction) was used. Other relevant features of the model are described in the section “Decision Analysis.” Calculations were performed using Excel^®^ with the model replicated in TreeAge Pro.77