# Introduction

This review updates the 2006 Agency for Healthcare Research and Quality (AHRQ) comparative effectiveness review of epoetin and darbepoetin for managing anemia in patients undergoing cancer treatment.1 Since that review was completed, further evidence concerning a number of the Key Questions (KQs) addressed in that review has become available. In addition and as a result of new evidence, the U.S. Food and Drug Administration (FDA) made several revisions to the approved labeling for erythropoietic-stimulating agents (ESAs). Based on these new developments, AHRQ concluded that aspects of the prior review required updating with recently published and presented evidence. Importantly, this update accordingly addresses only those questions where new evidence has become available.

The introduction is organized as follows. First, the basic biology of erythropoietin and ESAs is reviewed. We then discuss the significance of anemia and its treatment with ESAs in the setting of cancer therapy. This is followed by a description of previous AHRQ reports and associated collaborations with the Cochrane Hematologic Malignancies Group, who conducted additional evaluations, which provides a brief overview of prior evidence and conclusions. Subsequent changes in FDA-approved labeling are noted and chronicled. We present the scope of this report and KQs followed by an overview of the patient populations included, interventions, comparators, and outcomes. The types of studies included in the report are then discussed. Finally, we describe some important complexities presented by the evidence for synthesis, as these complexities directly or indirectly impact much of the analyses, conclusions, and research recommendations.

## Background

### Erythropoietin

Erythropoietin, a hormone produced in the kidney in response to tissue hypoxia, is the major regulator of red blood cell production (erythropoiesis). Erythropoietin binds to specific receptors on the surface of immature erythroid cells in the bone marrow that would otherwise undergo apoptosis.2 Binding initiates a cascade leading to the survival of these cells. Proliferation of erythroid cells may also be a consequence of erythropoietin stimulation. Circulating reticulocytes increase, followed by a more delayed increase in hemoglobin and red blood cell count.

Two commercially produced recombinant human erythropoietins—epoetin alfa (Epogen^®^; Procrit^®^) and epoetin beta (the latter not available in the United States)—have been extensively studied and used clinically for more than a decade to treat anemia in association with various diseases; they have similar clinical efficacy.3,4 Darbepoetin alfa (Aranesp^®^), more recently developed, produces a similar physiologic response when compared to recombinant human erythropoietin,5 has been tested in prospective clinical trials,6–8 and is commercially available in the United States. All ESAs increase the number of red blood cells within about 2 to 3 weeks when given to individuals with functioning erythropoiesis. In addition, erythropoietin has effects on megakaryocytopoiesis (platelet production and thrombopoiesis) possibly related to structural similarities with thrombopoietin.2

### Anemia

Anemia, a deficiency in the concentration of hemoglobin-containing red blood cells, is prevalent among cancer patients. The National Cancer Institute and others classify anemia based on hemoglobin (Hb) values:9

- Grade 0, within normal limits, Hb values are 12.0–16.0 g/dL for women and 14.0–18.0 g/dL for men
- Grade 1, mild (Hb 10 g/dL to normal limits)
- Grade 2, moderate (Hb 8.0–10.0 g/dL)
- Grade 3, serious/severe (Hb 6.5–7.9 g/dL)
- Grade 4, life threatening (Hb less than 6.5 g/dL).

#### Anemia and Cancer

The prevalence of anemia varies according to the type of neoplasia and treatment.10 Patients with chronic hematological malignancies or solid tumors frequently experience anemia, which may result from the malignancy itself or from treatment or both. For example, the prevalence of anemia at diagnosis is approximately 40 percent of patients with non-Hodgkin’s or Hodgkin lymphoma; following 3 to 4 cycles of chemotherapy up to 70 percent of these patients will be anemic.11 The European Cancer Anaemia Survey (ECAS) reported on a subset of cancer patients (“incidence population”) who were neither anemic at enrollment in the survey nor treated for anemia and who received at least their first two myelosuppressive chemotherapy treatment cycles during the survey.12 Among these patients, those with lung or gynecologic cancer were three times more likely to become anemic than those with GI/colorectal cancer. In addition, anemia was twice as likely with platinum treatment than with non-platinum treatment. Additional analysis of a lung cancer population revealed anemia incidences of 80 percent in patients treated with chemotherapy, 31 percent for patients treated with chemotherapy plus radiotherapy, and 15 percent for patients treated with radiotherapy alone.13

The pathophysiology of anemia accompanying malignancies is multifactorial. For example, in advanced stages of hematologic malignancies, malignant cells replace most of the normal hematopoietic cells in the bone marrow, leading to progressive anemia. In general, after exclusion of other causes (e.g., iron or vitamin deficiencies, occult bleeding, autoimmune hemolysis, or pure red blood cell aplasia), anemia is typically attributed to “anemia of chronic disease.” It is characterized by a close interaction between the tumor cell population and the immune system, leading to the activation of macrophages and increased expression of various cytokines. This results in insufficient endogenous erythropoietin synthesis, suppressed differentiation of erythroid precursor cells in the bone marrow, and alterations of iron metabolism.14 Anemia of chronic disease is the most common type of anemia in patients with malignant disease, but it can be aggravated by chemotherapy or radiotherapy. In particular, platinum-based chemotherapy regimens may diminish endogenous erythropoietin production by damaging renal tubular cells.15

Manifestation and severity of anemia vary considerably among individual cancer patients. Mild to moderate anemia developing over a short time can cause symptoms including headache, palpitations, tachycardia, and shortness of breath. Chronic anemia may result in severe organ damage affecting the cardiovascular system, immune system, lungs, kidneys, muscles, and central nervous system.16 In addition to the physical symptoms, the subjective impact of cancer-related anemia on quality of life (QoL), mental health, and social activities may be substantial. Studies have reported correlations between hemoglobin levels and quality of life.17–19

Anemia may also be associated with outcomes or have direct effects on the tumor itself. In malignant diseases like Hodgkin’s lymphoma, chronic lymphocytic leukemia, cervical carcinoma, and cancer of the head and neck, anemia is reportedly a prognostic factor.20 There is evidence that anemia, causing tumor hypoxia, might result in a poorer response to radio- or chemotherapy.21 These factors may lead to a higher tumor burden and decrease overall survival.21–24 Although the prognostic significance of anemia may simply reflect progressive or advanced disease, the observation generated the hypothesis that strategies to diminish cancer-related anemia might alleviate not only anemia-related symptoms and improve quality of life, but also might improve tumor response and extend overall survival time.

#### Correcting Anemia With Blood Transfusion

Historically, blood transfusion was the treatment of choice for severe cancer-related anemia. The literature generally supports treating hemoglobin concentrations below 8 g/dL, while mild-to-moderate cancer-related anemia (hemoglobin level 8 to 10 g/dL) often goes untreated.25 Although homologous blood transfusion is the fastest method to alleviate symptoms, short and long term risks exist.26 These include transmitting infectious diseases, transfusion reactions, alloimmunization, overtransfusion, and immune modulation with theoretically possible adverse effects on tumor growth.27 The risk of severe infectious complications of blood transfusions are 1:30,000 to 1:250,000 units of blood transfused for Hepatitis B, 1:30,000 to 1:150,000 for Hepatitis C and 1:250,000 to 1:1,000,000 for HIV.28 Emerging infections, such as the West Nile virus epidemic in 2002 in the United States are of concern.29,30 Still, in decision-analytic models of ESAs, any risk accompanying blood transfusion appears not to meaningfully impact results due to the infrequent occurrence of severe adverse events.31,32

## Prior EPC Pooled Analyses of ESA Treatment Outcomes

The development of intensified antineoplastic therapies has increased the risk for anemia and the need for correction of anemia by blood transfusion or treatment with ESAs. Initially, adverse effects such as hypertension, headaches, and thrombotic events that could be attributed to erythropoietin treatment had been reported in very few patients;33 however, more recently randomized controlled trials have reported increased incidence of thrombotic events34,35 and reduced survival.35–37 This resulted in several pooled analyses of ESA trial data over several years, as well as regulatory actions by the U.S. Food and Drug Administration (FDA). Following is a summary of analyses authored, or contributed to, by the Blue Cross and Blue Shield Association Technology Evaluation Center (BCBSA TEC) Evidence-based Practice Center (EPC).

In 2001, the AHRQ-sponsored systematic review “Uses of Epoetin for Anemia in Oncology” was completed.38 The American Society of Clinical Oncology (ASCO) and the American Society of Hematology (ASH), who intended to use the evidence review as the scientific basis for a joint clinical guideline, originally proposed the topic to AHRQ. Members of the ASCO/ASH joint guideline committee participated on the Technical Expert Panel for the systematic review, and subsequently a member of the BCBSA TEC EPC systematic review team participated as an ad hoc nonvoting member of the guideline panel. It was clear that administering epoetin given to cancer patients treated with chemotherapy and subsequently found moderately anemic (hemoglobin <10 g/dL) resulted in increased hemoglobin levels and fewer transfusions. Major questions at the time were whether initiating epoetin treatment before patients became moderately anemic (i.e., hemoglobin between 10 and 12 g/dL) would result in fewer patients transfused or would improve quality of life. However, the systematic review concluded that the available evidence was inadequate to answer either question.

The database constructed for the 2001 BCBSA TEC EPC systematic review was shared with the Cochrane Hematologic Malignancies Group with permission from AHRQ; the data provided a starting point for a Cochrane Review completed in 2004.^39^ The results of this review were also consistent with erythropoietin reducing blood transfusions in anemic patients with cancer. Evidence as to whether erythropoietin affected tumor response and overall survival was inconclusive. It was also unclear whether erythropoietin increased the risk of hypertension and thrombotic complications or improved quality of life and reduced fatigue.

In 2006, the BCBSA TEC EPC published a comparative effectiveness review (CER) of epoetin and darbepoetin treatment for anemia related to cancer treatment under the AHRQ contract.1 This review was conducted collaboratively between TEC and the Cochrane Hematologic Malignancies Group.

The 2006 CER found no clinically meaningful difference between epoetin and darbepoetin with regard to hemoglobin response, transfusion reduction, or thromboembolic events. Three trials40–42 failed to show better transfusion-sparing effects when ESA treatment was initiated immediately versus only if hemoglobin fell below a specified threshold (9 or 10 g/dL). When comparing epoetin or darbepoetin to control, there was an increase in thromboembolic events associated with ESA use, but variability in event rates between control arms of different trials was high, and several studies targeted higher hemoglobin levels than recommended by product labels at the time. Too few trial results were available to perform a subgroup analysis conforming to label recommendations. Quality-of-life measures, viewed at the time as one of the most important outcomes of treatment, tended to favor ESA treatment, but variability in the amount of change, and potential for bias due to a number of methodologic factors made definitive conclusions difficult. Several trials included in the 2006 review showed an ESA-associated detriment in survival and others did not. Most of the included trials that raised concerns over safety, survival, and tumor response were unpublished. Information about trial design and results was available only from briefings presented to the FDA Oncologic Drugs Advisory Committee, May 4, 2004.^a^

a See http://www.fda.gov/ohrms/dockets/ac/04/briefing/4037b2.htm for May 2004 briefing information and http://www.fda.gov/ohrms/dockets/ac/04/slides/4037s2.htm for slides.

These trials, the 2006 CER, as well as several pooled analyses, led to a series of FDA-directed Physician Alerts and label changes to more stringent dosing recommendations (Table 1). By May 2007, there were data from six randomized trials showing decreased survival (five trials)34,35,43–45 and/or poorer local regional control and progression-free survival (two trials)34,46 in the ESA treatment arm. Three trials were stopped early because of adverse events in the treatment arms.45–47 In five of the six trials, the target hemoglobin exceeded 12 g/dL and patients’ baseline hemoglobin levels were more than 10 g/dL. Five of the six trials each enrolled patients with a specific tumor type; these were advanced breast, head and neck, lymphoid, or non-small cell lung cancer. The pooled analyses of the BCBSA TEC-authored AHRQ CER and the Cochrane Review were also available, along with other published meta-analyses. The most significant changes to the ESA labels occurred in 2007, and the issue of ESA effect on survival became paramount, with quality of life becoming less important by comparison.

Table 1 FDA alerts and actions related to ESA prescribing

Date | Notification Type | Content Change
June 2004 | Addition of clinical trial results and warning to label | Added descriptions of clinical trial results showing risks for tumor promotion and increased mortality among cancer patients who were receiving ESAs in the treatment of chemotherapy-induced anemia; an additional warning advised physicians of increased thromboembolic event risks with ESAs in the oncology setting.
November 2006 | FDA Alert regarding clinical trial results | The “Correction of Hemoglobin and Outcomes in Renal Insufficiency” (CHOIR) study50 showed that patients treated with an ESA and dosed to a target Hb of 13.5 g/dL were at a significantly increased risk for serious and life-threatening cardiovascular complications, compared to control Hb target of 11.3 g/dL; the alert emphasized then current dosing recommendation that the target Hb not exceed 12 g/dL.
March 2007 | New black box warning; updated warnings, and a change to the dosage and administration | Highlights the risk of death and serious cardiovascular events when the Hb target is greater than 12 g/dL and in specific patient categories; recommends avoiding serious cardiovascular and arterial and venous thromboembolic events using the lowest possible ESA dose to reach the lowest Hb level possible to avoid RBC transfusions. Added warnings about increased mortality, cardiovascular events, tumor progression and uncontrolled hypertension. Recommended withholding ESA dose if Hb increase exceeds 12 g/dL or rises by 1g/dL in any 2-week period.
November 2007 | Expanded black box warning and more specific dosing language | Revisions warn that data are not sufficient to exclude the possibility of shortened survival and tumor progression in patients with cancer when ESAs are dosed to reach a Hb level between 10 and 12 g/dL. Added information that ESAs caused tumor growth and shortened survival in patients with advanced breast, head and neck, lymphoid, and non–small-cell lung cancer when they received a dose that attempted to achieve Hb ≥12 g/dL.
March 2008 | Changed black box warning, modified labeling information | Described the results of two additional studies37,51 showing increased mortality and more rapid tumor progression in patients with nonadvanced breast and cervical cancers when dosed to target Hb of ≥12 g/dL.
July 2008 | Expanded black box warning; dosing language modified | ESAs should not be used in cancer patients receiving chemotherapy if a cure is anticipated. Also included is a statement that ESAs are not to be administered when Hb levels are ≥ 10 g/dL. Language was removed that seemed to imply that it was safe to continue treating patients until their Hb increased to 12 g/dL.
February 2010 | Announcement of risk evaluation and mitigation strategy (REMS) | The FDA requires all ESAs to be prescribed and used under the ESA APPRISE (Assisting Providers and cancer Patients with Risk Information for the Safe use of ESAs) Oncology Program, part of a REMS, to ensure safe use of the drugs. ESA manufacturers must ensure that only those hospitals and healthcare professionals who have enrolled and completed training in the ESA APPRISE program will prescribe and dispense ESAs to patients with cancer. The ESA APPRISE program began on March 24, 2010.
June 2011 | More conservative dosing guidelines for ESA use in treating anemia in patients CKD added to black box warning. | In controlled trials with CKD patients, patients experienced greater risks for death, serious adverse cardiovascular reactions, and stroke when administered ESAs to target a hemoglobin level of greater than 11 g/dL. Thus, the recommended hemoglobin level for starting ESA treatment is less than 10 g/dL.

Due to the limitations of pooled analyses from summary measures in published papers, and the inconclusive results regarding the overall effect of ESAs on survival, the Cochrane Hematologic Malignancies Group undertook an analysis of individual patient data (IPD) with BCBSA TEC Staff participating as members of the IPD Steering Committee. The initial IPD publication48 and concurrent Cochrane Review,49 found a significant increase in mortality during active treatment and poorer overall survival with ESAs in all cancer patients (regardless of cancer treatment status). The effect was not statistically significant for patients undergoing chemotherapy, but was consistent with an adverse effect. This and other meta-analyses are reviewed in detail later in this report.

## Current Guidelines for ESA Use in Cancer Patients

Table 2 summarizes important points of the FDA-approved label information, which is similar for all approved ESAs,36,52,53 and parallel information from joint guidelines for ESA use prepared by the American Society of Clinical Oncology (ASCO) and the American Society of Hematology (ASH),54,55 and from the National Comprehensive Cancer Network (NCCN) Guidelines for Cancer and Chemotherapy-Induced Anemia.56

Table 2 ESA prescribing information and guidelines relevant to ESA use in cancer patients

Topic | FDA-Approved Full Prescribing Information (similar for all approved ESAs)36,52,53 | American Society of Clinical Oncology/American Society of Hematology Clinical Practice Guideline Update54,55 | NCCN Guidelines, Cancer and Chemotherapy-Induced Anemia (V 2.2012)56
ESAs are indicated for: | The treatment of anemia due to the effect of concomitantly administered myelosuppressive chemotherapy | ESAs are a recommended treatment option for patients with chemotherapy-associated anemia; red blood cell transfusion may also be an option. ESAs are also a treatment option for patients with lower risk myelodysplastic syndrome (MDS) who are not undergoing concurrent chemotherapy. “Although the FDA label now limits the indication for ESA use to patients receiving chemotherapy for palliative intent . . . determining the treatment intent requires clinical judgment of an individual patient’s circumstances.” | Patients undergoing palliative treatment or myelosuppressive chemotherapy without curative intent may be treated with ESAs using FDA-approved indications/dosing/dosing adjustments OR may be treated with red blood cell transfusions per provided guidelines. Patients with anemia due to myelosuppressive chemotherapy should be assessed for risk of adverse events due to anemia, and need for initial transfusion.
ESAs are NOT indicated for: | Use in patients receiving hormonal agents, therapeutic biologic products, or radiotherapy unless receiving concomitant myelosuppressive chemotherapy; Use in patients receiving myelosuppressive therapy when the anticipated outcome is cure due to the absence of studies that adequately characterize the impact of ESAs on progression-free and overall survival; The treatment of anemia in cancer patients due to other reasons. As a substitute for RBC transfusion for immediate correction of anemia. | Clinicians should consider other correctable causes of anemia before considering ESA therapy. Recommends against using ESAs to treat anemia associated with malignancy in patients (excepting those with lower risk MDS) who are not receiving concurrent myelosuppressive chemotherapy. | ESA treatment is not recommended when patients are treated with myelosuppressive chemotherapy with curative intent.
ESA treatment symptom outcomes | ESA use has not been demonstrated in controlled clinical trials to improve quality of life, fatigue, or patient well-being. | Evidence does not conclusively show that ESA use leads to improved quality of life as can be perceived and valued by patients; recommends that the goal of ESA use should be to avoid transfusions. | Not discussed.
Risk evaluation and mitigation strategy (REMS) | Prescribers and hospitals must enroll in and comply with the ESA APPRISE (Assisting Providers and cancer Patients with Risk Information for the Safe Use of ESAs) Oncology Program, part of a REMS, to prescribe and/or dispense ESAs to patients with cancer. | Notes requirement | Notes requirement
Hb levels for ESA initiation | ESA therapy should not be initiated at Hb levels ≥10 g/dL. | Recommended when Hb level has decreased to <10 g/dL. Whether or not to initiate treatment when Hb is between 10 and 12 g/dL should be determined by clinical judgment, consideration of ESA risks and benefits (transfusion avoidance) and patient preferences. Transfusion is also an option. | If Hb is ≤11 g/dL or >2 g/dL below baseline, an evaluation for possible causes of anemia is suggested. If a cause is not identified, then anemia due to myelosuppressive chemotherapy is considered. When anemia symptoms, risk, or co-morbidities indicate, ESAs are a treatment option (along with RBC transfusion), per FDA-approved indications, unless treatment intent is curative.
Span of ESA treatment | ESA therapy should be discontinued following the completion of a chemotherapy course. | Recommends discontinuing ESA treatment when chemotherapy concludes, per FDA guidelines. | Physicians are advised not to administer ESAs outside the treatment period of cancer-related chemotherapy.
ESA dosing modifications | Starting ESA dose should be reduced by 25% when Hb reaches a level needed to avoid transfusion or increases >1 g/dL in any 2-week period. ESA dose should be withheld if Hb exceeds a level needed to avoid transfusion. (Restart at 25% below the previous dose when the Hb approaches a level where transfusions may be required.) Starting ESA dose may be increased (per specific product label) if response after 4 weeks Hb increases by less than 1 g/dL and remains below 10 g/dL. ESA should be discontinued if after 8 weeks of therapy if there is no response as measured by Hb levels or if transfusions are still required. | Recommends ESA starting doses and dose adjustments follow FDA guidelines, noting that alternative doses and schedules have not improved medical outcomes. Refers to product label directing clinicians to use the lowest possible ESA dose (i.e., minimize ESA exposure) to reach the lowest hemoglobin level sufficient to avoid RBC transfusions. | Dosing and titration directions for epoetin-alfa and darbepoetin-alfa are reproduced from the FDA-approved labels.
Hb target | None given (“level needed to avoid transfusion”) | Hb can be raised to the lowest hemoglobin level needed to avoid RBC transfusions. An optimal target Hb cannot be determined from the available evidence. | No Hb target is mentioned; notes that the risks of shortened survival and tumor progression have not been excluded when ESAs are dosed to a target Hb <12 g/dL.
Iron | Prior to and during ESA therapy, should be evaluated. Virtually all patients will eventually require supplemental iron. | Iron studies at baseline and periodically during treatment may be valuable to minimize the need for ESA treatment, maximize improvement of symptoms, or determine the reason for failure to respond. | Iron studies and supplementation of functional iron deficiency are recommended for patients treated with ESAs.
Survival | The black box warning states that ESAs shortened overall survival and/or increased the risk of tumor progression or recurrence in clinical studies of patients with breast, non-small cell lung, head and neck, lymphoid, and cervical cancers. | Evidence on survival outcomes is reviewed and discussed. The guideline recommends the use of clinical judgment in assessing risks vs. benefits of ESA use for individual patients. | Decreased survival is listed as a risk of ESA use in the cancer setting. Evidence is briefly discussed and cited; a link to further information on the FDA website is provided.
Thromboembolic risk | Using ESAs to target a hemoglobin level of greater than 11 g/dL increases the risk of serious adverse cardiovascular reactions and has not been shown to provide additional benefit. | Caution is urged in the use of these agents with patients judged to be at high risk for thromboembolic events, and regarding ESA use together with therapies that increase risk of thromboembolic events. | Patients with previous risk factors for thrombosis may be at higher risk when administered ESAs and should undergo risk assessment; the risk of ESA-associated thrombosis is independent of Hb levels.
Response to treatment | If the patient fails to respond or to maintain a response to doses within the recommended dosing range after 8 weeks of therapy, ESA treatment should be discontinued and other etiologies of anemia should be considered and evaluated. | If a patient does not respond to ESAs after 6 to 8 weeks, despite a dose increase, ESA therapy should be discontinued and the clinician should investigate possible underlying tumor progression, iron deficiency, or other causes of the anemia. | ESA therapy should be discontinued if a patient shows no response despite iron supplementation after 8–9 weeks of treatment.

ESA = erythropoietic-stimulating agent; FDA = U.S. Food and Drug Administration; Hb = hemoglobin; MDS = myelodysplastic syndrome; NCCN = National Comprehensive Cancer Network; RBC = red blood cell

## KQs and Rationale for Update

The Southern California EPC reviewed a sample of literature published through 2008 and obtained four expert opinions regarding the need to update conclusions for each KQ57 included in the 2006 CER.1 The consistency and strength of the evidence and expert opinion supporting recommendations to update specific key questions were evaluated by the EPC together with more recent evidence. Based on that appraisal, the three KQs listed below were judged relevant and are the questions addressed in this CER and illustrated in the analytic framework (Figure 1).

Figure 1 Analytic framework for effectiveness of epoetin and darbepoetin for managing anemia in patients undergoing cancer treatment—update

ESAs = erythropoietic-stimulating agents; Hct = hematocrit; KQ = Key Question; QoL = quality of life

Figure 1 is an analytical framework for the comparative effectiveness of epoetin and darbepoetin for managing anemia in patients undergoing cancer treatment addressing key questions 1, 2, and 3. Key question 1 addresses the benefits and harms of Erythropoietic Stimulating Agents (ESA) and transfusion on intermediate outcomes (increasing hgb, hgb response, tumor response and decreased transfusions) and ultimately on final health outcomes (mortality/survival, thromboembolic events and QoL). Key question 2 addresses the effect of thresholds for initiatiting treamment on ESAs and Key question 3 addresses the effect of criteria for stopping and duration of treatment on ESAs.

### KQ1 What are the comparative benefits and harms of erythropoiesis stimulating agent (ESA) strategies and non-ESA strategies to manage anemia in patients undergoing chemotherapy or radiation for malignancy (excluding myelodysplastic syndrome and acute leukemia)?

Outcomes of interest include overall survival (on-study and longest available follow-up), progression-free survival, quality of life, hematologic responses, transfusions, tumor response to therapy, thromboembolic complications, and other adverse events. Specific comparisons to be included are:

1. Epoetin alfa or beta versus no ESA;
2. Darbepoetin versus no ESA;
3. Epoetin alfa or beta or darbepoetin versus no ESA; and
4. Epoetin alfa or beta versus darbepoetin.

### KQ2 How do alternative thresholds for initiating treatment compare as regards their effect on the benefits and harms of erythropoietic stimulants?

Evidence is limited to directly comparative data from randomized controlled trials. Outcomes of interest to include: hematologic response (change in hemoglobin or hematocrit), proportion of patients transfused, quality of life, survival (overall and progression-free), and adverse effects.

### KQ3 How do different criteria for discontinuing therapy or for optimal duration of therapy compare as regards their effect on the benefits and harms of erythropoietic stimulants?

Evidence is limited to directly comparative data from randomized controlled trials. Outcomes of interest to include: hematologic response (change in hemoglobin or hematocrit), proportion of patients transfused, quality of life, survival (overall and progression-free), and adverse effects.

A brief summary of the rationale applied to updating key questions from the 2006 CER follows.

The 2006 CER revealed safety concerns for erythropoietic stimulants. Moreover, these safety concerns could not be narrowly attributed to use of ESAs to achieve high hemoglobin (Hb) targets, but might also be associated with usual use according to the label at the time.

In 2007, the FDA issued warnings and labeling changes consistent with the safety concerns that we raised in the 2006 CER. As noted in the rationale for an updated review,57 the “CER may need updating based on new data presented to the FDA and difference in expert opinion.”

The 2006 findings on quality of life were not judged to require updating.57 The EPC agreed in substance and noted that the FDA has stated that there is insufficient evidence to support claims of improved quality of life with use of ESAs. However, it was judged important that issues surrounding quality of life be at least qualitatively addressed, and quantitatively examined for the most important and commonly ascertained outcome—fatigue. The principles of critical appraisal of use and interpretation of disease-specific quality of life instruments that were raised in the 2006 CER should continue to be accessible to users of the current Update. Moreover, these points should be tied to the Guidance for measurement of patient-reported outcomes that was issued by the FDA in 2008.

Issues raised in the 2006 CER were broader than a comparison of epoetin and darbepoetin, and were more fundamentally a question of approaches to managing anemia of cancer treatment. Thus for the current Update, the proposed KQs were modified accordingly. Most notably, KQ1 was been modified from “What are the comparative efficacy and safety of epoetin (alfa or beta) and darbepoetin?” to “What are the comparative benefits and harms of erythropoiesis-stimulating (ESA) strategies and non-ESA strategies to manage anemia in patients undergoing chemotherapy or radiation for malignancy?”

An update of KQ2 was not recommended57— “How do alternative dosing strategies affect the comparative efficacy and safety of epoetin (alfa or beta) and darbepoetin?” and the TEC EPC concurred. It is not included in the current Update KQs.

KQ 3, “How do alternative thresholds for initiating treatment or alternative criteria for discontinuing therapy or the duration of therapy affect the comparative efficacy and safety of epoetin (alfa or beta) and darbepoetin?” was judged as needing updating due to FDA changes to labeling and expert opinion.57 Accordingly, the question is included in the current Update.

Finally, an update of KQ4 was not recommended,57 “Are any patient characteristics at baseline or early hematologic changes useful to select patients or to predict responses to treatment with erythropoietin?” This recommendation was based on expert opinion that referred to patient treatment characteristics and FDA labeling. However, the BCBSA TEC EPC judged that updating this question would be of little value. The literature reviewed in the 2006 CER was related to single or multifactorial algorithmic predictive testing. None was promising, and the literature has no bearing on the FDA changes to labeling, which are closely tied to the evidence for KQ1. This question was not included in the update.

Table 3 reviews the current ESA approval status and approved starting dose.

Table 3 ESAs, approval status, and approved starting dose

ESA | Approval Status U.S. | Approval Status European Union | Approved Dose
Epoetin alfa | EPOGEN^®^ (Amgen) PROCRIT^®^ (Ortho Biotech) | Eprex^®^ (Janssen-Cilag) | Epoetin alfa preparations are formulated for IV or SC administration. The recommended adult starting dose is 150 Units/kg SC 3 times per week or 40,000 Units SC weekly. Dose may be modified depending on Hb response.
Darbepoetin alfa | Aranesp^®^ (Amgen) | Aranesp^®^ (Amgen) | Aranesp^®^ is formulated for IV or SC administration. The recommended initial adult dose is either 2.25 mcg/kg SC weekly or 500 mcg SC every 3 weeks. Dose may be modified depending on Hb response.
Epoetin beta | Not approved for use in the U.S.^*^ | NeoRecormon^®^ (Hoffmann-La Roche) | NeoRecormon^®^ is formulated for IV or SC administration. The recommended initial dose is 30,000 IU per week given as one injection per week or in divided doses 3 to 7 times per week. Dose may be modified depending on Hb response.

ESA = erythropoietic-stimulating agent; Hb = hemoglobin; IV = intravenous; IU = international unit; kg = kilogram; mcg = microgram; SC = subcutaneous

* See also Background. While not approved in the United States, effects are considered exchangeable with epoetin alfa.