# Peer Reviewers

Prior to publication of the final evidence report, the EPC sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Murat O. Arcasoy, M.D., FACP
  Associate Professor of Medicine
  Duke University School of Medicine
  Durham, NC
- M. Hassan Murad, M.D., M.P.H.
  Associate Professor
  Mayo Clinic
  Rochester, MN
- Jerry Spivak, M.D.
  Professor of Medicine and Oncology
  Director, Center for the Chronic Myeloproliferative Disorders
  The Johns Hopkins University
  Baltimore, MD