# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Guido Schwartzer, M.Sc., Ph.D., for helpful comments; Lisa Sarsany, M.A., for government project management; and Sharon Flaherty, M.A., for contracts support.