# Discussion

Previous systematic reviews have shown erythropoietic-stimulating agents to have comparable hematologic effects and comparable harms. Their results, together with the biochemical and mechanistic similarities of the different agents, argue that evidence from different ESAs is appropriately combined for synthesis. The body of evidence included here is substantial and adequate to provide sufficient certainty to address the most important questions regarding the effects of these drugs: (1) their effect on hemoglobin levels and transfusions, (2) impact on HRQoL, and (3) adverse consequences including thromboembolic events and mortality.

The collection of included trials was clinically heterogeneous. Nevertheless, there is convincing evidence that ESAs can improve hemoglobin in the setting of cancer treatment, and when successful, result in a commensurate reduction in the risk of transfusion. In slightly more than half, but not all patients, ESAs improve hemoglobin and help avoid transfusion. ESAs reduce the proportion of patients transfused by approximately 40 percent but do not eliminate it—25 percent of patients receiving ESAs in the trials reviewed here required ≥1 transfusion.

Whether, and by what magnitude, ESA use in anemia related to cancer treatment might improve quality of life has been the focus of considerable study. The evidence found through systematic search in this update, and documented in the previous report, is consistent. In the most relevant domain of fatigue, better scores on a well-validated instrument such as FACT-Fatigue accompany the higher hemoglobin levels achieved with ESA use. In contrast, patients randomized to a transfusion strategy experience on average a small decline in FACT-Fatigue score. The magnitude of mean difference in change between the two groups was less than the estimated reported minimal clinically important difference; the difference in fatigue experienced by patients, is on average, less than clinically meaningful.

The increased incidence of thromboembolic events and mortality during ESA treatment that has been noted here has also been reported by several others, and is consistent with a plausible and causal effect of these agents. The relative and absolute increases in thromboembolic events allow a high degree of certainty regarding the magnitude of effect.

The consistent increase in pooled on-study mortality accompanying ESA treatment found in systematic reviews is consistent with a causal effect. The increased relative risk estimate during the on-study period reported by Bohlius et al.,48 including all trials regardless of cancer treatment, and therefore patients with longer ESA exposure, similarly supports a causal effect. Although the magnitude of the on-study mortality risk on average is not large, the increase in risk alters the balance of benefit and harm. While there was no discernible increase in mortality with ESA use over the longest available follow-up, many trials did not include an overall survival endpoint and potential time-dependent confounding was not considered.

Much of the evidence included here was obtained under treatment protocols that used higher baseline and target hemoglobin levels than those used in current practice. While it is possible that adverse event rates might be somewhat different with lower baseline and target hemoglobin levels, we found little difference in effect when baseline hemoglobin was less than, or exceeded 10 g/dL, the currently recommended threshold for ESA initiation. This result is similar to an individual patient data meta-analysis.48 Additionally, three trials included in KQ1 enrolled patients predominantly undergoing radiotherapy. Although not an FDA-approved indication for ESA use, those results were included because the population of interest was patients undergoing treatment for cancer. Moreover, we did not find those trial results influential in these analyses.

Some outcomes and aspects of this evidence are accompanied by important uncertainty. First, whether ESAs enhance tumor progression remains unanswered in this review. The evidence surrounding tumor progression is heterogeneous and insufficient to support conclusions. Evidence examining progression-free survival is similarly varied and limited. Likely the most salient uncertainty pertains to possible subgroups at highest risk of mortality and/or thromboembolic events. We were not able to effectively address those questions with the data included in this review; nor does individual trial data address those questions. There are clues that lack of response to ESAs35 and dose escalation might be associated with mortality higher than with standard dosing in responders. This notion is also supported by data obtained in other settings. Among patients with end-stage renal disease managed with hemodialysis and ESA treatment the epoetin dose required to attain defined hematocrit values has been reported to be an independent predictor of total mortality.202 Similar results have been reported in diabetics with chronic kidney disease not on dialysis.203 However, for cancer patients, detailed patient-level data are unavailable even in individual patient data meta-analyses.

Finally, the most important concern regarding ESAs in the setting of cancer therapy is the balance of potential benefits and harms. While ESAs reduce the need for transfusions and increase the risk of thromboembolism, a detectable relative increase in mortality risk—higher with lower underlying absolute mortality risk—accompanies their use. An individual patient receiving ESAs will have, on average, better quality of life FACT-Fatigue scores, but of a magnitude less than the minimal clinically important difference. For the population of patients undergoing cancer treatment, ESAs are similarly accompanied by greater expected quality adjusted, yet fewer total life years. The expected loss of life is greater with higher underlying absolute mortality risk.

## Future Research

Given the current state of evidence, unanswered questions, and balance of benefit and harms, how should future research be considered? Given the magnitude of relative mortality increase and underlying mortality rates in this patient population, it is clear that attempts to reduce uncertainty in relative risk of mortality through clinical trials would require very large samples. The confidence and credible intervals for the estimated relative increase in mortality span a range of values—the true relative increase in risk for adults could be higher or lower than 1.17 estimated here. Still these data do establish with sufficient certainty that mortality rates increase. Questions are therefore raised regarding equipoise in pursuing some “true” relative risk in further clinical trials.

At the same time these agents will continue to be used for reasons beyond the scope of this review—for example, patient preference, availability of blood, possible emergence of infectious agents in the blood supply. It is therefore important to address whether there are patient subgroups with low risk of harm and how dosing practices influence harms. Unfortunately, these questions present complexities not addressed even in the most carefully designed trials. The fundamental complexity concerns time-varying treatment and confounding—ESA dose is typically varied depending on the hemoglobin level achieved. It is well known that traditional analytical approaches fail to correctly estimate treatment effects under these conditions.139,204 Accordingly, it is unlikely that any future meta-analysis or systematic review will be able to inform these questions.

Still, there is a compelling rationale to examine observational data (e.g., carefully conducted registries) using methods appropriate to these questions—whether there is a subgroup and dosing strategy accompanied by some lower risk. A large registry with accurate and precise information on ESA dose (amount, frequency, duration, escalation), hemoglobin (baseline, and all recorded values preferably at times specified by protocol), stage of malignancy, treatment regimen and response, and outcomes (including but not limited to thromboembolism, myocardial infarction, death including underlying and contributory causes) would provide the best opportunity to examine these questions. The Dosing and Outcomes Study of Erythropoiesis-Stimulating Therapies (DOSE) is one example.205 While deriving conclusions from appropriate analytical methods—inverse probability weighting, G-methods, and marginal structural models—requires some assumptions for inference, they are approaches most able to address unanswered questions.

Lastly, we found many registered completed trials without clearly or readily identified results. The goals of trial registration fall short when results from completed trials are difficult to identify. Investigators and trials registries must adopt effective procedures to assure timely reporting of results in registries.

In summary, a large collection of trials examining ESA use in patients undergoing cancer treatment provides evidence sufficient to conclude that hemoglobin levels are improved and transfusions avoided together with higher rates of thromboembolic events and mortality. Whether there are subgroups at higher and lower risk of adverse events and mortality is unclear. Future research to address the unanswered questions should be limited to examination of observational data collected during the course of usual patient care.