# Other Tumor Outcomes

Appendix Table J1 Other tumor outcomes—epoetin or darbepoetin

Author | Drug | Outcome | ESA Events/sample size | Control Events/sample size | Relative Risk [underlined: Hazard Ratio] (95% CI)
Blohmer 2011 1 | Epoetin | relapse-free survival | 23/127 | 35/129 | 0.66 (0.39–1.12), p=0.06
Engert 2009 2 | Epoetin | freedom from treatment failure | n/644 | n/641 | [underlined: 0.9] (0.6–1.2)
Goss 2005 3 | Epoetin | median time to progression | 15.8m | 16.5m | NR
Goss 2005 3 | Epoetin | time to progression | NR | NR | NR
Gupta 2009 4 | Epoetin | 2-year DFS | 36/58 | 34/57 | 0.96 (0.72, 1.29)^a^
Henke 2003 5 Stratum I | Epoetin | locoregional tumor progression or death | 47/102 | 41/94 | 0.95 (0.69, 1.29)^a^
Henke 2003 Stratum II | Epoetin | locoregional tumor progression or death | 30/39 | 16/38 | 0.55 (0.36, 0.83)^a^
Henke 2003 Stratum III | Epoetin | locoregional tumor progression or death | 39/39 | 35/39 | 0.90 (0.81, 1.00)^a^
Henke 2003 | Epoetin | locoregional tumor progression | 65/180 | 49/171 | 1.69 (1.16, 2.47)
Henke 2003 | Epoetin | locoregional PFS | 116/180 | 92/171 | 1.62 (1.22, 2.14)
Hoskin 2009 6 | Epoetin | median duration local DFS | 85/151, 31.5 mo | 84/149, 35.4 mo | 1.04 (0.77, 1.41)
Hoskin 2009 | Epoetin | median DFS | 87/151, 30.1 mo | 85/149, 35.4 mo | 1.06 (0.79, 1.43)
Hoskin 2009 | Epoetin | time to local disease recurrence | NR | NR | 0.94 (0.64, 1.38)
Machtay 2007 7 | Epoetin | locoregional failure | 31/72 | 27/69 | 0.91 (0.61, 1.35)^a^
Machtay 2007 | Epoetin | 2-year locoregional failure | 29/72 | 25/69 | 0.90 (0.59, 1.37)^a^
Machtay 2007 | Epoetin | 3-year locoregional failure | 32/72 | 25/69 | 1.20 (0.72, 2.02)
Machtay 2007 | Epoetin | 2-year locoregional PFS | 36/72 | 40/69 | 1.16 (0.85, 1.57)^a^
Machtay 2007 | Epoetin | 3-year locoregional PFS | 33/72 | 36/69 | 1.19 (0.76, 1.86)
Moebus 2007 8 | Epoetin | 56m DFS | 70.70% | 72% | NR
Moebus 2007 | Epoetin | 62m DFS | 240/333 | 231/325 | 0.99 (0.90, 1.09)^a^
Thomas 2008 9 | Epoetin | 3-year PFS | 23/57 | 18/52 | 0.86 (0.53, 1.40)^a^
Thomas 2008 | Epoetin | 3-year PFS | 59% | 62% | 1.06 (0.58, 1.91)
Thomas 2008 | Epoetin | recurrence (local+distant) | 19/57 | 13/52 | 0.75 (0.41, 1.36) a
Wagner 2004 10 | Epoetin | PFS | 38.9%±11.5% | 25.0%±8.8% | NR
Overgaard 2009 11 | Darbepoetin | 5-year locoregional control | 135/255 | 171/259 | 1.51 (1.05, 2.17)
Overgaard 2009 | Darbepoetin | 5-year DFS | 84/255 | 119/259 | 1.52 (1.07, 2.16)
Overgaard 2009 | Darbepoetin | locoregional tumor control | 143/255 | 179/260 | 0.81 (0.71, 0.93)
Overgaard 2009 | Darbepoetin | locoregional PFS | 130/255 | 174/260 | 0.52 (0.36, 0.74)
Untch 2011 12 | Darbepoetin | 3-year DFS (med follow-up 43.5 mos) | 106/345 | 90/369 | 1.31 (0.99, 1.74)

a Calculated from events abstracted

Author | Comments
Blohmer 2004 13 | KM analysis p=0.0831, trend favoring ESA group. Info from Amgen ODAC 2008. total n for each group calculated based on reported 17% and 25% in Amgen ODAC 2008, total n =250
Blohmer 2004 | abstract 2004
Engert 2009 2 | slide presentation
Goss 2005 3 | Amgen ODAC 2008
Goss 2005 | abstract, “no significant difference”
Gupta 2009 4 | numbers calculated from reported 62% and 60% respectively in full-text
Henke 2003 5 Stratum I | Kaplan Meier estimate, median locoregional progression-free survival in days: EPO: 1,049d, control 1,152d, p=0.9
Henke 2003 Stratum II | Kaplan Meier estimate, median locoregional progression-free survival in days: EPO 377d, control 1,791d p=0.001
Henke 2003 Stratum III | Kaplan Meier estimate, median locoregional progression-free survival in days: EPO 141d, control 207d, p=0.006
Henke 2003 | full text publication, ITT population, adjusted for stratum and American Joint Committee on Cancer stage. 115 and 122 patients were censored. Kaplan Meier estimate, median EPO 280 days vs. control not reached, p=0.09). Tumor progression was assumed when tumor size increased more than 25%.
Henke 2003 | full text and FDA 2007. ITT population, adjusted for stratum and American Joint Committee on Cancer Stage, 79 and 64 pts respectively were censored. Kaplan Meier estimate, median locoregional PFS in days, EPO 406d, control 745 d, p=0.04
Hoskin 2009 6 | full-text publication and Amgen ODAC 2008
Hoskin 2009 | full-text publication
Hoskin 2009 | full-text publication
Machtay 2007 7 | numbers reported in figure 1, full-text publication
Machtay 2007 | numbers calculated from reported 40% and 36% in full-text publication
Machtay 2007 | numbers calculated from reported 44% and 36% in full-text publication and Amgen ODAC 2008
Machtay 2007 | numbers calculated from reported 50% and 58% in full-text publication
Machtay 2007 | numbers calculated from reported 46.5% and 51.5% in full-text publication and Amgen ODAC 2008
Moebus 2007 8 | Amgen ODAC 2008. n per group not reported. Total n=643
Moebus 2007 | numbers calculated from reported 72% and 71% respectively in abstract publication
Thomas 2008 9 | full text publication, figure 1
Thomas 2008 | KM estimates from Amgen ODAC 2008. N per group not reported. Total n=114
Thomas 2008 | full-text publication
Wagner 2004 10 | probability of PFS at five years
Overgaard 2009 11 | numbers calculated from reported 53% and 66% in slide presentation ASCO 2009
Overgaard 2009 | numbers calculated from reported 33% and 46% in ASCO slide presentation
Overgaard 2009 | from Cochrane review 2009 (Lambin et al.)
Overgaard 2009 | from Cochrane review 2009
Untch 2008 14 | numbers calculated from reported 73% and 79% in Amgen ODAC 2008. Interim data

## Appendix J References

1 Blohmer JU, Paepke S, Sehouli J, et al. Randomized phase III trial of sequential adjuvant chemoradiotherapy with or without erythropoietin Alfa in patients with high-risk cervical cancer: results of the NOGGO-AGO intergroup study. J Clin Oncol. Oct. 1. 2011;29(28):3791-7. [pmid: 21860000].
2 Engert A, Borchmann P, Fuchs M. A prospectively randomized placebo-controlled trial of epoetin-in patients with advanced-stage Hodgkin lymphoma: Final analysis of the GHSG HD15-EPO trial. Haematologica. 2009;94.
3 Goss G, Feld R, BezJak A, et al. Impact of maintaining Hb with epoetin alfa on time to progression (TTP), overall survival (OS), quality of life (QOL) and transfusion reduction in limited disease SCLC patients. Lung Cancer. 2005;49(S53):O-154.
4 Gupta S, Singh PK, Bisth SS, et al. Role of recombinant human erythropoietin in patients of advanced cervical cancer treated “by chemoradiotherapy”. Cancer Biol Ther. Jan. 2009;8(1):13-7. [pmid: 18981719].
5 Henke M, Laszig R, Rube C, et al. Erythropoietin to treat head and neck cancer patients with anaemia undergoing radiotherapy: randomised, double-blind, placebo-controlled trial. Lancet. Oct. 18. 2003;362(9392):1255-60. [pmid: 14575968].
6 Hoskin PJ, Robinson M, Slevin N, et al. Effect of epoetin alfa on survival and cancer treatment-related anemia and fatigue in patients receiving radical radiotherapy with curative intent for head and neck cancer. J Clin Oncol. Dec. 1. 2009;27(34):5751-6. [pmid: 19884550].
7 Machtay M, Pajak TF, Suntharalingam M, et al. Radiotherapy with or without erythropoietin for anemic patients with head and neck cancer: a randomized trial of the Radiation Therapy Oncology Group (RTOG 99-03). Int J Radiat Oncol Biol Phys. Nov. 15. 2007;69(4):1008-17. [pmid: 17716826].
8 Moebus V, Lueck HJ, Thomssen C, et al. The impact of epoetin-alpha on anemia, red blood cell (RBC) transfusions, and survival in breast cancer patients (pts) treated with dose-dense sequential chemotherapy: Mature results of an AGO phase III study (ETC trial). J Clin Oncol. 2007;25:569.
9 Thomas G, Ali S, Hoebers FJ, et al. Phase III trial to evaluate the efficacy of maintaining hemoglobin levels above 12.0 g/dL with erythropoietin vs above 10.0 g/dL without erythropoietin in anemic patients receiving concurrent radiation and cisplatin for cervical cancer. Gynecol Oncol. Feb. 2008;108(2):317-25. [pmid: 18037478].
10 Wagner LM, Billups CA, Furman WL, et al. Combined use of erythropoietin and granulocyte colony-stimulating factor does not decrease blood transfusion requirements during induction therapy for high-risk neuroblastoma: a randomized controlled trial. J Clin Oncol. May. 15. 2004;22(10):1886-93. [pmid: 15143081].
11 Overgaard J Sr, Hoff CM, Hansen HS, et al. Randomized study of darbepoetin alfa as modifier of radiotherapy in patients with primary squamous cell carcinoma of the head and neck (HNSCC): Final outcome of the DAHANCA 10 trial. J Clin Oncol. 2009;27(15S):6007.
12 Untch M, von Minckwitz G, Konecny GE, et al. PREPARE trial: a randomized phase III trial comparing preoperative, dose-dense, dose-intensified chemotherapy with epirubicin, paclitaxel, and CMF versus a standard-dosed epirubicin-cyclophosphamide followed by paclitaxel with or without darbepoetin alfa in primary breast cancer--outcome on prognosis. Ann Oncol. Sep. 2011;22(9):1999-2006. [pmid: 21382868].
13 Blohmer JU, Wuerschmidt J, Petry K, et al. Results with sequential adjuvant chemo-radiotherapy with vs. without epoetin alfa for patients with high-risk cervical cancer: results of a prospective, randomized, open and controlled AGO and NOGGO-intergroup study. Ann Oncol. 2004;15(Suppl 3):128.
14 Untch M, Fasching P, Bauerfeind I, et al. PREPARE trial. A randomized phase III trial comparing preoperative, dose-dense, dose-intensified chemotherapy with epirubicin, paclitaxel and CMF with a standard dosed epirubicin/cyclophosphamide followed by paclitaxel +/− darbepoetin alfa in primary breast cancer: A preplanned interim analysis of efficacy at surgery. [abstract no. 517]. J Clin Oncol. 2008;26(15S Part I):10.