# FACT-Fatigue Subscale

Appendix Table I1 FACT-Fatigue subscale, trials comparing ESA to placebo or no treatment and reporting sufficient data for meta-analysis

Study (ESA) | 1°/2° outcome | N, ESA (% not evaluated) | N, Ctl (% not evaluated) | Blinding to treatment/Patient blinded to Hb | ESA duration/Trial follow-up for QoL (weeks) | Baseline Hb (g/dL) | Hb Target (g/dL) | ESA Baseline FACT-F Mean (SD) | Ctl Baseline FACT-F Mean (SD) | Adjusted for baseline QoL/Hb in reported analysis | ESA Mean Change (SD) | Ctl Mean Change (SD) | Mean Diff (95% CI)
Boogaerts 2003 84 (Epo) | 1 | 133 (22) | 129 (16) | N/Y | 12/12 | <10 | 12–14 | 27 (12) | 31 (11) | N/N | 5.47 (14.47) | 0.41 (8.47) | 5.06 (1.86 to 8.26)
Chang 2005 87 (Epo) | 1 | 175 (4) | 175 (3) | N/Y | 16/12 | 10–12 | 14 | NR | NR | Y/N | 1.85 (10.52) | −3.55 (11.14) | 5.1 (2.79 to 7.41)
Christodoulou 2009 88 (Epo) | 1 | 167 (54) | 170 (55) | N/NR | NR/26 | 10–12 | >12 | 33 (12) non-plat; 32 (11) plat | 32 (12) non-plat; 27(13) plat | Y/Y (>or ≤10.5) | 3.87 (11.99) | 0.71 (12.43) | 3.16 (−0.72 to 7.04)
Hedenus 2003 123 (Darb) | 2 | 176 (14) | 173 (13) | Y/Y | 12/12 | ≤10 | 13–14 F | NR | NR | Stratified analysis/N | 2.68 (8.88) | 0.8 (9.71) | 1.88 (−0.22 to 3.98)
Hoskin 2009 2 (Epo) | 2 | 151 (0) | 149 (0) | N/NR | 12/2 | >12 | >12 | NR | NR | N/N | −2.6 (10.67) | −2.6 (12.45) | 0 (−2.63 to 2.63)
Iconomou 2003 103 (Epo) | 1 | 61 (7) | 61 (10) | N/NR | 12/12 | 10–12 | NR | 22 (12) | 23 (11) | N/N | 4.6 (12.5) | −1 (12.8) | 5.6 (0.91 to 10.29)
Kotasek 2003 126 (Darb) | 2 | 208 (5) | 51 (0) | Y/NR | 12/10 | <10 | 13–14 F | 27 (12) | 27 (12) | N/N | 3.4 (12.6) | 2.3 (11.6) | 1.1 (−2.58 to 4.78)
Littlewood 2001 104 (Epo) | 2 | 251 (23) | 124 (29) | Y/NR | 28/4 to 24 | <10 | <15 | NR | NR | N/N | 3 (13.5) | −2.2 (12.5) | 5.2 (2.01 to 8.39)
Osterborg 2002 110 (Epo) | 2 | 170 (38) | 173 (40) | Y/Y | 16/16 | <10 | 13–14 | 29 (11) | 29 (11) | Y/N | 5.2 (12.2) | 3 (12.1) | 2.2 (−0.74 to 5.14)
Pirker 2008 127 (Darb) | 2 | 299 (18) | 301 (21) | Y/NR | 19/19 | 10–12 | 13–14 | 31 (11) | 31 (11) | Y/N | 1.5 (13.15) | 0.7 (13.3) | 0.8 (−1.56 to 3.16)
Savonije 2005 116 (Epo) | 2 | 211 (26) | 104 (38) | N/NR | 1414 | 10–12 | 13–14 | NR | NR | N/N | 3.48 (12.67) | −1.67 (11.61) | 5.15 (1.70 to 8.60)
Tsuboi 2009 120 (Epo) | 2 | 63 (3) | 59 (5) | Y/NR | 8/8 | 10–12 | <14 | 36 (10) | 34 (10) | Stratified analysis/Hb change influenced QoL change | −0.5 (9.4) | −3.6 (9) | 3.1 (−0.27 to 6.47)
Vansteenkiste 2002 11 (Darb) | 2 | 156 (19) | 158 (19) | Y/Y | 12/52 | 10–12 | 13–14 F | NR | NR | N/N | 0.8 (10) | −0.6 (10.7) | 1.4 (−0.89 to 3.69)
Witzig 2005 122 (Epo) | 1 | 174 (13) | 170 (13) | Y/Y | 16/16 | <=10 | 13–15 | 26 (11) | 28 (12) | N/N | 1.56 (12.07) | 0.31 (14.48) | 1.25 (−1.77 to 4.27)
Pooled | | | | | | | | | | | 2.11 (3.90 to 8.07) | −0.57 (−6.47 to 5.28) | 2.74 (1.69 to 3.74)