# PFS and Other Outcomes

Appendix Table H1 Summary of trials reporting results related to tumor progression

| ESA | Progression-Free Survival | Disease-Free survival | Time to Progression | Proportion of Patients with Progressive Disease
Aapro 2008 | epo | Metastatic breast cancer; No definition of progression; HR=1.07; 95% CI, 0.89 to 1.30; P=0.448 at 18 mo. (treatment = 24 wk)
Antonadou 2001 | epo | | Pelvic malignancies receiving RT; No definition of DFS; 4-yr DFS 85.3% (epo) vs. 67.2%, p=0.0008
Blohmer 2011 | epo | | | | At median follow-up of 50.3 mos, proportion with recurrence (18.1% epo vs 27.1%)
Engert 2010 | epo | | | | Hodgkin’s Lymphoma; No definition of progression; Proportion with progression or relapse (8.3% epo vs. 7.8%), proportion with progressive disease (2.9% epo vs. 1.9%)
EPO-INT-1 | epo | | | Ovarian cancer; no definition of progression; 16% (epo) vs. 15%
Fujisaka 2011 | epo | | | | Tumor progression during treatment (27% epo vs 26.1%)
Goss 2005, EPO-CAN-15 | epo | | | Limited disease SCLC on chemoRx; no definition of progression; TTP, p=0.83
Grote 2005, N03-004 | epo | | | | SCLC on chemo; 14.7% (epo) vs. 12.2% ; PD defined as (1) >25% increase in the size of at least one measurable malignant lesion or >25% increase in the estimated size of any assessable but nonmeasurable lesion; or (2) >25% increase in the estimated extent of assessable disease or >25% increase in the estimated extent of unmeasurable disease; or (3) development of a new malignant lesion.
Henke 2003 | epo | [underlined: Locoregional] PFS; Tumour progression was assumed when tumour size increased by >25%; RR=1·69 (1·16–2·47, p=0·007)
Hoskin 2009, EPO-GBR-7 | epo | | H&N Ca on radiotx; [underlined: Local] tumor recurrence was assessed clinically, and radiologically; HR=1.04; 95% CI, 0.77 to 1.41
Leyland-Jones 2005 | epo | | | | Metastatic breast cancer on chemo; tumor response assessed by WHO criteria; 27% (epo) vs 22%
Machtay 2007 | epo | H&N Ca on radiotx ± chemo; Local–regional failure was defined as the failure to obtain a complete response after definitive radiotherapy, or the reappearance of local and/or regional head-and-neck cancer after a complete response; biopsy confirmation was not required if convincing clinical/radiographic evidence of locoregional persistence/recurrence in treating oncologist opinion [underlined: Locoregional] PFS, multi-variate HR 1.26 (95% CI, 0.80–1.99)
Moebus 2007 | epo | | High risk breast cancer on chemo; no definition of DFS; 5-year DFS 72% (epo) vs. 71% (p=0.86)
Osterborg 2005 | epo | | | | B-CLL, NHL, MM; No definition of disease progression; 18% (epo) vs 23%
Ray-Coquard 2009 | epo | | | solid or hematologic tumors on chemo; no definition of disease progression; median PFS (epo) 5.0 months (95% CI: 4.3–6.6) vs 4.4 months (95% CI: 3.8–5.2)
Thomas 2008, GOG-0191 | epo | Cervical cancer on chemoradiotx; Progression was defined as > 50% increase in the cross-product of the existing primary tumor relative to the smallest cross-product from all previous exams; 58% (epo) vs. 65% at 3 years
Wilkinson 2006 | epo | | | | ovarian cancer on chemo; no definition of disease progression; 11% (epo) vs 2%, P=0.425)
Witzig 2005 | epo | | | | incurable cancer on chemo; no definition of disease progression; 33% (epo) vs 29% (p=0.86)
Overgaard 2009 | darb | H&N on chemo; no definition of disease progression; RR: 1.47 (1.14–1.94) | RR: 1.32 (1.04–1.68)
Pirker 2008 | darb | Extensive stage SCLC on chemo; disease progression defined by modified Response Evaluation Criteria in Solid Tumors; HR=1.02, (0.86 to 1.21)
Untch 2011 | darb | | 3-year DFS 74.3% (darb) vs 80%; HR 1.31 (p=0.061) | | breast cancer on chemo; no definition of disease progression; 27% (darb) vs 21%
Vansteenkiste 2002 | darb | | | Lung cancer on chemo; no definition of disease progression; median duration 22 weeks (95% CI 18 to 31 weeks, darb) vs 20 weeks (95% CI 17 to 23)