# ESA Trials Included in Published Meta-Analyses Evaluated in This Review

Appendix Table G1 ESA trials included in published meta-analyses evaluated in this review

| Publication status | ESA | Glaspy 2010 | Bohlius 2009 | Bennett 2008 | Ludwig 2009
Number of included studies | | | 60 | 53 | 51 | 7
Sample size exclusions? | | | None | Yes^a^ | None | None
Individual patient data meta-analysis? | | | No | Yes | No | Yes
Trials included in meta-analysis:
Aapro 2008 | full | epo-b | • | •
Abels 1993 | full | epo-a | • | • | •
Bamias 2003 | full | epo-a | • | | •
Blohmer 2003/4 | abs | epo-a | • | | •
Boogaerts 2003 (Coiffier 2001) | full | epo-b | • | • | •
Cascinu 1994 | full | epo-a | •
Case 1993 | full | epo-a | • | • | •
Cazzola 1995 | full | epo-b | • | • | •
Chang 2005 (EPO-CAN-17) | full | epo-a | • | • | •
Charu 2007 | full | darb | • | • | •
Dammacco 2001 | full | epo-a | • | • | •
Debus 2007 | abs | epo-a | • | • | •
Del Mastro 1997 | full | epo-? | • | | •
Dunphy 1999 | full | epo-? | • | | •
Engert 2007 | unpub | epo-a | •
EPO-CAN-203 | unpub | epo-a | •
EPO-CAN-303 | unpub | epo-a | •
EPO-GER-20 | unpub | epo-a | | •
OBE/EPO-INT-03 | unpub | epo-a | | •
Gordon 2006 | abs | darb | • | • | •
Goss 2005 (EPO-CAN-15) | abs | epo-a | • | • | •
Grote 2005 (N93-004) | full | epo-a | • | • | •
Hedenus 2002 | full | darb | • | | | •
Hedenus 2003 | full | darb | • | • | • | •
Henke 2003 | full | epo-b | • | • | •
Henry 1995 | full | epo-a | • | • | •
Huddart 2002 | abs | epo-a | | •
Kotasek 2002 | abs | darb | | • | | •
Kotasek 2003 | full | darb | • | • | • | •
Kurz 1997 | full | epo-a | •
Leyland-Jones 2005 | full | epo-a | • | • | •
Littlewood 2001 | full | epo-a | • | • | •
Machtay 2007 | full | epo-a | • | • | •
Milroy 2003 | abs | epo-a | • | •
Moebus 2007 | abs | epo-a | • | • | •
Mystakidou 2005 | full | epo-a | • | | •
Oberhoff 1998 | full | epo-b | • | • | •
ODAC 2004, INT-1 | unpub | epo-a | • | • | •
ODAC 2004, INT-3 | unpub | epo-a | • | • | •
ODAC 2004, EPO-GBR-07 (Hoskin 2004) | unpub | epo-a | • | • | •
ODAC 2004, P-174 (Pangalis 1995) | unpub | epoa | • | • | •
O'Shaughnessy 2005 | full | epo-a | • | • | •
Osterborg 1996 | full | epo-b | • | • | •
Osterborg 2002/2005 | full | epo-b | • | • | •
Overgaard 2007 (ended early) | abs | darb | • | | •
Pirker 2008 (Amgen DA 145) | full | darb | • | • | • | •
Prozanto 2002 | abs | epo-a | • | •
Quirt 1996 | abs | epo-a | | •
Ray-Coquard 2006 | abs | epo-a | | •
Razzouk 2004/2006 (all patients) | abs/full | epo-a | • | | •
Razzouk 2006 (NHL/solid tumors only) | full | epo-a | | •
Rose 1994 | abs | epo-a | • | • | •
Savonije 2005 | full | epo-a | • | • | •
Smith 2003 | full | darb | • | | •
Smith 2008 (Glaspy 2007) | full | darb | • | • | •
Strauss 2008 | full | epo-b | • | • | •
Taylor 2005 | abs | darb | • | • | • | •
Ten Bokkel Huinink 1998 | full | epo-b | • | • | •
Thatcher 1999 | full | epo-a | • | • | •
Thomas 2002 | abs | epo-a | | •
Thomas 2008 (GOG-191) | full | epo-a | • | • | •
Throuvalas 2000 | abs | epo-? | • | | •
Untch 2008 (PREPARE) | abs | darb | • | • | •
Vadhan-Raj 2004 | abs | epo-a | • | • | •
Vansteenkiste 2002 | full | darb | • | • | • | •
Wilkinson 2006 | full | epo-a | • | • | •
Witzig 2005 | full | epo-a | • | • | •
Wright 2007 (EPO-CAN-20) | full | epo-a | • | • | •

a Excluded RCTs with <100 patients or analyses based on <50 patients