# Changes in Trials Included in Current and 2006 Reviews

Appendix Table F1 Changes in trials included in current and 2006 reviews

| | Trials | Hematologic Response Study
Darbepoetin vs. Epoetin | Excluded | 2 | Glaspy 2003, Alexopoulos 2004
Darbepoetin vs. Epoetin | Included unchanged | 2 | Glaspy 2002, Waltzman 2005
Darbepoetin vs. Epoetin | Data updated | 0
Darbepoetin vs. Epoetin | New data
Darbepoetin vs. Epoetin | Total Studies Included | 0
Epoetin vs. Control | Excluded | 2 | Cazzola 1995, Osterborg 1996
Epoetin vs. Control | Included unchanged | 12 | Bamias 2003, Boogaerts 2003, Case 1993, Chang 2005, Dammacco 2001, Henry 1995, Iconomou 2003, Littlewood 2001, Oberhoff 1998, Osterborg 2002, Rose 1994, Witzig 2005
Epoetin vs. Control | Data updated | 1
Epoetin vs. Control | New data | 3 | Razzouk 2006, Aapro 2008, ML17620
Epoetin vs. Control | Total Studies Included | 16
Darbepoetin vs. Control | Excluded | 1 | Hedenus 2002
Darbepoetin vs. Control | Included unchanged | 2 | Hedenus 2003, Kotasek 2003
Darbepoetin vs. Control | Data updated | 0
Darbepoetin vs. Control | New data | 0
Darbepoetin vs. Control | Total Studies Included | 2
| | Trials | Transfusion Rates Study
Darbepoetin vs. Epoetin | Excluded | 1 | Alexopoulos 2004
Darbepoetin vs. Epoetin | Included unchanged | 2 | Glaspy 2002, Schwartzberg 2004
Darbepoetin vs. Epoetin | Data updated | 2 | Glaspy 2005 → Glaspy 2006, Waltzman 2005 → Waltzman 2005
Darbepoetin vs. Epoetin | New data | 1 | Kotsori 2006
Darbepoetin vs. Epoetin | Total Studies Included | 5
Epoetin vs. Control | Excluded | 18 | Aravantinos 2003, Carabantes 1999, Cascinu 1994, Cazzola 1995, Del Mastro 1997, Dunphy 1999, Henze 2002, Huddart 2002, Kunikane 2001, Kurz 1997, Osterborg 1996, Quirt 1996, Ten Bokkel Huinink 1998, Thatcher 1999, Throuvalas 2000, Vadhan-Raj 2004, Welch 1995, Wurnig 1996
Epoetin vs. Control | Included unchanged | 13 | Bamias 2003, Boogaerts 2003, Case 1993, Chang 2005, Dammacco 2001, Henry 1995, Iconomou 2003, Littlewood 2001, Oberhoff 1998, Osterborg 2002, Thomas 2002, Rose 1994, Witzig 2005
Epoetin vs. Control | Data updated | 3 | Razzouk 2004 → Razzouk 2006, Janinis 2003→ Christodoulou 2009, Savonije 2004→Savonije 2005
Epoetin vs. Control | New data | 15 | Aapro 2008, Blohmer 2004, EPO-INT-3, Fujisaka 2011, Goss 2005, Grote 2005, Gupta 2009, Leyland-Jones 2005, Milroy 2011, Moebus 2007, Porter 1996, Pronzato 2010, Ray-Coquard 2009, Tsuboi 2009, Wilkinson 2006
Epoetin vs. Control | Total Studies Included | 28
Darbepoetin vs. Control | Excluded | 1 | Hedenus 2002
Darbepoetin vs. Control | Included unchanged | 3 | Hedenus 2003, Kotasek 2003, Vansteenkiste 2002
Darbepoetin vs. Control | Data updated | 0
Darbepoetin vs. Control | New data | 4 | Hernandez 2009, Katakami 2008, Pirker 2008, Untch 2011
Darbepoetin vs. Control | Total Studies Included | 7
| | Trials | Overall Survival Study
Darbepoetin vs. Epoetin | Excluded | 1 | Waltzman 2005 (abstract)→ Waltzman 2005 (included in on-study mortality)
Darbepoetin vs. Epoetin | Included unchanged | 0
Darbepoetin vs. Epoetin | Data updated | 0
Darbepoetin vs. Epoetin | New data | 0
Darbepoetin vs. Epoetin | Total Studies Included | 2
Epoetin vs. Control | Excluded | 13 | Cascinu 1994, Cazzola 1995, Del Mastro 1997, Dunphy 1999, EPO-CAN-20, Kurz 1997, O’Shaughnessy 2005, Osterborg 1996, P-174, ten Bokkel 1998, Thatcher 1999, Throuvalas 2000, Vadhan-Raj 2004
Epoetin vs. Control | Included unchanged | 1 | Bamias 2003
Epoetin vs. Control | Data updated | 21 | Case 1993 → Case 1993 IPD, Chang 2005 → Chang 2005 IPD, Coiffier 2001 → Boogaerts 2003 IPD, Dammacco 2001 → Dammacco 2001 IPD, Henke 2003 → Henke 2003 IPD, Henry 1995 → Henry 1995 IPD, Leyland-Jones 2003 → Leyland-Jones 2005 IPD, Littlewood 2001 → Littlewood 2001 IPD, Machtay 2004 → Machtay 2007, Oberhoff 1998 → Oberhoff 1998 IPD, Osterborg 2005 → Osterborg 2002 IPD, Rose 1994 → Rose 1994 IPD, Savonije 2004 → Savonije 2005 IPD, Witzig 2005 → Witzig 2005 IPD, EPO-CAN-15 → Goss 2005 IPD, EPO GBR-07 → Hoskin 2009 IPD, GOG-191 → Thomas 2008, N93004 2004 → Grote 2005 IPD, INT-1 → EPO-INT-1IPD, INT-3 → EPO-INT-3 IPD
Epoetin vs. Control | New data | 16 | Aapro 2008 IPD, Fujisaka 2011, Pronzato 2002 IPD, Ray-Coquard 2009 IPD, Thomas 2002 IPD, Wilkinson 2006 IPD, Milroy 2003 IPD, Moebus 2007 IPD, Debus 2006 IPD, Antonadou 2001, Blohmer 2004, Christodoulou 2009, Gupta 2009, Tsuboi 2009, Engert 2009, ML17620
Epoetin vs. Control | Total Studies Included | 38
Darbepoetin vs. Control | Excluded | 1 | Hedenus 2002
Darbepoetin vs. Control | Included unchanged | 4 | Hedenus 2003, Kotasek 2003, Vansteenkiste 2002
Darbepoetin vs. Control | Data updated | 0
Darbepoetin vs. Control | New data | 4 | Hernandez 2009, Pirker 2008, Overgaard 2009, Untch 2011
Darbepoetin vs. Control | Total Studies Included | 8
| | Trials | Thromboembolic Events Study
Darbepoetin vs. Epoetin | Excluded | 0
Darbepoetin vs. Epoetin | Included unchanged | 1 | Schwartzberg 2004
Darbepoetin vs. Epoetin | Data updated | 2 | Glaspy 2005 → Glaspy 2006, Waltzman 2005 → Waltzman 2005
Darbepoetin vs. Epoetin | New data | 0
Darbepoetin vs. Epoetin | Total Studies Included | 3
Epoetin vs. Control | Excluded | 10 | Cascinu 1994, Osterborg 1996, P-174, Rosenzweig 2004, Ten Bokkel 1998, Thatcher 1999, Throuvalas 2000, Vadhan-Raj 2004, Welch 1995, EPO-CAN-20
Epoetin vs. Control | Included unchanged | 13 | Bamias 2003, Case J&J 2004, Chang 2005, Dammacco J&J 2004, EPO-INT-1 J&J 2004, EPO-INT-3 J&J 2004, Henke Roche 2004, Henry J&J 2004, Leyland-Jones J&J 2004, Littlewood J&J 2004, Osterborg 2002, Rose J&J 2004, Witzig J&J 2004
Epoetin vs. Control | Data updated | 7 | EPO-CAN-15 → Goss 2005, N93004 2004 → Grote 2005, EPO-GBR-07 → Hoskin 2009, GOG 191 → Thomas 2008, Machtay 2004 → Machtay 2007, Savonije 2004→ Savonije 2005, Razzouk 2004 → Razzouk 2006
Epoetin vs. Control | New data | 12 | Aapro 2008, Blohmer 2011, J&J 2004, Debus 2006, J&J 2007, Engert 2009; Fujisaka 2011, Gupta 2009, Milroy 2011, Moebus 2007, Pronzato 2010, Ray-Coquard 2009, Tsuboi 2009, Wilkinson 2006
Epoetin vs. Control | Total Studies Included | 32
Darbepoetin vs. Control | Excluded
Darbepoetin vs. Control | Included unchanged | 1 | Vansteenkiste 2002
Darbepoetin vs. Control | Data updated
Darbepoetin vs. Control | New data | 5 | Hedenus 2003, Hernandez 2009, Pirker 2008, Overgaard 2009, Untch 2011
Darbepoetin vs. Control | Total Studies Included | 6
| | Trials | QoL FACT-Fatigue (Complete Data) Study
Darbepoetin vs. Epoetin | Excluded | 0
Darbepoetin vs. Epoetin | Included unchanged | 0
Darbepoetin vs. Epoetin | Data updated | 1 | Glaspy 2005 → Glaspy 2006
Darbepoetin vs. Epoetin | New data | 0
Darbepoetin vs. Epoetin | Total Studies Included | 1
Epoetin vs. Control | Excluded | 0
Epoetin vs. Control | Included unchanged | 7 | Boogaerts 2003, Chang 2005, Hedenus 2003, Iconomou 2003, Littlewood 2001, Osterborg 2002, Witzig 2005
Epoetin vs. Control | Data updated | 0
Epoetin vs. Control | New data | 4 | Christodoulou 2009, Hoskin 2009, Savonije 2005, Tsuboi 2009
Epoetin vs. Control | Total Studies Included | 11
Darbepoetin vs. Control | Excluded | 0
Darbepoetin vs. Control | Included unchanged | 1 | Vansteenkiste 2002
Darbepoetin vs. Control | Data updated | 0
Darbepoetin vs. Control | New data | 2 | Kotasek 2003, Pirker 2008
Darbepoetin vs. Control | Total Studies Included | 3
| | Trials | Tumor Response Study
Darbepoetin vs. Epoetin | Excluded | 0
Darbepoetin vs. Epoetin | Included unchanged | 0
Darbepoetin vs. Epoetin | Data updated | 0
Darbepoetin vs. Epoetin | New data | 0
Darbepoetin vs. Epoetin | Total Studies Included | 0
Epoetin vs. Control | Excluded | 3 | Throuvalas 2000, N93004 2004, Vadhan-Raj 2004
Epoetin vs. Control | Included unchanged | 1 | Henke 2003
Epoetin vs. Control | Data updated | 4 | EPO-CAN-15 → Goss 2005, EPO-GBR-07 → Hoskin 2009, GOG 191 → Thomas 2008, Machtay 2004 → Machtay 2007
Epoetin vs. Control | New data | 8 | Blohmer 2011, Debus 2006, Engert 2009, Gupta 2009, Milroy 2011, Moebus 2007, Pronzato 2010, Wagner 2004
Epoetin vs. Control | Total Studies Included | 13
Darbepoetin vs. Control | Excluded | 0
Darbepoetin vs. Control | Included unchanged | 0
Darbepoetin vs. Control | Data updated | 0
Darbepoetin vs. Control | New data | 2 | Overgaard 2009, Untch 2011
Darbepoetin vs. Control | Total Studies Included | 2
| | Trials | ADE (Hypertension) Study
Darbepoetin vs. Epoetin | Excluded | 0
Darbepoetin vs. Epoetin | Included unchanged | 0
Darbepoetin vs. Epoetin | Data updated | 0
Darbepoetin vs. Epoetin | New data | 0
Darbepoetin vs. Epoetin | Total Studies Included | 0
Epoetin vs. Control | Excluded | 9 | Cascinu 1994, Kunikane 2001, Osterborg 1996, Rosenzweig 2004, Silvestris 1995, Ten Bokkel Huinink 1998, Thatcher 1999, Welch 1995
Epoetin vs. Control | Included unchanged | 7 | Bamias 2003, Case 1993, Dammaccco 2001, Henry 1995, Iconomou 2003,^a^ Littlewood 2001, Rose 1994
Epoetin vs. Control | Data updated | 0
Epoetin vs. Control | New data | 8 | Fujisaka 2011, Hoskin 2009, Milroy 2011, Osterborg 2002, Razzouk 2006, Savonije 2005, Wilkinson 2006, Tsuboi 2009
Epoetin vs. Control | Total Studies Included | 15
Darbepoetin vs. Control | Excluded | 0
Darbepoetin vs. Control | Included unchanged | 1 | Vansteenkiste 2002
Darbepoetin vs. Control | Data updated | 0
Darbepoetin vs. Control | New data | 2 | Hernandez 2009, Pirker 2008
Darbepoetin vs. Control | Total Studies Included | 3
| | Trials | ADE (Thrombocytopenia/Hemorrhage) Study
Darbepoetin vs. Epoetin | Excluded | 0
Darbepoetin vs. Epoetin | Included unchanged | 0
Darbepoetin vs. Epoetin | Data updated | 0
Darbepoetin vs. Epoetin | New data | 1 | Pirker 2008
Darbepoetin vs. Epoetin | Total Studies Included | 1
Epoetin vs. Control | Excluded | 4 | Cascinu 1994, Del Mastro 1997, Kunikane 2001, Thatcher 1999
Epoetin vs. Control | Included unchanged | 3 | Bamias 2003, Boogaerts 2003, Dammacco 2001
Epoetin vs. Control | Data updated | 0
Epoetin vs. Control | New data | 7^a^ | Fujisaka 2011, Goss 2005, Littlewood 2001, Milroy 2010, Savonije 2005, Tsuboi 2009, Witzig 2005
Epoetin vs. Control | Total Studies Included | 12
Darbepoetin vs. Control | Excluded | 0
Darbepoetin vs. Control | Included unchanged | 0
Darbepoetin vs. Control | Data updated | 0
Darbepoetin vs. Control | New data | 2 | Pirker 2008, Untch 2011
Darbepoetin vs. Control | Total Studies Included | 2
| | Trials | ADE (Rash) Study
Darbepoetin vs. Epoetin | Excluded | 0
Darbepoetin vs. Epoetin | Included unchanged | 0
Darbepoetin vs. Epoetin | Data updated | 0
Darbepoetin vs. Epoetin | New data | 0
Darbepoetin vs. Epoetin | Total Studies Included | 0
Epoetin vs. Control | Excluded | 5 | Del Mastro 1997, Kurz 1997, Osterborg 1996, Thatcher 1999, Welch 1995
Epoetin vs. Control | Included unchanged | 1 | Henry 1995
Epoetin vs. Control | Data updated | 0
Epoetin vs. Control | New data | 5 | Gupta 2009, Milroy 2011, Osterborg 2002, Tsuboi 2009, Witzig 2005
Epoetin vs. Control | Total Studies Included | 6
Darbepoetin vs. Control | Excluded | 0
Darbepoetin vs. Control | Included unchanged | 0
Darbepoetin vs. Control | Data updated | 0
Darbepoetin vs. Control | New data | 0
Darbepoetin vs. Control | Total Studies Included | 0
| | Trials | ADE (Seizure) Study
Darbepoetin vs. Epoetin | Excluded | 1 | Glaspy 2003
Darbepoetin vs. Epoetin | Included unchanged | 0
Darbepoetin vs. Epoetin | Data updated | 0
Darbepoetin vs. Epoetin | New data | 0
Darbepoetin vs. Epoetin | Total Studies Included | 0
Epoetin vs. Control | Excluded | 1 | Cascinu 1994
Epoetin vs. Control | Included unchanged | 2 | Case 1993, Henry 1995
Epoetin vs. Control | Data updated | 0
Epoetin vs. Control | New data | 1 | Savonije 2005
Epoetin vs. Control | Total Studies Included | 3
Darbepoetin vs. Control | Excluded | 0
Darbepoetin vs. Control | Included unchanged | 0
Darbepoetin vs. Control | Data updated | 0
Darbepoetin vs. Control | New data | 2 | Hernandez 2009, Pirker 2008
Darbepoetin vs. Control | Total Studies Included | 2
| | Trials | ADE (Antibodies) Study
Darbepoetin vs. Epoetin | Excluded | 1 | Glaspy 2003
Darbepoetin vs. Epoetin | Included unchanged | 2 | Schwartzberg 2004, Glaspy 2002
Darbepoetin vs. Epoetin | Data updated | 1 | Glaspy 2005 → Glaspy 2006
Darbepoetin vs. Epoetin | New data | 1 | Waltzman 2005
Darbepoetin vs. Epoetin | Total Studies Included | 4
Epoetin vs. Control | Excluded | 2 | Thatcher 1999, Ten Bokkel 1998
Epoetin vs. Control | Included unchanged | 4 | Chang 2005, Henry 1995, Oberhoff 1998, Osterborg 2002
Epoetin vs. Control | Data updated | 0
Epoetin vs. Control | New data | 1 | Tsuboi 2009
Epoetin vs. Control | Total Studies Included | 5
Darbepoetin vs. Control | Excluded | 0
Darbepoetin vs. Control | Included unchanged | 1 | Vansteenkiste 2002
Darbepoetin vs. Control | Data updated | 0
Darbepoetin vs. Control | New data | 4 | Hedenus 2003, Hernandez 2009, Kotasek 2003, Pirker 2008
Darbepoetin vs. Control | Total Studies Included | 5

a No events

a Gupta 2009 also reported thrombocytopenia but without consistent event frequency so not included in results.