# Data Used in Meta-Analyses and Not Included in the Text

Appendix Table E1 Hematologic response

Study | Treated Events | Treated Total | Control^a^ Events | Control Total | Drug
Aapro 2008 | 157 | 231 | 32 | 232 | Epoetin
Bamias 2003 | 15 | 72 | 2 | 72 | Epoetin
Boogaerts 2003 | 63 | 133 | 17 | 129 | Epoetin
Case 1993 | 46 | 79 | 10 | 74 | Epoetin
Chang 2005 | 115 | 175 | 11 | 175 | Epoetin
Dammacco 2001 | 38 | 66 | 6 | 66 | Epoetin
Henry 1995 | 31 | 64 | 4 | 61 | Epoetin
Iconomou 2003 | 25 | 57 | 7 | 55 | Epoetin
Littlewood 2001 | 172 | 244 | 22 | 115 | Epoetin
Milroy 2011 | 37 | 189 | 5 | 191 | Epoetin
ML17620 2006 | 29 | 61 | 14 | 60 | Epoetin
Oberhoff 1998 | 38 | 114 | 7 | 104 | Epoetin
Osterborg 2005 | 114 | 170 | 46 | 173 | Epoetin
Razzouk 2006 | 63 | 111 | 39 | 111 | Epoetin
Rose 1994 | 67 | 142 | 13 | 79 | Epoetin
Savonije 2005 | 143 | 208 | 31 | 100 | Epoetin
Witzig 2005 | 120 | 165 | 52 | 164 | Epoetin
Hedenus 2003 | 104 | 174 | 31 | 170 | Darbepoetin
Katakami 2008 | 57 | 103 | 21 | 104 | Darbepoetin
Kotasek 2003a | 8 | 32 | 1 | 8 | Darbepoetin
Kotasek 2003b | 8 | 17 | 1 | 8 | Darbepoetin
Kotasek 2003c | 23 | 46 | 2 | 9 | Darbepoetin
Kotasek 2003d | 17 | 28 | 1 | 8 | Darbepoetin
Kotasek 2003e | 20 | 35 | 1 | 9 | Darbepoetin
Kotasek 2003f | 20 | 40 | 1 | 9 | Darbepoetin
Glaspy 2002A | 31 | 59 | 38 | 53 | Darb vs Epo
Waltzman 2005 | 74 | 177 | 101 | 175 | Darb vs Epo

a For darbepoetin versus epoetin control is epoetin, otherwise placebo

Appendix Table E2 Proportion transfused

Study | Treated Events | Treated Total | Control Events | Control Total | Drug
Aapro 2008 | 33 | 231 | 63 | 232 | Epoetin
Bamias 2003 | 11 | 72 | 24 | 72 | Epoetin
Blohmer 2011 | 14 | 127 | 38 | 129 | Epoetin
Boogaerts 2003 | 43 | 133 | 67 | 129 | Epoetin
Case 1993 | 32 | 79 | 36 | 74 | Epoetin
Chang 2005 | 15 | 175 | 40 | 175 | Epoetin
Christodoulou 2009 | 16 | 167 | 36 | 170 | Epoetin
Dammacco 2001 | 19 | 69 | 36 | 76 | Epoetin
EPO-INT-3 | 21 | 136 | 23 | 65 | Epoetin
Fujisaka 2011 | 4 | 89 | 18 | 92 | Epoetin
Goss 2005 | 8 | 52 | 27 | 52 | Epoetin
Grote 2005 | 26 | 109 | 42 | 115 | Epoetin
Gupta 2009 | 9 | 58 | 25 | 57 | Epoetin
Henry 1995 | 34 | 64 | 42 | 61 | Epoetin
Iconomou 2003 | 9 | 57 | 14 | 55 | Epoetin
Leyland-Jones 2005 | 47 | 469 | 66 | 470 | Epoetin
Littlewood 2001 | 62 | 251 | 49 | 124 | Epoetin
Milroy 2011 | 16 | 189 | 43 | 191 | Epoetin
Moebus 2007 | 41 | 320 | 86 | 305 | Epoetin
Oberhoff 1998 | 32 | 114 | 44 | 104 | Epoetin
Osterborg 2005 | 65 | 169 | 90 | 173 | Epoetin
Porter 1996 | 9 | 10 | 10 | 10 | Epoetin
Pronzato 2010 | 8 | 107 | 18 | 109 | Epoetin
Ray-Coquard 2009 | 39 | 108 | 61 | 105 | Epoetin
Razzouk 2006 | 72 | 111 | 86 | 111 | Epoetin
Rose 1994 | 65 | 142 | 47 | 79 | Epoetin
Savonije 2005 | 77 | 211 | 66 | 102 | Epoetin
Thomas 2002 | 7 | 62 | 31 | 65 | Epoetin
Tsuboi 2009 | 7 | 61 | 7 | 56 | Epoetin
Wilkinson 2006 | 9 | 114 | 18 | 59 | Epoetin
Witzig 2005 | 42 | 166 | 65 | 164 | Epoetin
Hedenus 2003 | 52 | 167 | 79 | 165 | Darbepoetin
Hernandez 2009 | 58 | 193 | 91 | 193 | Darbepoetin
Katakami 2008 | 7 | 103 | 20 | 104 | Darbepoetin
Kotasek 2003a | 8 | 30 | 4 | 8 | Darbepoetin
Kotasek 2003b | 5 | 17 | 4 | 8 | Darbepoetin
Kotasek 2003c | 12 | 41 | 4 | 9 | Darbepoetin
Kotasek 2003d | 7 | 27 | 4 | 8 | Darbepoetin
Kotasek 2003e | 9 | 35 | 3 | 8 | Darbepoetin
Kotasek 2003f | 7 | 38 | 4 | 9 | Darbepoetin
Pirker 2008 | 52 | 298 | 116 | 298 | Darbepoetin
Untch 2011 | 1 | 356 | 0 | 377 | Darbepoetin
Vansteenkiste 2002 | 53 | 156 | 89 | 158 | Darbepoetin
Glaspy 2002A | 8 | 59 | 12 | 53 | Darb vs. Epo
Glaspy 2006 | 157 | 582 | 126 | 571 | Darb vs. Epo
Kotsori 2006 | 9 | 55 | 3 | 55 | Darb vs. Epo
Schwartzberg 2004a | 4 | 72 | 11 | 69 | Darb vs. Epo
Schwartzberg 2004b | 14 | 51 | 9 | 51 | Darb vs. Epo
Schwartzberg 2004c | 7 | 34 | 6 | 35 | Darb vs. Epo
Waltzman 2005 | 29 | 163 | 20 | 155 | Darb vs. Epo

Appendix Table E3 Overall survival

Study | Treated Events | Treated Total | Control Events | Control Total | Observed- Expected | Variance | Drug
Aapro 2008 | 169 | 231 | 169 | 232 | 5.77 | 85.29 | Epoetin
Antonadou 2001 | 10 | 190 | 30 | 195 | −10.4 | 10 | Epoetin
Bamias 2003 | 7 | 72 | 4 | 72 | 1.5 | 2.56 | Epoetin
Blohmer 2004 | 25 | 127 | 29 | 129 | −1.71 | 13.34 | Epoetin
Boogaerts 2003 | 16 | 132 | 12 | 127 | 2.85 | 6.71 | Epoetin
Case 1993 | 10 | 81 | 9 | 76 | 0.49 | 4.73 | Epoetin
Chang 2005 | 27 | 176 | 28 | 178 | −0.84 | 13.64 | Epoetin
Christodoulou 2009 | 71 | 167 | 87 | 170 | 8.83 | 39.5 | Epoetin
Dammacco 2001 | 1 | 69 | 7 | 76 | −3.03 | 2.06 | Epoetin
Debus 2006 | 146 | 195 | 159 | 190 | −15.56 | 73.82 | Epoetin
Engert 2009 | 27 | 648 | 36 | 655 | −7.15 | 20.05 | Epoetin
EPO-INT-1 | 11 | 165 | 3 | 81 | 2.02 | 3.19 | Epoetin
EPO-INT-3 | 9 | 135 | 3 | 65 | 1.19 | 2.71 | Epoetin
Fugisaka 2011 | 37 | 89 | 34 | 92 | 2.09 | 10.84 | Epoetin
Goss 2005 | 28 | 52 | 29 | 52 | 1.71 | 14 | Epoetin
Grote 2005 | 100 | 109 | 101 | 115 | 7.84 | 49.92 | Epoetin
Gupta 2009 | 17 | 58 | 14 | 57 | −1.25 | 11.88 | Epoetin
Hedenus 2003 | 101 | 176 | 82 | 173 | 12.44 | 44.82 | Darbepoetin
Henke 2003 | 109 | 180 | 89 | 171 | 16.08 | 48.83 | Epoetin
Henry 1995 | 7 | 67 | 10 | 65 | −1.61 | 4.18 | Epoetin
Hernandez 2009 | 17 | 196 | 20 | 195 | −1.62 | 9.31 | Darbepoetin
Hoskin 2009 | 74 | 151 | 75 | 149 | 1.45 | 36.89 | Epoetin
Kotasek 2003 | 4 | 208 | 1 | 51 | −0.01 | 0.8 | Darbepoetin
Leyland-Jones 2005 | 121 | 469 | 91 | 470 | 18.23 | 53.04 | Epoetin
Littlewood 2001 | 155 | 251 | 82 | 124 | −11.23 | 50.33 | Epoetin
Machtay 2007 | 37 | 77 | 32 | 71 | 3.01 | 17.28 | Epoetin
Milroy 2003 | 136 | 214 | 126 | 210 | 7.74 | 63.36 | Epoetin
ML17620 2006 | 4 | 61 | 0 | 60 | 1.98 | 0.97 | Epoetin
Moebus 2007 | 59 | 324 | 56 | 319 | 0.28 | 28.43 | Epoetin
Oberhoff 1998 | 9 | 116 | 10 | 111 | −2.08 | 4.36 | Epoetin
Osterborg 2002 | 110 | 173 | 109 | 176 | 2.14 | 54.57 | Epoetin
Overgaard 2009 | 144 | 255 | 119 | 259 | 15.02 | 64.98 | Darbepoetin
Pirker 2008 | 243 | 299 | 254 | 301 | −7.26 | 117.39 | Darbepoetin
Pronzato 2002 | 23 | 110 | 20 | 113 | 0.52 | 10.72 | Epoetin
Ray-Coquard 2009 | 75 | 110 | 84 | 108 | −9.37 | 39.76 | Epoetin
Razzouk 2004 | 2 | 112 | 2 | 110 | −0.02 | 0.99 | Epoetin
Rose 1994 | 16 | 142 | 6 | 79 | 2.63 | 5.19 | Epoetin
Savonije 2005 | 132 | 211 | 61 | 104 | 5.7 | 43.51 | Epoetin
Thomas 2002 | 4 | 65 | 5 | 65 | −0.52 | 2.21 | Epoetin
Thomas 2008 | 22 | 58 | 17 | 56 | 2.38 | 9.66 | Epoetin
Tsuboi 2009 | 21 | 61 | 19 | 56 | −0.98 | 15.76 | Epoetin
Untch 2008 | 59 | 345 | 48 | 369 | 7.54 | 26.45 | Darbepoetin
Vansteenkiste 2002 | 101 | 159 | 118 | 161 | −12.4 | 52.62 | Darbepoetin
Wilkinson 2006 | 3 | 121 | 0 | 61 | 0.99 | 0.66 | Epoetin
Witzig 2005 | 121 | 174 | 119 | 170 | 7.01 | 57.33 | Epoetin

Appendix Table E4 On-study mortality

Study | Treated Events | Treated Control | Control Events | Control Total | Observed-Expected | Variance | Drug
Aapro 2008 | 47 | 231 | 35 | 232 | 6.57 | 20.4 | Epoetin
Bamias 2003 | 7 | 72 | 4 | 72 | 1.5 | 2.56 | Epoetin
Boogaerts 2003 | 10 | 132 | 10 | 127 | 0.1 | 4.94 | Epoetin
Case 1993 | 10 | 81 | 9 | 76 | 0.49 | 4.73 | Epoetin
Chang 2005 | 7 | 176 | 5 | 178 | 0.93 | 3.01 | Epoetin
Dammacco 2001 | 1 | 69 | 7 | 76 | −3.03 | 2.06 | Epoetin
Debus 2006 | 26 | 195 | 18 | 190 | 3.51 | 10.91 | Epoetin
EPO-INT-1 | 6 | 165 | 2 | 81 | 0.74 | 1.79 | Epoetin
EPO-INT-3 | 9 | 135 | 3 | 65 | 1.19 | 2.71 | Epoetin
Fujisaka 2011 | 1 | 89 | 0 | 92 | 0.508 | 0.249 | Epoetin
Goss 2005 | 4 | 52 | 1 | 52 | 1.53 | 1.25 | Epoetin
Grote 2005 | 16 | 109 | 21 | 115 | −2.13 | 9.04 | Epoetin
Henke 2003 | 9 | 180 | 7 | 171 | 0.8 | 4.01 | Epoetin
Henry 1995 | 7 | 67 | 10 | 65 | −1.61 | 4.18 | Epoetin
Hoskin 2009 | 5 | 151 | 2 | 149 | 1.51 | 1.76 | Epoetin
Leyland-Jones 2005 | 121 | 469 | 91 | 470 | 18.23 | 53.04 | Epoetin
Littlewood 2001 | 40 | 251 | 22 | 124 | −3.29 | 13.26 | Epoetin
Machtay 2007 | 5 | 77 | 3 | 71 | 0.9 | 1.99 | Epoetin
Milroy 2011 | 51 | 214 | 38 | 210 | 8.1 | 21.79 | Epoetin
ML17620 2006 | 4 | 61 | 0 | 60 | 1.98 | 0.97 | Epoetin
Moebus 2007 | 0 | 324 | 0 | 319 | 0 | 0 | Epoetin
Oberhoff 1998 | 9 | 116 | 10 | 111 | −2.08 | 4.36 | Epoetin
Osterborg 2005 | 24 | 173 | 19 | 176 | 2.73 | 10.73 | Epoetin
Pronzato 2010 | 4 | 110 | 8 | 113 | −1.98 | 3.02 | Epoetin
Ray-Coquard 2009 | 18 | 110 | 23 | 108 | −3.09 | 10.26 | Epoetin
Razzouk 2006 | 2 | 112 | 2 | 110 | −0.02 | 0.99 | Epoetin
Rose 1994 | 16 | 142 | 6 | 79 | 2.63 | 5.19 | Epoetin
Savonije 2005 | 24 | 211 | 13 | 104 | −0.75 | 7.93 | Epoetin
Thomas 2002 | 4 | 65 | 4 | 65 | −0.02 | 2.01 | Epoetin
Thomas 2008 | 1 | 58 | 1 | 56 | −0.03 | 0.5 | Epoetin
Wilkinson 2006 | 2 | 121 | 0 | 61 | 0.69 | 0.45 | Epoetin
Witzig 2005 | 31 | 174 | 25 | 170 | 2.77 | 13.91 | Epoetin
Hedenus 2003 | 10 | 176 | 4 | 173 | 3.05 | 3.48 | Darbepoetin
Hernandez 2009 | 17 | 196 | 20 | 195 | −1.62 | 9.31 | Darbepoetin
Kotasek 2003 | 4 | 208 | 1 | 51 | −0.01 | 0.8 | Darbepoetin
Pirker 2008 | 53 | 299 | 51 | 301 | 0.52 | 26.45 | Darbepoetin
Untch 2011 | 0 | 353 | 0 | 376 | 0 | 0 | Darbepoetin
Vansteenkiste 2002 | 23 | 159 | 21 | 161 | 0.63 | 10.82 | Darbepoetin
Glaspy 2006 | 67 | 611 | 84 | 598 | −9.31 | 33.06 | Darb vs. Epo
Waltzman 2005 | 34 | 180 | 25 | 178 | 4.34 | 12.35 | Darb vs. Epo

Appendix Table E5 Thromboembolic events

Study | Treated Events | Treated Total | Control Events | Control Total | Drug
Aapro 2008 | 29 | 231 | 13 | 231 | Epoetin
Bamias 2003 | 0 | 72 | 1 | 72 | Epoetin
Blohmer 2011 | 2 | 127 | 3 | 129 | Epoetin
Case 1993 | 2 | 81 | 3 | 76 | Epoetin
Chang 2005 | 19 | 176 | 14 | 178 | Epoetin
Dammacco 2001 | 5 | 69 | 1 | 76 | Epoetin
Debus 2006 | 38 | 192 | 23 | 191 | Epoetin
Engert 2010 | 45 | 645 | 44 | 644 | Epoetin
EPO-INT-1 | 3 | 164 | 1 | 80 | Epoetin
EPO-INT-3 | 8 | 135 | 1 | 65 | Epoetin
Fujisaka 2011 | 1 | 89 | 0 | 92 | Epoetin
Goss 2005 | 16 | 52 | 2 | 52 | Epoetin
Grote 2005 | 12 | 109 | 11 | 115 | Epoetin
Gupta 2009 | 0 | 57 | 0 | 59 | Epoetin
Henke 2003 | 10 | 180 | 6 | 171 | Epoetin
Henry 1995 | 6 | 67 | 8 | 65 | Epoetin
Hoskin 2009 | 4 | 133 | 2 | 149 | Epoetin
Leyland-Jones 2005 | 36 | 448 | 25 | 456 | Epoetin
Littlewood 2001 | 14 | 251 | 5 | 124 | Epoetin
Machtay 2011 | 2 | 72 | 0 | 68 | Epoetin
Milroy 2011 | 18 | 189 | 13 | 191 | Epoetin
Moebus 2007 | 9 | 305 | 5 | 288 | Epoetin
Osterborg 2005 | 1 | 170 | 0 | 173 | Epoetin
Pronzato 2010 | 4 | 109 | 1 | 111 | Epoetin
Ray-Coquard 2009 | 5 | 110 | 4 | 107 | Epoetin
Razzouk 2006 | 6 | 112 | 2 | 110 | Epoetin
Rose 1994 | 9 | 142 | 2 | 79 | Epoetin
Savonije 2005 | 7 | 211 | 1 | 104 | Epoetin
Thomas 2008 | 10 | 58 | 5 | 55 | Epoetin
Tsuboi 2009 | 1 | 62 | 0 | 58 | Epoetin
Wilkinson 2006 | 10 | 121 | 1 | 60 | Epoetin
Witzig 2005 | 9 | 168 | 6 | 165 | Epoetin
Hedenus 2003 | 6 | 175 | 1 | 169 | Darbepoetin
Hernandez 2009 | 16 | 194 | 11 | 192 | Darbepoetin
Overgaard 2009 | 7 | 255 | 3 | 259 | Darbepoetin
Pirker 2008 | 65 | 301 | 43 | 296 | Darbepoetin
Untch 2011 | 20 | 318 | 17 | 396 | Darbepoetin
Vansteenkiste 2002 | 7 | 155 | 5 | 159 | Darbepoetin
Glaspy 2006 | 37 | 611 | 42 | 598 | Darb vs. Epo
Schwartzberg 2004 | 2 | 157 | 2 | 155 | Darb vs. Epo
Waltzman 2005 | 17 | 177 | 20 | 175 | Darb vs. Epo