# Data Forms

Study Eligibility Form

Study Validity Form

Data Extraction Main Review

Data Extraction

Trial Selection Form