# Evidence Tables

Appendix Table C1 KQ1: Epoetin versus control, study characteristics, Part I

Appendix Table C1 KQ1: Epoetin versus control, study characteristics, Part II

Appendix Table C2 KQ1: Darbepoetin versus control, study characteristics, Part I

Appendix Table C2 KQ1: Darbepoetin versus control, study characteristics, Part II

Appendix Table C3 KQ1: Darbepoetin versus epoetin, study characteristics, Part I

Appendix Table C3 KQ1: Darbepoetin versus epoetin, study characteristics, Part II

Appendix Table C4 KQ1: Epoetin versus control, study quality

Appendix Table C5 KQ1: Darbepoetin versus control, study quality

Appendix Table C6 KQ1: Darbepoetin versus epoetin, study quality

Appendix Table C7 KQ1 Outcome I. Hematologic response: Epoetin versus control

Appendix Table C8 KQ1 Outcome I. Hematologic response: Darbepoetin versus control

Appendix Table C9 KQ1d Outcome I. Hematologic response: Darbepoetin versus epoetin

Appendix Table C10 KQ1 Outcome I. Hematologic response studies omitted from meta-analysis: Epoetin versus control

Appendix Table C11 KQ1 Outcome I. Hematologic response study omitted from meta-analysis: Darbepoetin versus control

Appendix Table C12 KQ1 Outcome I. Hematologic response studies omitted from meta-analysis: Darbepoetin versus epoetin

Appendix Table C13 KQ1 Outcome I. Hematologic response subgroup analysis: Epoetin versus control; no additional information

Appendix Table C14 KQ1 Outcome I. Hematologic response subgroup analysis: Darbepoetin versus control; no additional information

Appendix Table C15 KQ1 Outcome I. Hematologic response subgroup analysis: Darbepoetin versus epoetin

Appendix Table C16 KQ1 Outcome II. Transfusion: Epoetin versus control

Appendix Table C17 KQ1 Outcome II. Transfusion: Darbepoetin versus control

Appendix Table C18 KQ1 Outcome II. Transfusion: Darbepoetin versus epoetin

Appendix Table C19 KQ1 Outcome II. Transfusion studies omitted from meta-analysis: Epoetin versus control

Appendix Table C20 KQ1 Outcome II. Transfusion studies omitted from meta-analysis: Darbepoetin versus control

Appendix Table C21 KQ1 Outcome II. Transfusion subgroup analysis: Epoetin versus control

Appendix Table C22 KQ1 Outcome II. Transfusion subgroup analysis: Darbepoetin versus control

Appendix Table C23 KQ1 Outcome II. Transfusion subgroup analysis: Darbepoetin versus epoetin

Appendix Table C24 KQ1 Outcome VI. Thromboembolic complications: Epoetin versus control; definition for thromboembolic events as defined in journal publications

Appendix Table C25 KQ1 Outcome VI. Thromboembolic complications: Darbepoetin versus control; definition for thromboembolic events as defined in journal publications

Appendix Table C26 KQ1 Outcome VI. Thromboembolism data sources: Epoetin versus control, updated 2009/2010

Appendix Table C27 KQ1 Outcome VI. Thromboembolism data sources: Darbepoetin versus control

Appendix Table C28 KQ1 Outcome VI. Thromboembolic complications: Epoetin versus control

Appendix Table C29 KQ1 Outcome VI. Thromboembolic complications: Darbepoetin versus control

Appendix Table C30 KQ1 Outcome VII. Other adverse events -- hypertension: Epoetin versus control, evidence table and definition for hypertension

Appendix Table C31 KQ1 Outcome VII. Other adverse events -- hypertension: Darbepoetin versus control, evidence table and definition for hypertension

Appendix Table C32 KQ1 Outcome VII. Other adverse events -- thrombocytopenia: Epoetin versus control

Appendix Table C33 KQ1 Outcome VII. Other adverse events -- thrombocytopenia: Darbepoetin versus control

Appendix Table C34 KQ1 Outcome VII. Other adverse events -- rash: Epoetin versus control

Appendix Table C35 KQ1 Outcome VII. Other adverse events -- seizures: Epoetin versus control

Appendix Table C36 KQ1 Outcome VII. Other adverse events -- seizures: Darbepoetin versus control

Appendix Table C37 KQ1 Outcome VI. Antibodies: Epoetin versus control

Appendix Table C38 KQ1 Outcome VI. Antibodies: Darbepoetin versus control

Appendix Table C39 KQ2: Study characteristics, Part I

Appendix Table C39 KQ2: Study characteristics, Part II

Appendix Table C40 KQ2: Study quality

Appendix Table C41 KQ2: Hematologic response

Appendix Table C42 KQ2: Studies not included for hematologic response

Appendix Table C43 KQ2: Transfusion

Appendix Table C44 KQ2: Thrombotic events

Appendix Table C45 KQ2: QoL data from Straus et al. 2006

Appendix Table C46 KQ2: QoL data from Charu 2007

Appendix Table C47 KQ2: QoL data from Glaspy 2009

Appendix Table C48 KQ2: On study mortality

Appendix Table C49 KQ2: Overall survival*