# Excluded Studies

These studies were excluded at the level of full-text paper or abstract if not published as full text.

## Abbreviations/Key to Reasons for Exclusion

nrct: No Randomized-Controlled Trial
allo: Trials with inadequate allocation concealment, e.g. where patients were allocated by alternation, the use of case record numbers, dates of birth or day of week, and any other procedure that is transparent before allocation, such as an open list of random numbers
ong: Ongoing studies and interim analyses
none: Studies of patients with a malignant disease NOT undergoing anticancer-therapy
mbt: Studies of high-dose Myeloablative chemotherapy regimens followed by bone marrow or peripheral Blood stem cell Transplantation
ept: Studies using Erythropoietin for short-term Preoperative Treatment to correct anemia or to support collection of autologous blood prior to cancer surgery for administration during or after surgery
surg: Studies in which patients received surgical treatment while being administered ESA
nop: Number Of Patients: Trials with 50 or fewer randomized (≤)participants per study arm for studies of adults; 10 or fewer (≤)participants per study arm in paediatric samples
msl: Studies on patients with Myelodysplastic Syndrome or acute Leukaemia
ora: Other Reasons or Anemia, such as hemolysis, iron deficiency and occult bleeding, should have been excluded
eqol: Quality of life using LASA, VAS and CLAS scales are excluded
dup: Duplicate Publication
other reasons: Study objective than comparison of erythropoiesis-stimulating products or comparison to control; different drug used than epoetin alfa, beta or darbepoetin; different randomization than defined for this review.
add reference: Additional reference
comment: ?
dose-finding: ?

## List of Excluded Studies

1 Abdelrazik N, Fouda M. Once weekly recombinant human erythropoietin treatment for cancer-induced anemia in children with acute lymphoblastic leukemia receiving maintenance chemotherapy: a randomized case-controlled study. Hematology. 2007;12(6):533-541. Notes: KQ1 a-c: msl. [pmid: 17852440].
2 Abels RI, Larholt KM, Krantz KD, et al. Recombinant Human Erythropoietin (rHuEPO) for the Treatment of the Anemia of Cancer. Oncologist. 1996;1(3):140-150. Notes: KQ1 a-c: none. [pmid: 10387980].
3 Alexopoulos CG, Kotsori AA. A randomized comparison of rHuEPO with darbepoetin for cancer related anemia. [abstract]. Ann Oncol. 2004;15(Suppl 3). <page no>. Notes: KQ1 d: nop.
4 High-dose erythropoietin linked to longer survival in patients with MM and anemia. Oncol Rep. FALL. 2005:91. Notes: KQ1 a-c: nrct.
5 Epoetin alfa shows greater increase in hemoglobin levels than darbepoetin alfa. Oncol Rep. FALL. 2005:122-123. Notes: KQ1 a-c: other reasons.
6 Aravantinos G, Linardou H, Makridaki D, et al. Recombinant human erythropoietin for platinum-based chemotherapy-induced anaemia: A single-centre randomised study. Journal of BUON. 2003;8(2):127-132. Notes: KQ1 a-c: nop. [pmid: 17472238].
7 Arcasoy MO. Erythropoiesis-stimulating agents in cancer. J Clin Oncol. 2008;26(18):3097-3098. Notes: KQ1 a-c: comment. [pmid: 18565902].
8 Auerbach M, Ballard H, Trout JR, et al. Intravenous iron optimizes the response to recombinant human erythropoietin in cancer patients with chemotherapy-related anemia: a multicenter, open-label, randomized trial. J Clin Oncol. 2004;22(7):1301-1307. Notes: KQ1 a-c: other reasons. [pmid: 15051778].
9 Aziz K, Hashem T, Mobarek N, et al. Does Recombinant Human Erythropoietin Improve the Outcome of Radiation Therapy in Head and Neck Cancer Patients?. [Abstract]. Proceedings of ASTRO. 2001. #2274. Notes: KQ1 a-c: nop.
10 Ban HJ, Chi SY, Park CK, et al. Efficacy of darbepoetin alfa in anemia developed during chemotherapy for lung cancer. Tuberc Respir Dis. 2009;66(2):104-109. Notes: KQ1 a-c: nrct.
11 Becker G, Momm F, Xander C, et al. Religious belief as a coping strategy: an explorative trial in patients irradiated for head-and-neck cancer. Strahlenther Onkol. 2006;182(5):270-276. Notes: KQ1 a-c: other reasons. [pmid: 16673060].
12 Beggs VL, Disalvo WM, Meyer LP, et al. Fatigue and plasma cytokines in a randomized double-blind placebo-controlled trial of epoetin alfa in patients undergoing combined modality therapy for unresectable non-small cell lung cancer (NSCLC). [abstract]. Proc Am Soc Clin Oncol. 2003;22:733. Notes: KQ1 a-c: nop.
13 Blakely L, Schwartzberg LS, Henry D, et al. Randomized study of early intervention compared to standard intervention with darbepoetin-alpha (DA) for chemotherapy-induced anemia (CIA) in early stage breast cancer (ESBC). [abstract]. J Clin Oncol. 2007;25(18S):19538. Notes: KQ2: other reasons.
14 Blayney D, Fesen M, Mirtsching BC, et al. Every-2-week darbepoetin alfa improves hemoglobin in anemic patients with cancer undergoing chemotherapy: A stratified analysis by tumor type. Blood. 2003;102(11). Notes: KQ1 a-c: other reasons.
15 Boccia R, Lillie T, Tomita D, et al. The effectiveness of darbepoetin alfa administered every 3 weeks on hematologic outcomes and quality of life in older patients with chemotherapy-induced anemia. Oncologist. 2007;12(5):584-593. Notes: KQ1 a-c: nrct. [pmid: 17522247].
16 Bradbury J. Less-frequent erythropoietin for cancer-associated anaemia. Lancet Oncol. 2006;7(4):286. Notes: KQ1 a-c: nrct. [pmid: 16598876].
17 Buchner A, Pias P. Epoetin theata shows efficacy and safety in placebo controlled, randomized phase III study in cancer patients receiving non-platinum chemotherapy. Oral Presentation at DGHO. 2009:348. Notes: KQ1 a-c: other reasons.
18 Burstein HJ, Parker LM, Doherty J, et al. Use of the long-acting hematopoietic growth factors pegfilgrastim and darbepoetin alfa in support of dose-dense adjuvant chemotherapy. J Supportive Oncol. 2005;3(2 SUPPL 1):50-51. Notes: KQ1 a-c: nrct.
19 Campos SM, Duh MS, Lefebvre P, et al. Benefits associated with an early hemoglobin response to epoetin alfa therapy in the treatment of chemotherapy-related anemia. J Natl Compr Canc Netw. 2005;3(6):807-816. Notes: KQ1 a-c: other reasons. [pmid: 16316616].
20 Canon JL, Vansteenkiste J, Bodoky G, et al. Randomized, double-blind, active-controlled trial of every-3-week darbepoetin alfa for the treatment of chemotherapy-induced anemia. J Natl Cancer Inst. 2006;98(4):273-284. Notes: KQ1 a-c: dose-finding. [pmid: 16478746].
21 Carabantes FJ, Benavides M, Trujillo R, et al. Epoetin alfa in the prevention of anemia in cancer patients undergoing platinum-based chemotherapy (CT). A prospective randomized study. [Abstract]. Proceedings of ASCO. 1999. #2303. Notes: KQ1 a-c: nop.
22 Casadevall N, Durieux P, Dubois S, et al. Health, economic, and quality-of-life effects of erythropoietin and granulocyte colony-stimulating factor for the treatment of myelodysplastic syndromes: a randomized, controlled trial. Blood. 2004;104(2):321-327. Notes: KQ1 a-c: msl. [pmid: 15054036].
23 Cascinu S, Fedeli A, Del Ferro E, et al. Recombinant human erythropoietin treatment in cisplatin-associated anemia: a randomized, double-blind trial with placebo. J Clin Oncol. 1994;12:1058-1062. Notes: KQ1 a-c: nop. [pmid: 8164030].
24 Cazzola M, Messinger D, Battistel V, et al. Recombinant human erythropoietin in the anemia associated with multiple myeloma or non-hodgkin’s lymphoma: dose finding and identification of predictors of response. Blood. 1995;86(12):4446-4453. Notes: KQ1 a-c: nop. [pmid: 8541533].
25 Cazzola M. Can EPO reduce blood transfusion requirements during induction therapy for high-risk neuroblastoma?. Nat Clin Pract Oncol. 2004;1(1):22-23. Notes: KQ1 a-c: comment. [pmid: 16264794].
26 Cella D, Viswanathan HN, Hays RD, et al. Development of a fatigue and functional impact scale in anemic cancer patients receiving chemotherapy. Cancer. 2008;113(6):1480-1488. Notes: KQ1 a-c: nrct. [pmid: 18642348].
27 Charu V, Belani C, Gill A, et al. A controlled, randomized, open-label study to evaluate the effects of every-2-week darbepoetin alfa for anemia of cancer. J Supportive Oncol. 2005;3(2 SUPPL 1):12-13. Notes: KQ1 a-c: none.
28 Charu V, Belani CP, Gill AN, et al. Efficacy and safety of every-2-week darbepoetin alfa in patients with anemia of cancer: a controlled, randomized, open-label phase II trial. Oncologist. 2007;12(6):727-737. Notes: KQ1 a-c: none. [pmid: 17602062].
29 Charu V, Moyo V, Luo D, et al. Erythroid response to epoetin alfa (epo) 120,000 units (u) every three weeks (q3w) initiated early or at a standard threshold in chemotherapy-induced anemia (CIA). [Abstract]. Blood (ASH Annual Meeting Abstracts). 2007;110(11):3770. Notes: KQ2: dup.
30 Clark J, Schergen A. Advantages of every-3-week dosing of erythropoietic agents to manage chemotherapy-induced anemia. Oncology. 2006;20(7):795-800. Notes: KQ1 a-c: nrct. [pmid: 16841803].
31 Codacci-Pisanelli G, Spinelli GP, Tomao S. Effect of epoetin on survival in patients with breast cancer. J Clin Oncol. 2008;26(15):2599. Notes: KQ1 a-c: comment. [pmid: 18487580].
32 Coleman EA, Anaissie EJ, Kennedy RL, et al. Predictors of deep vein thrombosis (DVT) in newly diagnosed multiple myeloma (MM) patients with and without prophylactic recombinant erythropoietin (EPO) therapy. [Abstract]. ASCO Meeting Abstracts. 2009;27(15S):9554. Notes: KQ1 a-c: nrct.
33 De Campos E, Radford J, Steward, et al. Clinical and in vitro effects of recombinant human erythropoietin in patients receiving intensive chemotherapy for small-cell lung cancer. J Clin Oncol. 1995;13(7):1623-1631. Notes: KQ1 a-c: nop. [pmid: 7602351].
34 Del Mastro L, Venturini M, Lionetto R, et al. Randomized phase III trial evaluating the role of erythropoietin in the prevention of chemotherapy-induced anemia. JlClinl Oncol. 1997;15(7):2715-2721. Notes: KQ1 a-c: nop.
35 Delarue R, Mounier N, Haioun C, et al. Safety of prophylactic use of darbepoetin alfa in patients with diffuse large B-cell lymphoma (DLBCL) treated with R-CHOP 14 or R-CHOP21: preliminary results of the LNH03-6B randomized GELA study. [Abstract]. Blood (ASH Annual Meeting Abstracts). 2006;108(11):2436. Notes: KQ1 d: other reasons.
36 Dougherty FC, Reigner B, Jordan P, et al. CERA (continuous erythropoiesis receptor activator): Dose-response, pharmacokinetics, and tolerability in phase I multiple ascending dose studies. J Supportive Oncol. 2005;3(2 SUPPL 1):10-11. Notes: KQ1 a-c: other reasons.
37 Dunphy FR, Harrison BR, Dunleavy TL, et al. Erythropoietin reduces anemia and transfusions. Cancer. 1999;86:1362-1367. Notes: KQ1 a-c: nop. [pmid: 10506726].
38 EPO-GER-20. EPO-GER-20. Bohlius J. 2009. Erythropoietin or Darbepoetin for patients with cancer - meta-analysis based on individual patient data. Notes: KQ1 a-c: nop.
39 Famoyin C, Byrnes C, Roberts S, et al. A randomized phase II study of thalidomide with or without erythropoietin (EPO) in metastatic renal cell carcinoma (RCC). J Clin Oncol. 2004;22(14S). Notes: KQ1 a-c: ong.
40 Gebbia V, Di Marco P, Citarrella P. Systemic chemotherapy in elderly patients with locally advanced and/or inoperable squamous cell carcinoma of the head and neck: impact of anemia and role of recombinant human erythropoietin. Crit Rev Oncol Hematol. 2003;48:49-55. Notes: KQ1 a-c: nop.
41 Glaspy J, Tchekmedyian NS. Darbepoetin alfa administered every 2 weeks alleviates anemia in cancer patients receiving chemotherapy. Oncology (Huntingt). 2002;16(10 Suppl 11):23-29. Notes KQ1 d: nop. [pmid: 12435170].
42 Glaspy J, Berg R, Tomita D, et al. Final results of a phase 3, randomized, open-label study of darbepoetin alfa 200 mcg every 2 weeks (Q2W) versus epoetin alfa 40,000 U weekly (QW) in patients with chemotherapy-induced anemia (CIA). [Abstract]. ASCO Meeting Abstracts. 2005;23(16_suppl):8125. Notes: KQ1 d: dup.
43 Glaspy JA, Jadeja JS, Justice G, et al. A randomized, active-control, pilot trial of front-loaded dosing regimens of darbeopetin-alfa for the treatment of patients with anemia during chemotherapy for malignant disease. Cancer. 2003;97:1312-1320. Notes: KQ1 d: nop. [pmid: 12599240].
44 Glossmann JP, Engert A, Wassmer G, et al. Recombinant human erythropoietin, epoetin beta, in patients with relapsed lymphoma treated with aggressive sequential salvage chemotherapy--results of a randomized trial. Ann Hematol. 2003;82(8):469-475. Notes: KQ1 a-c: nop. [pmid: 12910374].
45 Gordon D, Nichols G, Ben-Jacob A, et al. Treating anemia of cancer with every-4-week darbepoetin alfa: final efficacy and safety results from a phase II, randomized, double-blind, placebo-controlled study. Oncologist. 2008;13(6):715-724. Notes: KQ1 a-c: none. [pmid: 18586927].
46 Granetto C, Ricci S, Martoni A, et al. Comparing the efficacy and safety of fixed versus weight-based dosing of epoetin alpha in anemic cancer patients receiving platinum-based chemotherapy. Oncology Reports. 2003;10(5):1289-1296. Notes: KQ1 a-c: dose-finding. [pmid: 12883695].
47 Gregory SA, Blayney DW, Vadhan-Raj S, et al. Efficacy of darbepoetin alfa in the treatment of chemotherapy-induced anemia in non-Hodgkin’s lymphoma. J Supportive Oncol. 2005;3(2 SUPPL 1):24-25. Notes: KQ1 a-c: nrct.
48 Han HS, Han JY, Yu SY, et al. Randomized phase 2 study of subcutaneous amifostine versus epoetin-alpha given 3 times weekly during concurrent chemotherapy and hyperfractionated radiotherapy for limited-disease small cell lung cancer. Cancer. 2008;113(7):1623-1631. Notes: KQ1 a-c: nop. [pmid: 18671241].
49 Harousseau JL, Fumoleau P, Lange W, et al. Increasing hemoglobin levels with epoetin alfa in anemic hematologic cancer patients receiving chemotherapy correlates significantly with improved quality of life. J Supportive Oncol. 2005;3(2 SUPPL 1):20-21. Notes: KQ1 a-c: dose-finding.
50 Hedenus M, Hansen S, Taylor K, et al. Randomized, dose-finding study of darbepoetin alfa in anaemic patients with lymphoproliferative malignancies. Br J Haematol. 2002;119(1):79-86. Notes: KQ1 a-c: nop. [pmid: 12358906].
51 Hellström Lindberg E, Ahlgren T, Beguin Y, et al. Treatment of anemia in myelodysplastic syndromes with granulocyte colony-stimulating factor plus erythropoietin: results from a randomized phase ii study and long-term follow-up of 71 Patients. Blood. 1998;92(1):68-75. Notes: KQ1 a-c: msl. [pmid: 9639501].
52 Henke M, Guttenberger R, Barke A, et al. Erythropoietin for patients undergoing radiotherapy: a pilot study. Radiother Oncol. 1999;50(2):185-190. Notes: KQ1 a-c: nop. [pmid: 10368042].
53 Henry DH. Extended-dosing epoetin alfa for chemotherapy-induced anemia: Focus on elderly breast and colorectal cancer patients. Community Oncol. 2008;5(6):310-323. Notes: KQ1 a-c: dose-finding.
54 Henze G, Michon J, Morland B, et al. Phase III randomized study: efficacy of epoetin alfa in reducing blood transfusions in newly diagnosed pediatric cancer patients receiving chemotherapy. [Abstract]. Proc Am Soc Clin Oncol. 2002;21. #1547. Notes: KQ1 a-c: msl.
55 Hesketh PJ, Arena F, Patel D, et al. A randomized controlled trial of darbepoetin alfa administered as a fixed or weight-based dose using a front-loading schedule in patients with anemia who have nonmyeloid malignancies. Cancer. 2004;100(4):859-868. Notes: KQ1 a-c: dose-finding. [pmid: 14770445].
56 Hirsh V, Glaspy J, Mainwaring P, et al. Phase II study of two dose schedules of C.E.R.A. (Continuous Erythropoietin Receptor Activator) in anemic patients with advanced non-small cell lung cancer (NSCLC) receiving chemotherapy. Trials. 2007;8:8. Notes: KQ1 a-c: other reasons. [pmid: 17341293].
57 Huddart RA, Welch RS, Chan S, et al. A prospective randomised comparative-group evaluation of epoetin alfa for the treatment of anaemia in UK cancer patients receiving platinum-based chemotherapy. Ann Oncol. 2002;13(Suppl 5):177-177. Notes: KQ1 a-c: nop. [pmid: 12401687].
58 Italian Cooperative Study Group For rHuEpo In Myelodysplastic. A randomized double-blind placebo-controlled study with subcutaneous recombinant human erythropoietin in patients with low-risk myelodysplastic syndromes. Br J Haematol. 1998;103:1070-1074. Notes: KQ1 a-c: nop. [pmid: 9886322].
59 Jakubowski AA, Hurria A, Williams D. Head-to-head comparison of epoetin alfa 40,000 QW vs darbepoetin alfa 200 mcg Q2W in anemic patients with cancer receiving chemotherapy: preliminary results. [Abstract]. Blood. 2003;102(11). Notes: KQ1 d: ong.
60 James RD, Wilkinson PM, Belli F, et al. Recombinant human erythropoietin in patients with ovarian carcinoma and anaemia secondary to cisplatin and carboplatin chemotherapy: preliminary results. Acta Haematol. 1992;87(Suppl 1):12-15. Notes: KQ1 a-c: nop. [pmid: 1574960].
61 Johansson JE, Wersall P, Brandberg Y, et al. Efficacy of epoetin beta on hemoglobin, quality of life, and transfusion needs in patients with anemia due to hormone-refractory prostate cancer--a randomized study. Scandi J Urol Nephrol. 2001;35(4):288-294. Notes: KQ1 a-c: dose-finding.
62 Justice G, Kessler JF, Jadeja J, et al. A randomized, multicenter study of subcutaneous and intravenous darbepoetin alfa for the treatment of chemotherapy-induced anemia. Ann Oncol. 2005;16(7):1192-1198. Notes: KQ1 a-c: other reasons. [pmid: 15860486].
63 Kettelhack C, Hones C, Messinger D, et al. Randomized multicenter trial of the influence of recombinant human erythropoietin on intraoperative and postoperative transfusion need in anemic patients undergoing right hemicolectomy for carcinoma. Br J Surg. 1998;85(1):63-67. Notes: KQ1 a-c: surg. [pmid: 9462386].
64 Kosmadakis N, Messaris E, Maris A, et al. Perioperative erythropoietin administration in patients with gastrointestinal tract cancer: prospective randomized double-blind study. Ann Surg. 2003;237(3):417-421. Notes: KQ1 a-c: surg. [pmid: 12616127].
65 Kotasek D, Albertsson M, Mackey J, et al. Once per cycle dosing of darbepoetin alfa is feasible in anemic cancer patients receiving chemotherapy. Ann Oncol. 2002;13(suppl 5):170. Notes: KQ1 a-c: nop. [pmid: 11863101].
66 Kotasek D, Albertsson M, Mackey J, et al. Randomized, double-blind, placebo-controlled, dose-finding study of darbepoetin alfa administered once every 3 (Q3W) or 4 (Q4W) weeks in patients with solid tumors. [Abstract]. Proc Am Soc Clin Oncol. 2002;21:356a. Notes: KQ1 a-c: nop.
67 Kotasek D, Canon JL, San Miguel J, et al. Correction/maintenance dosing (front loading) of darbepoetin alfa: Final results from a randomized phase III active-controlled trial. J Supportive Oncol. 2005;3(2 SUPPL 1):16-17. Notes: KQ1 a-c: dose-finding.
68 Kotsori AA, Vaslamatzis MM, Alexopoulos CG. A randomized comparison of darbepoetin alfa every three weeks with epoetin thrice weekly for chemotherapy induced anemia in nonhematological cancer patients. [Abstract]. ASCO Meeting Abstracts. 2007;25(18_suppl):19625. Notes: KQ1 d: nop.
69 Krzakowski M. Epoetin delta: efficacy in the treatment of anaemia in cancer patients receiving chemotherapy. Clin Oncol. 2008;20(9):705-713. Notes: KQ1 a-c: other reasons.
70 Kunikane H, Watanabe K, Fukuoka M, et al. Double-blind randomized control trial of the effect of recombinant human erythropoietin on chemotherapy-induced anemia in patients with non-small cell lung cancer. Int J Clin Oncol. 2001;6:296-301. Notes: KQ1 a-c: nop. [pmid: 11828949].
71 Kurz C, Marth C, Windbichler G, et al. Erythropoietin treatment under polychemotherapy in patients with gynecologic malignancies: a prospective, randomized, double-blind placebo-controlled multicenter study. Gynecol Oncol. 1997;65(3):461-6. Notes: KQ1 a-c: nop. [pmid: 9190976].
72 Larholt K, Pashos CL, Wang Q, et al. Dosing and Outcomes Study of Erythropoiesis-Stimulating Therapies (DOSE) : a registry for characterizing anaemia management and outcomes in oncology patients. Clin Drug Investig. 2008;28(3):159-167. Notes: KQ1 a-c: ong.
73 Lonnroth C, Svensson M, Wang W, et al. Survival and erythropoietin receptor protein in tumours from patients randomly treated with rhEPO for palliative care. Med Oncol. 2008;25(1):22-29. Notes: KQ1 a-c: nop. [pmid: 18188711].
74 Luksenburg H, Weir AW. EPO-CAN-20: Safety concerns associated with Aranesp (darbepoetin alfa) Amgen Inc and Procrit (epoetin alfa) Ortho Biotech L.P. for the treatment of anemia associated with cancer chemotherapy. http://www.fda.gov/ohrms/dockets/ac/04/briefing/4037b2_04.pdf. date of last access March 27, 2009. Notes: KQ1 a-c: nop.
75 Lyman GH, Glaspy J. Examining the benefits of early erythropoietic intervention in patients with chemotherapy-induced anemia. Am J Oncol Rev. 2006;5(4):236-241. Notes: KQ1 a-c: other reasons.
76 Malik IA, Khan ZK, Hakimali A, et al. The effect of subcutaneous recombinant human erythropoietin (r-HuEPO) on anemia in cancer patients receiving platinum-based chemotherapy. J Pak Med Assoc. 1998;48(5):127-31. Notes: KQ1 a-c: nop. [pmid: 9813972].
77 Mealy NE, Bayes M. R-744. Drugs Future. 2005;30(5):533-534. Notes: KQ1 a-c: nrct.
78 Merlano M, Ricci S, Martoni A. Comparing the efficacy of fixed versus weight-based dosing of epoetin alfa in anemic cancer patients receiving platinum-based chemotherapy. Eur J Can. 2003;37(Suppl 6):S346. Notes: KQ1 a-c: dose-finding.
79 Miller KB, Kim HT, Greenberg P, et al. Phase III prospective randomized trial of EPO with or without G-CSF versus supportive therapy alone in the treatment of myelodyplastic syndromes (MDS): results of the ECOG-CLSG trial (E1996). Blood. 2004;104(11):70. Notes: KQ1 a-c: other reasons.
80 ML17616. Multicenter, open label study of NeoRecormon treatment for anemia in adult patients with multiple myeloma, low grade non-Hodgkin’s lymphoma or chronic lymphocytic leukemia who have a relatively erythropoietin deficiency and are receiving anti-tumor chemotherapy: ML17616. Shanghai, China. Shanghai Roche Pharmaceuticals Ltd. 2006. available: http://www.centerwatch.com/clinical-trials/listings/studydetails.aspx?StudyID=97120. accessed: 30.09.09. Notes: KQ1 a-c: nop.
81 Morishima Y, Ogura M, Yoneda S, et al. Once-weekly epoetin-beta improves hemoglobin levels in cancer patients with chemotherapy-induced anemia: A randomized, double-blind, dose-finding study. Jpn J Clin Oncol. 2006;36(10):655-661. Notes: KQ1 a-c: dose-finding. [pmid: 16987908].
82 Mystakidou K, Kalaidopoulou O, Katsouda E, et al. Evaluation of epoetin supplemented with oral iron in patients with solid malignancies and chronic anemia not receiving anticancer treatment. Antican Res. 2005;25(5):3495-3500. Notes: KQ1 a-c: nop.
83 O’Shaughnessy JA, Vukelja SJ, Holmes FA, et al. Feasibility of quantifying the effects of epoetin alfa therapy on cognitive function in women with breast cancer undergoing adjuvant or neoadjuvant chemotherapy. Clinical Breast Cancer. 2005;5(6):439-446. Notes: KQ1 a-c: nop. [pmid: 15748464].
84 O’Shaugnessy J, Vukelja S, Savin M, et al. Effects of epoetin alfa (Procrit) on cognitive function, mood, asthenia, and quality of life in women with breast cancer undergoing adjuvant or neoadjuvant chemotherapy: a double-blind, randomized, placebo-controlled trial. [Abstract]. Proc Am Soc Clin Oncol. 2002;21:363a. Notes: KQ1 a-c: nop.
85 OBE/EPO-INT-03. OBE/EPO-INT-03. Bohlius J. 2009. Erythropoietin or Darbepoetin for patients with cancer - meta-analysis based on individual patient data. Notes: KQ1 a-c: nop.
86 Osterborg A, Boogaerts MA, Cimino R, et al. Recombinant human erythropoietin in transfusion-dependent anemic patients with multiple myeloma and non-hodgkin’s lymphoma - a randomized multicenter study. Blood. 1996;87(7):2675-2682. Notes: KQ1 a-c: nop. [pmid: 8639883].
87 P-174. P-174. Bohlius J. 2009. Erythropoietin or Darbepoetin for patients with cancer - meta-analysis based on individual patient data 2010. Notes: KQ1 a-c: nop.
88 Pierelli L, Perillo A, Greggi S, et al. Erythropoietin addition to granulocyte colony-stimulating factor abrogates life-threatening neutropenia and increases peripheral-blood progenitor-cell mobilization after epirubucin, paclitaxel and cisplatin combination chemotherapy: results of a randomized comparison. J Clin Oncol. 1999;17(4):1288-95. Notes: KQ1 a-c: nop. [pmid: 10561191].
89 Ponton Sivilla JL, Feliu Frasnedo E, Modamio Charles P, et al. Study of effectiveness of 3 schedules of administration of erythropoietic colony-stimulating factors in anemic patients under chemotherapy for solid or hematology malignancy. Med Clin (Barc). 2008;131(12):447-451. Notes: KQ1 a-c: nrct. [pmid: 18928734].
90 Posner MR. Erythropoietin therapy corrects anemia but does not improve survival in H&N study. Oncol Rep. SPRING. 2005:76-77. Notes: KQ1 a-c: nrct.
91 Quirt I, Micucci S, Moran LA, et al. The role of recombinant human erythropoietin (EPO) in reducing red blood cell transfusions and maintaining quality of life (QOL) in patients with lymphoma and solid tumors receiving cytotoxic chemotherapy. Results of a randomized, double-blind, placebo-controlled clinical trial. Blood. 1996;88(10 (Suppl 1)):347a-347a. Notes: KQ1 a-c: nop.
92 Recasens V, Rubio-Martinez A, Gomez-Barrera M, et al. A pharmacoeconomical analysis comparing Epoetin Alpha vs transfusion in patients with anemia associated to multiple myeloma. Blood. 2003;102(11). Notes: KQ1 a-c: ong.
93 Reddy GK, Shivakumar L, Muneer S, et al. Preliminary results of a phase II dose-finding study of subcutaneous Hematide(trademark) in patients with cancer receiving chemotherapy. Supportive Cancer Ther. 2007;4(2):74-75. Notes: KQ1 a-c: nop.
94 Reed N, Chan S, Hayward C, et al. Impact of epoetin beta on the survival of anemic patients with ovarian cancer receiving platinum-based chemotherapy. [Abstract]. J Clin Oncol. 2005;23(16_suppl):5102. Notes: KQ1 a-c: nop.
95 Reed SD, Radeva JI, Daniel DB, et al. Economic evaluation of weekly epoetin alfa versus biweekly darbepoetin alfa for chemotherapy-induced anaemia: evidence from a 16-week randomised trial. Pharmacoeconomics. 2006;24(5):479-494. Notes: KQ1 a-c: comment. [pmid: 16706573].
96 Rexer H. Darbepoetin alfa (Aranesp) as supportive therapy in patients with germ cell tumors. Urologe A. 2006;45(8):1017-1018. Notes: KQ1 a-c: ong. [pmid: 16896758].
97 Richardson P, Schlag R, Khuageva NK, et al. Erythropoiesis-stimulating agents do not adversely affect long-term outcomes nor increase the risk of thromboembolic events in multiple myeloma patients treated in the phase III VISTA trial. [Abstract]. Blood. 2008;112(11):1741. Notes: KQ1 a-c: nrct.
98 Rosen FR, Haraf DJ, Kies MS, et al. Multicenter randomized Phase II study of paclitaxel (1-hour infusion), fluorouracil, hydroxyurea, and concomitant twice daily radiation with or without erythropoietin for advanced head and neck cancer. Clinical Cancer Research. 2003;9(5):1689-1697. Notes: KQ1 a-c: nop. [pmid: 12738722].
99 Rosenzweig MQ, Bender CM, Lucke JP, et al. The decision to prematurely terminate a trial of R-HuEPO due to thrombotic events. J Pain Sympt Manag. 2004;27(2):185-190. Notes: KQ1 a-c: nop.
100 Samper Ots P, Rodriguez Perez A, Martin de Miguel M, et al. Treatment of anemia in patients under radiotherapy with subcutaneous epoetenium alpha 10000 IU three times a week and 40000 IU once a week. Oncologia. 2002;25(8):40-46. Notes: KQ1 a-c: dose-finding.
101 Schwartzberg L, Rearden T, Yee L, et al. A phase II, randomized, open-label study to assess the efficacy of extended-dose schedule administration of darbepoetin alfa in cancer patients with chemotherapy-induced anemia. J Supportive Oncol. 2007;5(4 SUPPL 2):22-23. Notes: KQ1 a-c: dose-finding.
102 Schwartzberg LS. Darbepoetin alfa and pegfilgrastim facilitate dose-dense chemo in breast cancer patients. Oncol Rep. SPRING. 2005:124-125. Notes: KQ1 a-c: other reasons.
103 Scott SN, Boeve TJ, McCulloch TM, et al. The effects of epoetin alfa on transfusion requirements in head and neck cancer patients: a prospective, randomized, placebo-controlled study. Laryngoscope. 2002;112(7 Pt 1):1221-1229. Notes: KQ1 a-c: surg. [pmid: 12169903].
104 Shasha D, George MJ, Harrison LB. Once. -weekly dosing of epoetin-alpha increases hemoglobin and improves quality of life in anemic cancer patients receiving radiation therapy either concomitantly or sequentially with chemotherapy. Cancer. 2003;98(5):1072-1079. Notes: KQ1 a-c: nrct. [pmid: 12942577].
105 Silvestris F, Romito A, Fanelli P, et al. Long-term therapy with recombinant human erythropoietin (rHu-EPO) in progressing multiple myeloma. Ann Hematol. 1995;70:313-318. Notes: KQ1 a-c: nop. [pmid: 7632811].
106 Smith RE, Tchekmedyian NS, Chan D, et al. A dose- and schedule-finding study of darbepoetin alpha for the treatment of chronic anaemia of cancer. Br J Can. 2003;88(12):1851-1858. Notes: KQ1 a-c: nop.
107 Steensma DP, Molina R, Sloan JA, et al. Phase III study of two different dosing schedules of erythropoietin in anemic patients with cancer. J Clin Oncol. 2006;24(7):1079-1089. Notes: KQ1 a-c: dose-finding. [pmid: 16505427].
108 Suzuki Y, Tokuda Y, Fujiwara Y, et al. Weekly epoetin beta maintains haemoglobin levels and improves quality of life in patients with non-myeloid malignancies receiving chemotherapy. Jpn J Clin Oncol. 2008;38(3):214-221. Notes: KQ1 a-c: nrct. [pmid: 18296425].
109 Sweeney PJ, Nicolae D, Ignacio L, et al. Effect of subcutaneous recombinant human erythropoietin in cancer patients receiving radiotherapy: final report of a randomized, open- labelled, phase II trial. Br J Can. 1998;77(11):1996-2002. Notes: KQ1 a-c: nop.
110 Ten Bokkel, Huinink WW, De Swart CAM, Van Toorn DW, et al. Controlled multicentre study of the influence of subcutaneous recombinant human erythropoietin on anaemia and transfusion dependency in patients with ovarian carcinoma treated with platinum-based chemotherapy. Med Oncol. 1998;15(3):174-182. Notes: KQ1 a-c: nop. [pmid: 9819794].
111 Thatcher N, De Campos ES, Bell DR, et al. Epoetin alpha prevents anaemia and reduces transfusion requirements in patients undergoing primarily platinum-based chemotherapy for small cell lung cancer. Br J Can. 1999;80(3–4):396-402. Notes: KQ1 a-c: nop.
112 Thompson JA, Gilliland DG, Prchal JT, et al. Effect of recombinant human erythropoietin combined with granulocyte/macrophage colony-stimulating factor in the treatment of patients with myelodysplastic syndrome. Blood. 2000;95:1175-1179. Notes: KQ1 a-c: nop. [pmid: 10666187].
113 Throuvalas NA, Antonadou D, Boufi M, et al. Erythropoietin decreases transfusion requirements during radiochemotherapy. [Abstract]. Proceedings of ASCO. 2000. #1558. Notes: KQ1 a-c: nop.
114 Untch M, Jackisch C, Lenhard MS, et al. Epoetin-alpha reduces red blood cell transfusions (RBC) in high-risk breast cancer patients with adjuvant dose-dense, sequential chemotherapy with epirubicin (E), paclitaxel (T) and cyclophosphamide (C) (ETC). J Clin Oncol. 2005;23(16_suppl):613. Notes: KQ1 a-c: dup.
115 Vadhan-Raj S, Skibber JM, Crane C, et al. Randomized, double-blind, placebo-controlled trial of epoetin alfa (Procrit) in patients with rectal and gastric cancer undergoing chemo-radiotherapy (CT/RT) followed by surgery: early termination of the trial due to increased incidence of thrombo-embolic events (TEE). 2004;104:2915. Notes: KQ1 a-c: nop.
116 Vansteenkiste J, Hedenus M, Gascon P, et al. Darbepoetin alfa for treating chemotherapy-induced anemia in patients with a baseline hemoglobin level < 10 g/dL versus > or = 10 g/dL: an exploratory analysis from a randomized, double-blind, active-controlled trial. BMC Cancer. 2009;9:311. Notes: KQ2: other reasons. [pmid: 19728887].
117 Velilla Millan C, Polo Jaime S, Lopez P, et al. Efecto sobre la emoglobina de dos esquemas de administracion de eritropyetina en cancer de mama tratado con radioterapia. Oncologia. 2003;26(8):45-51. Notes: KQ1 a-c: dose-finding.
118 Vijayakumar S, Roach M, Wara W, et al. Effect of subcutaneous recombinant human erythropoietin in cancer patients receiving radiotherapy: preliminary results of a randomized, open-labeled, phase II trial. Int J Rad Oncol Biol Phy. 1993;26:721-729. Notes: KQ1 a-c: nop.
119 Voravud N, Sriuranpong V, Suwanrusme H. Antianemic effect of once weekly regimen of epoetin alfa 40,000 units in anemic cancer patients receiving chemotherapy. J Med Assoc Thai. 2007;90(6):1082-1088. Notes: KQ1 a-c: nrct. [pmid: 17624200].
120 Waltzman R, Croot C, Justice GR, et al. Randomized comparison of epoetin alfa (40,000 U weekly) and darbepoetin alfa (200 microg every 2 weeks) in anemic patients with cancer receiving chemotherapy. Oncologist. 2005;10(8):642-650. Notes: KQ1 d: dup. [pmid: 16177289].
121 Waxman IM. Epoeitin alfa use in children undergoing myelosuppressive chemotherapy. [14]. J Clin Oncol. 2007;25(7):919. Notes: KQ1 a-c: comment. [pmid: 17327622].
122 Welch RS, James RD, Wilkinson PE. Recombinant human erythropoietin and platinum-based chemotherapy in advanced ovarian cancer. Cancer Journal of the Scientific American. 1995;1(4):261-261. Notes: KQ1 a-c: nop.
123 Winquist E, Julian JA, Moore MJ, et al. Randomized, double-blind, placebo-controlled trial of epoetin alfa in men with castration-resistant prostate cancer and anemia. J Clin Oncol. 2009;27(4):644-646. Notes: KQ1 a-c: nop. [pmid: 19103725].
124 Wright JR, Ung YC, Julian JA, et al. Randomized, double-blind, placebo-controlled trial of erythropoietin in non-small-cell lung cancer with disease-related anemia. J Clin Oncol. 2007;25(9):1027-1032. Notes: KQ1 a-c: nop. [pmid: 17312332].
125 Wurnig C, Windhager R, Schwameis E, et al. Prevention of chemotherapy-induced anemia by the use of erythropoietin in patients with primary malignant bone tumors (a double-blind, randomized, phase III study). Transfusion. 1996;36(2):155-159. Notes: KQ1 a-c: nop. [pmid: 8614967].
126 Yang MC. Comment: Epoetin alfa versus darbepoetin alfa for cancer patients with treatment-related anemia. Ann Pharmacother. 2006;40(5):998-999. Notes: KQ1 a-c: comment. [pmid: 16670351].
127 Yurut-Caloglu V, Caloglu M. Treatment of anemia by recombinant human erythropoietin in cancer patients undergoing radiotherapy. Asia Pac J Clin Oncol. 2008;4(4):199-207. Notes: KQ1 a-c: nrct.
128 Zagari M, Wacholz M, Xiu L. An open-label, controlled, randomized, dose comparison study of epoetin alfa for the treatment of anemia in cancer patients receiving platinum containing chemotherapy. [Abstract]. Hematol J. 2003;61(4(suppl 2)). #0177. Notes: KQ1 a-c: dose-finding.
129 Zajda K, Krzakowski M. Epoetin delta in the management of anaemia in cancer patients. [Abstract]. ASCO Meeting Abstracts. 2007;25(18_suppl):1955. Notes: KQ1 a-c: other reasons.
130 Aapro M, Osterwalder B, Scherhag A, et al. Epoetin-beta treatment in patients with cancer chemotherapy-induced anaemia: the impact of initial haemoglobin and target haemoglobin levels on survival, tumour progression and thromboembolic events. Br J Cancer. 2009;101(12):1961-71. Notes: KQ1 identified in RCT search update; nrct; also considered in meta-analysis review. [pmid: 19997109].
131 Cabanillas ME, Kantarjian H, Thomas DA, et al. Epoetin alpha decreases the number of erythrocyte transfusions in patients with acute lymphoblastic leukemia, lymphoblastic lymphoma, and Burkitt leukemia/lymphoma: results of a randomized clinical trial. Cancer. 2012;118(3):848-55. Notes: KQ1 msl. [pmid: 21751205].
132 Minton O, Richardson A, Sharpe M, et al. Drug therapy for the management of cancer-related fatigue. Cochrane Database Syst Rev. 2010;(7):CD006704. Notes: KQ1 identified in RCT search update KQ1: nrct; also considered in meta-analysis review. [pmid: 20614448].
133 Nagel S, Kellner O, Engel-Riedel W, et al. Addition of darbepoetin alfa to dose-dense chemotherapy: results from a randomized phase II trial in small-cell lung cancer patients receiving carboplatin plus etoposide. Clin Lung Cancer. 2011;12(1):62-9. Notes: KQ1 identified in RCT search update; nop. [pmid: 21273182].
134 Revicki DA, Stull D, Vernon M, et al. Assessing the effect of darbepoetin alfa on patient-reported fatigue in chemotherapy-induced anemia in four randomized, placebo-controlled clinical trials. Qual Life Res. 2012;21(2):311-21. Notes: KQ1 identified in RCT search update: nrct; also considered in meta-analysis review. [pmid: 21644007].