# Search Strategies

Randomized Controlled Trial Search Strategy: PubMed/MEDLINE^®^

#97 | Search #90 NOT #96 | 664
#96 | Search #94 NOT #92 | 455958
#94 | Search “Animals”[Mesh] Limits: Entrez Date from 2005/03/11 to 2009/10/22 | 2477346
#92 | Search “Humans”[Mesh] Limits: Entrez Date from 2005/03/11 to 2009/10/22 | 2021388
#90 | Search #64 AND #84 Limits: Entrez Date from 2005/03/11 to 2009/10/22 | 717
#89 | Search #64 AND #84 | 2133
#84 | Search #70 OR #73 OR #74 OR #77 OR #82 OR #83 | 4817344
#83 | Search control OR controlled OR controls OR prospectiv* OR volunteer* | 3143028
#82 | Search ((“Research Design”[Mesh] OR “Comparative Study “[Publication Type]) OR “Evaluation Studies “[Publication Type]) OR “Follow-Up Studies”[Mesh] | 2021817
#77 | Search “Placebos”[Mesh] OR placebo* OR random* | 672908
#74 | Search (singl* OR doubl* OR trebl* OR tripl*) AND (mask* OR blind*) | 150424
#73 | Search (“Clinical Trial “[Publication Type] OR “Clinical Trials as Topic”[Mesh]) OR “clinical trial” | 735975
#70 | Search ((((“Randomized Controlled Trial “[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh])) OR “Controlled Clinical Trial “[Publication Type]) OR “Random Allocation”[Mesh]) OR “Double-Blind Method”[Mesh] | 460955
#64 | Search #63 AND #62 | 5655
#63 | Search #58 OR #59 | 22990
#62 | Search “Neoplasms”[Mesh] OR “Carcinoma”[Mesh] OR malignan* OR cancer OR cancers OR cancerous OR oncolog* OR myelodysplas* OR tumor OR tumors OR tumour* OR neoplas* OR carcinom* | 2658404
#59 | Search erythropoietin OR epoetin* OR eprex OR neorecormon OR aranesp OR procrit OR darbepoetin OR CERA OR “C.E.R.A.” | 22990
#58 | Search (((“Erythropoietin, Recombinant”[Mesh] OR “Erythropoietin”[Mesh] OR “continuous erythropoietin receptor activator “[Substance Name])) OR (“Epoetin Alfa”[Mesh] OR “epoetin beta “[Substance Name])) OR “darbepoetin alfa “[Substance Name] | 17551

Identified in Updated Search (1/4/2012) | 172

Randomized Controlled Trial Search Strategy: EMBASE

#7 | 850
#5 AND #6
#6 [embase]/lim NOT [medline]/lim AND [2005–2010]/py | 1,318,658
#5 #3 AND #4 | 2,107
#4 ‘randomized controlled trial’/exp OR ‘randomised controlled trial’/exp OR ‘controlled clinical trial’/exp OR ‘random allocation’/exp OR ‘double-blind method’/exp OR ‘single-blind method’/exp OR ‘clinical trial’/exp OR (singl* OR doubl* OR trebl* OR tripl* AND (mask* OR blind*)) OR placebo* OR random* OR ‘research design’/exp OR ‘comparative study’/exp OR ‘evaluation studies’/exp OR ‘follow-up studies’/exp OR ‘control’/exp OR controlled OR controls OR prospectiv* OR volunteer* AND [2005–2010]/py | 1,959,179
#3 #1 AND #2 | 3,171
#2 ‘neoplasms’/exp OR ‘carcinoma’/exp OR malignan* OR ‘cancer’/exp OR ‘cancers’/exp OR cancerous OR oncolog* OR myelodysplas* OR ‘tumor’/exp OR tumors OR tumour* OR neoplas* AND [2005–2010]/py | 606,635
#1 ‘erythropoietin, recombinant’/exp OR ‘erythropoietin’/exp OR ‘epoetin alfa’/exp OR ‘epoetin beta’/exp OR ‘epoetin’/exp OR ‘eprex’/exp OR ‘neorecormon’/exp OR ‘aranesp’/exp OR ‘procrit’/exp OR ‘continuous erythropoietin receptor activator’/exp OR ‘cera’/exp OR ‘c.e.r.a.’ OR ‘darbepoetin’/exp OR ‘darbepoetin alfa’/exp AND [2005–2010]/py | 9,914

Identified in Updated Search (1/4/2012) | 454

Observational Study Search Strategy: PubMed/MEDLINE^®^

#4 | Search #1 AND #2 AND #3 | 158
#3 | Search (“Neoplasms”[Mesh] OR “Carcinoma”[Mesh] OR malignan* OR cancer OR cancers OR cancerous OR oncolog* OR myelodysplas* OR tumor OR tumors OR tumour* OR neoplas* OR carcinom*) | 2741885
#2 | Search AND (“Erythropoietin, Recombinant”[Mesh] OR “Erythropoietin”[Mesh] OR “continuous erythropoietin receptor activator “[Substance Name] OR (“Epoetin Alfa”[Mesh] OR “epoetin beta “[Substance Name] OR “darbepoetin alfa “[Substance Name] OR erythropoietin OR epoetin* OR eprex OR neorecormon OR aranesp OR procrit OR darbepoetin OR CERA OR “C.E.R.A.”) | 23621
#1 | Search Retrospective Studies[MH] | 344634

Note: search results were the same using (“observational/descriptive studies”[MH] ) OR “retrospective studies”[MH] for #1

Identified in Updated Search (1/4/2012) | 17

Meta-analysis Search Strategy: PubMed/MEDLINE^®^

Hits: 61 #1 AND #2 AND #3 #1 neoplasms (mesh) OR cancer OR cancer* #2 darbepoetin OR darbepo* OR epoetin OR epoetin* OR erythropoie* #3 meta-analysis OR meta-analys* OR “meta-analysis” (publication type)

Identified in Updated Search (1/4/2012) | 18

Meta-analysis Search Strategy: Cochrane

Hits: 273 #2 (epoetin OR epoetin* OR darbepoetin OR darbepo* OR ESA or erythropoie*) AND #1 (cancer OR cancer* OR neoplasms)