# References

1 Goldstraw P, Ball D, Jett JR, et al. Non-small-cell lung cancer. Lancet. Nov. 12. 2011;378(9804):1727-40. [pmid: 21565398].
2 Jemal A, Siegel R, Xu J, et al. Cancer statistics, 2010. CA Cancer J Clin. Sep–Oct. 2010;60(5):277-300. [pmid: 20610543].
3 Pfister DG, Johnson DH, Azzoli CG, et al. American Society of Clinical Oncology treatment of unresectable non-small-cell lung cancer guideline: update 2003. J Clin Oncol. Jan. 15. 2004;22(2):330-53. [pmid: 14691125].
4 Detterbeck FC, Boffa DJ, Tanoue LT. The new lung cancer staging system. Chest. Jul. 2009;136(1):260-71. [pmid: 19584208].
5 Rankin SC. Staging of non-small cell lung cancer (NSCLC). Cancer Imaging. 2006;6:1-3. [pmid: 16478697].
6 Goldstraw P, Crowley J, Chansky K, et al. The IASLC Lung Cancer Staging Project: proposals for the revision of the TNM stage groupings in the forthcoming (seventh) edition of the TNM Classification of malignant tumours. J Thorac Oncol. Aug. 2007;2(8):706-14. [pmid: 17762336].
7 Robinson CG, Bradley JD. The treatment of early-stage disease. Semin Radiat Oncol. Jul. 2010;20(3):178-85. [pmid: 20685580].
8 Rami-Porta R, Ball D, Crowley J, et al. The IASLC Lung Cancer Staging Project: proposals for the revision of the T descriptors in the forthcoming (seventh) edition of the TNM classification for lung cancer. J Thorac Oncol. Jul. 2007;2(7):593-602. [pmid: 17607114].
9 Cerfolio RJ, Bryant AS. Survival of patients with true pathologic stage I non-small cell lung cancer. Ann Thorac Surg. Sep. 2009;88(3):917-22. discussion 22–3. [pmid: 19699920].
10 Colice GL, Shafazand S, Griffin JP, et al. Physiologic evaluation of the patient with lung cancer being considered for resectional surgery: ACCP evidenced-based clinical practice guidelines (2nd edition). Chest. Sep. 2007;132(3 Suppl):161S-77S. [pmid: 17873167].
11 Myrdal G, Gustafsson G, Lambe M, et al. Outcome after lung cancer surgery. Factors predicting early mortality and major morbidity. Eur J Cardiothorac Surg. Oct. 2001;20(4):694-9. [pmid: 11574210].
12 Christie NA, Pennathur A, Burton SA, et al. Stereotactic radiosurgery for early stage non-small cell lung cancer: rationale, patient selection, results, and complications. Semin Thorac Cardiovasc Surg. Winter. 2008;20(4):290-7. [pmid: 19251167].
13 Crino L, Weder W, van Meerbeeck J, et al. Early stage and locally advanced (nonmetastatic) non-small-cell lung cancer: ESMO Clinical Practice Guidelines for diagnosis, treatment and follow-up. Ann Oncol. May. 2010;21(Suppl 5):v103-15. [pmid: 20555058].
14 Decker RH, Tanoue LT, Colasanto JM, et al. Evaluation and definitive management of medically inoperable early-stage non-small-cell lung cancer. Part 1: Assessment and conventional radiotherapy. Oncology (Williston Park). Jun. 2006;20(7):727-36. [pmid: 16841796].
15 McGarry RC, Song G, des Rosiers P, et al. Observation-only management of early stage, medically inoperable lung cancer: poor outcome. Chest. Apr. 2002;121(4):1155-8. [pmid: 11948046].
16 Raz DJ, Zell JA, Ou SH, et al. Natural history of stage I non-small cell lung cancer: implications for early detection. Chest. Jul. 2007;132(1):193-9. [pmid: 17505036].
17 Palma D, Lagerwaard F, Rodrigues G, et al. Curative Treatment of Stage I Non-small-cell Lung Cancer in Patients with Severe COPD: Stereotactic Radiotherapy Outcomes and Systematic Review. Int J Radiat Oncol Biol Phys. 2011. Jun. 1. [pmid: 21640513].
18 Mohiuddin MM, Choi NC. The role of radiation therapy in non-small cell lung cancer. Semin Respir Crit Care Med. Jun. 2005;26(3):278-88. [pmid: 16052429].
19 Patel RR, Mehta M. Three-dimensional conformal radiotherapy for lung cancer: promises and pitfalls. Curr Oncol Rep. Jul. 2002;4(4):347-53. [pmid: 12044245].
20 Powell JW, Dexter E, Scalzetti EM, et al. Treatment advances for medically inoperable non-small-cell lung cancer: emphasis on prospective trials. Lancet Oncol. Sep. 2009;10(9):885-94. [pmid: 19717090].
21 Widesott L, Amichetti M, Schwarz M. Proton therapy in lung cancer: clinical outcomes and technical issues. A systematic review. Radiother Oncol. Feb. 2008;86(2):154-64. [pmid: 18241945].
22 Heinzerling JH, Kavanagh B, Timmerman RD. Stereotactic ablative radiation therapy for primary lung tumors. Cancer J. Jan–Feb. 2011;17(1):28-32. [pmid: 21263264].
23 Martel MK. Advanced radiation treatment planning and delivery approaches for treatment of lung cancer. Hematol Oncol Clin North Am. Feb. 2004;18(1):231-43. [pmid: 15005291].
24 Low DA, Moran JM, Dempsey JF, et al. Dosimetry tools and techniques for IMRT. Med Phys. Mar. 2011;38(3):1313-38. [pmid: 21520843].
25 Santos RS, Raftopoulos Y, Keenan RJ, et al. Bronchoscopic palliation of primary lung cancer: single or multimodality therapy?. Surg Endosc. Jun. 2004;18(6):931-6. [pmid: 15108108].
26 Zhu JC, Yan TD, Morris DL. A systematic review of radiofrequency ablation for lung tumors. Ann Surg Oncol. Jun. 2008;15(6):1765-74. [pmid: 18368456].
27 Haasbeek CJ, Senan S, Smit EF, et al. Critical review of nonsurgical treatment options for stage I non-small cell lung cancer. Oncologist. Mar. 2008;13(3):309-19. [pmid: 18378542].
28 Das M, Abdelmaksoud MH, Loo BW Jr, et al. Alternatives to surgery for early stage non-small cell lung cancer-ready for prime time?. Curr Treat Options Oncol. Jun. 2010;11(1–2):24-35. [pmid: 20577833].
29 Stewart AJ, Mutyala S, Holloway CL, et al. Intraoperative seed placement for thoracic malignancy-A review of technique, indications, and published literature. Brachytherapy. Jan–Mar. 2009;8(1):63-9. [pmid: 19056322].
30 Dagnault A, Ebacher A, Vigneault E, et al. Retrospective study of 81 patients treated with brachytherapy for endobronchial primary tumor or metastasis. Brachytherapy. Jul–Sep. 2010;9(3):243-7. [pmid: 20122873].
31 Ernst A, Feller-Kopman D, Becker HD, et al. Central airway obstruction. Am J Respir Crit Care Med. Jun. 15. 2004;169(12):1278-97. [pmid: 15187010].
32 Amjadi K, Voduc N, Cruysberghs Y, et al. Impact of interventional bronchoscopy on quality of life in malignant airway obstruction. Respiration. 2008;76(4):421-8. [pmid: 18758153].
33 Morris CD, Budde JM, Godette KD, et al. Palliative management of malignant airway obstruction. Ann Thorac Surg. Dec. 2002;74(6):1928-32. discussion 32–3. [pmid: 12643375].
34 Cardona AF, Reveiz L, Ospina EG, et al. Palliative endobronchial brachytherapy for non-small cell lung cancer. Cochrane Database Syst Rev. 2008;(2):CD004284. [pmid: 18425900].
35 Yerushalmi R, Fenig E, Shitrit D, et al. Endobronchial stent for malignant airway obstructions. Isr Med Assoc J. Sep. 2006;8(9):615-7. [pmid: 17058411].
36 Maiwand MO, Asimakopoulos G. Cryosurgery for lung cancer: clinical results and technical aspects. Technol Cancer Res Treat. Apr. 2004;3(2):143-50. [pmid: 15059020].
37 Helfand M, Balshem H. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. August. 2009. Rockville, MD. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayProduct&productID=318.
38 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLo S Med. Jul. 21. 2009;6(7):e1000097. [pmid: 19621072].
39 Pham B, Klassen TP, Lawson ML, et al. Language of publication restrictions in systematic reviews gave different results depending on whether the intervention was conventional or complementary. J Clin Epidemiol. Aug. 2005;58(8):769-76. [pmid: 16086467].
40 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
41 Deeks JJ, Dinnes J, D’Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-x. 1. 173. [pmid: 14499048].
42 Carey TS, Boden SD. A critical guide to case series reports. Spine (Phila Pa 1976). Aug. 1. 2003;28(15):1631-4. [pmid: 12897483].
43 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
44 Guyatt GH, Oxman AD, Vist G, et al. GRADE guidelines: 4. Rating the quality of evidence—study limitations (risk of bias). J Clin Epidemiol. 2011;64(4):407-15. [pmid: 21247734].
45 Brown P, Brunnhuber K, Chalkidou K, et al. How to formulate research recommendations. BMJ. Oct. 14. 2006;333(7572):804-6. [pmid: 17038740].
46 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. [pmid: 21463926].
47 Iwata H, Murakami M, Demizu Y, et al. High-dose proton therapy and carbon-ion therapy for stage I nonsmall cell lung cancer. Cancer. May. 15. 2010;116(10):2476-85. [pmid: 20225229].
48 Takeda A, Sanuki N, Kunieda E, et al. Stereotactic Body Radiotherapy for Primary Lung Cancer at a Dose of 50 Gy Total in Five Fractions to the Periphery of the Planning Target Volume Calculated Using a Superposition Algorithm. International Journal of Radiation Oncology Biology Physics. 2009;73(2):442-8.
49 Shibamoto Y, Hashizume C, Baba F, et al. Stereotactic body radiotherapy using a radiobiology-based regimen for stage I nonsmall cell lung cancer: a multicenter study. Cancer. Apr. 15. 2012;118(8):2078-84. [pmid: 22009495].
50 Bogart JA. Fractionated radiotherapy for high-risk patients with early-stage non-small cell lung cancer. Semin Thorac Cardiovasc Surg. Spring. 2010;22(1):44-52. [pmid: 20813316].
51 Bradley JD, Wahab S, Lockett MA, et al. Elective nodal failures are uncommon in medically inoperable patients with Stage I non-small-cell lung carcinoma treated with limited radiotherapy fields. Int J Radiat Oncol Biol Phys. Jun. 1. 2003;56(2):342-7. [pmid: 12738307].
52 Bush DA, Slater JD, Shin BB, et al. Hypofractionated proton beam radiotherapy for stage I lung cancer. Chest. Oct. 2004;126(4):1198-203. [pmid: 15486383].
53 Kopek N, Paludan M, Petersen J, et al. Co-morbidity index predicts for mortality after stereotactic body radiotherapy for medically inoperable early-stage non-small cell lung cancer. Radiother Oncol. Dec. 2009;93(3):402-7. [pmid: 19559492].
54 Mirri MA, Arcangeli G, Benassi M, et al. Hypofractionated Conformal Radiotherapy (HCRT) for primary and metastatic lung cancers with small dimension : efficacy and toxicity. Strahlenther Onkol. Jan. 2009;185(1):27-33. [pmid: 19224144].
55 Narayan S, Henning GT, Ten Haken RK, et al. Results following treatment to doses of 92.4 or 102.9 Gy on a phase I dose escalation study for non-small cell lung cancer. Lung Cancer. Apr. 2004;44(1):79-88. [pmid: 15013586].
56 Nyman J, Johansson KA, Hulten U. Stereotactic hypofractionated radiotherapy for stage I non-small cell lung cancer--mature results for medically inoperable patients. Lung Cancer. Jan. 2006;51(1):97-103. [pmid: 16213059].
57 Ricardi U, Filippi AR, Guarneri A, et al. Stereotactic body radiation therapy for early stage non-small cell lung cancer: results of a prospective trial. Lung Cancer. Apr. 2010;68(1):72-7. [pmid: 19556022].
58 Taremi M, Hope A, Dahele M, et al. Stereotactic Body Radiotherapy for Medically Inoperable Lung Cancer: Prospective, Single-Center Study of 108 Consecutive Patients. Int J Radiat Oncol Biol Phys. 2011. Mar. 4. [pmid: 21377293].
59 Vahdat S, Oermann EK, Collins SP, et al. CyberKnife radiosurgery for inoperable stage IA non-small cell lung cancer: 18F-fluorodeoxyglucose positron emission tomography/computed tomography serial tumor response assessment. J Hematol Oncol. 2010;3:6. [pmid: 20132557].
60 Andratschke N, Zimmermann F, Boehm E, et al. Stereotactic radiotherapy of histologically proven inoperable stage I non-small cell lung cancer: Patterns of failure. Radiother Oncol. Nov. 2011;101(2):245-9. [pmid: 21724287].
61 Baumann P, Nyman J, Hoyer M, et al. Outcome in a prospective phase II trial of medically inoperable stage I non-small-cell lung cancer patients treated with stereotactic body radiotherapy. J Clin Oncol. Jul. 10. 2009;27(20):3290-6. [pmid: 19414667].
62 Baumann P, Nyman J, Lax I, et al. Factors important for efficacy of stereotactic body radiotherapy of medically inoperable stage I lung cancer. A retrospective analysis of patients treated in the Nordic countries. Acta Oncol. 2006;45(7):787-95. [pmid: 16982541].
63 Burdick MJ, Stephans KL, Reddy CA, et al. Maximum standardized uptake value from staging FDG-PET/CT does not predict treatment outcome for early-stage non-small-cell lung cancer treated with stereotactic body radiotherapy. Int J Radiat Oncol Biol Phys. Nov. 15. 2010;78(4):1033-9. [pmid: 20472359].
64 Coon D, Gokhale AS, Burton SA, et al. Fractionated stereotactic body radiation therapy in the treatment of primary, recurrent, and metastatic lung tumors: the role of positron emission tomography/computed tomography-based treatment planning. Clin Lung Cancer. Jul. 2008;9(4):217-21. [pmid: 18650169].
65 Dunlap NE, Larner JM, Read PW, et al. Size matters: a comparison of T1 and T2 peripheral non-small-cell lung cancers treated with stereotactic body radiation therapy (SBRT). J Thorac Cardiovasc Surg. Sep. 2010;140(3):583-9. [pmid: 20478576].
66 Fritz P, Kraus HJ, Blaschke T, et al. Stereotactic, high single-dose irradiation of stage I non-small cell lung cancer (NSCLC) using four-dimensional CT scans for treatment planning. Lung Cancer. May. 2008;60(2):193-9. [pmid: 18045732].
67 Olsen JR, Robinson CG, El Naqa I, et al. Dose-response for stereotactic body radiotherapy in early-stage non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. Nov. 15. 2011;81(4):e299-303. [pmid: 21477948].
68 Pennathur A, Luketich JD, Heron DE, et al. Stereotactic radiosurgery for the treatment of stage I non-small cell lung cancer in high-risk patients. J Thorac Cardiovasc Surg. Mar. 2009;137(3):597-604. [pmid: 19258073].
69 Scorsetti M, Navarria P, Facoetti A, et al. Effectiveness of stereotactic body radiotherapy in the treatment of inoperable early-stage lung cancer. Anticancer Res. Sep–Oct. 2007;27(5B):3615-9. [pmid: 17972525].
70 Song SY, Choi W, Shin SS, et al. Fractionated stereotactic body radiation therapy for medically inoperable stage I lung cancer adjacent to central large bronchus. Lung Cancer. 2009;66(1):89-93. [pmid: 19168260].
71 Stephans KL, Djemil T, Reddy CA, et al. A comparison of two stereotactic body radiation fractionation schedules for medically inoperable stage I non-small cell lung cancer: the Cleveland Clinic experience. J Thorac Oncol. Aug. 2009;4(8):976-82. [pmid: 19633473].
72 Turzer M, Brustugun OT, Waldeland E, et al. Stereotactic body radiation therapy is effective and safe in patients with early-stage non-small cell lung cancer with low performance status and severe comorbidity. Case Rep Oncol. 2011;4(1):25-34. [pmid: 21526003].
73 van der Voort van Zyp NC, Prevost JB, Hoogeman MS, et al. Stereotactic radiotherapy with real-time tumor tracking for non-small cell lung cancer: clinical outcome. Radiother Oncol. Jun. 2009;91(3):296-300. [pmid: 19297048].
74 Videtic GMM, Stephans K, Reddy C, et al. Intensity-Modulated Radiotherapy-Based Stereotactic Body Radiotherapy for Medically Inoperable Early-Stage Lung Cancer: Excellent Local Control. International Journal of Radiation Oncology Biology Physics. 2010;77(2):344-9.
75 Bollineni VR, Widder J, Pruim J, et al. Residual (18)F-FDG-PET Uptake 12 Weeks After Stereotactic Ablative Radiotherapy for Stage I Non-Small-Cell Lung Cancer Predicts Local Control. Int J Radiat Oncol Biol Phys. Jul. 15. 2012;83(4):e551-5. [pmid: 22417800].
76 Campeau MP, Herschtal A, Wheeler G, et al. Local control and survival following concomitant chemoradiotherapy in inoperable stage I non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. Aug. 1. 2009;74(5):1371-5. [pmid: 19250769].
77 Graham PH, Vinod SK, Hui AC. Stage I non-small cell lung cancer: results for surgery in a patterns-of-care study in Sydney and for high-dose concurrent end-phase boost accelerated radiotherapy. J Thorac Oncol. Oct. 2006;1(8):796-801. [pmid: 17409962].
78 Jimenez MF, van Baardwijk A, Aerts HJ, et al. Effectiveness of surgery and individualized high-dose hyperfractionated accelerated radiotherapy on survival in clinical stage I non-small cell lung cancer. A propensity score matched analysis. Radiother Oncol. Dec. 2010;97(3):413-7. [pmid: 20851487].
79 Nakayama H, Sugahara S, Tokita M, et al. Proton beam therapy for patients with medically inoperable stage I non-small-cell lung cancer at the university of tsukuba. Int J Radiat Oncol Biol Phys. Oct. 1. 2010;78(2):467-71. [pmid: 20056349].
80 Pennathur A, Luketich JD, Abbas G, et al. Radiofrequency ablation for the treatment of stage I non-small cell lung cancer in high-risk patients. J Thorac Cardiovasc Surg. Oct. 2007;134(4):857-64. [pmid: 17903496].
81 Chen VJ, Oermann E, Vahdat S, et al. CyberKnife with Tumor Tracking: An Effective Treatment for High-Risk Surgical Patients with Stage I Non-Small Cell Lung Cancer. Front Oncol. 2012;2:9. [pmid: 22655258].
82 Lagerwaard FJ, Verstegen NE, Haasbeek CJ, et al. Outcomes of Stereotactic Ablative Radiotherapy in Patients with Potentially Operable Stage I Non-Small-Cell Lung Cancer. Int J Radiat Oncol Biol Phys. 2011. Nov. 19. [pmid: 22104360].
83 Onishi H, Shirato H, Nagata Y, et al. Stereotactic body radiotherapy (SBRT) for operable stage I non-small-cell lung cancer: can SBRT be comparable to surgery?. Int J Radiat Oncol Biol Phys. Dec. 1. 2011;81(5):1352-8. [pmid: 20638194].
84 Onishi H, Shirato H, Nagata Y, et al. Hypofractionated stereotactic radiotherapy (HypoFXSRT) for stage I non-small cell lung cancer: updated results of 257 patients in a Japanese multi-institutional study. J Thorac Oncol. Jul. 2007;2(7 Suppl 3):S94-100. [pmid: 17603311].
85 Mallick I, Sharma SC, Behera D, et al. Optimization of dose and fractionation of endobronchial brachytherapy with or without external radiation in the palliative management of non-small cell lung cancer: a prospective randomized study. J Cancer Res Ther. Jul–Sep. 2006;2(3):119-25. [pmid: 17998689].
86 Langendijk H, de Jong J, Tjwa M, et al. External irradiation versus external irradiation plus endobronchial brachytherapy in inoperable non-small cell lung cancer: a prospective randomized study. Radiother Oncol. Mar. 2001;58(3):257-68. [pmid: 11230886].
87 Stout R, Barber P, Burt P, et al. Clinical and quality of life outcomes in the first United Kingdom randomized trial of endobronchial brachytherapy (intraluminal radiotherapy) vs. external beam radiotherapy in the palliative treatment of inoperable non-small cell lung cancer. Radiother Oncol. Sep. 2000;56(3):323-7. [pmid: 10974381].
88 Chella A, Ambrogi MC, Ribechini A, et al. Combined Nd-YAG laser/HDR brachytherapy versus Nd-YAG laser only in malignant central airway involvement: a prospective randomized study. Lung Cancer. Mar. 2000;27(3):169-75. [pmid: 10699690].
89 Diaz-Jimenez JP, Martinez-Ballarin JE, Llunell A, et al. Efficacy and safety of photodynamic therapy versus Nd-YAG laser resection in NSCLC with airway obstruction. Eur Respir J. Oct. 1999;14(4):800-5. [pmid: 10573224].
90 Boxem T, Muller M, Venmans B, et al. Nd-YAG laser vs bronchoscopic electrocautery for palliation of symptomatic airway obstruction: a cost-effectiveness study. Chest. Oct. 1999;116(4):1108-12. [pmid: 10531180].
91 Lencioni R, Crocetti L, Cioni R, et al. Response to radiofrequency ablation of pulmonary tumours: a prospective, intention-to-treat, multicentre clinical trial (the RAPTURE study). Lancet Oncol. Jul. 2008;9(7):621-8. [pmid: 18565793].
92 Allison R, Sibata C, Sarma K, et al. High-dose-rate brachytherapy in combination with stenting offers a rapid and statistically significant improvement in quality of life for patients with endobronchial recurrence. Cancer J. Nov–Dec. 2004;10(6):368-73. [pmid: 15701268].
93 Chhajed PN, Baty F, Pless M, et al. Outcome of treated advanced non-small cell lung cancer with and without central airway obstruction. Chest. Dec. 2006;130(6):1803-7. [pmid: 17167000].
94 Celebioglu B, Gurkan OU, Erdogan S, et al. High dose rate endobronchial brachytherapy effectively palliates symptoms due to inoperable lung cancer. Jpn J Clin Oncol. Nov. 2002;32(11):443-8. [pmid: 12499415].
95 Aumont-le Guilcher M, Prevost B, Sunyach MP, et al. High-dose-rate brachytherapy for non-small-cell lung carcinoma: a retrospective study of 226 patients. Int J Radiat Oncol Biol Phys. Mar. 15. 2011;79(4):1112-6. [pmid: 20510543].
96 Petera J, Spasova I, Neumanova R, et al. High dose rate intraluminal brachytherapy in the treatment of malignant airway obstructions. Neoplasma. 2001;48(2):148-53. [pmid: 11478697].
97 Jones BU, Helmy M, Brenner M, et al. Photodynamic therapy for patients with advanced non-small-cell carcinoma of the lung. Clinical Lung Cancer. 2001;3(1):37-41. [pmid: 14656388].
98 Muto P, Ravo V, Panelli G, et al. High-dose rate brachytherapy of bronchial cancer: treatment optimization using three schemes of therapy. Oncologist. 2000;5(3):209-14. [pmid: 10884499].
99 Vucicevic S, Stankovic J, Jovanovic N, et al. Combined high-dose rate brachytherapy and external beam irradiation for non-small cell lung carcinoma. Journal of B.U.ON. 1999;4(4):377-82.
100 Celikoglu F, Celikoglu SI, York AM, et al. Intratumoral administration of cisplatin through a bronchoscope followed by irradiation for treatment of inoperable non-small cell obstructive lung cancer. Lung Cancer. Feb. 2006;51(2):225-36. [pmid: 16359751].
101 Weinberg BD, Allison RR, Sibata C, et al. Results of combined photodynamic therapy (PDT) and high dose rate brachytherapy (HDR) in treatment of obstructive endobronchial non-small cell lung cancer (NSCLC). Photodiagnosis Photodyn Ther. Mar. 2010;7(1):50-8. [pmid: 20230994].
102 Moghissi K, Bond MG, Sambrook RJ, et al. Treatment of endotracheal or endobronchial obstruction by non-small cell lung cancer: lack of patients in an MRC randomized trial leaves key questions unanswered. Medical Research Council Lung Cancer Working Party. 1999. www.mrw.interscience.wiley.com/cochrane/clcentral/articles/873/CN-00166873/frame.html.
103 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):502-12. [pmid: 18823754].
104 Tipton KN, Sullivan N, Bruening W, et al. Stereotactic Body Radiation Therapy. Rockville (MD). 2011.
105 Kvale PA, Selecky PA, Prakash UB. Palliative care in lung cancer: ACCP evidence-based clinical practice guidelines (2nd edition). Chest. Sep. 2007;132(3 Suppl):368S-403S. [pmid: 17873181].
106 Comabella CCi, Gibbons E, Fitzpatrick R. A Structured Review of Patient-Reported Outcome Measures for Patients With Lung Cancer, 2010-Report to the Department of Health, 2010. University of Oxford. UK. 2010.
107 Pan H, Rose BS, Simpson DR, et al. Clinical Practice Patterns of Lung Stereotactic Body Radiation Therapy in the United States: A Secondary Analysis. Am J Clin Oncol. 2012. Apr. 6. [pmid: 22495454].
108 Pan H, Simpson DR, Mell LK, et al. A survey of stereotactic body radiotherapy use in the United States. Cancer. Oct. 1. 2011;117(19):4566-72. [pmid: 21412761].
109 Dupuy DE. Image-guided thermal ablation of lung malignancies. Radiology. Sep. 2011;260(3):633-55. [pmid: 21846760].
110 Goldberg SN, Hahn PF, Tanabe KK, et al. Percutaneous radiofrequency tissue ablation: does perfusion-mediated tissue cooling limit coagulation necrosis?. J Vasc Interv Radiol. Jan–Feb. 1998;9(1 Pt 1):101-11. [pmid: 9468403].
111 Gomez FM, Palussiere J, Santos E, et al. Radiofrequency thermocoagulation of lung tumours. Where we are, where we are headed. Clin Transl Oncol. Jan. 2009;11(1):28-34. [pmid: 19155201].
112 Nguyen NP, Garland L, Welsh J, et al. Can stereotactic fractionated radiation therapy become the standard of care for early stage non-small cell lung carcinoma. Cancer Treat Rev. Dec. 2008;34(8):719-27. [pmid: 18657910].
113 Lee P, Kupeli E, Mehta AC. Therapeutic bronchoscopy in lung cancer. Laser therapy, electrocautery, brachytherapy, stents, and photodynamic therapy. Clin Chest Med. Mar. 2002;23(1):241-56. [pmid: 11901914].
114 Gliklich REDN, editor. Registries for Evaluating Patient Outcomes: A User’s Guide. (Prepared by Outcome DEcIDE Center [Outcome Sciences, Inc. dba Outcome] under Contract No. 290-2005-0035-I AHRQ Publication No. 07-EHC-001-1. Rockville, MD. Agency for Healthcare Research and Quality. April. 2007. www.effectivehealthcare.ahrq.gov/repFiles/PatOutcomes.pdf.