# Methods

This chapter describes the methods used to produce this comparative effectiveness review (CER). Methodological practices followed in this review were derived from the Methods Guide37 and its subsequent updates. The main sections in this chapter reflect the elements of the protocol established for the CER; certain methods map to the Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) checklist.38

## Topic Refinement and Review Protocol

The topic for this report and preliminary Key Questions arose through a public process involving the public and various stakeholder groups. Initially a panel of Key Informants gave input on draft Key Questions. Key Informants are the end users of research, including patients and caregivers, practicing clinicians, relevant professional and consumer organizations, purchasers of health care, and others with experience in making health care decisions. Within the Evidence-based Practice Center (EPC) program, the role of Key Informant is to provide input in identifying relevant Key Questions for research that inform healthcare decisions. The EPC solicits input from the Key Informants when developing questions for systematic review or when identifying high priority research gaps and to identify topics for future research. Key Informants were not involved in analyzing the evidence or writing the report and have not reviewed the report except through the peer or public review mechanism. Key Informants had to disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. The Agency for Healthcare Research and Quality (AHRQ) Task Order Officer (TOO) and the EPC worked to balance, manage, or mitigate any potential conflicts of interest identified.

The draft Key Questions were posted on AHRQ’s website for public comment on October 5, 2011 for 4 weeks. During this period, the EPC drafted a protocol for the CER and recruited a Technical Expert Panel (TEP) that comprised individuals with clinical expertise in radiation oncology, thoracic surgery and surgical oncology, pulmonology, and general oncology. The TEP provided input throughout the development of the review but was not involved in subsequent evidence analysis or drafting the report.

We received comments on the draft Key Questions, scope, and content of the proposed CER from several individuals and specialty societies. We addressed all the comments in discussions with the TOO and during conference calls with the TEP. Specifically, we eliminated a Key Question aimed at “technically inoperable” patients, and expanded the list of adverse events (AEs) we would attempt to capture for each intervention. The final protocol was posted on AHRQ’s website on February 22, 2012.

## Literature Search Strategy

### Search Strategy

The databases listed below were searched electronically by a medical librarian for citations from January 1995 through July 25, 2012:

- MEDLINE^®^
- Embase^®^
- Cochrane Controlled Trials Register

The search was limited to English language studies based on the following rationale. First, evidence suggests that language restrictions do not change results of systematic review for conventional medical interventions.39 Second, input from the TEP suggested that most if not all of the pivotal studies in this area would be captured in the English language evidence base and that restriction to English language would not introduce bias.

Our search strategy used the National Library of Medicine’s Medical Subject Headings (MeSH^®^) keyword nomenclature developed for MEDLINE^®^ and adapted for use in other databases. The searches were limited to studies of human subjects and those published in English. The full search strings and strategies can be found in Appendix A.

### Grey Literature

Grey literature was sought by searching for clinical trials (Clinicaltrials.gov), the Food and Drug Administration website, and relevant conference abstracts (American Society of Clinical Oncology, and American Society for Radiation Oncology). We limited the grey literature search until 2010. We reviewed Scientific Information Packets provided by the Scientific Resource Center. Study authors were not contacted for unpublished results. Our goal was to include only phase 3 randomized controlled trials (RCTs) that we had not identified in our main electronic or hand searches.

## Study Selection

### Inclusion Criteria

Studies of any design were included if they fulfilled all of the following inclusion criteria.

#### Key Questions 1 and 2

1. Inclusion of medically inoperable NSCLC stage I patients (T1N0M0 and T2 N0M0) or medically operable NSCLC stage I patients (T1N0M0 and T2N0M0) who refuse surgery.
2. Such patients received only 1 of the following interventions:
  - Conformal radiotherapy methods (including stereotactic body radiotherapy (SBRT), three-dimensional conformal radiotherapy (3DRT), intensity-modulated radiotherapy (IMRT))
  - Proton beam radiotherapy (PBRT)
  - Radiofrequency ablation (RFA)
3. Reported data on one or more of the following outcome data for such patients:
  - Survival outcome (overall survival or cancer-specific survival)
  - Local control (an outcome defined as the arrest of cancer growth at the site of origin)
  - Pulmonary quality of life (QOL)
  - AEs

#### Key Question 3

1. Inclusion of NSCLC patients of any stage with a symptomatic endoluminal obstruction.
2. Such patients received 1 or more of the following interventions:
  - Conformal radiotherapy methods (including SBRT, 3DRT, IMRT)
  - Conventional 2D external beam radiotherapy (2DRT)
  - PBRT
  - RFA
  - Brachytherapy
  - Cryoablation
  - Laser Therapy
  - Electrocautery
  - Endobronchial debridement and stents
3. Reported data on one or more of the following outcome data for such patients:
  - Survival outcome (overall survival or disease specific survival)
  - Local control (an outcome defined as the arrest of cancer growth at the site of origin)
  - Symptom relief
  - Pulmonary QOL
  - AEs

### Exclusion Criteria

- Editorials, commentaries, abstracts, animal studies, case report, non-English language and diagnostic accuracy study.
- On advice of our TEP, primary studies published prior to January 1, 1995 were excluded, to assure we considered current techniques and methods.
- Other reasons used to exclude studies were based on an assessment of the presence of duplicate patients in more than one paper; in that event, we included the article that included the same patients at longest follow up, cross-indexing that in the abstraction tables.
- No definitive surgical intervention was considered for any Key Question.
- For Key Questions 1 and 2, we compared single interventions, for example two different conformal radiotherapy methods, or RFA compared with a conformal radiotherapy method. We excluded studies that used any post-intervention systemic (e.g., chemotherapy) or local nonsurgical therapy but did not define the therapy or disaggregate the clinical outcomes of such patients.

A list of excluded primary studies and reasons for exclusion is provided in Appendix B.

### Study Selection Process

Electronic search results were transferred to EndNote^®^ and subsequently into Distiller SR^®^ for study screening and selection. Using the study selection criteria (outlined above in this section) for screening titles and abstracts, each citation was marked as: 1) eligible for review as full-text articles; or 2) ineligible for full-text review. At least one training set (n=100) of representative titles and abstracts for each Key Question was examined initially by all team members to assure uniform application of screening criteria. A subsequent set was assessed to establish concordance among the team. Title and abstract screening was performed by two junior and one senior level team members. A reference was excluded only when both team members made independent decision to exclude it. In case of disagreement, the team leader adjudicated in consensus with all team members.

A test set of three references relevant to the three Key Questions was evaluated in full-text by junior and senior team members, including the team leader, to ensure selection criteria were applied correctly. Subsequently, two junior team members and the team leader reviewed full-text articles independently to determine their inclusion in the systematic review. The reason for exclusion of each full-text article reviewed was recorded in the Distiller SR^®^ database. A paper could have been excluded for multiple reasons but only one reason was recorded. Team meetings were held regularly to discuss progress and to ensure the team leader was aware of difficulties or problems in this process. The process is shown schematically in Figure 3.

Figure 3 Schematic for data management

This figure depicts the data management steps for the systematic review. The process starts with title and abstract screening, then onto full text screening, then proceeds onto data abstraction, the creation of summary evidence tables and ends with data synthesis.

## Data Extraction and Management

The main data elements for the CER were abstracted directly into Microsoft Word^®^ tables. Other elements and the study risk of bias assessments were abstracted in Distiller SR.^®^ A data abstraction guide was created that detailed the process of abstraction of data and definition of key data elements to ensure accuracy and consistency in data abstraction procedure across the team. The evidence tables were divided by Key Question and assigned for abstraction to all team members. One reviewer performed primary data abstraction of all data elements into the evidence tables, and a second reviewer reviewed the articles and evidence tables for accuracy. Disagreements were resolved by discussion, and if necessary, by consultation with a third reviewer.

### Data Elements

- Study Attributes
  ○ Design
  ○ Author
  ○ Country
  ○ Year
  ○ Study start date
  ○ Study end date
  ○ Study setting
  ○ Treatment setting
  ○ Institution setting(s):
  ○ Criteria for staging:
  ○ Conflict of interest
  ○ Study funding
- Patient Characteristics
  ○ Patients Enrollment numbers
  ○ Lost to followup/Excluded
  ○ Inclusion/Exclusion Criteria
  ○ Stage Distribution
  ○ Tumor Location
  ○ Tumor Histopathology
  ○ Age
  ○ Women
  ○ Race
  ○ Comorbidities
  ○ Performance status
  ○ Histopathology confirmation
- Study Objective
- Primary Outcome
- Secondary Outcome(s)
- List of Outcome(s)
- Cause of Death
- Length of Followup
- Treatment Details
  ○ Intervention name
  ○ Vendor name
  ○ Dose/frequency/details
  ○ Technical details
  ○ Treatment Intention
- Followup and Evaluation Criteria
- Study Outcomes
  ○ Survival
    ■ Overall survival
    ■ Disease-specific survival
    ■ Local control
  ○ Lung Outcomes
    ■ Lung function
    ■ Obstructive symptoms
    ■ QOL
    ■ Performance status
    ■ Others
  ○ AEs

## Quality (Risk of Bias) Assessment of Individual Studies

In adherence with the Methods Guide,37 the risk of bias of individual comparative studies was assessed by the U.S. Preventive Services Task Force (USPSTF) criteria.40 The quality of the abstracted studies was assessed by one reviewer, and examined by the senior team member. Assessment of the quality of included nonrandomized comparative intervention studies by this approach was informed by a selection of items proposed by Deeks et al.41

- The quality of comparative studies was assessed on the basis of the following criteria:
  ○ Initial assembly of comparable groups: adequate randomization, including concealment and whether potential confounders (e.g., other concomitant care) were distributed equally among groups.
  ○ Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination).
  ○ Important differential loss to followup or overall high loss to followup.
  ○ Measurements: equal, reliable, and valid (includes masking of outcome assessment).
  ○ Clear definition of interventions.
  ○ All important outcomes considered.
  ○ Analysis:
    ■ For RCTs: intention-to-treat, covariate adjustment
    ■ For cohort studies: adjustment for potential confounders for cohort studies

Comparative studies were rated according to one of three quality categories:

Good. Meets all criteria; comparable groups are assembled initially and maintained throughout the study (followup at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis was used for RCTs.

Fair. Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: In general, comparable groups are assembled initially, but some questions remain about whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and are generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis has been done for RCTs.

Poor. Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups; and key confounders are given little or no attention; lack of masked outcome assessment; and for RCTs, intention-to-treat analysis is lacking.

The quality of the single-arm intervention studies was assessed by Carey and Boden criteria.42 These include eight criteria, which are as follows:

1. Clearly defined study questions
2. Well-described study population
3. Well-described intervention
4. Use of validated outcome measures
5. Appropriate statistical analyses
6. Well-described results
7. Discussion and conclusion supported by data
8. Acknowledgement of the funding source

We created thresholds for converting the Carey and Boden risk assessment tool into the AHRQ format of standard quality ratings (good, fair, and poor). This allowed us to differentiate the quality of single-arm studies as good, fair, or poor. For a study to be ranked good quality, all eight Carey and Boden criteria mentioned above had to be met. For a fair quality assessment, 7 of 8 criteria had to be met. A study that met fewer than 7 of 8 criteria was rated as poor quality. These quality rankings for these studies can be found in Appendix C.

## Data Synthesis

Given the lack of appropriate comparative studies for all Key Questions, this evidence review did not incorporate formal data synthesis involving meta-analysis. The quality of individual studies was assessed as outlined above, and the strength of the body of evidence for each Key Question was evaluated as follows.

## Strength of the Body of Evidence

We graded the strength of the overall body of evidence for overall survival, symptom relief, quality of life and harms. The system used for rating the strength of the overall body of evidence is outlined in the AHRQ Methods Guide37 and based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.43 Further, we also used the GRADE guideline on assessing the risk of bias.44 This system explicitly addressed four required domains: risk of bias, consistency, directness, and precision. Two independent reviewers rated all studies on domain scores and resolved disagreements by consensus discussion; the same reviewers also used the domain scores to assign an overall strength of evidence (SOE) grade.

The process of grading the body of evidence43 was as follows. A body of evidence represented by RCT(s) would have a starting strength of high. A body of evidence represented by nonrandomized comparative studies would generally have a starting strength of low. For all study designs, the strength of evidence would be reduced by one level if there was high risk of bias, inconsistency or unknown consistency, indirectness and imprecision. Further, based on GRADE guidelines on assessing the risk of bias,44 when the evidence was generated from studies that had very serious risk of bias, the strength of evidence was rated down by two levels. Case series or single-arm studies were deemed “indirect,” “imprecise” and “unknown” for the domains of “directness,” “precision” and “consistency.”

The grade of evidence strength was classified into the following four categories:

- High. High confidence that the evidence reflected the true effect. Further research was very unlikely to change our confidence in the estimate of effect.
- Moderate. Moderate confidence that the evidence reflected the true effect. Further research may have changed our confidence in the estimate of effect and may have changed the estimate.
- Low. Low confidence that the evidence reflected the true effect. Further research was likely to change our confidence in the estimate of effect and was likely to change the estimate.
- Insufficient. Evidence was either unavailable or did not permit estimation of an effect.

Additional domains including strength of association, publication bias, coherence, dose-response relationship, and residual confounding were not addressed in this review.

## Applicability

Applicability of findings in this review was assessed according to the AHRQ Comparative Effectiveness Methods Guide using the PICOTS (Population, Intervention, Comparator, Outcome, Timing, Setting) framework.37,45,46 Included studies were assessed for relevance against target populations, interventions and comparators of interest, and outcomes of interest.

## Peer Review and Public Commentary

Peer Reviewers were invited to provide written comments on the draft report based on their clinical, content, or methodological expertise. Peer review comments on the preliminary draft of the report were considered by the EPC in preparation of the final draft of the report. Peer Reviewers did not participate in writing or editing of the final report or other products. The synthesis of the scientific literature presented in the final report does not necessarily represent the views of individual reviewers. The dispositions of the peer review comments were documented and published after the publication of the evidence report.

Potential reviewers disclosed any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Invited Peer Reviewers did not have any financial conflict of interest greater than $10,000. Peer Reviewers who disclose potential business or professional conflicts of interest could submit comments on draft report through the public comment mechanism.