# Introduction

## Background

### Non–Small-Cell Lung Cancer (NSCLC)

NSCLC refers to any type of epithelial lung cancer other than small-cell lung cancer.1 The disease arises from epithelial cells of the lung, from the central bronchi to terminal alveoli. The histological type correlates with site of origin, reflecting the variation in respiratory tract epithelium by location. The most common types of NSCLC are adenocarcinoma, squamous cell carcinoma, and large cell carcinoma, but several other types occur less frequently; all types can occur in unusual histological variants. Squamous cell carcinoma typically originates near a central bronchus. Adenocarcinoma and adenocarcinoma in situ (formerly bronchioloalveolar carcinoma) usually arise in peripheral lung tissue. Adenocarcinomas are frequently associated with cigarette smoke, but may occur in patients who have never smoked.

Over 1 million deaths are attributed per year to NSCLC, making it the leading cause of cancer-related mortality worldwide.2 In the United States, lung cancer is the leading cause of cancer death, and in 2010, an estimated 222,520 cases were expected to be diagnosed, with 157,300 deaths due to the disease.2

NSCLC may be symptomatic at presentation or it may be incidentally discovered at a routine chest imaging examination. The most common symptoms at presentation are progressive cough or chest pain. Other presenting symptoms include hemoptysis, malaise, weight loss, dyspnea, and hoarseness. Symptoms may result from local invasion or compression of adjacent thoracic structures such as compression involving the esophagus causing dysphagia, compression of laryngeal nerves causing hoarseness, or compression of the superior vena cava causing facial edema and distension of the superficial veins of the head and neck. Symptoms from distant metastases may also be present and include neurological defect or personality change from brain metastases or pain from bone metastases. Physical examination may identify enlarged supraclavicular lymphadenopathy, pleural effusion or lobar collapse, unresolved pneumonia, or signs of associated disease such as chronic obstructive pulmonary disease or pulmonary fibrosis.

#### NSCLC Staging

The prognosis of an NSCLC patient, and the subsequent treatment plan, are a function of disease stage.3 NSCLC stage is defined by the TNM system, which was initially developed by the Union Internationale Contre le Cancer (UICC) and the American Joint Committee for Cancer Staging (AJCC). The TNM system takes into account the size of the primary tumor (T); the extent of regional lymph node involvement (N); and, the presence or absence of distant metastases (M).4 The current Revised International System for Staging Lung Cancer, based on information from a clinical database of nearly 70,000 patients, was subsequently adopted by the AJCC and UICC.4 Current TNM staging groups are summarized in Table 1.

Table 1 TNM staging groups

Overall Stage | T | N | M
Stage 0 | Tis (in situ) | N0 | M0
Stage IA | T1a, b | N0 | M0
Stage IB | T2a | N0 | M0
Stage IIA | T1a, b T2a T2b | N1 N1 N0 | M0 M0 M0
Stage IIB | T2b T3 | N1 N0 | M0 M0
Stage IIIA | T1, T2 T3 T4 | N2 N1, N2 N0, N1 | M0 M0 M0
Stage IIIB | T4 Any T | N2 N3 | M0 M0
Stage IV | Any T | Any N | M 1a, b

M = presence of absence of distant metastases; N = extent of regional lymph node involvement; T = size of the primary tumor

Imaging methods used to stage NSCLC patients may include 18F-fluorodeoxyglucose positron emission tomography (FDG PET), computed tomography (CT) or magnetic resonance imaging (MRI).5 The presence of symptoms, physical signs, laboratory findings, or perceived risk of distant metastasis ultimately drives evaluation for nodal and distant metastatic disease. Bone scans, FDG PET, CT, or MRI may be performed if initial assessments suggest nodal or more distant metastases or if a patient with more advanced disease is under consideration for aggressive local nonsurgical and combined modality treatments. Surgical staging of the mediastinum is considered the standard to evaluate local nodal status.

#### Treatment Options for NSCLC

Patients who are diagnosed with NSCLC can be divided into three general groups that reflect the extent of disease, which in turn dictates the initial treatment approach, not considering systemic therapies, which are not typically used in this setting until or unless a patient develops recurrence or distal disease:

- Surgically resectable disease (generally stage I, stage II, and selected stage III tumors).
- Potentially operable or inoperable locally (T3–T4) or regionally (N2–N3) advanced disease.
- Inoperable distant metastatic disease (includes distant metastases [M1] that are found at the time of diagnosis).

##### Surgical Resection for Stage I NSCLC

Based on the International Association for the Study of Lung Cancer (IASLC) database of more than 100,000 patients treated between 1990 and 2002, about 20–−25 percent of NSCLC patients present with stage I (T1N0M0, T2N0M0) disease.6 Resection is considered the standard of care for surgically eligible patients in this setting. This would preferably be a lobectomy for most patients, alternatively a pneumonectomy for tumors in which sleeve resection or bronchoplasty would not allow achievement of adequate margins.7 Data from the IASLC database of patients shows 5-year overall survival rates may range from 71 to 77 percent for stage IA NSCLC and 35 to 58 percent for stage IB disease.8 Improvements in the use of staging methods including FDG PET and CT have led to improved surgical outcomes, exemplified by a report including 405 stage IA and Stage IB patients who had a 5-year overall survival of 80 percent and 72 percent, respectively.9

A comprehensive preoperative assessment must be performed to assess the risk for morbidity and mortality in NSCLC stage I patients being considered for curative-intent surgery.10 Surgical morbidity and mortality are typically low in most modern series in the stage I setting, with major complications reported in about 6 percent of lobectomy cases and 18 percent in pneumonectomy cases.11 The estimated risk of surgical mortality should be less than 4 percent for lobectomy and less than 9 percent for pneumonectomy in order to proceed to surgery.7,10

##### Local Nonsurgical Treatment Options for Stage I NSCLC

Surgery is the standard of care for patients with resectable stage I NSCLC. However, alternative treatments are needed for two subsets of stage I NSCLC patients. First is a subset that comprises about 20–30 percent of stage I patients, who have resectable tumors but are deemed medically inoperable due to comorbidities such as diminished cardiac reserve, poor pulmonary function, and poor performance status.7,12–14 A second, much less common subset comprises patients who are deemed operable but decline surgery. Medically inoperable patients are more likely to die from intercurrent illness than from lung cancer; however, evidence exists to question this assumption.7 For example, among a group of 128 patients with stage I or II NSCLC treated between 1994 and 1999, 49 received no treatment because they were deemed medically inoperable; 53 percent of the latter succumbed to lung cancer.15 Among 1,432 untreated medically inoperable stage I NSCLC patients reported to a registry in California, the lung cancer-specific survival rate at 5 years was 16 percent, suggesting the need for alternative interventions in such patients.16

A recent systematic review reported postsurgical 30-day mortality ranged from 7 percent to 25 percent among patients with poor ventilatory function, with a weighted mean of 10 percent.17 These patients would not be considered for surgery, but would be offered nonsurgical options that are outlined in the following section of this report.

###### Radiotherapy

External-beam radiotherapy (EBRT) has a role in the definitive treatment of patients with stage I NSCLC who are deemed medically inoperable, or in those who decline surgery.7,13 Ideally, EBRT balances delivery of a cytotoxic dose of ionizing radiation to the tumor volume, attempting to minimize adverse effects (AEs) of radiation on adjacent normal lung tissue and thoracic structures. A “standard” total dose is typically 60 to 70 Gray (Gy), delivered in increments (fractions) over variable periods, depending on the technology that is used and the therapeutic intent. All available radiotherapy platforms use a medical linear accelerator to deliver photon radiation, typically in the energy range of 6–10 MeV. Several modalities have been used to treat patients with stage I NSCLC, as follows.

###### Conventional Two-Dimensional External-Beam Radiotherapy (2DRT)

Conventional wide-field 2DRT has been used extensively to treat medically inoperable patients with stage I NSCLC. Delivery of radiation to a total dose that ranged from 31 to 103 Gy, in daily fractions of 1.8–2 Gy, has been reported to produce overall survival rates of 17 percent to 42 percent among patients with early stage disease.14 However, this technique is no longer in routine use in modern radiation oncology practice in this setting. Thus, it was not considered for the stage I setting in this comparative effectiveness review (CER).

###### External-Beam Conformal Radiotherapy Options

A quest to improve upon survival rates achieved with conventional 2DRT has led to development of conformal radiotherapy methods for definitive (curative) treatment of inoperable patients with stage I NSCLC. Conformal radiotherapy refers to modalities in which cytotoxic radiation beams are “shaped” to cover the tumor volume plus a surrounding tissue margin to treat microscopic disease that may reside there. Photon-based modalities include three-dimensional conformal radiation therapy (3DRT); intensity-modulated radiation therapy (IMRT); and stereotactic body radiation therapy (SBRT), which is also known as stereotactic ablative radiotherapy.18–20 For purposes of this report, we will use the term “SBRT.” Charged particle-based therapy such as proton beam radiotherapy (PBRT) is also available.21

###### Three-dimensional Conformal Radiation Therapy (3DRT)

3DRT employs CT simulation, allowing for more accurate dose calculations by taking into account axial anatomy and complex tissue contours. Three-dimensional anatomic information from diagnostic CT scans are used to deliver multiple highly focused beams of radiation that converge at the tumor site.12 This allows accurate and precise conformity of the radiation to the tumor volume, with very rapid dose fall-off in surrounding normal lung parenchyma. A 3DRT treatment protocol typically comprises 25–40 fractions (usually 1.8–2 Gy) delivered over a period of 5–10 weeks.

###### Intensity-Modulated Radiation Therapy (IMRT)

IMRT allows for the modulation of both the number of fields and the intensity of radiation within each field, allowing for greater control of the dose distribution to the target.17,20,21 A potential theoretical benefit of IMRT is the ability to deliver higher doses to the tumor than with other methods, with greater tumoricidal effectiveness. A typical total dose of 60 to 70 Gy is usually delivered in 25–40 fractions over a period of 5–10 weeks. Dose-volume histogram studies suggest IMRT allows better conformality of the high-dose volume to the tumor. However, questions continue about the relative benefits and harms of this technique because a larger volume of lung receives a low radiation dose with IMRT, which may actually increase the rate of injury.19

###### Stereotactic Body Radiation Therapy (SBRT)

SBRT delivers very high, conformal ablative doses of radiation in fewer treatment sessions than other conformal modalities, with the potential to cause less damage to surrounding normal tissue.22 SBRT regimens generally deliver a total dose of 60 Gy at greater than 10 Gy per fraction. Four-dimensional monitoring of tumor motion during the breathing cycle is accomplished by using a number of imaging techniques (CT, X-ray, ultrasound) that depend on the platform, tracking on bony structures or implanted fiducials. SBRT can deliver very high biologically effective doses (BED) above 100 Gray equivalent (GyE) that are needed to ablate the tumor and sterilize the tumor margins, minimizing damage to adjacent normal tissue. Conventionally fractionated schemes, delivering a similar total dose in 25–40 fractions, typically do not reach a similar BED range.

###### Proton Beam Radiotherapy (PBRT)

PBRT delivers high doses of radiation to the tumor. Proton beams enter the body with a low radiation dose, stop at the tumor, match its shape and volume or depth, and deposit the bulk of their cytotoxic energy within the tumor; thus this type of treatment may cause less damage to surrounding healthy tissue.21 Analysis of the application of PBRT to NSCLC presents challenges secondary to the small number of institutions that have experience with this technique and small reported patient numbers.21

###### Summary: Radiotherapy

The optimal definitive external radiotherapy modality is not defined for patients with medical contraindications (medically inoperable patients) or for those with stage I NSCLC who elect nonsurgical treatment.20 3DRT and IMRT are distinguished from SBRT therapeutically primarily as a function of the fractionation schemes employed and the higher BED delivered to the tumor with SBRT compared to either 3DRT or IMRT. Technological distinctions include the methods or equipment used in patient positioning, patient immobilization, tumor tracking methods, control systems, beam collimation, and treatment-planning software. Conformal radiotherapy procedures are generally time-intensive, require significant training, and necessitate substantial advance planning.19,23 Institutional quality control processes are required to assure their safe and effective use, in particular IMRT.24

###### Interventional Treatment Options

Interventional treatment options for stage I NSCLC include radiofrequency ablation (RFA).22,25 Percutaneous RFA is a minimally invasive technique that uses high-frequency electric currents to heat and destroy tumor and is typically performed in a single session.26 The most frequent complication of RFA is pneumothorax.27

Analysis of the application of RFA to NSCLC presents challenges secondary to the small number of institutions that have experience with this technique and limited patient data.21,26,28

Earlier brachytherapy was used as a definitive treatment of stage I nonsurgical patients, but is now considered appropriate only as an adjunct to surgery.29 It was not considered in the stage I setting in this CER.

##### Local Nonsurgical Treatment Options for Symptomatic Malignant Endobronchial NSCLC

About 20 percent to 30 percent of NSCLC patients experience airway obstruction from non-resectable primary or recurrent lesions, with symptoms that may include disabling dyspnea, cough, and hemoptysis.30,31 Up to 40 percent of lung cancer deaths may be attributed to such locoregional disease. Management of these patients is a significant challenge. The ability to promptly alleviate airway distress may be lifesaving, as some patients may succumb to suffocation within hours of presentation.31–33 Patients in this situation often require emergency treatment to relieve airway obstruction or to stop bleeding. Intervention typically is palliative, but may be performed with curative intent in some cases.

###### Radiotherapy

Patients with good performance status may benefit from EBRT (conventional 2DRT or conformal methods outlined above) to quickly ameliorate symptoms (e.g., hemoptysis, cough, chest pain, dyspnea, obstructive pneumonia, dysphagia, etc.) associated with an airway obstructive tumor.33 However, if they have already been heavily pretreated or the tumor is located close to radiosensitive organs or other anatomic structures, interventional options may become necessary.

###### Interventional Options

###### Brachytherapy

Brachytherapy is another option for treating airway obstruction and can be used alone, or in combination with EBRT to boost the total dose of irradiation used.33,34 It has been used in combination with high-dose EBRT as a potential curative primary treatment in selected cases. Serious complications have been described with brachytherapy, including massive hemoptysis, tracheoesophageal fistulas, bronchial stenosis and radiation bronchitis.34

The role of brachytherapy for the palliative treatment of symptomatic patients with airway obstruction is unclear. It has been used as a palliative treatment in case of endobronchial tumor recurrence after EBRT. Brachytherapy also may be an option for patients in whom EBRT fails to relieve symptoms, or those with endobronchial disease who require lung re-expansion before or in conjunction with radiotherapy.33

###### Bronchoscopy and Stents, Cryoablation and Photodynamic Therapy (PDT)

Several interventional methods are used to palliate symptoms in patients with an obstructive endobronchial NSCLC.25,32,33,35 Interventional bronchoscopy with mechanical tumor debridement and stent placement can rapidly reestablish airway patency and relieve dyspnea and respiratory distress in patients with airway obstruction due to a malignant endoluminal tumor.32,35 In a large cryosurgery series, 86 percent of 521 patients experienced improvement in one or more symptoms including cough, dyspnea, hemoptysis, and chest pain.36 Laser resection involving the neodymium-doped yttrium aluminum garnet (Nd-YAG) laser and PDT using porfimer sodium have been investigated in this setting with suggestion of symptomatic improvement in some cases.25 RFA also has been used in this setting.

## Scope of the Review

This Agency for Healthcare Research and Quality (AHRQ) -sponsored CER of local nonsurgical therapies for stage I (T1N0M0, T2N0M0) NSCLC and airway obstruction due to NSCLC is intended as a comprehensive systematic review of the relative benefits and harms of lung-directed nonsurgical therapies in two disease settings encompassing four distinct patient populations (see PICOTS, below). Several local nonsurgical therapies are available for definitive treatment of inoperable stage I NSCLC, or those with operable lesions who decline surgery. These include conformal radiation modalities (3DRT, IMRT, SBRT, PBRT), and interventional methods such as RFA. Likewise, numerous methods are used to treat patients with symptomatic malignant airway obstruction, including EBRT methods, brachytherapy, surgical debridement and stent placement, and others (e.g., Nd-YAG laser, RFA, cryoablation).

### Rationale

Surgery is currently regarded as the standard of care for eligible patients with stage I NSCLC. However, alternative treatments are needed for a subset of stage I NSCLC patients for whom surgery is contraindicated because of underlying comorbidities. Alternatives also are needed for another smaller proportion of stage I patients who are medically operable but decline surgery. Comparison of outcomes with alternative procedures to those achieved with surgery is outside the scope of the CER. Instead, the CER is focused on local nonsurgical modalities for inoperable patients in Key Question 1, and in operable patients who decline surgery in Key Question 2.

Key Question 3 addresses the comparative benefits and harms of local nonsurgical therapies in patients with inoperable NSCLC who have symptoms secondary to the presence of an endoluminal lesion. The optimal approach in these patients is not established. These patients often require urgent care; typically have a short expected life span and interventions are often palliative.

All of the alternative modalities under consideration are clinically relevant and merit comparative evaluation due to uncertainty surrounding their optimal use in these settings. They are important to health care providers, patients, and policy makers given the substantial disease burden of NSCLC, especially in the elderly population.

## Key Questions

The Key Questions and CER analytical frameworks (Figure 1 and Figure 2) are structured consistent with the PICOTS (Populations, Interventions, Comparators, Outcomes, Timeframes, Settings) framework, as laid out in the AHRQ Evidence-based Practice Center (EPC) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews”37 (hereafter Methods Guide).

Figure 1 Analytical framework for comparative effectiveness of local nonsurgical definitive therapies for adult patients (age 18 years or older) with documented (clinical or biopsy) stage I (T1N0M0 or T2N0M0) medically inoperable NSCLC or those with documented stage I NSCLC who are deemed operable but decline surgery

3DRT = three-dimensional radiotherapy; AE = adverse event; IMRT = intensity-modulated radiotherapy; KQ = Key Question; NSCLC = non–small-cell lung cancer; PBRT = proton beam radiotherapy; RFA = radiofrequency ablation; SBRT = stereotactic body radiotherapy

This figure depicts key questions 1 and 2 within the context of the PICOTS described in a later section. The figure illustrates how local curative therapies for documented (biopsy or clinical) stage I (T1N0M0, T2N0M0) non-small-cell lung cancer may improve overall survival, cancer-specific survival, pulmonary quality-of-life, and performance status and affect intermediate outcomes such as local control and recurrence. Important adverse effects include RT-associated AEs (eg, pneumonitis, cardiotoxicity, hemoptysis, dermatitis, etc), pneumothorax, and pleural effusion.

Figure 2 Analytical framework for comparative effectiveness of local nonsurgical curative or palliative therapies for adult patients (age 18 years or older) with symptomatic inoperable endobronchial obstruction due to NSCLC

2DRT = two-dimensional, wide-field radiotherapy; 3DRT = three-dimensional radiotherapy; AE = adverse event; FEV = forced expiratory volume; IMRT = intensity-modulated radiotherapy; KQ = Key Question; NSCLC = non–small-cell lung cancer; PBRT = proton beam radiotherapy; RFA = radiofrequency ablation; SBRT = stereotactic body radiotherapy; YAG = yttrium aluminum garnet

This figure depicts key question 3 within the context of the PICOTS described in a later section. The figure illustrates how local curative or palliative therapies for unresectable, advanced stage (IIIa, IIIb, and IV) non-small-cell lung cancer may improve overall survival, cancer-specific survival, pulmonary quality-of-life, and performance status in patients with pulmonary signs and symptoms of obstruction, and affect intermediate outcomes such as local control, recurrence, lung function (eg,FEV1), dyspnea, bleeding, and infections. Important adverse effects include RT-associated AEs (eg, pneumonitis, cardiotoxicity, hemoptysis, dermatitis, etc), pneumothorax, pleural effusion, and procedural mortality.

Key Question 1. What are the comparative benefits and harms of local nonsurgical definitive therapies for documented (clinical or biopsy) stage I (T1N0M0, T2N0M0) NSCLC in adult patients (age 18 years or older) who are not surgical candidates because of the presence of contraindications to major surgery, for example, cardiac insufficiency, poor pulmonary function, presence of severe intercurrent illness, or poor performance status?

Key Question 2. What are the comparative benefits and harms of local nonsurgical definitive therapies for documented (clinical or biopsy) stage I (T1N0M0, T2N0M0) NSCLC in adult patients (age 18 years or older) who are deemed operable but decline surgery?

Key Question 3. What are the comparative short- and long-term benefits and harms of local nonsurgical therapies given with palliative or curative intent to patients with endoluminal NSCLC causing obstruction of the trachea, main stem, or lobar bronchi and recurrent or persistent thoracic symptoms such as hemoptysis, cough, dyspnea, and post obstructive pneumonitis?

## PICOTS Framework

### Key Questions 1 and 2

#### Population(s)

Key Question 1: Adult patients (age 18 years or older) with documented (clinical or biopsy) stage I (T1N0M0 and T2N0M0) NSCLC who were not deemed surgical candidates because of the documented presence of contraindications to major surgery, for example, cardiac insufficiency, poor pulmonary function, presence of severe intercurrent illness, or poor performance status.

Key Question 2: Adult patients (age 18 years or older) with documented (clinical or biopsy) stage I (T1N0M0 and T2N0M0) NSCLC who would otherwise be deemed surgical candidates according to current clinical criteria but decline surgery.

#### Interventions

- Conformal radiotherapy methods (including SBRT, 3DRT, IMRT)
- PBRT
- RFA

#### Comparators

- Interventions were compared with each other as noted above.

#### Outcomes

- [underlined: Final health outcomes]: Overall survival, cancer-specific survival, performance status, pulmonary quality of life
- [underlined: Intermediate outcomes]: Local control
- [underlined: Adverse outcomes]: Includes, but not limited to, radiotherapy-associated AEs (e.g., pneumonitis, cardiotoxicity, hemoptysis, dermatitis, etc.), non-radiotherapy-associated AEs (e.g., pneumothorax, hemothorax, pleural effusion)

#### Timing

- The relevant periods occur at the time of treatment through followup over months (palliation) or years (overall survival).

#### Settings

- Inpatient and outpatient

### Key Question 3

#### Population

Adult patients (age 18 years or older) with NSCLC with endoluminal obstruction of the trachea, main stem, or lobar bronchi and recurrent or persistent thoracic symptoms such as hemoptysis, cough, dyspnea and post obstructive pneumonitis, who were treated with curative or palliative intent.

#### Interventions

- Conventional 2DRT
- Conformal radiotherapy methods (including SBRT, 3DRT, IMRT)
- Brachytherapy
- RFA
- Cryoablation
- Laser therapy
- Endobronchial debridement and stents
- Electrocautery
- Combinations were considered, for example endobronchial debridement plus a stent, compared with debridement alone; or, combination of 2DRT with brachytherapy compared with radiotherapy alone.

#### Comparators

- Interventions were compared with each other as noted above.

#### Outcomes

- [underlined: Final health outcomes]: Overall survival, performance status, pulmonary quality of life
- [underlined: Intermediate outcomes]: Local control, lung function (e.g., forced expiratory volume [FEV1]), symptom relief (e.g., dyspnea, hemoptysis), respiratory tract infection
- [underlined: Adverse outcomes]: Includes, but not limited to, radiotherapy-associated AEs (e.g., pneumonitis, cardiotoxicity, hemoptysis, dermatitis, etc.), non-radiotherapy-associated AEs (e.g., pneumothorax, pleural effusion, transesophageal fistula, pericardial effusion)

#### Timing

- The relevant periods occur at the time of treatment through followup over months (palliation) or years (overall survival).

#### Settings

- Inpatient and outpatient

## Organization of This Report

This report is organized into three chapters: Methods, Results and Discussion. The Methods chapter describes the search strategy used to identify the published and unpublished evidence relevant to Key Questions, the processes used to systematically review and assess individual clinical studies for inclusion or exclusion, data elements that were abstracted from these articles to compile evidence tables and method use to assess quality ratings for individual studies as well as strength of evidence (SOE) ratings. The Results chapter is structured to sequentially address Key Questions 1, 2 and 3. Results of each Key Question include evidence summary tables, an analysis of the quality and risk of bias of individual clinical studies, key points of evidence for the patient-important clinical outcomes, and a detailed synthesis of compiled evidence for each outcome according to Key Question. The Discussion chapter addresses key findings and the strength of evidence for all Key Questions using standard systematic review procedures outlined by AHRQ, a discussion of how the findings relate to or compare to existing standards, and the applicability of the body of evidence for each Key Question in terms of the PICOTS framework. The Discussion chapter also addresses implications for policy decisions, in the context of limitations of the systematic review processes used and the evidence itself. This chapter concludes with a section devoted to outlining the gaps in the available evidence base for each Key Question, and a Conclusions section that interprets the findings in the context of all considered factors.

Detailed electronic search strategy for this report is located in Appendix A. A list of excluded studies with reasons for exclusion is provided in Appendix B. Data abstraction tables for each Key Question can be found in Appendix C.