# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Jessica Donington, M.D.
  Assistant Professor of Cardiothoracic Surgery
  New York University School of Medicine
  New York, NY
- Stephen M. Hahn, M.D.
  Chair, Department of Radiation Oncology
  Director, Photodynamic Therapy Program
  Perelman Center for Advanced Medicine
  Philadelphia, PA
- Michael Lanuti, M.D.
  Director, Thoracic Oncology
  Division of Thoracic Surgery
  Massachusetts General Hospital
  Boston, MA
- William Moore, M.D.
  Chief of Thoracic Imaging
  Stony Brook Cancer Center
  Stony Brook, NY