# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- James Adamson, M.D.
  Vice President and Medical Officer for National Accounts
  Arkansas Blue Cross and Blue Shield
  Little Rock, AR
- Damian Dupuy, M.D.
  Professor, Diagnostic Imaging
  Warren Alpert Medical School
  Brown University
  Director of Tumor Ablation
  Rhode Island Hospital
  Providence, RI
- Mark Ferguson, M.D.
  Professor of Surgery
  Head, Thoracic Surgery Service
  University of Chicago Cancer Research Center
  Chicago, IL
- Brian Funaki, M.D.
  Section Chief, Vascular/Interventional Radiology
  University of Chicago Medical Center
  Chicago, IL
- Renuka Malik, M.D.
  Instructor, Radiation/Cellular Oncology
  University of Chicago Hospitals
  Chicago, IL
- Jyoti Patel, M.D.
  Associate Professor, Hematology/Oncology
  Feinberg School of Medicine
  Northwestern University
  Chicago, IL
- Douglas Wood, M.D.
  Chief, Cardiothoracic Surgery
  University of Washington
  Seattle, WA